# Abbreviations

AA (20:4 n-6) | Arachidonic acid
ACP | Teller Acuity Card Procedure
AE | adverse effects
AGA | Adequate for gestational age
AHRQ | Agency for Healthcare Research Quality
AI | Adequate Intake
ALA (18:3 n-3) | Alpha linolenic acid
ALSPAC | Avon Longitudinal Study of Pregnancy and Childhood
ANCOVA | analysis of co-variance
ANOVA | analysis of variance
AS | active sleep
BAEP | Brainstem auditory evoked potentials
BAEP test | brainstem auditory evoked potential
BMI | body mass index
BP | Blood pressure
BRS | Behavioral Rating Scale
C5a | Complement fragment 5a
CA | corrected age
CAM | complementary alernative medicine
cAMP | Cyclic adenosine monophosphate
CNS | central nervous system
COX | Cyclooxygenase
CSFII | Continuing Survey of Food Intakes by Individuals
DHA (22:6 n-3) | Docosahexaenoic acid
DPA | docosapentaenoic acid
DQ | developmental quotient
DTS | Dense tubular system
EAR | Estimated Average Requirement
EEG | Electroencephalogram
EFA | Essential fatty acid
EPA (20:5 n-3) | Eicosapentaenoic acid
ERG | Electroretinogram
ERG | electroretinogram
FA | fatty acids
FLP | Forced Choice Preferential Looking Procedure
GA | Gestational age
GHT | Gestational hypertension
GLA (18:3 n-6) | Gamma linolenic acid
GM DQ | gross motor developmental quotient
GOS | Groningen Developmental Scale
HC | Head circumference
HDL | High density lipoprotein
HM | Human milk
IFN | Interferon
IgE | Immunoglobulin E
IL | Interleukin
ITT | intention-to-treat
IUGR | Intra-uterine growth retardation
K-ABC | Kaufman Assessment Battery for Children
LA (18:2 n-6) | Linoleic acid
LBW | low birth weight
LC PUFA | Long-chain polyunsaturated fatty acid
LDL | Low density lipoprotein
LGA | large for gestational age
LT | Leukotriene
MAR | Minimal angle of resolution
MDI | Mental developmental index
MDI | Mental Developmental Index (Bayley Scales of Infant Development)
MJ/day | daily energy intake
MLR | multiple linear regression
MLU | Mean length of utterance
MRC | Medical Research Council
NCV | Nerve conduction velocity
NEC | Necrotizing enterocolitis
NEC | Necrotizing enterocolitis
NHANES III | National Health and Nutrition Examination (NHANES III)
NICU | neonatal intensive care unit
NIH | National Institutes of Health
NOS | Newcastle and Ottawa Scale
ODS | Office of Dietary Supplements
OPL | Operant preferential looking
PC | phosphatidyl choline
PCA | post conceptional age
PDI | Psychomotor developmental index
PDI | psychomotor developmental index
PE | phosphatidyl ethanolamine
PG | Prostaglandin
PGI2 | antiaggregatory prostacyclin
PL | Phospholipids
PPAR | Peroxisome proliferator activated receptor
PPVT-R | Peabody Picture Vocabulary Test - Receptive Vocabulary
PUFA | Polyunsaturated fatty acid
QS | quiet sleep
QUORUM | Quality of the reporting of meta-analysis
RBC | red blood cells
RCT | Randomized Controlled Trial
RDA | Recommended Dietary Allowances
SCN | special care nursery
SCO | single cell oils
SD | standard deviation
SEMs | standard errors of the means
SGA | Small for gestational age
SIDS | sudden infant death syndrome
Sp | species
SREBP | Sterol regulatory element binding protein
TEP | technical expert panel
Tg | Triglycerides
TGL | triglyceride
TNF | Tumor necrosis factor
TPN | Total parenteral nutrition
Tx | Thromboxane
TXA2 | proaggregatory thromboxane
UK | United Kingdom
USDA | United States Department of Agriculture
VEP | Visual evoked potentials
VLBW | Very low birth weight
VLDL | Very low density lipoprotein
VLN-3FA | very long chain n-3 fatty acids
WAIS-R | Wechsler Adult Intelligence Scale - Revised
WMD | weighted mean difference