# Summary Table

Summary Table 1: Omega-3 fatty acid influences on the duration of gestation in women with or without a history of a previous preterm birth

Summary Table 1: Omega-3 fatty acid influences on the duration of gestation in women with or without a history of a previous preterm birth

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Olsen, 1992, Denmark: NR parallel RCT ^209^ | 2.7g n-3 FAs fish oil (n=266) | Olive oil (n=136)/ pb (n=131) | S↑ GA in fish oil grp^++^ | Jadad total: 2 [Grade: C]; Schulz: Inadequate | III
Bulstra-Ramakers, 1994, Netherlands: 27 wks parallel RCT ^238^ | n-3 FA-enriched capsules: EPA 3 g/d DHA NR (n=32) | Control capsules: coconut oil (n=31) | NS in % premature deliveries | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
Onwude, 1995, UK: NR parallel RCT ^233^ | DHA+EPA (1620mg EPA+1080mg DHA) (n=113) | pb (n=119) | NS in GA NS in % premature deliveries | Jadad total: 5 [Grade: A]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significantly different;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

GA = gestational age;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001; PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 2: Omega-3 fatty acid influences on the duration of gestation in women with or without a history of a previous preterm birth

Summary Table 2: Omega-3 fatty acid influences on the duration of gestation in women with or without a history of a previous preterm birth

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Olsen, 2000a, multicenter: 20 wks parallel RCT ^230^ | Earl-PD: Pikasol (fish oil) 0.9g DHA, 1.3g EPA capsules (n=110) | Olive oil capsules (n=122) | (ITT) S↑ GA in fish oil gp^+^ S↓ % Premature delivery in fish oil gp^+^ | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Olsen, 2000b, multicenter: 20 wks parallel RCT ^230^ | Earl-IUGR: Pikasol (fish oil) 0.9g DHA, 1.3g EPA capsules (n=141) | Olive oil capsules (n=139) | (ITT) S↑ GA in fish oil gp^+^ | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Olsen, 2000c, multicenter: 20 wks parallel RCT ^230^ | Earl-PIH: Pikasol (fish oil) 0.9g DHA, 1.3g EPA capsules (n=184) | Olive oil capsules (n=202) | (ITT) NS in GA | Jadad total: 2 [Grade: C]; Schulz: Adequate | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significantly different;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

GA = gestational age;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001; PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Earl-PD = pregnant women with antecedent of premature delivery;

Earl-IUGR = pregnant women with antecedent of IUGR;

Earl-PIH = pregnant women with antecedent of gestational hypertention in past pregnancies

Summary Table 3: Omega-3 fatty acid influences on the duration of gestation in women with or without a history of a previous preterm birth

Summary Table 3: Omega-3 fatty acid influences on the duration of gestation in women with or without a history of a previous preterm birth

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Olsen, 2000d, multicenter: 20 wks parallel RCT ^230^ | Twins trial: Pikasol (fish oil) 0.9g DHA, 1.3g EPA capsules (n=289) | Olive oil capsules (n=290) | (ITT) NS in GA | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Olsen, 2000e, multicenter: 33 wks parallel RCT ^230^ | Threat-PE: Pikasol (fish oil) 2.1g DHA, 2.9g EPA capsules (n=44) | Olive oil capsules (n=35) | (ITT) NS in GA | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Olsen, 2000f, multicenter: 33 wks parallel RCT ^230^ | Susp-IUGR: Pikasol (fish oil) 2.1g DHA, 2.9g EPA capsules (n=36) | Olive oil capsules (n=27) | (ITT) S↑ GA in fish oil gp^+^ | Jadad total: 2 [Grade: C]; Schulz: Adequate | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significantly different;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

GA = gestational age;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001; PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Threat-PE = pregnant women with threatening preeclampsia;

Susp-IUGR = pregnant women with suspected IUGR

Summary Table 4: Omega-3 fatty acid influence on the duration of gestation in women with or without a history of a previous preterm birth

Summary Table 4: Omega-3 fatty acid influence on the duration of gestation in women with or without a history of a previous preterm birth

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Helland, 2001, Norway: 8 mo parallel RCT ^141^ | CGA 1183 mg/d DHA + 803 mg/d EPA + 27.5 mg/d AA (n=301) | COG pb 8.3mg/d DHA (n=289) | NS in GA | n/a | Jadad total: 4 [Grade: A]; Schulz: Unclear | III
Smuts, 2003, US: 13 wk parallel RCT ^232^ | High-DHA eggs (183.9 mg/d DHA) (n=18) | Regular-DHA eggs (35.1 mg/d DHA) (n=19) | NS in GA High-DHA eggs ↓ PTDR than control (no p-value) | n/a | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
Smuts, 2003, US: 13 wk parallel RCT ^234^ | High-DHA eggs (133 mg/d DHA) (n=176) | Regular-DHA eggs (33 11mg/d DHA) (n=174) | S↑ in GA in High-DHA vs Regular-DHA^+^ NS in PTDR | S (+) correlation between infant RBC DHA & GA^+^ NS correlation between maternal RBC DHA & GA | Jadad total: 3 [Grade: B]; Schulz: Inadequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3 fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significantly different;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

CGA = cod liver oil group;

COG = corn oil group;

GA = gestational age;

PTDR = preterm delivery rate;

RBC = red blood cells;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001; PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 5: Omega-3 fatty acid influence on the duration of gestation in women with or without a history of a previous preterm birth

Summary Table 5: Omega-3 fatty acid influence on the duration of gestation in women with or without a history of a previous preterm birth

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Malcolm, 2003, Denmark: 15 wks parallel RCT ^235^ | Fish oil (DHA 100 mg) capsules (n=50) | pb (n=50) | NS in GA | NS correlation umbilical cord DHA & GA | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
Dunstan, 2004, Australia: 19 wk parallel RCT ^231^ | LCPUFA (2.2 g/d DHA + 1.1 g/d EPA) (n=40) | pb (n=43) | NS in GA | NS correlation between infant RBC DHA, EPA, AA & GA | Jadad total: 3 [Grade: B]; Schulz: Unclear | III
de Groot, 2004, Netherlands: 24 wk parallel RCT ^196^ | LCPUFA (9.02 g/d LA+2.82 g/d ALA) (n=40) | pb (10.94 g/d LA+0.03 g/d ALA) (n=39) | NS in GA | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significantly different;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

GA = gestational age;

RBC = red blood cells;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

LA = linoleic acid;

ALA = alpha-linolenic acid;

Summary Table 6: Influence of maternal intake of omega-3 fatty acids on the incidence of preeclampsia, eclampsia or gestational hypertension

Summary Table 6: Influence of maternal intake of omega-3 fatty acids on the incidence of preeclampsia, eclampsia or gestational hypertension

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
D'Almeida, 1992, Angola: 24 wk parallel RCT ^236^ | n-3 FA-enriched capsules: fish & primrose oil EPA 0.15 g/d DHA 0.08 g/d (n=50) | Mg^2+^ oxide capsules: 1 g/d (n=50)/ olive oil capsules: (n=50) | Rate of GHT ↑ in grps 1–3 vs. grp 2 (p = NR) Rate of preeclampsia/eclampsia ↑ in grp 3 vs. grps 1–2^+++^ | Jadad total: 2 [Grade: C]; Schulz: Inadequate | III
Laivuori, 1993, Finland: 8 wk parallel RCT ^237^ | n-3 FA-enriched capsules: fish oil EPA 1.80 g/d DHA 1.20 g/d (n=5) | Primrose oil capsules: LA 3.75 g/d GLA 0.45 g/d (n=7)/ maize-olive oil capsules: 10 g/d (n=6) | NS BP, proteinuria, & rate of edema (grp 1 vs. grps 2–3) | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Bulstra-Ramakers, 1995, Netherlands 27 wks parallel RCT ^238^ | n-3 FA-enriched capsules: EPA 3 g/d DHA NR (n=32) | Control capsules: coconut oil (n=31) | NS rate of GHT (grp 1 vs. grp 2) | Jadad total: 5 [Grade: A]; Schulz: Adequate | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

GLA = gamma-linolenic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significantly different;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

GHT = gestational hypertension;

BP = blood pressure;

GHT = gestational hypertension

Summary Table 7: Influence of maternal intake of omega-3 fatty acids on the incidence of preeclampsia, eclampsia or GHT

Summary Table 7: Influence of maternal intake of omega-3 fatty acids on the incidence of preeclampsia, eclampsia or GHT

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Onwude, 1995, UK: 14 wks parallel RCT ^233^ | n-3 FA-enriched capsules: fish oil EPA 1.62 g/d DHA 1.08 g/d (n=113) | Control capsules: air-filled (n=119) | NS rate of GHT (grp 1 vs. grp 2) | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Olsen, 1992, Denmark: NR parallel RCT ^209^ | n-3 FA-enriched capsules: fish oil EPA 1.30 g/d DHA 0.90 g/d (n=266) | Control capsules: olive oil 4 g/d LA 12% (n=136)/ placebo capsules: no oil (n=131) | NS in BP or rates of GHT & preeclampsia (grp 1 vs. grps 2–3) NS in BP (grp 1 vs. grps 2–3) | Jadad total: 2 [Grade: C]; Schulz: Inadequate | III
Olsen, 2000, multicenter* 20 wks parallel RCT ^230^ | Twins trial: n-3 FA-enriched capsules: fish oil EPA 1.30 g/d DHA 0.90 g/d (n=289) | Control capsules: olive oil 4 g/d LA 12% (n=290) | (ITT) NS in rates of GHT & preeclampsia (grp 1 vs. grp 2) NS BP (grp 1 vs. grp 2) | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Olsen, 2000, multicenter* 20 wks parallel RCT ^230^ | Earl-PIH: n-3 FA-enriched capsules: fish oil EPA 1.30 g/d DHA 0.90 g/d (n=184) | Control capsules: olive oil 4 g/d LA 12% (n=202) | (ITT) NS in rates of GHT & preeclampsia (grp 1 vs. grp 2) NS in BP (grp 1 vs. grp 2) | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Smuts, 2003, US: 16 wks parallel RCT ^234^ | n-3 FA-enriched eggs: DHA 0.23 g/d (n=142) | Control regular eggs: DHA 0.056 g/d (n=149) | NS in rates preeclampsia (grp 1 vs. grp 2) | Jadad total: 3 [Grade: B]; Schulz: Inadequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

GLA = gamma-linolenic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significantly different;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

GHT = gestational hypertension;

BP = blood pressure;

* Denmark, Scotland, Sweden, UK, Italy, Netherlands, Norway, Russia, Belgium

Summary Table 8: Maternal intake of omega-3 fatty acids and the incidence of births of human infants small for gestational age

Summary Table 8: Maternal intake of omega-3 fatty acids and the incidence of births of human infants small for gestational age

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
D'Almeida, 1992, Angola: 24 wk parallel RCT ^236^ | n-3 FA-enriched capsules: fish & primrose oil EPA 0.15 g/d DHA 0.08 g/d (n=50) | Mg^2+^ oxide capsules: 1 g/d (n=50)/ olive oil capsules: (n=50) | % <2,000 g at birth: pb 3.3% vs. n-3: 1.3% vs. Mg^2+^: 4.7% (no p-value) | Jadad total: 2 [Grade: C]; Schulz: Inadequate | III
Olsen, 1992, Denmark: NR parallel RCT ^209^ | 2.7g n-3 FAs fish oil (n=266) | NR olive oil (n=136)/ pb (n=131) | NS birth wt | Jadad total: 2 [Grade: C]; Schulz: Inadequate | III
Bulstra-Ramakers, 1994, Netherlands 27 wks parallel RCT ^238^ | n-3 FA-enriched capsules: EPA 3 g/d (n=32) | Control capsules: coconut oil (n=31) | NS in IUGR recurrence rate (grp 1 vs. grp 2) | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
Onwude, 1995, UK: 14 wks parallel RCT ^233^ | n-3 FA-enriched capsules: EPA 1.62 g/d DHA 1.08 g/d (n=113) | Control capsules: air-filled (n=119) | NS in birth wt & IUGR recurrence rate (grp 1 vs. grp 2) | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Olsen, 2000a, multicenter: 20 wks parallel RCT ^230^ | Earl-PD: Pikasol (fish oil) 0.9g DHA, 1.3g EPA capsules (n=110) | Olive oil capsules (n=122) | (ITT) S↑ birth wt in fish oil NS % IUGR | Jadad total: 2 [Grade: C]; Schulz: Adequate | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

GA = gestational age;

IUGR = intrauterine growth retardation;

FA = fatty acids;

* Scotland, Sweden, UK, Italy, Netherlands, Norway, Russia, Belgium

Summary Table 9: Maternal intake of omega-3 fatty acids and the incidence of births of human infants small for gestational age

Summary Table 9: Maternal intake of omega-3 fatty acids and the incidence of births of human infants small for gestational age

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Olsen, 2000b, multicenter* 20 wks parallel RCT ^230^ | Earl-IUGR trial: n-3 FA-enriched capsules: fish oil EPA 1.30 g/d DHA 0.90 g/d (n=141) | Control capsules: olive oil (n=139) | (ITT) S↑ birth wt in olive oil NS % IUGR | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Olsen, 2000c, multicenter*: 20 wks parallel RCT ^230^ | Twins trial: n-3 FA-enriched capsules: fish oil EPA 1.30 g/d DHA 0.90 g/d (n=289) | Control capsules: olive oil (n=290) | (ITT) NS in birth wt & % IUGR | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Olsen, 2000d, multicenter*: 33 wks parallel RCT ^230^ | Susp-IUGR trial: n-3 FA-enriched capsules: fish oil EPA 2.9 g/d DHA 2.1 g/d (n=36) | Control capsules: olive oil (n=27) | (ITT) NS in birth wt & % IUGR | Jadad total: 2 [Grade: C]; Schulz: Adequate | III
Helland, 2001, Norway: 23 wks parallel RCT ^141^ | Cod liver oil: 10 mL/d EPA 0.80 g/d DHA 1.18 g/d (n=175) | Corn oil: 10 mL/d (n=166) | NS in birth wt, birth length, & HC (grp 1 vs. grp 2) | Jadad total: 4 [Grade: A]; Schulz: Unclear | III
Malcolm, 2003, Denmark: 15 wks Parallel RCT ^235^ | Fish oil (DHA 100 g) capsules (n=50) | pb n=50) | NS in birth wt, length & HC | Jadad total: 3 [Grade: B]; Schulz: Unclear | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

GA = gestational age;

IUGR = intrauterine growth retardation;

FA = fatty acids;

HC = head circumference;

* Scotland, Sweden, UK, Italy, Netherlands, Norway, Russia, Belgium

Summary Table 10: Maternal intake of omega-3 fatty acids and the incidence of births of human infants small for gestational age

Summary Table 10: Maternal intake of omega-3 fatty acids and the incidence of births of human infants small for gestational age

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker Correlations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Smuts, 2003, US: 16 wks parallel RCT ^232^ | n-3 FA-enriched eggs: DHA 0.23 g/d (n=18) | Control regular eggs (n=19)/ non-randomized low eggs grp (n=16) | Wt, length, & HC at birth ↑ in grp 1 vs. grp 2 (p-value: NR) rate of PD & LBW ↓ in grp 1 vs. grp 2 (p-value: NR) | n/a | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
Smuts, 2003, US: 16 wks parallel RCT ^234^ | n-3 FA-enriched eggs: DHA 0.23 g/d (n=142) | Control regular eggs (n=149) | NS in birth wt, birth length, HC, NS rate of LBW | n/a | Jadad total: 3 [Grade: B]; Schulz: Inadequate | II
de Groot, 2004, Netherlands: 26 wks parallel RCT ^196^ | n-3 FA- enriched margarine: 25 g/d ALA 2.82 g/d LA 9.02 g/d (n=29) | Control margarine: 25 g/d ALA 0.03 g/d LA 10.94 g/d (n=29) | Birth wt S ↑ in ALA+LA vs. LA^+^ | S (+) correlation maternal plasma & RBC DHA & birth wt S +correlation DHA intake & bith wt | Jadad total: 3 [Grade: B]; Schulz: Unclear | III
Dunstan, 2004, Australia, UK: 20 wks parallel RCT ^231^ | n-3 FA-enriched capsules: fish oil EPA 1.10 g/d DHA 2.20 g/d (n=40) | Control capsules: olive oil (n=43) | NS in length, wt, & HC at birth | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

GA = gestational age;

IUGR = intrauterine growth retardation;

FA = fatty acids;

PD = pre-term delivery (GA < 37 wks);

LBW = low birth weight;

HC = head circumference

Summary Table 11: Association between duration of gestation in women with or without a history of a previous preterm birth and the the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy (Observational studies)

Summary Table 11: Association between duration of gestation in women with or without a history of a previous preterm birth and the the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy (Observational studies)

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Reece, 1997, US: Case-control study ^239^ | Preterm births (n=37) | Term deliveries controls (n=34) | Maternal RBC LA, AA, DHA S ↑ in preterm vs. 34-wk control^+^ & term^+++^ | Quality score: 4 [Grade C] | III
| | | Maternal RBC EPA S ↑in term controls vs. both preterm & 34-wk control^++^
| | | Maternal RBC & plasma n-3/n-6 ratio was S↑ in term controls vs. preterm^++^
| | | NS Maternal RBC n-3/n6 between preterm & 34-wk control
| | | Maternal plasma LA S ↑ in preterm & 34-wk control vs. term control^+^
| | | Maternal plasma LA, AA, EPA S↑ in preterm vs. term controls^+^
Elias, 2001, Canada: Single prospective cohort ^240^ | Healthy pregnant women (n=84) | n/a | Umbilical cord plasma TGL & CE AA S (+) associated with GA^++^ | Quality score: 6 [Grade B] | III
| | | NS association between other maternal n-3 or n-6 BMK & GA
| | | Maternal plasma TGL AA S (+) correlated to GA^++^
Rump, 2001, Netherlands: Cross-sectional ^241^ | Healthy pregnant women-term infants (n=627) | n/a | NS correlation between maternal plasma FA at 11 (8) wk GA & at delivery & GA | Quality score: 9 [Grade A] | III

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

LA = linoleic acid;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

BMK = biomarker;

RBC = red blood cells;

PL = phospholipid;

CE = cholesteryl ester;

TGL = triacylglycerol;

GA = gestational age/duration of gestation;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction

Summary Table 12: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers during pregnancy and incidence of preeclampsia, eclampsia or GHT

Summary Table 12: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers during pregnancy and incidence of preeclampsia, eclampsia or GHT

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Wang, 1991, US: Cross sectional study ^242^ | Preeclampsia (n=9)/ | normal pregnant pts(n=11)/ nonpregnant women volunteers (n=10) | Total PUFA, LA (n-6), ALA (n-3) & EPA plasma of normal pregnant women was S > preeclamptic pts^+^ | Quality score: 5 [Grade B] | III
| | | NS between groups plasma AA & DHA
| | | S > EPA & DHA in normal pregnant women vs. nonpregnant^++^
Craig-Schmidt, 1994, US: Cross-sectional study ^243^ | preeclampsia (n=10)/ normal pregnancy (n=10) | GHT (n=10)/ CHT (n=6) | NS among groups in plasma saturated, monosaturated & PUFAs | Quality score: 2 [Grade C] | III
| | | NS in n-6 or n-3 FA between normal pregnancies & GHT, preeclamsia or CHT
| | | CHT S ↑ AA in plasma PL vs. other groups
| | | NS in plasma PL EPA among the groups
| | | NS in AA/EPA ratio & n-6/n-3 ratio
Al, 1995, Netherlands:nested case-control study ^179^ | GHT women (n=52) | Healthy pregnant controls (n=156) | NS in absolute FA composition (mg/L) of maternal plasma PL (before 16, at 22 & 32 wks GA) | Quality score: 11 [Grade A] | III
| | | Severe GHT women (n=17) mean GA & mean birth wt of their babies S ↓ than mild GHT
| | | During gestation & after delivery NS in maternal FA composition of the severe GHT vs. mild GHT

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

grp = group;

wk = week(s);

mo = month;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

GHT = gestational hypertension;

PL = phospholipids;

CHT = chronic hypertension

Summary Table 13: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers during pregnancy and incidence of preeclampsia, eclampsia or GHT

Summary Table 13: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers during pregnancy and incidence of preeclampsia, eclampsia or GHT

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Hofmann, 1998, Germany: Cross-sectional study ^229^ | Preeclampsia (n=14) | Healthy pregnant controls (n=16) | Total FA in plasma TGL during pregnancy were S > in preeclamptic group vs. control^+++^ | Quality score: 6 [Grade B] | III
| | | NS between groups in AA plasma TGL during pregnancy
| | | LA (n-6) & DHA (n-3) content in plasma TGL were S ↓ in preeclamptic pts vs. controls^+^
| | | NS between groups LA & AA (n-6) in plasma PL
| | | DHA plasma PL content was S ↓ in preeclamptic women^++^
Shouk, 1999, Egypt: Cross-sectional study ^244^ | severe preeclampsia in 3^rd^ trimester (n=25) | healthy pregnant controls (n=20) | AA in plasma was S > in preeclamptic women vs. control^+++^ | Quality score: 7 [Grade B] | III
| | | NS between groups LA & ALA (n-3) content

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

TGL = triglycerides

Summary Table 14: Incidence of births of SGA human infants and the association with the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy

Summary Table 14: Incidence of births of SGA human infants and the association with the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Vilbergson, 1991, Sweden: Cross-sectional ^247^ | SGA grp (n=13) | Term AGA (control) (n=20) | S↓ maternal plasma DHA & AA in SGA grp than in ctrl at 34 weeks GA & at delivery^+^ | Quality score: 7 [Grade B] | III
Matorras, 1994, Spain: Case-control ^245^ | IUGR grp (n=23) | AGA (control) (n=34) | S↑ maternal plasma EPA in IUGR grp than in ctrl at delivery^++^ | Quality score: 9 [Grade A] | III
| | | NS in maternal plasma DHA & AA at delivery

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

AGA = appropriate for gestational age;

IUGR = intrauterine growth restriction;

GA = gestational age;

ct = control group;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

BW = birth weight;

Fas = fatty acids;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

grp = group;

wk = week(s);

mo = month;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

SGA = small for gestational age;

AGA = adequate for gestational age;

IUGR = intrauterine growth retardation

Summary Table 15: Incidence of births of SGA human infants and the association with the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy

Summary Table 15: Incidence of births of SGA human infants and the association with the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Elias, 2001, Canada: Single prospective cohort ^240^ | Healthy pregnant women (n=84) | n/a | Maternal plasma TGL AA, S (+) correlated to infant birth wt & length^++^ | Quality score: 6 [Grade B] | III
Rump, 2001, Netherlands: Cross-sectional ^241^ | Healthy pregnant women-term infants (n=627) | n/a | NS relation between maternal plasma FA at 11 (8) wk GA & at delivery & infants BW | Quality score: 9 [Grade A] | III
Cetin, 2002, Italy: Case-control ^246^ | IUGR grp (n=10) | AGA (control) (n=11) | S↑ maternal plasma EPA in IUGR grp than in pb at ≈28.2(8.0) wk GA^+^ | Quality score: 5 [Grade B] | III
| | | NS in maternal plasma DHA & AA at ≈28.2 (8.0) wk GA

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

GA = gestational age;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

BW = birth weight;

TGL = triacylglycerol;

FAs = fatty acids;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

grp = group;

wk = week(s);

mo = month;

wt = weight;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

SGA = small for gestational age;

LGA = large for gestational age

Summary Table 16: Omega-3 fatty acids and its influence on growth patterns in infants after intake during pregnancy and breastfeeding

Summary Table 16: Omega-3 fatty acids and its influence on growth patterns in infants after intake during pregnancy and breastfeeding

Author, Year, Location: Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Helland, 2001, Norway: 34 wks parallel RCT ^141^ | Cod liver oil (DHA+AA+EPA) (n=301 mothers; n=175 infants) | Corn oil (LA+ALA) (n=289 mothers; n=166 infants) | NS between groups in weight, length & head circumference at any point | Jadad total: 4 [Grade: A]; Schulz: Unclear | III

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++p<.01;

+++p<.001;

++++p<.0001;

↑ = increase;

↓ = decrease/reduction

Summary Table 17: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences growth patterns in term or preterm human infants

Summary Table 17: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences growth patterns in term or preterm human infants

Author, Year, Location: Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Jensen, 1999, US: 120 d parallel RCT ^248^ | DHA algal (n=42) | High DHA fish oil (n=42)/ pb (n=42) | NS in wt, length & HC at 4–8 mo | Not assessed | X
Xiang, 2000, Sweden: Single prospective cohort ^249^ | Mother-breastfed term infants (n=19) | n/a | LA, ALA in maternal milk S↑ during 3 mo | Quality score: 5 [Grade B] | III
| | | DHA in maternal milk S↓ during 3 mo
| | | AA/DHA in maternal milk S correlated with infants' rate ↑HC at 1 & 3 mo^++^
| | | AA/DHA in maternal milk S correlated with infants' brain wt gain at 1 & 3 mo^++^
Rocquelin, 2003, The Congo & Burkina Faso: Cross-sectional study ^302^ | Mother-breastfed term infants Congo (n=102) | Mother-breastfed term infants Burkina Faso (n=101) | S↓ wt-for-age & wt-for height z-scores & wt gain (g) in Burkina Faso than in Congo^++++^ NS birth wt, age, weight gain of predominantly breastfed to complementary fed infants in Burkina Faso | Quality score: 5 [Grade B] | III

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

N/A = not applicable;

grp = group;

wk = week(s);

mo = month;

wt = weight;

+ p<.05 or significant with 95% confidence interval;

++p<.01;

+++p<.001;

++++p<.0001;

↑ = increase;

↓ = decrease/reduction;

HC = head circumference;

Summary Table 18: Omega-3 fatty acids and growth parameters of preterm infants

Summary Table 18: Omega-3 fatty acids and growth parameters of preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,^ ^3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Carlson, 1987 US: 4 wk parallel RCT ^250^ | MaxEPA preterm formula (n=30) | Preterm formula (n=31) | NS in Δ wt at 4 wks | n/a | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
Carlson, 1992 US: up to 57wk PCA parallel RCT ^185^ | marine oil (DHA+AA) formula (n=31*) | Control formula (n=34*) | S↓ wt, L, HC in marine oil at 40, 48, 57, 68, 79, 93 wks PCA^+^ | wt & L z-scores correlated + with plasma & RBC AA at 2,4,5,6,9, 12 mo | Jadad total: 4 [Grade: A]; Schulz: Adequate | II
| | | | HC correlated + plasma & RBC AA at 2, 4 mo
Uauy, 1992 US: 6 mo parallel RCT ^212^ | Soy/ marine oil formula (n=22)/ HM (n=10) | Soy oil formula (n=18)/ corn oil formula (n=20) | NS in wt, L, HC, TST, SST at 3, 9, 17, 26 wks | S correlation (-) between RBC AA at 57 wk & length z score at 57 wks PCA | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
Koletzko, 1994 Germany: 3 wk parallel RCT ^251^ | Egg lipids + primrose oil formula (DHA+EPA) (n=9) | Control formula (n=10)/ HM (n=8) | NS in wt, L, HC at 3 wks | n/a | Jadad total: 2 [Grade: C]; Schulz: Unclear | III
Carlson, 1996, US: 5 mo parallel RCT ^191^ | Marine oil (DHA +EPA) formula (n=26) | Control formula (n=33) | S↓ wt, L, HC in LCPUFA at 6^+^, 9^++^ mo PT | S (-) correlation between wt-for-L & RBC PE DHA at 5 mo | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
| | | | S (+) correlation between L & RBC PC AA at 5 mo
Faldella, 1996 Italy: up to 52 wk PCA parallel RCT ^198^ | DHA+EPA formula (n=23) | Control formula (n=26)/ HM (n=17) | NS in Δ wt, ΔL, ΔHC at 52 wks PCA | n/a | Jadad total: 1 [Grade: C]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

* = completed study;

PCA = postconceptional age;

ITT = intention to treat study;

HM = human milk group;

wt = weight;

L = length;

HC = head circumference;

Δ = change;

RBC = red blood cells;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

PE: phosphatidyl ethanolamine;

PC: phosphatidyl choline;

TST = triceps skinfold thickness;

SST = subscapular skinfold thickness

Summary Table 19: Omega-3 fatty acids and growth parameters of preterm infants

Summary Table 19: Omega-3 fatty acids and growth parameters of preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Vanderhoof, 1997, US: Up to 48 wk PCA parallel RCT ^218^ | Microbial fermentation (DHA+AA) formula (n=77) | Control formula (n=78)/ HM (n=133) | S↑ wt, L, HC, MAC in LCP & control than in HM at 40 wk PCA^+^ | n/a | Jadad total: 4 [Grade: A]; Schulz: Adequate | I
| | | NS in L, HC at 48 wks PCA S↑ L, MAC in LCP than in HM at 48 wks PCA | ^+^
| | | NS in wt, L, HC at 92 wks PCA
Lapillonne, 1997, France: 4 mo CA parallel RCT ^252^ | DHA+ EPA formula (n=11) | Control formula (n=12)/ HM (n=10) | NS in GP at 4 mo CA | n/a | Not assessed | X
Martinez, 1999, Brazil 30 d parallel RCT ^259^ | Egg-lipid + primrose oil (formula (n=20) | Control formula (n=20)/ HM (n=18) | NS in wt, L, HC at 30 d | n/a | Jadad total: 1 [Grade: C]; Schulz: Unclear | III
Woltil, 1999, Netherlands 6 wks parallel RCT ^225^ | High-DHA formula (n=16)/ HM (n=33) | Low-DHA formula (n=13) pb-1 (n=13)/ pb-2 (n=37)/ pb-3 (n=31) | NS in Δ wt, ΔL, & ΔHC between LCP-1, LCP-2 & pb at 1 mo | S (+) correlation between Δwt, ΔL, ΔHC & plasma & RBC DHA at 1mo | Jadad total: 1 [Grade: C]; Schulz: Unclear | III
| | | S↑ Δ wt, ΔL, Δ brain wt, ΔHC in pb-1 than in pb-2 & pb-3 at 1mo^+^
Ghebremeskel1999, UK: 11 wk parallel RCT ^253^ | Egg-lipid+ primrose oil (DHA+AA) +HM (n=12)/ control formula (n=8) | LCP formula (n=7)/ control formula+HM/ (n=14)/ HM (n=20) | NS in wt, L, HC at ≈11 wk among 5 grps | n/a | Jadad total: 2 [Grade: C]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

† = mg/kg/day;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

PCA = post conceptional age;

CA = corrected age;

HM = human milk group;

wt = weight;

L = length;

HC = head circumference;

MAC = mid arm circumference;

Δ = change;

GP = growth parameters;

RBC = red blood cells;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 20: Omega-3 fatty acids and growth parameters of preterm infants

Summary Table 20: Omega-3 fatty acids and growth parameters of preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Bougle, 1999, France: 1 mo parallel RCT ^254^ | LCP formula (n=14) | Control formula (n=11)/ HM (n=15) | S↑ Δ wt in LCP than in HM at 1 mo^+^ | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | III
| | | NS in wt, L, HC, ΔL, & Δ HC at 1 mo^+^
Field, 2000 Canada: 5.5 wk parallel RCT ^303^ | LCP formula (n=15) | Control formula (n=12)/ HM (n=17) | S↓ Δ wt in HM than in LCP & pb at 28 d^+^ | n/a | Jadad total: 1 [Grade: C]; Schulz: Unclear | II
| | | NS in L, HC at 35 d^+^
O'Connor, 2001 US, UK, Chile: 12 mo CA parallel RCT ^207^ | DHA+AA(Fish/ fungal oil) formula (n=140) | DHA+AA (Egg-TG/ fish oil) formula (n=143)/ control formula (n=144) | (ITT) NS Δ wt, ΔL, Δ HC at 8 wk, 4 mo, 12 mo CA | S (+) correlation rate wt gain & RBC PE AA at 28 d | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
| | | | wt & L S correlated RBC PE AA at 28 d
Fewtrell, 2002 UK: 9 mo CA parallel RCT ^273^ | LCPUFA formula (n=95) | Control formula (n=100)/ HM (n=88) | (ITT) S↓ wt, L in LCPUFA than in pb at 9, 18 mo CA^+^ | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
| | | NS in HC at 9, 18 mo CA
Clandinin 2002 Canada: 57 wk PMA parallel RCT ^193^ | DHA+AA (SCO) (n=112) | DHA+AA (fish oil) (n=130)/ control formula (n=119) | NS in GP at 40, 57 wks PMA | n/a | Not assessed | X
| | | S↑ wt in DHA+AA (SCO) than in control at 66–118 wks PMA^+^
| | | S↑ L in DHA+AA (SCO) than in other 2 formulas at 79, 92 wks PMA^+^

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

HM = human milk group;

wt = weight;

L = length;

HC = head circumference;

AC = arm circumference;

Δ = change;

RBC = red blood cells;

PE = phosphatidyl ethanolamine;

PC = phosphatidylcholine;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

PMA = postmenstrual age;

GP = growth patterns;

CA = corrected age;

SCO = single cell oil;

TG = tryglicerids

Summary Table 21: Omega-3 fatty acids and growth parameters of preterm infants

Summary Table 21: Omega-3 fatty acids and growth parameters of preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,^ ^3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Innis, 2002, US, Canada: 28 d multiceneter parallel RCT ^201^ | DHA+AA formula (n=66) | DHA formula (n=66)/ control formula (n=62) | S↑ Δ wt in DHA+AA than in control at 40 wks PMA^++^ | S (+) correlation between Δ wt & RBC PE AA at 8 wks S | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
| | | S↑ wt, L, wt-to-L in DHA+AA than in DHA at 48 wks PMA^++^ | (+) correlation between wt, L & RBC PE AA at 8 wks
| | | S↑ wt, wt-to-L in DHA+AA than in control at 48 wk PMA^++^
| | | NS in HC at 48, 57 wk PMA
Groh-Wargo, 2002, Canada, US: 12 mo CA parallel RCT ^256^ | LCP-1 (n=18) | LCP-2 (n=18)/ control formula (n=21) | NS in GP at 12 mo CA | n/a | Not assessed | X
Koletzko, 2003 Germany: 28 days parallel RCT ^257^ | LCP formula (n=15) | Control formula (n=15)/ HM (n=19) | NS wt, L, HC at 28 d | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | III
Fewtrell, 2004 UK: 9 mo CA parallel RCT ^258^ | LCPUFA formula (n=122) | Control formula (n=116) | (ITT) S↑ Δ wt, ΔL in LCPUFA than in control at 9 mo CA^+^ | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
| | | NS in HC at 9 mo CA NS in PG at 18 mo CA

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

ITT = intention to treat;

HM = human milk group;

wt = weight;

L = length;

HC = head circumference;

GP = growth parameters;

PMA = post menstrual age;

PT = post term;

CA = corrected age;

Δ = change;

RBC = red blood cells;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 22: Omega-3 fatty acids and growth parameters of term infants

Summary Table 22: Omega-3 fatty acids and growth parameters of term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Ponder, 1992, US: 8 wk parallel RCT ^260^ | Soy oil formula (n=11*) | Corn oil formula (n=14*)/ HM (n=18*) | NS in wt, L, HC at 3d, 4wk, 8wk | n/a | Jadad total: 1 [Grade: C]; Schulz: Unclear | II
Decsi, 1995, Hungary: parallel RCT ^261^ | DHA+EPA+AA formula (n=10) | Control formula (n=12) | NS in Δ wt, ΔL, ΔHC at 4 mo | n/a | Jadad total: 1 [Grade: C]; Schulz: Unclear | III
Makrides, 1995, Australia: 30 wk parallel RCT ^262^ | DHA+EPA+AA fish oil formula (n=13*) | Control formula (n=19*)/ HM (n=47*) | NS in wt, L, HC at 6, 16, 30 wks | NS correlation of RBC LCPUFA & GP | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
Jensen, 1997, US: 120 d parallel RCT ^203^ | F1 (LA/ALA 44) (n=20)/ F4 (LA/ALA 4.8) (n=20) | F2 (LA/ALA 18.2) (n=20)/ F3 (LA/ALA 9.7) (n=20) | S↓ wt in F4 than in F1 at 4 mo^+^ NS in L, HC, TST, & SST at 4 & 8 mo | S (+) correlation between W at 4 mo & plasma AA at 120d NS correlations between wt & plasma n-3 at 4 mo | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
Innis, 1997, US, Canada: 3 mo MLT parallel RCT ^263^ | LA/ALA 9.5 (n=69) | LA/ALA 7.3 (n=70)/ HM (n=99) | NS in wt, L, & HC at 3 mo | NS correlations between GP & plasma & RBC AA | Jadad total: 2 [Grade: C]; Schulz: Unclear | I
Auestad, 1997, US: 12 mo parallel ^104^ | DHA+AA (n=46*)/ HM (n=63*) | DHA (n=43*)/ control formula (n=45*) | NS in wt, L, HC at 12 mo | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

* = number of participants who completed study;

HM = human milk group;

BW = birth weight;

BL = birth length;

wt= weight;

L = length;

HC = head circumference;

Δ = change;

RBC = red blood cells;

GP = growth parameters;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p <.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

HM = human milk;

GP = growth parameters;

TST = triceps skinfold thickness;

SST = subscapular skinfold thickness

Summary Table 23: Omega-3 fatty acids and growth parameters of term infants

Summary Table 23: Omega-3 fatty acids and growth parameters of term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Jorgensen 1997, Denmark: 3 mo parallel RCT ^264^ | DHA+GLA formula (n=12)/ HM (n=17) | DHA formula (n=14)/ Control formula (n=11) | NS in wt, L, HC, GV at 1, 2, & 4 mo | n/a | Jadad total: 2 [Grade: C]; Schulz: unclear | III
Birch, 1998, US: 17 wk parallel RCT ^182^ | DHA+AA (n=26)/ HM (n=29) | DHA (n=26)/ control formula (n=26) | NS in wt, L, HC, TST, SST at 17wk | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
Willatts, 1998, UK: 4 mo parallel RCT ^223^ | DHA + AA formula (n=20) | Control formula (n=20) | NS wt, L, HC at 3 mo | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
Makrides, 1999, Australia: 12 mo parallel RCT ^205^ | DHA+AA formula (n=28)/ HM (n=63) | DHA formula (n=27)/ control formula (n=28) | NS in wt, L, HC at 6, 16, 34 wk, 12 mo & 24 mo | S (-) correlation of plasma DHA at 16 wks & wt at 12 mo & 24 mo | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
Lucas, 1999, UK: 6 mo parallel RCT ^265^ | LCPUFA formula (n=154) | control formula (n=155)/ HM (n=138) | NS in wt, L, HC, MAC, SST at 6, 9, 18 mo (ITT) | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Makrides, 2000, Australia: 34 wk parallel RCT ^266^ | LA/ALA 10 formula (n=36) | LA/ALA 5 formula (n=37)/ HM (n=103) | NS in Δ wt, ΔL, Δ HC between 10:1-F & 5:1-F at 6, 16, 34 wks | n/a | Jadad total: 5 [Grade: A];Schulz: Adequate | II
| | | S↑ wt at 6 wks & L at 16 wks in 5:1 F^+^

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

HM = human milk group;

wt = weight;

L = length;

HC = head circumference;

RBC = red blood cells;

GV = growth velocity;

PC = phosphatidylcholine;

PE = phosphatidylethanolamine;

TST = triceps skinfold thickness;

SST = subscapular skinfold thicknessITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 24: Omega-3 fatty acids and growth parameters of term infants

Summary Table 24: Omega-3 fatty acids and growth parameters of term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Lapillonne, 2000, France: 4 mo parallel RCT ^267^ | DHA(fish oil)- low EPA formula (n=12) | Control formula (n=12)/ HM (n=13) | S↑ HC in control than in LCPUFA & HM at 4mo^+^ NS in wt, L, at 2, 4 mo | Jadad total: 1 [Grade: C]; Schulz: Unclear | III
Morris, 2000, UK: 12 wk parallel RCT ^268^ | DHA-TGL formula (n=54*) | Control formula (n=55*) | S↑ SST in DHA at 6 wk & 3 mo^+^ NS at 6 mo & 12 mo NS in wt, L, HC, MAC, TST at 6 wk, 12 wk, 6 mo, 12 mo | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
Auestad, 2001a, US: 12 mo parallel RCT ^227^ | DHA+ AA (egg-TG) formula (n=80) | DHA+ AA (fish/fungal) formula (n=82)/ control formula (n=77) | NS in wt, L, HC at 1, 2, 4, 6, 9, & 12 mo S↑ wt gain in males in DHA+AA (egg) at 4 mo | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
Auestad, 2001b, US: 1 y, parallel RCT ^227^ | DHA + AA formula + HM (n=83) | Control formula + HM (n=82) | NS in wt, L, HC at 1, 2, 4, 6, 9, & 12 mo or in wt, L, HC gain | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
Birch, 2002, US: 46 wk parallel RCT ^269^ | LCP formula (n=32) | Control formula (n=33) | NS in wt, L, HC, TST & SST at 0,6,17,26 & 52 wks | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Hoffman, 2003 US: 7 mo Parallel RCT ^270^ | DHA+AA formula (n=30) | Control formula (n=31) | NS in wt, L, HC, wt-for-L at 4,6,9 & 12 mo | Jadad total: 3 [Grade:B]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

FAs = fatty acids;

* = number of participants who completed study;

HM = human milk group;

W = weight;

L = length;

HC = head circumference;

MAC = mid-arm circumference;

SST = sum of skinfold thickness;

TST = triceps skinfold thickness;

SST = subscapular skinfold thickness;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 25: Association between growth patterns and biomarker content in infants

Summary Table 25: Association between growth patterns and biomarker content in infants

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,^ ^3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Guesnet, 1999, France: 6 wk parallel RCT ^143^ | High-EPA (n=23)/ HM (n=15) | Low-EPA (n=24)/ pb (n=21) | S (-) correlation between Δ L & plasma & RBC EPA at birth | Jadad total: 2 [Grade: C]; Schulz: Unclear | III
Innis, 2001, Canada: prospective single cohort ^271^ | Term breastfed infants (n=83) | n/a | RBC CPG DHA^++^ & EPG DHA^+^ negative correlation with infant weight (6 mo); no correlation at 12 mo; no correlation of blood AA & growth patterns at any age | Quality score: 8 [Grade A] | III

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

Δ = change;

L = length;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction;

HM = human milk;

L = length

Summary Table 26: Influence of omega-3 fatty acids intake during pregnancy on neurological development of their infants

Summary Table 26: Influence of omega-3 fatty acids intake during pregnancy on neurological development of their infants

Author, Year, Location: Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Helland, 2001, Norway: 34 wks parallel RCT ^141^ | Cod liver oil DHA+EPA (n=301) | Corn oil LA+ALA (n=289) | NS EEGs scores between groups (3 mo) | Jadad total: 4 [Grade: A]; Schulz: Unclear | III

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction;

EEG = electroencephalogram

Summary Table 27: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences neurological development in term or preterm human infants

Summary Table 27: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences neurological development in term or preterm human infants

Author, Year, Location: Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Gibson, 1997, Australia: 12 wk parallel RCT ^138^ | 1.3 g/d DHA (n=8)/ 0.2 g/d DHA (n=10) | 0.9 g/d DHA (n=10)/ 0.4 g/d DHA (n=12)/ pb (n=12) | NS in PDI at 12 mo and 24 mo | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
| | | No correlation of sociodemographics & PDI at 1 y
| | | Positive correlation between level of education of partner & PDI^+^
Agostoni, 2001, Italy: Single prospective cohort ^284^ | Term breastfed infants at 1 y-old (n=44) | n/a | NS correlation between Bayley's PDI & length of BF | Quality score: 8 [Grade A] | III
| | | NS correlation between Bayley's PDI & milk FA content

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

PDI = psychomotor developmental index;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction;

BF = breast feeding;

PDI = Bayley's psychomotor scale

Summary Table 28: Omega-3 fatty acids and its influence on neurological development in preterm infants

Summary Table 28: Omega-3 fatty acids and its influence on neurological development in preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Bougle, 1999, France: 30 d parallel RCT ^254^ | AA+EPA+ DHA formula (n=14) | LA (n-6)+ ALA (n-3) formula (n=11)/ HM (n=15) | NS LAEP between d 0 & 30d | Jadad total: 3 [Grade: B]; Schulz: Unclear | III
| | | S↑ Δ motor NCT (m/s) in DHA/EPA/AA supplemented formula & HM from d0-30^+^
| | | NS Δ sensory (m/s) test
O'Connor, 2001, US, UK, Chile: 12 mo parallel RCT ^207^ | DHA+AA (fish/fungal) (n=140)/ HM (n=43) | DHA+AA (egg-TG/fish) (n=143)/ Control formula (n=144) | (ITT) S↑ PDI score in <1250 g birth wt fed AA+DHA (egg-TG/fish) than control infants^++^ NS score control or AA+DHA (fish/fungal) groups | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
van Wezel-Meijler, 2002, The Netherlands: 6 mo, parallel RCT ^272^ | AA+DHA preterm formula (n=22) | Control formula (n=20) | S↑ PDI score unsupplemented group vs. supplemented formula at 3, 6, 12 & 24 mo^+^ | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
Fewtrell, 2002, UK: 33 d parallel RCT ^273^ | AA+DHA+EPA preterm formula (n=95) | Control formula (n=100)/ HM (n=88) | (ITT) NS PDI score between formula gps at 18 mo S ↑ PDI in the HM group vs. both formula gps | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
| | | NS between formula gps in KPSDSI at 9 mo; HM S ↑ quotient vs. formulas
Clandinin, 2002, Canada: 92 wks parallel RCT ^193^ | DAS (DHA+AA from SCO) (n=72)/ HM (n=105) | DAF (DHA from fish oils+AA from SCO) (n=90)/ Control formula (n=83) | S↑ PDI score formula gps (DAS, DAF) vs. control gp | Not assessed | X
Fewtrell, 2004, UK: 9 mo parallel RCT ^258^ | GLA+ DHA formula (n=122) | Control formula (n=116) | (ITT) NS formula groups in Bayley's PDI scores at 18 mo | Jadad total: 5 [Grade: A]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acidLength = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

grp = group;

wk = week(s);

mo = month;

wt = weight;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

NCT = nerve conduction test;

LAEP = latency auditory evoked potentials;

SCO = single-cell oil;

HM = human milk;

TG = triglycerides

Summary Table 29: Omega-3 fatty acids and its influence on neurological development in term infants

Summary Table 29: Omega-3 fatty acids and its influence on neurological development in term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,^ ^3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Agostoni, 1995, Italy: 4 mo Parallel RCT ^176^ | DHA+ EPA+ AA formula (n=27) | Control formula (n=29)/ HM (n=30) | S better score in DHA+EPA in Brunet-Lezine test (DQ) at 4^++^ | RBC DHA at 4 mo S + correlation with DQ at 4 mo NS at 24 mo | Jadad total: 4 [Grade: A]; Schulz: Unclear | II
| | | NS at 24 mo | NS at 24 mo
Auestad, 1997, US: 12 mo parallel RCT ^104^ | Formula DHA+AA (n=46)/ HM (n=63) | Formula DHA (n=43)/ control formula (n=45) | S better in control gp vs. DHA+AA in PDI at 12 mo | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
| | | NS among 3 gps
Lucas, 1999, UK: 6 mo parallel RCT ^265^ | Formula LCPUFA (n=154) | control formula (n=155)/ HM (n=138) | NS in PDI at 18 mo; NS in KPS at 9 mo (ITT) | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Birch, 1998, US: 17 wk parallel RCT ^182^ | Formula DHA+AA (n=27) | Formula DHA (n=26)/ NR pb (n=26) | NS in PDI at 18 mo; NS in BRS at 18 mo | NS correlation of PDI & BRS at 18 mo and plasma & RBC LA, ALA, AA, EPA, or DHA at 4 mo & 12 mo | Jadad total: 5 [Grade: A]; Schulz: Unclear | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA; n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = linolenic acid;

LA = alpha linoleic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

HM = human milk group;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

PDI = psychomotor developmental index, Bayley scale;

KPS = Knobloch, Passmark, and Sherrard's test;

BRS = behavioral rating scales;

RBC = red blood cells;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

DQ = developmental quotien;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001

Summary Table 30: Omega-3 fatty acids and its influence on neurological development in term infants

Summary Table 30: Omega-3 fatty acids and its influence on neurological development in term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,^ ^3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Makrides, 1999, Australia: 12 mo parallel RCT ^205^ | Formula DHA+AA (n=28)/ NR HM (n=63) | Formula DHA (n=27)/ NR pb (n=28) | NS in PDI at 12 & 24 mo | S correlation between PDI at 12 mo & plasma AA levels at 12 mo | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
Auestad, 2001a, US: 12 mo parallel RCT ^227^ | DHA+ AA (egg-TG) formula (n=80) | DHA+ AA (fish/fungal) formula (n=82)/ control formula (n=77) | NS in PDI at 6 & 12 mo | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
Auestad, 2001b, US: 1 y, parallel RCT ^227^ | DHA + AA formula/ HM (n=83) | Control formula/ HM (n=82) | NS in PDI at 6 & 12 mo | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
Jensen, 1997, US: 120 d parallel RCT ^203^ | Formula 1 LA/ALA 44/1 (n=20)/ F 3 LA/ALA 9.7/1 (n=20) | Formula 2 LA/ALA 18.2/1 (n=20)/ F 4 LA/ALA 4.7/1 (n=20) | NS in PDI at 12 mo | S correlation between plasma DHA & PDI | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
| | | S ↓ score (Gross motor DQ) in F 1 & F 3 vs. F2 & 4^+^ | NS correlation between RBC DHA & PDI

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

LA = linolenic acid;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

HM = human milk group;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = significant statistical difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

PDI = psychomotor developmental index, Bayley scale;

CLOG = cod liver oil group;

COG = corn oil group;

RBC = red blood cells;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001; ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

DQ = developmental quotien

Summary Table 31: Association of neurological development outcomes and biomarkers content in infants (observational study)

Summary Table 31: Association of neurological development outcomes and biomarkers content in infants (observational study)

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,^ ^3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Cheruku, 2002, US: Cross-sectional ^274^ | Healthy pregnant women high DHA (n=10) | Healthy pregnant women low DHA (n=7) | Maternal DHA was (-) associated with AS, AS:QS & sleep-wake transition^+^ (d 2) | Quality score: 6 [Grade B] | I
| | | Maternal DHA (+) associated with wakefulness^+^ (D2)
| | | n-6:n-3 ratio in maternal plasma was (+) associated with AS, AS:QS &sleep-wake transition^+^ (d 1)
| | | n-6:n-3 ratio in maternal plasma was (-) associated to wakefulness^+^ (d 1)

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction;

AS = active sleep;

QS = quiet sleep

Summary Table 32: Association of neurological development outcomes and biomarkers content in infants (observational study)

Summary Table 32: Association of neurological development outcomes and biomarkers content in infants (observational study)

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,^ ^3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Innis, 2001, Canada: Prospective single cohort ^271^ | Term breastfed infants (n=83) | n/a | NS RBC DHA or AA at 2 mo & Bayley's PDI score (6–12 mo) | Quality score: 8 [Grade A] | II

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction

Summary Table 33: Omega-3 fatty acids intake during pregnancy and its influence on visual function in term infants

Summary Table 33: Omega-3 fatty acids intake during pregnancy and its influence on visual function in term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,^ ^3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n) Group 5
Malcolm, 2003, Denmark: 15 wks Parallel RCT ^235^ | DHA (fish oil) capsules (n=50)/ term infants (n=31) | Pb capsules (oleic sunflower oil) (n=50)/ term infants (n=29) | NS in b wave implicit time | NS correlation of max combined ERG & cord blood DHA | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
| | | NS in Naka-Rushton function | NS (-) correlation of log δ & cord blood AA
| | | NS in log δ | S (+) correlation of log δ & cord RBC proportion DHA^+^ & total n-3 FA ^+^, n-6/n-3^+^
| | | NS in maximium combined ERG | S correlation of log δ & cord RBC quartiles of DHA^+++^, AA^+^, total n-3 LCPUFAs ^+^
Krasevec, 2002, Cuba: cross-sectional ^275^ | Healthy pregnant women (n=56) Breastfed infants (n=56) | HM + formula infants | Visual acuity scores 99% prediction for 2.5 mo old infants | NS correlation visual acuity & any individual PUFA concentration, ratio of PUFA concentrations or concentrations of groups of PUFAs in infant tissues | Quality score: 7 [Grade B] | III
| | | NS Mean values for visual acuity between HM vs. HM + formula infants

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction;

HM = human milk

Summary Table 34: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences visual function in term or preterm human infants

Summary Table 34: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences visual function in term or preterm human infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,^ ^3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n) Group 5
Gibson, 1997, Australia: 12 wk parallel RCT ^138^ | 1.3g/d DHA (n=8)/ 0.2g/d DHA (n=10) | 0.9g/d DHA (n=10)/ 0.4g/d DHA (n=12)/ pb (n=12) | NS VEP acuity between dietary groups at 12 & 16 wks | No correlation VEP & DHA HM, infant plasma or RBC LCPUFA | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
Jensen, 1999, US: 12 mo parallel RCT ^248^ | Algal DHA (n=42) | Fish oil DHA (n=42)/ Placebo (n=42) | NS VEP latency, sweep VEP acuity or Teller Card Acuity at 120 or 240 d | NS correlation visual function & infant plasma PL DHA at 120 d | Not assessed | X

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported; ;

S = statistically significant difference;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction;

BF = breast feeding;

VEP = visual evoked potentials;

HM = human milk

Summary Table 35: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences visual function in term or preterm human infants

Summary Table 35: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences visual function in term or preterm human infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,^ ^3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n) Group 5
Jorgensen, 2001, Denmark: Cross-sectional ^140^ | Term infants HM (BF) (n=39) | n/a | S association between visual acuity (VEP) at 4 mo & mother's milk DHA^+^ | NS association between AA, EPA, LA & ALA (n-3) with visual acuity | Quality score: 9 [Grade A] | III
Williams, 2001, UK: Prospective cohort ^276^ | Term infants HM (BF) (n=334) | Term infants never breastfed (n=101) | BF was S correlated to foveal (adult) stereacuity | S correlation between child's stereoacuity at 3.5 y & antenatal mother's RBC DHA content | Quality score: 9 [Grade A] | III
| | | Maternal oily fish intake during pregnancy was S correlated with foveal stereoacuity

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction;

BF = breast feeding;

VEP = visual evoked potentials;

HM = human milk

Summary Table 36: Omega-3 fatty acids intake associated with the visual function in preterm infants

Summary Table 36: Omega-3 fatty acids intake associated with the visual function in preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker^2,^ ^3^ correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Birch, 1992, US: 6 mo parallel RCT ^212^ | Soy/marine oil: EPA+ DHA (n=26)/ HM (n=8) | Soy oil: ALA (n=22)/ Corn oil (n=18) | S↓ in VEP for all grps at 57 wks | S correlation between: RBC-DHA/DPA & VEP^+++^ | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
| | | S ↓ VEP in DHA+EPA vs. grps 2–3 at 36–57 wks^+^ | RBC-DHA/DPA & FPL^+^ at 57 wks
| | | NS b-Rod ERG at 36–57 wks
Carlson, 1992, US: 12 mo parallel RCT ^185^ | Marine oil: DHA + EPA (n=33) | Control: LA (n=34) | S ↑ resolution acuity in DHA +EPA vs. control at 2 & 4 mo ^+++^ | S correlation (+) RBC DHA at 2 mo with visual acuity at 2,4 mo | Jadad total: 4 [Grade: A]; Schulz: Adequate | II
Koletzko, 1995, Germany: 21 d parallel RCT ^251^ | LCPUFA-enriched: DHA + EPA + ALA (n=9) | Control: (n=10)/ HM (n=8) | NS difference in visual acuity across at 21 d | n/a | Jadad total: 2 [Grade: C]; Schulz: Unclear | III
Carlson, 1996, US: 4 mo parallel RCT ^191^ | Marine oil: DHA +EPA (n=26) | Control ALA (n=23) | S↑ higher acuity in DHA+EPA vs. control at 2 mo^+^ NS at 4–12 mo | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
Faldella, 1996, Italy: 5 mo parallel RCT ^198^ | LCPUFA-enriched: DHA +EPA+ ALA (n=21) | Control EPA + ALA (n=25)/ HM (n=12) | S shorter wave (N4 & P4) latencies VEP in DHA+EPA vs. control at 52 wks PCA^++^ | At 52 wks PCA, inverse correlation between: RBC-DHA & N4 wave latency ^+^ & RBC-DHA & P4 wave latency^++^ | Jadad total: 1 [Grade: C]; Schulz: Unclear | III
| | | NS in BAEP & ERG (a & b) latencies) across grps1–3
Bougle, 1999, France: 30 d parallel RCT ^254^ | LCPUFA-enriched: DHA + EPA + ALA (n=14) | Control (n=11)/ HM (n=15) | NS in VEP (N1 wave latency) at 30 d | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

HM = human milk;

GA = gestational age;

PCA = postconception age;

CA = corrected age;

ERG = electroretinogram;

BAEP = brainstem acoustic evoked potential

Summary Table 37: Omega-3 fatty acids intake associated with the visual function in preterm infants

Summary Table 37: Omega-3 fatty acids intake associated with the visual function in preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
O'Connor, 2001, US, UK, Chile: 14 mo parallel RCT ^207^ | Fish/fungal oil: DHA 0.27% EPA 0.08% ALA 2.60% (n=140)/ HM (n=43) | Egg-TG/fish oil: DHA 0.24% ALA 2.50% (n=143)/ Control ALA 2.4% (n=144) | (ITT) NS in VEP/FPL acuity at 4 mo CA | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
| | | S ↑VEP acuity in grps1–2 vs. grp3 at 6 mo CA ^++^
| | | NS VEP acuity across both DHA+AA grps
van Wezel-Meijler, 2002, Netherlands: 8 mo parallel RCT ^272^ | LCPUFA-enriched: DHA 0.34% AA 0.70% (n=22) | Control (n=20) | NS in VEP (P200 & N300) wave latencies at 3 & 12 mo CA | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
| | | NS mean visual acuity at 3,6,12 mo CA
Innis, 2002, US, Canada: 28 d parallel RCT ^201^ | LCPUFA-enriched: DHA 0.33% AA 0.60% (n=66)/ HM (n=90) | LCPUFA-enriched: DHA 0.34% (n=66)/ Control (n=62) | NS in FPL visual acuity at 48 & 57 wks PCA | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
| | | S↑ visual acuity in HM than grps1–3 at 57 wks PCA ^+^

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

GA = gestational age;

PCA = postconception age;

CA = corrected age;

ERG = electroretinogram;

VEP = visual evoked potential;

FPL = forced-choice preferential looking using Teller's card test

Summary Table 38: Omega-3 fatty acids intake associated with visual function in term infants

Summary Table 38: Omega-3 fatty acids intake associated with visual function in term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Makrides, 1995 Australia: 30 wk parallel RCT ^262^ | DHA+GLA (n=13) | control (n=19) | S improved VA of DHA+GLA infants at 16 wk^+++^ & 30 wk^++^ | S correlation RBC DHA & VEP acuity at 16 wk^+++^ & 30 wk^++^ of age | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
| | | S ↑ % of DHA+GLA infants were able to evoke cortical responses to the smallest checkerboard pattern^+++^
Carlson, 1996, US: 12 mo parallel RCT ^277^ | DHA+AA (n=19) | Control (n=20) | S better VA with DHA+AA at 2 mo of age ^++^ | n/a | Jadad total: 3 [Grade: B]; Schulz: unclear | II
Jorgensen, 1998, Denmark: 4 mo parallel RCT ^264^ | DHA+EPA (n=12) | DHA+EPA+GLA (n=14)/ control (n=11) | NS effect of DHA on VA | NS VA at 4 mo & RBC DHA, EPA, or AA S negative correlation VA & RBC CPG LA^+^ | Jadad total: 2 [Grade: C]; Schulz: Unclear | III
Auestad, 1997, US: 12 mo parallel RCT ^104^ | DHA 0.01% fa (n=43) | DHA+AA (n=46)/ control (n=45) | NS acuity thresholds at 2,4,6,9 or 12 mo of age using either VA method NS FPL at 2,4,6,9, 12 or 39 mo of age | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
Innis,1997, US, Canada: 90 d parallel RCT ^263^ | LA/ALA 9.5/1 (n=59) | LA/ALA 7.3/1 (n=57) | NS FPL at 90 d of age | NS VA & plasma & RBC CPG DHA | Jadad total: 2 [Grade: C] Schulz: Unclear | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

VA = visual acuity;

PL = phospholipids;

d = day(s);

GLA = γ-linolenic acid;

FPL = forced-choice preferential looking using Teller's card test

Summary Table 39: Omega-3 fatty acids intake associated with visual function in term infants

Summary Table 39: Omega-3 fatty acids intake associated with visual function in term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Jensen,1997, US: 120 d parallel RCT ^203^ | F1 (LA/ALA 44) (n=20)/ F4 (LA/ALA 4.8) (n=20) | F2 (LA/ALA 18.2) (n=20)/ F3 (LA/ALA 9.7) (n=20) | NS latency VEP among gps at 120 & 240 d | NS plasma & RBC PL DHA & amplitude at 120 & 240 d | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
| | | NS amplitude VEP among gps at 120 & 240 d
Birch, 1998, US: 4 mo parallel RCT ^182^ | DHA (n=20) | DHA + AA (n=19)/ control (n=21) | S poorer sweep VEP acuity in control than DHA^+++^ or DHA^+^AA ^+++^ at 6 wk; DHA^++^ or DHA^+^AA^+^ at 17 wks; DHA^++^ or DHA^+^AA^++^ at 52 wks | S RBC DHA 17 wks & better sweep VEP acuity at 6 wk^+++^, 17 wk^++^ & 52 wk^+++^ | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
| | | NS diet on FPL acuity | S 6 wk sweep VEP acuity & 17 wk RBC n-3/n-6 LCPUFA^+++^
| | | S better ERG & DHA or DHA^+^AA at 6 wk^+^ | S 17 wk RBC n-3/n-6 LCPUFA & sweep VEP at 6 wk^+++^, 17 wk+, 52 wk^+++^
| | | | S log k & RBC CPG DHA at 6 wk^+^
Auestad, 2001a, US: 4 mo parallel RCT ^227^ | DHA+ AA (egg-TG) formula (n=80) | DHA+ AA (fish/fungal) formula (n=82)/ control formula (n=77) | NS FPL at 2,4,6 & 12 mo of age | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
Auestad, 2001b, US: 4 mo parallel RCT ^227^ | DHA + AA formula/ HM (n=83) | Control formula/ HM (n=82) | NS VA between groups | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

VA = visual acuity;

PL = phospholipids;

d = day(s);

FPL = forced-choice preferential looking using Teller's card test;

HM = human milk;

VEP = visual evoked potential;

F = formula;

ERG = electroretinogram

Summary Table 40: Omega-3 fatty acids intake associated with visual function in term infants

Summary Table 40: Omega-3 fatty acids intake associated with visual function in term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Makrides, 1999, Australia: 1 y Parallel RCT ^205^ | DHA (n=22) | DHA+AA (n=19)/ control (n=19) | NS VEP acuity at 16 or 34 wk | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
Makrides, 2000, Australia: 34 wk Parallel RCT ^266^ | LA/ALA 10/1 (n=30) | LA/ALA 5/1 (n=28) | NS VEP acuity at 16 & 34 wk | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Birch, 2002 US: 46 wk Parallel RCT ^269^ | DHA+AA (n=30) | Control (n=28) | NS DHA^+^AA on sweep VEP at 6 wk | S better sweep VEP & plasma AA at 17^++^, 52^+++^ wk & plasma DHA at 17^+++^, 52^+++^ wk | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
| | | S DHA^+^AA & better sweep VEP 17^++^, 26^+++^ & 52 wk ^+++^ | S better sweep VEP & RBC AA at 52 wk^++^ & RBC DHA at 17^++^ & 52^+++^ wk
| | | S DHA+AA & better FPL at 17^++^ | NS sweep VEP & plasma or RBC LA or ALA at 17 or 52 wk
| | | | S better FPL & plasma DHA at 17 wk^++^ or RBC LA at 17 wk^+++^
| | | | NS FPL & plasma or RBC ALA, AA, plasma LA, or RBC DHA
Hoffman, 2003 US: 7 mo Parallel RCT ^270^ | DHA+AA (n=30) | Control (n=31) | S better sweep VEP & DHA+AA at 12 mo^+++^ | S better sweep VEP at 12 mo & RBC | Jadad total: 3 [Grade:B]; Schulz: Adequate | II
| | | NS DHA+AA & FPL at 4,6,9, & 12 mo | DHA^+++^, Σ n-3 LCPUFAs^+++^, n-3/n-6 LCPUFAs^++^, DHA/DPA^++^, n-6 unsaturation index^++^
| | | | S poorer sweep VEP at 12 mo & RBC LA^++^, AA^++^
| | | | NS FPL & RBC n-3 or n-6 FA

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

VA = visual acuity;

PL = phospholipids;

d = day(s);

FPL = forced-choice preferential looking using Teller's card test;

VEP = visual evoked potentials

Summary Table 41: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and visual function development in term and preterm infants

Summary Table 41: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and visual function development in term and preterm infants

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Birch, 1993a, US: Cross-sectional ^278^ | Preterm infants breastfed (n=15) | Preterm infants corn oil formula (n=15) | LogMAR acuity was S correlated with the ratio [DHA n-3/DPA n-6] in total RBC lipids^+++^ | Quality score: 4 [Grade B] | III
| | | FPL acuity LogMAR was S correlated with the ratio DHA n-3/DPA n-6^++^
| | | RBC ratio was S ↑ in HM than in formula fed^++++^
Birch, 1993b, US: Cross-sectional ^278^ | Term infants 4 mo CA breastfed (n=NR) / Term infants 36 mo CA corn oil formula (n=NR) | Term infants 4 mo CA corn oil formula (n=NR) / Term infants 36 mo CA breastfed (n=NR) | Mean VEP & FPL acuities better in HM than in formula (4 mo)^+^ | Quality score: 4 [Grade B] | III
| | | Mean RBC DHA/DPA in total RBC lipids was S ↑^++++^ HM than in formula group & stereo acuity was S correlated with the end-product ratio^+^
| | | Letter matching (36 mo) was S correlated with ratio, RBC DHA/DPA (4 mo)^+^
Makrides, 1993, Australia: Cross-sectional ^280^ | Term infants breastfed (n=8) | Term infants formula fed (n=8) | HM group S ↓ logMAR (i.e., better VEP acuity) than formula-fed (5 mo) | Quality score: 4 [Grade B] | III
| | | S correlation between logMAR (VEP acuity) & % DHA^+^ & LA^+^ in RBC PL

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

LBM = low breast milk;

HBM = high breast milk;

FPL = forced-choice preferential looking;

HM = human milk;

CA = corrected age;

ERG = electroretinogram;

VEP = visual evoked potential

Summary Table 42: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and visual function development in term and preterm infants

Summary Table 42: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and visual function development in term and preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Innis, 1994, Canada: Cross-sectional ^281^ | Term infants breastfed (n=17) | Term infants formula fed (n=18) | NS between groups in visual acuity test (14 d & 3 mo) | Quality score: 5 [Grade B] | III
| | | Visual acuity NS to diet or plasma PL, RBC PC or PE concentrations of DHA on entire group of infants or within the breastfed or formula-fed group of infants
Leaf, 1996, Australia: Cross-sectional ^279^ | Preterm infants HBM (n=9) | Preterm infants LBM (n=9) | S (+) correlation between scotopic b wave implicit time & % DHA in plasma^+++^ & RBC PL^+^, total n-3 LCPUFA in plasma^++^ & RBC PL^++^ | Quality score: 6 [Grade B] | III
| | | (+) correlation between RBC AA^+^ & total n-6 LCPUFA^+^ & scotopic a-b amplitude
| | | NS relationships were seen between photopic ERGs & plasma or RBC LCPUFAs
Jorgensen, 1996, Denmark: Cross-sectional ^282^ | Term infants breastfed (n=17) | Term infants formula fed (n=16) | Visual acuity ↑ overtime in both feeding groups^+++^, S ↑ increase in HM group^+++^ | Quality score: 5 [Grade B] | III
| | | NS correlation between RBC DHA & visual between groups (4 mo)
| | | NS correlation between AA levels & visual acuity

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction

Summary Table 43: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and visual function development in term and preterm infants

Summary Table 43: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and visual function development in term and preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Innis, 2001, Canada: Cross-sectional ^271^ | Term infants breastfed (n=83) | n/a | RBC PE DHA (2 mo) was S (+) correlated to visual acuity at 2 mo^++^ & 12 mo^+^ | Quality score: 8 [Grade A] | III
| | | NS at 4 & 6 mo
| | | Infants with RBC PE DHA <8.53g/100g had S ↓ visual acuity at 2 & 12 mo than infants with > 10.78g/100g FA^+^
Krasevec, 2002, Cuba: Cross-sectional ^275^ | Mother/term infants breastfed (n=31) | Mother/term infants formula fed (n=23) | NS correlations between visual acuity & EFA concentration, ratio of EFA, or group of PUFA in infant tissues | Quality score: 7 [Grade B] | III
| | | NS correlation for full sample & each feeding group (i.e., exclusively breast milk vs. not exclusively breastfed)
| | | NS correlation between PUFA profiles of maternal tissues for exclusively breastfed infants & visual acuity

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction

Summary Table 44: Omega-3 fatty acids and its influence on cognitive development in infants after intake during pregnancy and breast feeding

Summary Table 44: Omega-3 fatty acids and its influence on cognitive development in infants after intake during pregnancy and breast feeding

Author, Year, Location: Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Helland, 2001, Norway: 34 wks parallel RCT ^141^ | Cod liver oil (DHA+EPA) (n=301) | Corn oil (LA+ALA) (n=289) | NS novelty preference (Fagan test) at 6 & 9 mo | Jadad total: 4 [Grade: A]; Schulz: Unclear | III
| | | NS correlation between level DHA & novelty preference (6 & 9 mo)
| | | Cod liver oil > Mental Processing K-ABC score than corn oil (4 y)^+^

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

N/A = not applicable;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction

Summary Table 45: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences cognitive development in term or preterm human infants

Summary Table 45: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences cognitive development in term or preterm human infants

Author, Year, Location: Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Gibson, 1997, Australia: 12 wk parallel RCT ^138^ | 1.3g/d DHA (n=8)/ 0.2g/d DHA (n=10) | 0.9g/d DHA (n=10)/ 0.4g/d DHA (n=12)/ pb (n=12) | S correlation between MDI & DHA in infants's diet & status (RBC & plasma at 12 wks) at 1 y^+^ | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
| | | NS at 2 y
| | | S correlation MDI & length of BF at 1 y^+^
| | | NS at 2 y
Agostoni, 2001, Italy: Single prospective cohort ^284^ | Term breastfed infants at 1 y-old (n=44) | n/a | S correlation between Bayley's MDI & milk total fat content at 6 mo^++^, but NS at 12 mo | Quality score: 8 [Grade A] | III
| | | NS AA, DHA milk content correlation with MDI at 12 mo

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

MDI = Mental Developmental Index;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction;

BF = breast feeding

Summary Table 46: Omega-3 fatty acids and its influence on cognitive development in preterm infants

Summary Table 46: Omega-3 fatty acids and its influence on cognitive development in preterm infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Carlson, 1992, US: 6 mo parallel RCT ^185^ | Supplemented formula (marine oil) (n=31) | control formula (n=34) | DHA-supplemented infants had a S ↓ novelty preference vs. control group | Jadad total: 4 [Grade: A]; Schulz: Adequate | II
O'Connor, 2001, US, UK, Chile: 12 mo parallel RCT ^207^ | DHA+AA (fish/fungal) (n=140)/ Human milk (reference standard) (n=43) | DHA+AA (egg-TG/fish) (n=143)/ Control formula (n=144) | (ITT) NS Bayley's MDI (12 mo) M novelty preference look (Fagan test) AA+DHA (egg-TG/fish) > control & AA+DHA (fish/fungal) (6 mo)^++^ | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
van Wezel-Meijler, 2002, The Netherlands: 6 mo, parallel RCT ^272^ | AA+DHA preterm formula (n=22) | Control formula (n=20) | NS Bayley's MDI (3, 6, 12 & 24 mo) | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
Fewtrell, 2002, UK: 33 d parallel RCT ^273^ | AA+DHA+EPA preterm formula (n=95) | Control formula (n=100)/ human milk (n=88) | (ITT) NS Bayley's MDI (18 mo) | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Clandinin, 2002, Canada: 92 wks parallel RCT ^193^ | DAS (DHA+AA from SCO) (n=72)/ human milk (n=105) | DAF (DHA from fish oils+AA from SCO) (n=90)/ Control formula (n=83) | Bayley's MDI: DAS & DAF formulas had > scores than control formula^+^. HM had > scores than the other groups (118 wks PMA)^+^ | Not assessed | X
Fewtrell, 2004, UK: 9 mo parallel RCT ^258^ | GLA+ DHA formula (n=122) | Control formula (n=116) | (ITT) NS Bayley's MDI (18 mo). Boys in formula > score vs. control^+^ | Jadad total: 5 [Grade: A]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

grp = group;

wk = week(s);

mo = month;

wt = weight;

MDI = Mental Developmental Index;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

SCO = single-cell oil

Summary Table 47: Omega-3 fatty acids as supplemental treatment for cognitive development in term infants

Summary Table 47: Omega-3 fatty acids as supplemental treatment for cognitive development in term infants

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Auestad, 1997, US: 4 mo parallel RCT ^104^ | AA+DHA formula (n=46)/ HM (n=63) | DHA formula (n=43)/ Control formula (n=45) | NS Bayley's MDI between grps at 12 mo | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | I
Birch, 1998, US: 17 wk parallel RCT ^182^ | DHA+AA formula (n=27) | DHA formula (n=26)/ Control formula (n=26) | MDI S better in n-3 formulas vs. control at 18 mo | MDI score at 18 mo correlated (+) with plasma & RBC DHA at 4 mo | Jadad total: 5 [Grade: A]; Schulz: Unclear | I
| | | | RBC-LA & ALA correlated (-) with MDI at 18 mo
Willatts, 1998, UK: 4 mo parallel RCT ^223^ | DHA + AA formula (n=20) | Control formula (n=20) | NS problem-solving scores, intention score & number of solutions at 3 mo | n/a | Jadad total: 3 [Grade: B]; Schulz: Unclear | II
Lucas, 1999, UK: 6 mo, parallel RCT ^265^ | LCPUFA formula (n=154) | Control formula (n=155)/ HM (n=138) | NS Bayley's MDI between grps at 18 mo (ITT) | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Makrides, 1999, Australia: 1 y parallel RCT ^205^ | DHA+ AA formula (n=24)/ HM (n=46) | DHA formula (n=23)/ pb (n=21) | NS Bayley's MDI between groups at 1 or 2 y | NS FA variables correlated MDI scores at 1 or 2 y | Jadad total: 5 [Grade: A]; Schulz: Adequate | III
Auestad, 2001a, US: 1 y, parallel RCT ^227^ | DHA+ AA (egg-TG) formula (n=80) | DHA+ AA (fish/fungal) formula (n=82)/ control formula (n=77) | NS Bayley's MDI between groups at 6 &12 mo | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
Auestad, 2001b, US: 1 y, parallel RCT ^227^ | DHA + AA formula/ HM (n=83) | Control formula/ HM (n=82) | NS Bayley's MDI between grps at 6 & 12 mo | n/a | Jadad total: 5 [Grade: A]; Schulz: Adequate | I
Jensen, 2002, US: 120 d parallel RCT ^203^ | ↑↑ ALA formula (n=20)/ ↓↓ ALA formula (n=20) | ↑ ALA formula (n=20)/ ↓ ALA formula (n=20) | NS Bayley's MDI between grps at 12 mo | NS correlations, CAT/CLAMS DQ & plasma or RBC PL n-3 or n-6 at 120 d CLAMS DQ correlated (+) with RBC PL EPA, not with plasma or RBC PL DHA | Jadad total: 2 [Grade: C]; Schulz: Unclear | II
| | | | CAT DQ correlated + with plasma PL LA (n-6) at 120 d

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acidLength = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

n/a = not applicable;

grp = group;

wk = week(s);

mo = month;

wt = weight;

RBC = red blood cells;

PL = phospholipid;

MDI = Mental Developmental Index;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase;

↓ = decrease/reduction;

HM = human milk;

CAT/CLAMS = Clinical Adaptative Test/Clinical Linguistic and Auditory Milestone Scale;

DQ = developmental quotien

Summary Table 48: Association of cognitive development outcomes and biomarkers content in infants (observational study)

Summary Table 48: Association of cognitive development outcomes and biomarkers content in infants (observational study)

Author, Year, Location: Design | Study groups^1^ | | Notable associations^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Innis, 2001, Canada: Prospective single cohort ^271^ | Term breastfed infants (n=83) | n/a | No correlation between RBC DHA & AA status & Bayley's MDI (6,12 mo), novelty preference (6,9 mo) | Quality score: 8 [Grade A] | III
Ghys, 2002, the Netherlands: Prospective single cohort ^285^ | Term infants (n=128) | n/a | No correlation between plasma or RBC DHA & AA & cognitive development (4 y) | Quality score: 8 [Grade A] | III

1 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

n = sample size;

pts = study participants;

NR = not reported;

S = statistically significant difference;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

MDI = Mental developmental scale;

y = year(s)