# Summary Matrix

Summary Matrix 1: Study quality and applicability of evidence for the influence of LCPUFA on the duration of gestation

Summary Matrix 1: Study quality and applicability of evidence for the influence of LCPUFA on the duration of gestation

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Onwude^A^ | 1995 | 233 | Smuts^I^ | 2003 | 350 | Sumts^U^ | 2003 | 73
| | | | | Malcolm^U^ | 2003 | 100
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Bulstra-Ramakers^A^ | 1994 | 68 | Dunstan^U^ | 2004 | 98 | Olsen^I^ | 1992 | 533
| | Helland^U^ | 2001 | 590 | De Groot^U^ | 2004 | 79 | Olsen^A^ | 2000 | see below^*^

n = number of allocated/selected participants

A RCT = Adequate vs ^U^Unclear allocation concealment

I = Inadequate

* Olsen 2000 6 trials: a) n=232; b)=280; c)n=579; d) n=386; e) n=79; f) n=63

Summary Matrix 2: Study quality and applicability of evidence for the effect of LCPUFA supplementation on the incidence of gestational hypertension, preeclampsia and eclampsia

Summary Matrix 2: Study quality and applicability of evidence for the effect of LCPUFA supplementation on the incidence of gestational hypertension, preeclampsia and eclampsia

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Onwude^A^ | 1995 | 233 | Smuts^I^ | 2003 | 350
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Bulstra-Ramakers^A^ | 1994 | 68 | | | | D'Almeida^I^ | 1992 | 150
| | | | | | | | Laivuori^A^ | 1993 | 18
| | | | | | | | Olsen^A^ | 2000 | 579*
| | | | | | | | Olsen^A^ | 2000 | 386**
| | | | | | | | Olsen^I^ | 1992 | 533

n = number of allocated/selected participants

A RCT = Adequate vs ^U^Unclear allocation concealment; ^I^ Inadequate

* “Earl-PIH” trial

** “Twins” trial

Summary Matrix 3: Study quality and applicability of the evidence for the effect of LCPUFA supplementation on the incidence of infants small for gestational age

Summary Matrix 3: Study quality and applicability of the evidence for the effect of LCPUFA supplementation on the incidence of infants small for gestational age

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Onwude^A^ | 1995 | 233 | Smuts^I^ | 2003 | 250 | Smuts^U^ | 2003 | 73
| | Helland^U^ | 2001 | 590 | Malcolm^U^ | 2003 | 100
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Bulstra-Ramakers^A^ | 1994 | 68 | Dunstan^U^ | 2004 | 98 | Olsen^I^ | 1992 | 533
| | | | | de Groot^U^ | 2004 | 79 | D'Almeida^I^ | 1992 | 150
| | | | | | | | Olsen^A^ | 2000 | 232*
| | | | | | | | Olsen^A^ | 2000 | 280**
| | | | | | | | Olsen^A^ | 2000 | 579***
| | | | | | | | Olsen^A^ | 2000 | 63ˆ

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment; ^I^ Inadequate

* “Earl-PD” trial;

** “Earl-IUGR” trial;

*** “Twins” trial;

ˆ “Susp-IUGR” trial

Summary Matrix 4: Association between duration of gestation in women with or without a history of a previous preterm birth and the the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy

Summary Matrix 4: Association between duration of gestation in women with or without a history of a previous preterm birth and the the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Rump | 2001 | 627 | Elias | 2001 | 84 | Reece | 1997 | 71

n = number of allocated/selected participants

Summary Matrix 5: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers during pregnancy and incidence of preeclampsia, eclampsia or GHT

Summary Matrix 5: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers during pregnancy and incidence of preeclampsia, eclampsia or GHT

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Al | 1995 | 208 | Wang | 1991 | 30 | Craig-Schmidt | 1994 | 36
| | | | | Hofmann | 1998 | 30
| | | | | Shouk | 1999 | 45

n = number of allocated/selected participants

Summary Matrix 6: Incidence of births of SGA human infants and the association with the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy

Summary Matrix 6: Incidence of births of SGA human infants and the association with the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Matorras | 1994 | 69 | Vilbergson | 1991 | 33
| | Rump | 2001 | 627 | Elias | 2001 | 84
| | | | | Cetin | 2002 | 21

n = number of allocated/selected participants

Summary Matrix 7: Omega-3 fatty acids and its influence on growth patterns in infants after intake during pregnancy and breastfeeding

Summary Matrix 7: Omega-3 fatty acids and its influence on growth patterns in infants after intake during pregnancy and breastfeeding

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Helland^ U ^ | 2001 | 590

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

Summary Matrix 8: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences growth patterns in term or preterm human infants

Summary Matrix 8: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences growth patterns in term or preterm human infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Xiang | 2000 | 19
| | | | | Rocquelin | 2003 | 203

n = number of allocated/selected participants;

U = unclear allocation concealment

Summary Matrix 9: Omega-3 fatty acids and growth parameters of preterm infants

Summary Matrix 9: Omega-3 fatty acids and growth parameters of preterm infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | Vanderhoof^A^ | 1997 | 288 | O'Connor^U^ | 2001 | 470
| | | | | Innis^U^ | 2002 | 194
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Carlson^A^ | 1992 | 79 | Carlson^U^ | 1996 | 36 | Carlson^U^ | 1987 | 61
| | Fewtrell^A^ | 2002 | 283 | | | | Uauy^U^ | 1992 | 81
| | Fewtrell^A^ | 2004 | 238 | | | | Ghbremeskel^U^ | 1999 | 61
| | | | | | | | Field^U^ | 2000 | 44
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Koletzko^U^ | 2003 | 49 | Koletzko^U^ | 1994 | 27
| | | | | Bougle^U^ | 1999 | 40 | Faldella^U^ | 1996 | 66
| | | | | | | | Woltil^U^ | 1999 | 143
| | | | | | | | Martinez^U^ | 1999 | 40

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

Summary Matrix 10: Omega-3 fatty acids and growth parameters of term infants

Summary Matrix 10: Omega-3 fatty acids and growth parameters of term infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | N | Author | Year | n
| | Auestad^A^ | 2001 | 239 | Auestad^U^ | 1997 | 274 | Innis^U^ | 1997 | 238
| | Auestad^A^ | 2001 | 165
| II | Author | Year | n | Author | Year | N | Author | Year | n
| | Lucas^A^ | 1999 | 447 | Birch^U^ | 1999 | 79 | Ponder^U^ | 1992 | 43
| | Makrides^A^ | 2000 | 176 | Willatts^U^ | 1998 | 40 | Makrides^U^ | 1995 | 89
| | Birch^A^ | 2002 | 65 | Morris^U^ | 2000 | 140 | Jensen^U^ | 1997 | 80
| | | | | Hoffman^A^ | 2003 | 68
| III | Author | Year | n | Author | Year | N | Author | Year | n
| | Makrides^A^ | 1999 | 146 | | | | Decsi^U^ | 1995 | 22
| | | | | | | | Jorgensen^U^ | 1998 | 39
| | | | | | | | Lapillone^U^ | 2000 | 24

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment; ^I^ Inadequate

Summary Matrix 11: Association between growth patterns and biomarker content in infants

Summary Matrix 11: Association between growth patterns and biomarker content in infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | N | Author | Year | n
| II | Author | Year | n | Author | Year | N | Author | Year | n
| III | Author | Year | n | Author | Year | N | Author | Year | n
| | Innis | 2001 | 83 | | | | Guesnet^U^ | 1999 | 68

n = number of allocated/selected participants;

U = Unclear allocation concealment

Summary Matrix 12: Influence of omega-3 fatty acids intake during pregnancy on neurological development of their infants

Summary Matrix 12: Influence of omega-3 fatty acids intake during pregnancy on neurological development of their infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | N | Author | Year | n
| II | Author | Year | n | Author | Year | N | Author | Year | n
| III | Author | Year | n | Author | Year | N | Author | Year | n
| | Helland^U^ | 2001 | 590

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

Summary Matrix 13: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences neurological development in term or preterm human infants

Summary Matrix 13: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences neurological development in term or preterm human infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | N | Author | Year | n
| II | Author | Year | n | Author | Year | N | Author | Year | n
| | | | | Gibson^U^ | 1997 | 52
| III | Author | Year | n | Author | Year | N | Author | Year | n
| | Agostoni | 2001 | 44

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

Summary Matrix 14: Study quality and applicability of evidence for the effect of LCPUFA supplementation on the neurological development in preterm infants

Summary Matrix 14: Study quality and applicability of evidence for the effect of LCPUFA supplementation on the neurological development in preterm infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | O'Connor^U^ | 2001 | 470
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Fewtrell^A^ | 2002 | 283
| | Fewtrell^A^ | 2004 | 238
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | van Wezel-Meijler^A^ | 2002 | 55 | Bougle^U^ | 1999 | 40

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

Summary Matrix 15: Omega-3 fatty acids and its influence on neurological development in term infants.

Summary Matrix 15: Omega-3 fatty acids and its influence on neurological development in term infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | Birch^U^ | 1998 | 79 | Auestad^U^ | 1997 | 274
| | Auestad^A^ | 2001 | 2391
| | Auestad^A^ | 2001 | 65
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Agostoni^U^ | 1995 | 60 | | | | Jensen^U^ | 1997 | 80
| | Lucas^A^ | 1999 | 447
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Makrides^A^ | 1999 | 146

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

Summary Matrix 16: Association of neurological development outcomes and biomarkers content in infants

Summary Matrix 16: Association of neurological development outcomes and biomarkers content in infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Cheruku | 2002 | 17
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n

n = number of allocated/selected participants

Summary Matrix 17: Association of neurological development outcomes and biomarkers content in infants

Summary Matrix 17: Association of neurological development outcomes and biomarkers content in infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Innis | 2001 | 83
| III | Author | Year | n | Author | Year | n | Author | Year | n

n = number of allocated/selected participants

Summary Matrix 18: Association of maternal intake of omega-3 fatty acids during pregnancy with full-term infant visual function

Summary Matrix 18: Association of maternal intake of omega-3 fatty acids during pregnancy with full-term infant visual function

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Malcolm^U^ | 2003 | 100
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Krasevec | 2002 | 56

n = number of allocated/selected participants;

A RCT= Adequate vs ^U^Unclear allocation concealment

Summary Matrix 19: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences visual function in term or preterm human infants

Summary Matrix 19: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences visual function in term or preterm human infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Gibson^U^ | 1997 | 52
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Jorgensen | 2001 | 39
| | Williams | 2001 | 435

n = number of allocated/selected participants;

A RCT = Adequete vs ^U^Unclear allocation concealment

Summary Matrix 20: Omega-3 fatty acid intake associated with the visual function in preterm infants

Summary Matrix 20: Omega-3 fatty acid intake associated with the visual function in preterm infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | O'Connor^U^ | 2001 | 470
| | | | | Innis^U^ | 2002 | 194
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Carlon^A^ | 1992 | 79 | Carlson^U^ | 1996 | 36 | Uauy^U^ | 1992 | 81
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | van Mezel-Meijler^A^ | 2002 | 55 | Bougle^U^ | 1999 | 40 | Koletzko^U^ | 1994 | 27
| | | | | | | | Faldella^U^ | 1996 | 66

n = number of allocated/selected participants;

A RCT = Adequete vs ^U^Unclear allocation concealment

Summary Matrix 21: Omega-3 fatty acids intake associated with the visual function in term infants

Summary Matrix 21: Omega-3 fatty acids intake associated with the visual function in term infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | Birch^U^ | 1998 | 79 | Auestad^U^ | 1997 | 274 | Innis^U^ | 1997 | 238
| | Auestad^A^ | 2001 | 239
| | Auestad^A^ | 2001 | 165
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Makrides^A^ | 2000 | 176 | Carlson^U^ | 1996 | 94 | Makrides^U^ | 1995 | 89
| | Birch^A^ | 2002 | 65 | Hoffman^A^ | 2003 | 68 | Jensen^U^ | 1997 | 80
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Makrides^A^ | 1999 | 146 | | | | Jorgensen^U^ | 1998 | 39

n = number of allocated/selected participants;

A RCT = Adequete vs ^U^Unclear allocation concealment

Summary Matrix 22: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and visual function development in term and preterm infants

Summary Matrix 22: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and visual function development in term and preterm infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Innis | 2001 | 83 | Birch | 1993 | 30
| | | | | Birch | 1993 | 73
| | | | | Makrides | 1993 | 16
| | | | | Innis | 1994 | 35
| | | | | Leaf | 1996 | 18
| | | | | Jorgensen | 1996 | 33
| | | | | Krasevec | 2002 | 56

n = number of allocated/selected participants

Summary Matrix 23: Omega-3 fatty acids and its influence on cognitive development in infants after intake during pregnancy and breast feeding

Summary Matrix 23: Omega-3 fatty acids and its influence on cognitive development in infants after intake during pregnancy and breast feeding

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Helland^U^ | 2001 | 590

n = number of allocated/selected participants

Summary Matrix 24: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences cognitive development in term or preterm human infants

Summary Matrix 24: Omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences cognitive development in term or preterm human infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Gibson^U^ | 1997 | 52
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Agostoni | 2001 | 44

n = number of allocated/selected participants

Summary Matrix 25: Omega-3 fatty acids and its influence on cognitive development in preterm infants

Summary Matrix 25: Omega-3 fatty acids and its influence on cognitive development in preterm infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | O'Connor^U^ | 2002 | 470
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Carlson^A^ | 1992 | 79
| | Fewtrell^A^ | 2002 | 238
| | Fewtrell^A^ | 2004 | 238
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Van Wezel-Meijler^A^ | 2002 | 55

n = number of allocated/selected participants;

A RCT = Adequate vs ^u^Unclear allocation concealment; ^I^Inadequate

Summary Matrix 26: Omega-3 fatty acids as supplemental treatment for cognitive development in term infants

Summary Matrix 26: Omega-3 fatty acids as supplemental treatment for cognitive development in term infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | Birch^U^ | 1998 | 79 | Auestad^U^ | 1997 | 274
| | Auestad^A^ | 2001a | 239
| | Auestad^A^ | 2001b | 165
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Lucas^A^ | 1999 | 447 | Willatts^U^ | 1998 | 40 | Jensen^U^ | 1997 | 80
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Makrides^A^ | 1999 | 146

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment;

Summary Matrix 27: Association of cognitive development outcomes and biomarkers content in infants

Summary Matrix 27: Association of cognitive development outcomes and biomarkers content in infants

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Innis | 2001 | 83
| | Ghys | 2002 | 128

n = number of allocated/selected participants