# References and Included Studies

1 USDA. Individual fatty acid intakes: Results from the 1995 Continuing Survey of Food Intakes by Individuals (data table set 4). 1995.
2 Institute of Medicine. Dietary Reference Intakes: Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids (Macronutrition). The National Academies Press, 2002.
3 Simopoulos A P, Leaf A, Salem N Jr. Essentiality of and recommended dietary intakes for omega-6 and omega-3 fatty acids. Ann Nutr Metab. 1999;43(2):127-130. [pmid: 10436312].
4 Fallon S Enig MG. “Tripping Lightly Down the Prostaglandin Pathways”. 2001. Price-Pottenger Nutrition Foundation.
5 Nair J, Vaca C E, Velic I, et al. High dietary omega-6 polyunsaturated fatty acids drastically increase the formation of etheno-DNA base adducts in white blood cells of female subjects. Cancer Epidemiol Biomarkers Prev. 1997;6(8):597-601. [pmid: 9264272].
6 James MJ, Gibson RA, Cleland LG. Dietary polyunsaturated fatty acids and inflammatory mediator production. [Review][33 refs]. Am J Clin Nutr 2000; 71(1:Suppl):Suppl-8S.
7 Krummel D. Nutrition in cardiovascular disease. In: Mahan LK, Escot-Sump S, editors. Krause's food, nutrition, and diet therapy. W.B. Saunder Company, 1966.
8 Omega-3 long-chain polyunsaturated fatty acids and health benefits. Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (Nutriscience), 2003.
9 Consensus workshop on dietary assessment: nutrition monitoring and tracking the year 2000 objectives. Hyattsville, MD: National Center for Health Statistics, 1994.
10 USDA National Nutrient Database for Standard Reference. [Release 16] Available at: http://www.nal.usda.gov/fnic/foodcomp; [underlined: Accessed November 3, 2003]2003. US Department of Agriculture Agricultural Research Service.
11 Simopoulos AP. Omega-3 fatty acids in growth and development. In: Lees RS, Karel M, editors. Omega-3 Fatty Acids in Health and Disease. New York: Marcel Dekker, Inc., 1990: 115–156.
12 Jump D B, Clarke S D, Thelen A, et al. Dietary polyunsaturated fatty acid regulation of gene transcription. Prog Lipid Res. 1996;35(3):227-241. [pmid: 9082451].
13 Litman B J, Niu S L, Polozova A, et al. The role of docosahexaenoic acid containing phospholipids in modulating G protein-coupled signaling pathways: visual transduction. J Mol Neurosci. 2001;16(23):237-242. [pmid: 11478379].
14 McCormick M C. The contribution of low birth weight to infant mortality and childhood morbidity. N Engl J Med. 1985;312(2):82-90. [pmid: 3880598].
15 Bernstein I, Gabbe SG. Intrauterine growth restriction. In: Gabbe SG, Niebyl JR, Simpson JL, Annas GJ, editors. Obstetrics: normal and problem pregnancies. 3rd ed. New York: Churchill-Livingstone, 1996: 863–886.
16 Lemons J A, Bauer C R, Oh W, et al. Very low birth weight outcomes of the National Institute of Child health and human development neonatal research network, January 1995 through December 1996. NICHD Neonatal Research Network. Pediatrics. 2001;107(1):E1. [pmid: 11134427].
17 Vohr B R, Msall M E. Neuropsychological and functional outcomes of very low birth weight infants. Semin Perinatol. 1997;21(3):202-220. [pmid: 9205976].
18 Saigal S. Follow-up of very low birthweight babies to adolescence. Semin Neonatol. 2000;5(2):107-118. [pmid: 10859705].
19 Kramer M S, Demissie K, Yang H, et al. The contribution of mild and moderate preterm birth to infant mortality. Fetal and Infant Health Study Group of the Canadian Perinatal Surveillance System. JAMA. 2000;284(7):843-849. [pmid: 10938173].
20 Barker D J, Osmond C. Infant mortality, childhood nutrition, and ischaemic heart disease in England and Wales. Lancet. 1986;1(8489):1077-1081. [pmid: 2871345].
21 Barker D J. The developmental origins of adult disease. Eur J Epidemiol. 2003;18(8):733-736. [pmid: 12974544].
22 Barker D J, Hales C N, Fall C H, et al. Type 2 (non-insulin-dependent) diabetes mellitus, hypertension and hyperlipidaemia (syndrome X): relation to reduced fetal growth. Diabetologia. 1993;36(1):62-67. [pmid: 8436255].
23 From the Centers for Disease Control and Prevention Increasing incidence of low birthweight--United States, 1981-1991 JAMA 1994 271 (23) 1821–1822
24 Committee to study the prevention of low birth weight DoHPaDIoM. Preventing low birth weight. Washinton DC: National Academy Press, 1985.
25 Olsen S F, Hansen H S, Sorensen T I, et al. Intake of marine fat, rich in (n-3)-polyunsaturated fatty acids, may increase birthweight by prolonging gestation. Lancet. 1986;2(8503):367-369. [pmid: 2874370].
26 Olsen S F. Consumption of marine n-3 fatty acids during pregnancy as a possible determinant of birth weight. A review of the current epidemiologic evidence. [Review] [112 refs]. Epidemiol Rev. 1993;15(2):399-413. [pmid: 8174664].
27 Olsen S F, Hansen H S, Sorensen T I, et al. Intake of marine fat, rich in (n-3)-polyunsaturated fatty acids, may increase birthweight by prolonging gestation. Lancet. 1986;2(8503):367-369. [pmid: 2874370].
28 Andersen H J, Andersen L F, Fuchs A R. Diet, pre-eclampsia, and intrauterine growth retardation. Lancet. 1989;1(8647):1146. [pmid: 2566093].
29 Olsen S F, Olsen J, Frische G. Does fish consumption during pregnancy increase fetal growth? A study of the size of the newborn, placental weight and gestational age in relation to fish consumption during pregnancy. Int J Epidemiol. 1990;19(4):971-977. [pmid: 2084030].
30 Olsen S F, Olsen J, Frische G. Does fish consumption during pregnancy increase fetal growth? A study of the size of the newborn, placental weight and gestational age in relation to fish consumption during pregnancy. Int J Epidemiol. 1990;19(4):971-977. [pmid: 2084030].
31 Olsen S F, Secher N J, Tabor A, et al. Randomised clinical trials of fish oil supplementation in high risk pregnancies. Fish Oil Trials In Pregnancy (FOTIP) Team. BJOG. 2000;107(3):382-395. [pmid: 10740336].
32 Dyerberg J, Bang HO. Pre-eclampsia and prostaglandins. Lancet 1985; 1(8440).
33 England M J, Atkinson P M, Sonnendecker E W. Pregnancy induced hypertension: will treatment with dietary eicosapentaenoic acid be effective?. [Review] [50 refs]. Med Hypotheses. 1987;24(2):179-186. [pmid: 2824973].
34 Secher N J, Olsen S F. Fish-oil and pre-eclampsia.[comment]. [Review] [25 refs]. Br J Obstet Gynaecol. 1990;97(12):1077-1079. [pmid: 2279017].
35 Norwitz E R, Robinson J N, Challis J R. The control of labor. N Engl J Med. 1999;341(9):660-666. [pmid: 10460818].
36 Walsh S W. Evidence for 5-hydroxyeicosatetraenoic acid (5-HETE) and leukotriene C4(LTC4) in the onset of labor. Ann N Y Acad Sci. 1991;622:341-354. [pmid: 2064194].
37 Karim S M. The role of prostaglandins in human parturition. Proc R Soc Med. 1971;64(1):10-12. [pmid: 5551436].
38 Sadovsky Y, Nelson D M, Muglia L J, et al. Effective diminution of amniotic prostaglandin production by selective inhibitors of cyclooxygenase type 2. Am J Obstet Gynecol. 2000;182(2):370-376. [pmid: 10694339].
39 Reece M S, McGregor J A, Allen K G, et al. Prostaglandins in selected reproductive tissues in preterm and full-term gestations. Prostaglandins Leukot Essent Fatty Acids. 1996;55(5):303-307. [pmid: 8981626].
40 Reece M S, McGregor J A, Allen K G, et al. Maternal and perinatal long-chain fatty acids: possible roles in preterm birth. Am J Obstet Gynecol. 1997;176(4):907-914. [pmid: 9125620].
41 Olsen S F, Sorensen J D, Secher N J, et al. Randomised controlled trial of effect of fish-oil supplementation on pregnancy duration.[comment]. Lancet. 1992;339(8800):1003-1007. [pmid: 1349049].
42 Leaver H A, Lytton F D, Dyson H, et al. The effect of dietary w3 and w6 polyunsaturated fatty acids on gestation, parturition and prostaglandin E2 in the untrauterine tissues and the kidney. Prog Lipid Res. 1986;25:143.
43 Olsen S F, Hansen H S, Jensen B, et al. Longer gestation in rats fed diet supplemented with (n-3) fatty acids that in rats fed diet dupplemented with (n-6) fatty acids. Sixth International Conference on Prostaglandins and Related Compounds, Florence, Italy, June 3–6, 1986. Adv Prostaglandin Thromboxane Leukotriene Res. 1986;15:89-93.
44 Mathias MM, Tsai A, Harris MA et al. Oral administration of menhaden oil alters gestation in rats. In: Lands WEM, editor. Polyunsaturated Fatty Acids and Polyunsaturated Fatty Acids and Eicosanoids. Champaign IL: American Oil Chemists' Society Press, 1987: 508–512.
45 Holman R T. Essential fatty acid deficiency. Prog Chem Fats Other Lipids. 1971;9:279-438.
46 Baguma-Nibasheka M, Brenna J T, Nathanielsz P W. Delay of preterm delivery in sheep by omega-3 long-chain polyunsaturates. Biol Reprod. 1999;60(3):698-701. [pmid: 10026118].
47 Resnik R. Intrauterine growth restriction. Obstet Gynecol. 2002;99(3):490-496. [pmid: 11864679].
48 Bernstein I M, Horbar J D, Badger G J, et al. Morbidity and mortality among very-low-birth-weight neonates with intrauterine growth restriction. The Vermont Oxford Network. Am J Obstet Gynecol. 2000;182(1 Pt 1):198-206. [pmid: 10649179].
49 Strauss R S, Dietz W H. Effects of intrauterine growth retardation in premature infants on early childhood growth. J Pediatr. 1997;130(1):95-102. [pmid: 9003857].
50 Leger J, Limoni C, Czernichow P. Prediction of the outcome of growth at 2 years of age in neonates with intra-uterine growth retardation. Early Hum Dev. 1997;48(3):211-223. [pmid: 9154413].
51 Bos A F, Einspieler C, Prechtl H F. Intrauterine growth retardation, general movements, and neurodevelopmental outcome: a review. Dev Med Child Neurol. 2001;43(1):61-68. [pmid: 11201426].
52 Bassan H, Trejo L L, Kariv N, et al. Experimental intrauterine growth retardation alters renal development. Pediatr Nephrol. 2000;15(34):192-195. [pmid: 11149109].
53 Sparre T, Reusens B, Cherif H, et al. Intrauterine programming of fetal islet gene expression in rats--effects of maternal protein restriction during gestation revealed by proteome analysis. Diabetologia. 2003;46(11):1497-1511. [pmid: 13680128].
54 Broberg C S, Giraud G D, Schultz J M, et al. Fetal anemia leads to augmented contractile response to hypoxic stress in adulthood. Am J Physiol Regul Integr Comp Physiol. 2003;285(3):R649-R655. [pmid: 12775557].
55 National High Blood Pressure Education Program Working Group. Working group report on high blood pressure in pregnancy. Washington, DC: National Heart Lung and Blood Institute, 2000. NHBPEP Publication No. 00-3029.
56 Ness R B, Roberts J M. Heterogeneous causes constituting the single syndrome of preeclampsia: a hypothesis and its implications. Am J Obstet Gynecol. 1996;175(5):1365-1370. [pmid: 8942516].
57 Roberts J M, Cooper D W. Pathogenesis and genetics of pre-eclampsia. Lancet. 2001;357(9249):53-56. [pmid: 11197372].
58 Wang Y P, Walsh S W, Guo J D, et al. The imbalance between thromboxane and prostacyclin in preeclampsia is associated with an imbalance between lipid peroxides and vitamin E in maternal blood. Am J Obstet Gynecol. 1991;165(6 Pt 1):1695-1700. [pmid: 1750462].
59 Walsh S W, Wang Y. Trophoblast and placental villous core production of lipid peroxides, thromboxane, and prostacyclin in preeclampsia. J Clin Endocrinol Metab. 1995;80(6):1888-1893. [pmid: 7775637].
60 Mills J L, DerSimonian R, Raymond E, et al. Prostacyclin and thromboxane changes predating clinical onset of preeclampsia: a multicenter prospective study. JAMA. 1999;282(4):356-362. [pmid: 10432033].
61 Kumar K V, Das U N. Effect of cis-unsaturated fatty acids, prostaglandins, and free radicals on angiotensin-converting enzyme activity in vitro. Proc Soc Exp Biol Med. 1997;214(4):374-379. [pmid: 9111529].
62 Das U N. Beneficial action(s) of eicosapentaenoic acid/docosahexaenoic acid and nitric oxide in systemic lupus erythematosus. Med Sci Res. 1995;23:723.
63 Bang H O, Dyerberg J, Nielsen A B. Plasma lipid and lipoprotein pattern in Greenlandic West-coast Eskimos. Lancet. 1971;1(7710):1143-1145. [pmid: 4102857].
64 Pauletto P, Puato M, Caroli M G, et al. Blood pressure and atherogenic lipoprotein profiles of fish-diet and vegetarian villagers in Tanzania: the Lugalawa study. Lancet. 1996;348(9030):784-788. [pmid: 8813985].
65 Woodcock B E, Smith E, Lambert W H, et al. Beneficial effect of fish oil on blood viscosity in peripheral vascular disease. Br Med J (Clin Res Ed). 1984;288(6417):592-594.
66 Prisco D, Paniccia R, Bandinelli B, et al. Effect of medium-term supplementation with a moderate dose of n-3 polyunsaturated fatty acids on blood pressure in mild hypertensive patients. Thromb Res. 1998;91(3):105-112. [pmid: 9733153].
67 Popeski D, Ebbeling L R, Brown P B, et al. Blood pressure during pregnancy in Canadian Inuit: community differences related to diet. CMAJ. 1991;145(5):445-454. [pmid: 1878826]. [pmcid: 1335827].
68 Walsh S W. Preeclampsia: an imbalance in placental prostacyclin and thromboxane production. Am J Obstet Gynecol. 1985;152(3):335-340. [pmid: 3923838].
69 Antihypertensive effects of fish oil. N Engl J Med 1989 321 (23) 1610–1611
70 Lorenz R, Spengler U, Fischer S, et al. Platelet function, thromboxane formation and blood pressure control during supplementation of the Western diet with cod liver oil. Circulation. 1983;67(3):504-511. [pmid: 6821892].
71 Knapp HR. n-3 fatty acids and blood pressure regulation in man. In: Frolich JC, vonSchacky C, editors. Fish, fish oil and human health, Clinical Pharmacology. Munich: Zuchschwerdt, 1993: 112–122.
72 Kenny D, Warltier D C, Pleuss J A, et al. Effect of omega-3 fatty acids on the vascular response to angiotensin in normotensive men. Am J Cardiol. 1992;70(15):1347-1352. [pmid: 1442589].
73 Yoshimura T, Matsui K, Ito M, et al. Effects of highly purified eicosapentaenoic acid on plasma beta thromboglobulin level and vascular reactivity to angiotensin II. Artery. 1987;14(5):295-303. [pmid: 2821970].
74 Crawford M. Placental delivery of arachidonic and docosahexaenoic acids: implications for the lipid nutrition of preterm infants. Am J Clin Nutr. 2000;71(1 Suppl):275S-284S. [pmid: 10617983].
75 Hornstra G, Al M D, van Houwelingen A C, et al. Essential fatty acids in pregnancy and early human development. [Review] [35 refs]. Eur J Obstet Gynecol Reprod Biol. 1995;61(1):57-62. [pmid: 8549848].
76 Olsen S F. Further on the association between retarded foetal growth and adult cardiovascular disease. Could low intake or marine diets be a common cause?. [Review] [46 refs]. J Clin Epidemiol. 1994;47(5):565-569. [pmid: 7730882].
77 Anon. Division of vital statistics. Denver CO: Colorado Department of Health and Environment, 1997.
78 Farquharson J, Cockburn F, Patrick W A, et al. Effect of diet on infant subcutaneous tissue triglyceride fatty acids. Arch Dis Child. 1993;69(5):589-593. [pmid: 8257182].
79 Clandinin M T, Chappell J E, Heim T, et al. Fatty acid utilization in perinatal de novo synthesis of tissues. Early Hum Dev. 1981;5(4):355-366. [pmid: 7285840].
80 van Houwelingen A C, Foreman-van Drongelen M M, Nicolini U, et al. Essential fatty acid status of fetal plasma phospholipids: similar to postnatal values obtained at comparable gestational ages. Early Hum Dev. 1996;46(12):141-152. [pmid: 8899362].
81 Clandinin M T, Chappell J E, Leong S, et al. Intrauterine fatty acid accretion rates in human brain: implications for fatty acid requirements. Early Hum Dev. 1980;4(2):121-129. [pmid: 7408742].
82 Carlson S E, Rhodes P G, Ferguson M G. Docosahexaenoic acid status of preterm infants at birth and following feeding with human milk or formula. Am J Clin Nutr. 1986;44(6):798-804. [pmid: 2947455].
83 Al M D, van Houwelingen A C, Kester A D, et al. Maternal essential fatty acid patterns during normal pregnancy and their relationship to the neonatal essential fatty acid status. Br J Nutr. 1995;74(1):55-68. [pmid: 7547829].
84 Al M D, Badart-Smook A, von Houwelingen A C, et al. Fat intake of women during normal pregnancy: relationship with maternal and neonatal essential fatty acid status. J Am Coll Nutr. 1996;15(1):49-55. [pmid: 8632115].
85 Innis S M, Sprecher H, Hachey D, et al. Neonatal polyunsaturated fatty acid metabolism. Lipids. 1999;34(2):139-149. [pmid: 10102240].
86 Poisson J P, Dupuy R P, Sarda P, et al. Evidence that liver microsomes of human neonates desaturate essential fatty acids. Biochim Biophys Acta. 1993;1167(2):109-113. [pmid: 8466936].
87 Rodriguez A, Sarda P, Nessmann C et al. Delta6- and Delta5-desaturase activities in the human fetal liver: Kinetic aspects. J Lipid Res 1998; 39(9).
88 Haggarty P, Page K, Abramovich D R, et al. Long-chain polyunsaturated fatty acid transport across the perfused human placenta. Placenta. 1997;18(8):635-642. [pmid: 9364598].
89 Dutta-Roy A K. Transport mechanisms for long-chain polyunsaturated fatty acids in the human placenta. Am J Clin Nutr. 2000;71(1 Suppl):315S-322S. [pmid: 10617989].
90 Al M D, van Houwelingen A C, Hornstra G. Relation between birth order and the maternal and neonatal docosahexaenoic acid status. Eur J Clin Nutr. 1997;51(8):548-553. [pmid: 11248881].
91 Martinez M. Developmental profiles of polyunsaturated fatty acids in the brain of normal infants and patients with peroxisomal diseases: severe deficiency of docosahexanoenoic acid in Zellweger's and Pseudo-Sellweger's Syndrome. In: Simopoulos AP, Kifer RR, Martin RE, Marlow SM, editors. Health Effects of omega 3 polyunsaturated fatty acids in seafood, world Rev Nutr Diet, Vol 66. Basel: Karger, 1991: 87–102.
92 Martinez M. Polyunsaturated fatty acids in the developing human brain, red cells and plasma: influence of nutrition and peroxisomal disease. World Rev Nutr Diet. 1994;75:70-78. [pmid: 7871835].
93 Martinez M. Tissue levels of polyunsaturated fatty acids during early human development. J Pediatr. 1992;120(4 Pt 2):S129-S138. [pmid: 1532827].
94 Giusto N M, Pasquare S J, Salvador G A, et al. Lipid metabolism in vertebrate retinal rod outer segments. Prog Lipid Res. 2000;39(4):315-391. [pmid: 10856601].
95 Sastry P S. Lipids of nervous tissue: composition and metabolism. Prog Lipid Res. 1985;24(2):69-176. [pmid: 3916238].
96 Innis S, Uauy R, Heird W et al. Mechanisms of action of LCPUFA effects on infant growth and neurodevelopment: Perinatal biochemistry and physiology of LCPUFA discussion. J Pediatr 2003; 143(4 Suppl).
97 Benolken R M, Anderson R E, Wheeler T G. Membrane fatty acids associated with the electrical response in visual excitation. Science. 1973;182(118):1253-1254. [pmid: 4752217].
98 Innis S M. Essential fatty acids in growth and development. [Review] [566 refs]. Prog Lipid Res. 1991;30(1):39-103. [pmid: 1771170].
99 Bourre J M, Francois M, Youyou A, et al. The effects of dietary alpha-linolenic acid on the composition of nerve membranes, enzymatic activity, amplitude of electrophysiological parameters, resistance to poisons and performance of learning tasks in rats. J Nutr. 1989;119(12):1880-1892. [pmid: 2576038].
100 Innis S M. Essential fatty acids in growth and development. Prog Lipid Res. 1991;30(1):39-103. [pmid: 1771170].
101 Neuringer M, Connor W E, Lin D S, et al. Biochemical and functional effects of prenatal and postnatal omega 3 fatty acid deficiency on retina and brain in rhesus monkeys. Proc Natl Acad Sci U S A. 1986;83(11):4021-4025. [pmid: 3459166]. [pmcid: 323657].
102 Wheeler T G, Benolken R M, Anderson R E. Visual membranes: specificity of fatty acid precursors for the electrical response to illumination. Science. 1975;188(4195):1312-1314. [pmid: 1145197].
103 Yamamoto N, Hashimoto A, Takemoto Y, et al. Effect of the dietary alpha-linolenate/linoleate balance on lipid compositions and learning ability of rats. II. Discrimination process, extinction process, and glycolipid compositions. J Lipid Res. 1988;29(8):1013-1021. [pmid: 2903207].
104 Auestad N, Montalto M B, Hall R T, et al. Visual acuity, erythrocyte fatty acid composition, and growth in term infants fed formulas with long chain polyunsaturated fatty acids for one year. Ross Pediatric Lipid Study. Pediatr Res. 1997;41(1):1-10. [pmid: 8979282].
105 Connor W E, Neuringer M. The effects of n-3 fatty acid deficiency and repletion upon the fatty acid composition and function of the brain and retina. Prog Clin Biol Res. 1988;282:275-294. [pmid: 3241811].
106 Sprecher H, Chen Q, Yin F Q. Regulation of the biosynthesis of 22:5n-6 and 22:6n-3: a complex intracellular process. Lipids. 1999;34 Suppl:S153-S156. [pmid: 10419131].
107 Hrboticky N, MacKinnon M J, Innis S M. Effect of a vegetable oil formula rich in linoleic acid on tissue fatty acid accretion in the brain, liver, plasma, and erythrocytes of infant piglets. Am J Clin Nutr. 1990;51(2):173-182. [pmid: 2305703].
108 Frances H, Coudereau J P, Sandouk P, et al. Influence of a dietary alpha-linolenic acid deficiency on learning in the Morris water maze and on the effects of morphine. Eur J Pharmacol. 1996;298(3):217-225. [pmid: 8846819].
109 de la Presa O S, Innis S M. Docosahexaenoic and arachidonic acid prevent a decrease in dopaminergic and serotoninergic neurotransmitters in frontal cortex caused by a linoleic and alpha-linolenic acid deficient diet in formula-fed piglets. J Nutr. 1999;129(11):2088-2093. [pmid: 10539789].
110 Zimmer L, Vancassel S, Cantagrel S, et al. The dopamine mesocorticolimbic pathway is affected by deficiency in n-3 polyunsaturated fatty acids. Am J Clin Nutr. 2002;75(4):662-667. [pmid: 11916751].
111 Delion S, Chalon S, Guilloteau D, et al. alpha-Linolenic acid dietary deficiency alters age-related changes of dopaminergic and serotoninergic neurotransmission in the rat frontal cortex. J Neurochem. 1996;66(4):1582-1591. [pmid: 8627314].
112 de la Presa O S, Innis S M. Diverse, region-specific effects of addition of arachidonic and docosahexanoic acids to formula with low or adequate linoleic and alpha-linolenic acids on piglet brain monoaminergic neurotransmitters. Pediatr Res. 2000;48(1):125-130. [pmid: 10879811].
113 Zimmer L, Delion-Vancassel S, Durand G, et al. Modification of dopamine neurotransmission in the nucleus accumbens of rats deficient in n-3 polyunsaturated fatty acids. J Lipid Res. 2000;41(1):32-40. [pmid: 10627499].
114 Zimmer L, Hembert S, Durand G, et al. Chronic n-3 polyunsaturated fatty acid diet-deficiency acts on dopamine metabolism in the rat frontal cortex: a microdialysis study. Neurosci Lett. 1998;240(3):177-181. [pmid: 9502233].
115 Antal A, Keri S, Bodis-Wollner I. Dopamine D2 receptor blockade alters the primary and cognitive components of visual evoked potentials in the monkey, Macaca fascicularis. Neurosci Lett. 1997;232(3):179-181. [pmid: 9310309].
116 Basmak H, Yildirim N, Erdinc O, et al. [Effect of levodopa therapy on visual evoked potentials and visual acuity in amblyopia]. Ophthalmologica. 1999;213(2):110-113. [pmid: 9885387].
117 Bhargava V K, McKean C M. Role of 5-hydroxytryptamine in the modulation of acoustic brainstem (far-field) potentials. Neuropharmacology. 1977;16(6):447-449. [pmid: 143622].
118 Le Moal M, Simon H. Mesocorticolimbic dopaminergic network: functional and regulatory roles. Physiol Rev. 1991;71(1):155-234. [pmid: 1986388].
119 Kitajka K, Puskas L G, Zvara A, et al. The role of n-3 polyunsaturated fatty acids in brain: modulation of rat brain gene expression by dietary n-3 fatty acids. Proc Natl Acad Sci U S A. 2002;99(5):2619-2624. [pmid: 11880617]. [pmcid: 122397].
120 Makrides M, Neumann M A, Jeffrey B, et al. A randomized trial of different ratios of linoleic to alpha-linolenic acid in the diet of term infants: effects on visual function and growth.[comment]. Am J Clin Nutr. 2000;71(1):120-129. [pmid: 10617956].
121 Uauy R D, Birch D G, Birch E E, et al. Effect of dietary omega-3 fatty acids on retinal function of very-low-birth-weight neonates. Pediatr Res. 1990;28(5):485-492. [pmid: 2255573].
122 Carlson S E, Werkman S H, Rhodes P G, et al. Visual-acuity development in healthy preterm infants: effect of marine-oil supplementation. Am J Clin Nutr. 1993;58(1):35-42. [pmid: 8317386].
123 Carlson S E, Werkman S H, Tolley E A. Effect of long-chain n-3 fatty acid supplementation on visual acuity and growth of preterm infants with and without bronchopulmonary dysplasia. Am J Clin Nutr. 1996;63(5):687-697. [pmid: 8615350].
124 Birch E E, Hoffman D R, Uauy R, et al. Visual acuity and the essentiality of docosahexaenoic acid and arachidonic acid in the diet of term infants. Pediatr Res. 1998;44(2):201-209. [pmid: 9702915].
125 Makrides M, Neumann M, Simmer K, et al. Are long-chain polyunsaturated fatty acids essential nutrients in infancy?[comment]. Lancet. 1995;345(8963):1463-1468. [pmid: 7769900].
126 Carlson S E, Ford A J, Werkman S H, et al. Visual acuity and fatty acid status of term infants fed human milk and formulas with and without docosahexaenoate and arachidonate from egg yolk lecithin. Pediatr Res. 1996;39(5):882-888. [pmid: 8726246].
127 Makrides M, Neumann M A, Simmer K, et al. A critical appraisal of the role of dietary long-chain polyunsaturated fatty acids on neural indices of term infants: a randomized, controlled trial. Pediatrics. 2000;105(1 Pt 1):32-38. [pmid: 10617701].
128 Anderson JW, Johnstone BM, Remley DT. Breast-feeding and cognitive development: A meta-analysis. Am J Clin Nutr 1999; 70(4).
129 Byard R W, Makrides M, Need M, et al. Sudden infant death syndrome: effect of breast and formula feeding on frontal cortex and brainstem lipid composition. J Paediatr Child Health. 1995;31(1):14-16. [pmid: 7748681].
130 Farquharson J, Cockburn F, Patrick W A, et al. Infant cerebral cortex phospholipid fatty-acid composition and diet.[comment]. Lancet. 1992;340(8823):810-813. [pmid: 1357244].
131 Makrides M, Neumann MA, Bvard RW et al. Fatty acid composition of brain, retina, and erythrocytes in breast- and formula-fed infants. Am J Clin Nutr 1994; 60(2).
132 Lucas A, Stafford M, Morley R, et al. Efficacy and safety of long-chain polyunsaturated fatty acid supplementation of infant-formula milk: a randomised trial.[comment]. Lancet. 1999;354(9194):1948-1954. [pmid: 10622297].
133 Birch E E, Garfield S, Hoffman D R, et al. A randomized controlled trial of early dietary supply of long-chain polyunsaturated fatty acids and mental development in term infants. Dev Med Child Neurol. 2000;42(3):174-181. [pmid: 10755457].
134 Agostoni C, Trojan S, Bellu R, et al. Neurodevelopmental quotient of healthy term infants at 4 months and feeding practice: the role of long-chain polyunsaturated fatty acids. Pediatr Res. 1995;38(2):262-266. [pmid: 7478826].
135 Ruan C, Liu X, Man H, et al. Milk composition in women from five different regions of China: the great diversity of milk fatty acids. J Nutr. 1995;125(12):2993-2998. [pmid: 7500177].
136 Wang L, Shimizu Y, Kaneko S, et al. Comparison of the fatty acid composition of total lipids and phospholipids in breast milk from Japanese women. Pediatr Int. 2000;42(1):14-20. [pmid: 10703228].
137 Connor W E, Lowensohn R, Hatcher L. Increased docosahexaenoic acid levels in human newborn infants by administration of sardines and fish oil during pregnancy. Lipids. 1996;31(Suppl):S183-S187. [pmid: 8729116].
138 Gibson R A, Neumann M A, Makrides M. Effect of increasing breast milk docosahexaenoic acid on plasma and erythrocyte phospholipid fatty acids and neural indices of exclusively breast fed infants. Eur J Clin Nutr. 1997;51(9):578-584. [pmid: 9306083].
139 Innis S M, King D J. trans Fatty acids in human milk are inversely associated with concentrations of essential all-cis n-6 and n-3 fatty acids and determine trans, but not n-6 and n-3, fatty acids in plasma lipids of breast-fed infants. Am J Clin Nutr. 1999;70(3):383-390. [pmid: 10479201].
140 Jorgensen M H, Hernell O, Hughes E L, et al. Is there a relation between docosahexaenoic acid concentration in mothers' milk and visual development in term infants?. J Pediatr Gastroenterol Nutr. 2001;32(3):293-296. [pmid: 11345178].
141 Helland I B, Saugstad O D, Smith L, et al. Similar effects on infants of n-3 and n-6 fatty acids supplementation to pregnant and lactating women. Pediatrics. 2001;108(5):E82. [pmid: 11694666].
142 Foreman-van Drongelen M M, van Houwelingen A C, Kester A D, et al. Long-chain polyunsaturated fatty acids in preterm infants: status at birth and its influence on postnatal levels. J Pediatr. 1995;126(4):611-618. [pmid: 7699544].
143 Guesnet P. Blood lipid concentrations of docosahexaenoic and arachidonic acids at birth determine their relative postnatal changes in term infants fed breast milk or formula.[comment]. Am J Clin Nutr. 1999;70(2):292-298. [pmid: 10426708].
144 Innis S M. Plasma and red blood cell fatty acid values as indexes of essential fatty acids in the developing organs of infants fed with milk or formulas. [Review] [47 refs]. J Pediatr. 1992;120(4 Pt 2):S78-S86. [pmid: 1532829].
145 Ward G R, Huang Y S, Bobik E, et al. Long-chain polyunsaturated fatty acid levels in formulae influence deposition of docosahexaenoic acid and arachidonic acid in brain and red blood cells of artificially reared neonatal rats. J Nutr. 1998;128(12):2473-2487. [pmid: 9868196].
146 Rooke J A, Bland I M, Edwards S A. Relationships between fatty acid status of sow plasma and that of umbilical cord, plasma and tissues of newborn piglets when sows were fed on diets containing tuna oil or soyabean oil in late pregnancy. Br J Nutr. 1999;82(3):213-221. [pmid: 10655968].
147 Martinez M, Ballabriga A. Effects of parenteral nutrition with high doses of linoleate on the developing human liver and brain. Lipids. 1987;22(3):133-138. [pmid: 3106740].
148 Broughton, McCormack MJ, Pipkin F et al. Fish-oil and pre-eclampsia [1]. Br J Obstet Gynaecol 1991; 98(7).
149 Secher N J, Olsen S F. Fish-oil and pre-eclampsia. Br J Obstet Gynaecol. 1990;97(12):1077-1079. [pmid: 2279017].
150 Carlson S E, Cooke R J, Werkman S H, et al. First year growth of preterm infants fed standard compared to marine oil n-3 supplemented formula. Lipids. 1992;27(11):901-907. [pmid: 1491608].
151 Makrides M, Neumann M A, Simmer K, et al. Dietary long-chain polyunsaturated fatty acids do not influence growth of term infants: A randomized clinical trial. Pediatrics. 1999;104(3 Pt 1):468-475. [pmid: 10469771].
152 Simopoulos AP. Importance of the ratio of Omega-6/Omega-3 essential fatty acids: Evolutionary aspects. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 1–22.
153 McAuley L, Pham B, Tugwell P, et al. Does the inclusion of grey literature influence estimates of intervention effectiveness reported in meta-analyses?. Lancet. 2000;356(9237):1228-1231. [pmid: 11072941].
154 Moher D, Pham B, Lawson M L, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
155 Jadad AR. Randomised controlled trials. London: BMJ Publishing Group, 1998.
156 Moher D, Cook D J, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
157 Berlin J A. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-186. [pmid: 9250191].
158 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
159 Schulz K F, Chalmers I, Hayes R J, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-412. [pmid: 7823387].
160 Deeks J J, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-173. [pmid: 14499048].
161 Downs S H, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-384. [pmid: 9764259].
162 Wells GA Shea B O'Connell D Peterson J Welch V Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 3rd Symposium on Systematic Reviews: Beyond the Basics, July 2000 in Oxford. 2000.
163 Schachter, H., Reisman, J., Tran, K., Dale, B., Kourad, K., Barnes, D., Sampson, M., Morrison, A., Gaboury, I., and Blackman, J. Health Effects of Omega-3 Fatty Acids on Asthma. Evidence Report/Technology Assessment No. 91 (Prepared by University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021). Rockville MD: Agency for Healthcare Research and Quality, 2004. AHRQ Publication No. 04-E013-2.
164 Kang JX. The importance of Omega-6/Omega-3 fatty acid ratio in cell function: The gene transfer of Omega-3 fatty acid desaturase. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 23–36.
165 Yehuda S. Omega-6/omega-3 ratio and brain-related functions. [Review] [101 refs]. World Rev Nutr Diet. 2003;92:37-56. [pmid: 14579682].
166 de Lorgeril M, Salen P. Dietary prevention of coronary heart disease: Focus on Omega-6/Omega-3 essential fatty acid balance. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 57–73.
167 Pella D, Dubnov G, Singh RB et al. Effects of an Indo-Mediterranean diet on the Omega-6/Omega-3 ratio in patients at high risk of coronary artery disease: The Indian paradox. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 74–80.
168 Dubnov G, Berry EM. Omega-6/Omega-3 fatty acid ratio: The Israeli paradox. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 81–91.
169 Zampelas A, Paschos G, Rallidis L et al. Linoleic acid to alpha-linolenic acid ratio: From clinical trials to inflammatory markers of coronary artery disease. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 92–108.
170 Hamazaki T, Okuyama H. The Japan Society for Lipid Nutrition recommends to reduce the intake of linoleic acid: A review and critique of the scientific evidence. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 109–132.
171 Chajès V, Bournoux P. Omega-6/Omega-3 polyunsaturated fatty acid ratio and cancer. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 133–151.
172 Cleland LG, James MJ, Proudman SM. Omega-6/Omega-3 fatty acids and arthritis. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 152–168.
173 Simopoulos A P. Essential fatty acids in health and chronic disease. Am J Clin Nutr. 1999;70(3 Suppl):560S-569S. [pmid: 10479232].
174 Kris-Etherton P M, Taylor D S, Yu-Poth S, et al. Polyunsaturated fatty acids in the food chain in the United States. Am J Clin Nutr. 2000;71(1 Suppl):179S-188S. [pmid: 10617969].
175 Sugano M, Hirahara F. Polyunsaturated fatty acids in the food chain in Japan. Am J Clin Nutr. 2000;71(1 Suppl):189S-196S. [pmid: 10617970].
176 Agostoni C, Trojan S, Bellu R, et al. Neurodevelopmental quotient of healthy term infants at 4 months and feeding practice: the role of long-chain polyunsaturated fatty acids. Pediatr Res. 1995;38(2):262-266. [pmid: 7478826].
177 Agostoni C, Trojan S, Bellu R, et al. Developmental quotient at 24 months and fatty acid composition of diet in early infancy: a follow up study. Arch Dis Child. 1997;76(5):421-424. [pmid: 9196357].
178 Agostoni C, Riva E, Trojan S, et al. Docosahexaenoic acid status and developmental quotient of healthy term infants.[comment]. Lancet. 1995;346(8975):638. [pmid: 7651024].
179 Al M D, van Houwelingen A C, Badart-Smook A, et al. The essential fatty acid status of mother and child in pregnancy-induced hypertension: a prospective longitudinal study. Am J Obstet Gynecol. 1995;172(5):1605-1614. [pmid: 7755079].
180 Al M D, von Houwelingen A C, Hasaart T H, et al. The relationship between the essential fatty acid status of mother and child and the occurrence of pregnancy-induced hypertension. Intermediate results of a prospective longitudinal study. World Rev Nutr Diet. 1994;76:110-113. [pmid: 7856218].
181 Auestad N, Scott D T, Janowsky J S, et al. Visual, cognitive, and language assessments at 39 months: a follow-up study of children fed formulas containing long-chain polyunsaturated fatty acids to 1 year of age. Pediatrics. 2003;112(3 Pt 1):e177-e183. [pmid: 12949309].
182 Birch E E, Hoffman D R, Uauy R, et al. Visual acuity and the essentiality of docosahexaenoic acid and arachidonic acid in the diet of term infants. Pediatr Res. 1998;44(2):201-209. [pmid: 9702915].
183 Birch E E, Garfield S, Hoffman D R, et al. A randomized controlled trial of early dietary supply of long-chain polyunsaturated fatty acids and mental development in term infants. Dev Med Child Neurol. 2000;42(3):174-181. [pmid: 10755457].
184 Hoffman D R, Birch E E, Birch D G, et al. Impact of early dietary intake and blood lipid composition of long-chain polyunsaturated fatty acids on later visual development. J Pediatr Gastroenterol Nutr. 2000;31(5):540-553. [pmid: 11144440].
185 Carlson S E, Cooke R J, Werkman S H, et al. First year growth of preterm infants fed standard compared to marine oil n-3 supplemented formula. Lipids. 1992;27(11):901-907. [pmid: 1491608].
186 Werkman S H, Carlson S E. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until nine months. Lipids. 1996;31(1):91-97. [pmid: 8649241].
187 Carlson S E, Cooke R J, Rhodes P G, et al. Long-term feeding of formulas high in linolenic acid and marine oil to very low birth weight infants: phospholipid fatty acids. Pediatr Res. 1991;30(5):404-412. [pmid: 1684416].
188 Carlson S E, Werkman S H, Rhodes P G, et al. Visual-acuity development in healthy preterm infants: effect of marine-oil supplementation. Am J Clin Nutr. 1993;58(1):35-42. [pmid: 8317386].
189 Carlson S E, Werkman S H, Peeples J M, et al. Arachidonic acid status correlates with first year growth in preterm infants. Proc Natl Acad Sci U S A. 1993;90(3):1073-1077. [pmid: 8430076]. [pmcid: 45813].
190 Carlson S E, Werkman S H, Cooke R J, et al. Docosahexaenoate (DHA) and eicosapentaenoate (EPA) status of preterm infants: relationship to the Fagantest of Infant Intelligence and the Bayley Scale of Mental Development. FASEB Journal. 1990;4:A1156.
191 Carlson S E, Werkman S H, Tolley E A. Effect of long-chain n-3 fatty acid supplementation on visual acuity and growth of preterm infants with and without bronchopulmonary dysplasia. Am J Clin Nutr. 1996;63(5):687-697. [pmid: 8615350].
192 Carlson S E, Werkman S H. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until two months. Lipids. 1996;31(1):85-90. [pmid: 8649239].
193 Clandinin M T V. Growth and development of very-low-birth-weight infants (VLBW) is enhanced by formulas supplemented with docosahexaenoic acid (DHA) and arachidonic acid (ARA). J Pediatr Gastroenterol Nutr. 2002;34(4):479.
194 Lim M. Formulas with docosahexaenoic acid (DHA) and arachidonic acid (ARA) for low-birth weight infants (LBW) are safe. Pediatr Res. 2002;51(4):319A.
195 Clandinin M T V. Safety of formulas with docosahexaenoic acid (DHA) and arachidonic acid (ARA) from single-cell and marine sources for low-birth-weight infants (LBW). J Pediatr Gastroenterol Nutr. 2002;34(4):484.
196 de Groot R H, Hornstra G, van Houwelingen A C, et al. Effect of alpha-linolenic acid supplementation during pregnancy on maternal and neonatal polyunsaturated fatty acid status and pregnancy outcome. Am J Clin Nutr. 2004;79(2):251-260. [pmid: 14749231].
197 De Groot R H M, Adam J, Jolles J, et al. Alpha-linolenic acid supplementation during human pregnancy does not effect cognitive functioning. Prostaglandins Leukot Essent Fatty Acids. 2004;70(1):41-47. [pmid: 14643178].
198 Faldella G, Govoni M, Alessandroni R, et al. Visual evoked potentials and dietary long chain polyunsaturated fatty acids in preterm infants. Arch Dis Child Fetal Neonatal Ed. 1996;75(2):F108-F112. [pmid: 8949693].
199 Faldella G, Govoni M, Alessandroni R, et al. Maturation of the visual cortex in relation to dietary intake of polyenoic fatty acids in preterm infants. Bambini e Nutrizione. 1995;2(3):116-120.
200 Helland I B, Smith L, Saarem K, et al. Maternal supplementation with very-long-chain n-3 fatty acids during pregnancy and lactation augments children's IQ at 4 years of age. Pediatrics. 2003;111(1):e39-e44. [pmid: 12509593].
201 Innis S M, Adamkin D H, Hall R T, et al. Docosahexaenoic acid and arachidonic acid enhance growth with no adverse effects in preterm infants fed formula. J Pediatr. 2002;140(5):547-554. [pmid: 12032520].
202 Riemersma R, Armstrong R, Kelly RW, editors. Docosahexaenoic acid plus arachidonic acid enhance preterm infant growth. Champaign; USA: AOCS Press, 1998.
203 Jensen C L, Prager T C, Fraley J K, et al. Effect of dietary linoleic/alpha-linolenic acid ratio on growth and visual function of term infants.[comment]. J Pediatr. 1997;131(2):200-209. [pmid: 9290604].
204 Voigt R G, Jensen C L, Fraley J K, et al. Relationship between omega3 long-chain polyunsaturated fatty acid status during early infancy and neurodevelopmental status at 1 year of age. J Hum Nutr Diet. 2002;15(2):111-120. [pmid: 11972740].
205 Makrides M, Neumann M A, Simmer K, et al. Dietary long-chain polyunsaturated fatty acids do not influence growth of term infants: A randomized clinical trial. Pediatrics. 1999;104(3 Pt 1):468-475. [pmid: 10469771].
206 Makrides M, Neumann M A, Simmer K, et al. A critical appraisal of the role of dietary long-chain polyunsaturated fatty acids on neural indices of term infants: a randomized, controlled trial. Pediatrics. 2000;105(1 Pt 1):32-38. [pmid: 10617701].
207 O'Connor D L, Hall R, Adamkin D, et al. Growth and development in preterm infants fed long-chain polyunsaturated fatty acids: a prospective, randomized controlled trial. Pediatrics. 2001;108(2):359-371. [pmid: 11483801].
208 O'Connor D L J. Growth and development of premature infants fed predominantly human milk, predominantly premature infant formula, or a combination of human milk and premature formula. J Pediatr Gastroenterol Nutr. 2003;37(4):437-446. [pmid: 14508214].
209 Olsen S F, Sorensen J D, Secher N J, et al. Randomised controlled trial of effect of fish-oil supplementation on pregnancy duration.[comment]. Lancet. 1992;339(8800):1003-1007. [pmid: 1349049].
210 Olsen S F, Soorensen J D, Secher N J, et al. [Fish oil supplementation and duration of pregnancy. A randomized controlled trial]. [Danish]. Ugeskr Laeger. 1994;156(9):1302-1307. [pmid: 8009754].
211 Salvig J D, Olsen S F, Secher N J. Effects of fish oil supplementation in late pregnancy on blood pressure: a randomised controlled trial. Br J Obstet Gynaecol. 1996;103(6):529-533. [pmid: 8645644].
212 Birch D G, Birch E E, Hoffman D R, et al. Retinal development in very-low-birth-weight infants fed diets differing in omega-3 fatty acids. Invest Ophthalmol Vis Sci. 1992;33(8):2365-2376. [pmid: 1386065].
213 Uauy R, Hoffman D R, Birch E E, et al. Safety and efficacy of omega-3 fatty acids in the nutrition of very low birth weight infants: soy oil and marine oil supplementation of formula. J Pediatr. 1994;124(4):612-620. [pmid: 7908693].
214 Hoffman D R, Birch E E, Birch D G, et al. Fatty acid profile of buccal cheek cell phospholipids as an index for dietary intake of docosahexaenoic acid in preterm infants. Lipids. 1999;34(4):337-342. [pmid: 10443966].
215 Hoffman D R, Birch E E, Birch D G, et al. Effects of supplementation with omega 3 long-chain polyunsaturated fatty acids on retinal and cortical development in premature infants. Am J Clin Nutr. 1993;57(5 Suppl):807S-812S. [pmid: 8475899].
216 Birch E E, Birch D G, Hoffman D R, et al. Dietary essential fatty acid supply and visual acuity development. Invest Ophthalmol Vis Sci. 1992;33(11):3242-3253. [pmid: 1399429].
217 Uauy R D, Birch D G, Birch E E, et al. Effect of dietary omega-3 fatty acids on retinal function of very-low-birth-weight neonates. Pediatr Res. 1990;28(5):485-492. [pmid: 2255573].
218 Vanderhoof J, Gross S, Hegyi T, et al. Evaluation of a long-chain polyunsaturated fatty acid supplemented formula on growth, tolerance, and plasma lipids in preterm infants up to 48 weeks postconceptional age. J Pediatr Gastroenterol Nutr. 1999;29(3):318-326. [pmid: 10467999].
219 Vanderhoof J, Gross S, Hegyi T. A multicenter long-term safety and efficacy trial of preterm formula supplemented with long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr. 2000;31(2):121-127. [pmid: 10941962].
220 Vanderhoof J, Gross S, Hegvi T et al. A new arachidonic acid (ARA) and docosahexanoic acid (DHA) supplemented preterm formula: growth and safety assessment. Pediatr Res 1997;242A, #1440.
221 Vilbergsson G, Samsioe G, Wennergren M, et al. Essential fatty acids in pregnancies complicated by intrauterine growth retardation. Int J Gynaecol Obstet. 1991;36(4):277-286. [pmid: 1684761].
222 Ghebremeskel K, Leighfield M. Infant brain lipids and diet.[comment]. Lancet. 1992;340(8827):1093. [pmid: 1357473].
223 Willatts P, Forsyth J S, DiModugno M K, et al. Effect of long-chain polyunsaturated fatty acids in infant formula on problem solving at 10 months of age. Lancet British edition. 1998;352(9129):688-691.
224 Willatts P, Forsyth J S, DiModugno M K, et al. Influence of long-chain polyunsaturated fatty acids on infant cognitive function. Lipids. 1998;33(10):973-980. [pmid: 9832076].
225 Woltil H A, van Beusekom C M, Okken-Beukens M, et al. Development of low-birthweight infants at 19 months of age correlates with early intake and status of long-chain polyunsaturated fatty acids. Prostaglandins Leukot Essent Fatty Acids. 1999;61(4):235-241. [pmid: 10574647].
226 Woltil H A, van Beusekom C M, Schaafsma A, et al. Long-chain polyunsaturated fatty acid status and early growth of low birth weight infants. Eur J Pediatr. 1998;157(2):146-152. [pmid: 9504790].
227 Auestad N, Halter R, Hall R T, et al. Growth and development in term infants fed long-chain polyunsaturated fatty acids: a double-masked, randomized, parallel, prospective, multivariate study. Pediatrics. 2001;108(2):372-381. [pmid: 11483802].
228 Birch E, Birch D, Hoffman D, et al. Breast-feeding and optimal visual development. J Pediatr Ophthalmol Strabismus. 1993;30(1):33-38. [pmid: 8455123].
229 Hofmann M, Bahlmann F, Pollow K et al. Phospholipid and triglycerid composition in patients with preeclampsia compared with normal pregnancies - Deficiency of essential polyunsaturated fatty acids. Geburtshilfe Frauenheilkd 1998; 58(9).
230 Olsen S F, Secher N J, Tabor A, et al. Randomised clinical trials of fish oil supplementation in high risk pregnancies. Fish Oil Trials In Pregnancy (FOTIP) Team. BJOG. 2000;107(3):382-395. [pmid: 10740336].
231 Dunstan J A, Mori T A, Barden A, et al. Effects of n-3 polyunsaturated fatty acid supplementation in pregnancy on maternal and fetal erythrocyte fatty composition. Eur J Clin Nutr. 2004;58(3):429-437. [pmid: 14985680].
232 Smuts C M, Borod E, Peeples J M, et al. High-DHA eggs: feasibility as a means to enhance circulating DHA in mother and infant. Lipids. 2003;38(4):407-414. [pmid: 12848286].
233 Onwude J L, Lilford R J, Hjartardottir H, et al. A randomised double blind placebo controlled trial of fish oil in high risk pregnancy. Br J Obstet Gynaecol. 1995;102(2):95-100. [pmid: 7756226].
234 Smuts C M, Huang M, Mundy D, et al. A randomized trial of docosahexaenoic acid supplementation during the third trimester of pregnancy. Obstet Gynecol. 2003;101(3):469-479. [pmid: 12636950].
235 Malcolm C A, Hamilton R, McCulloch D L, et al. Scotopic electroretinogram in term infants born of mothers supplemented with docosahexaenoic acid during pregnancy. Invest Ophthalmol Vis Sci. 2003;44(8):3685-3691. [pmid: 12882824].
236 D'Almeida A, Carter J P, Anatol A, et al. Effects of a combination of evening primrose oil (gamma linolenic acid) and fish oil (eicosapentaenoic + docahexaenoic acid) versus magnesium, and versus placebo in preventing pre-eclampsia. Women Health. 1992;19(23):117-131. [pmid: 1492408].
237 Laivuori H, Hovatta O, Viinikka L, et al. Dietary supplementation with primrose oil or fish oil does not change urinary excretion of prostacyclin and thromboxane metabolites in pre-eclamptic women. Prostaglandins Leukot Essent Fatty Acids. 1993;49(3):691-694. [pmid: 8248275].
238 Bulstra-Ramakers M T, Huisjes H J, Visser G H. The effects of 3g eicosapentaenoic acid daily on recurrence of intrauterine growth retardation and pregnancy induced hypertension. Br J Obstet Gynaecol. 1995;102(2):123-126. [pmid: 7756203].
239 Reece M S, McGregor J A, Allen K G, et al. Maternal and perinatal long-chain fatty acids: possible roles in preterm birth.[comment]. Am J Obstet Gynecol. 1997;176(4):907-914. [pmid: 9125620].
240 Elias S L, Innis S M. Infant plasma trans, n-6, and n-3 fatty acids and conjugated linoleic acids are related to maternal plasma fatty acids, length of gestation, and birth weight and length.[comment]. Am J Clin Nutr. 2001;73(4):807-814. [pmid: 11273857].
241 Rump P, Mensink R P, Kester A D, et al. Essential fatty acid composition of plasma phospholipids and birth weight: a study in term neonates.[comment]. Am J Clin Nutr. 2001;73(4):797-806. [pmid: 11273856].
242 Wang Y P, Kay H H, Killam A P. Decreased levels of polyunsaturated fatty acids in preeclampsia.[comment]. Am J Obstet Gynecol. 1991;164(3):812-818. [pmid: 1900662].
243 Craig-Schmidt M C, Carlson S E, Crocker L, et al. Plasma total phospholipid arachidonic acid and eicosapentaenoic acid in normal and hypertensive pregnancy. World Rev Nutr Diet. 1994;76:126-129. [pmid: 7856222].
244 Shouk T A, Omar M N, Fayed S T. Essential fatty acids profile and lipid peroxides in severe pre-eclampsia. Ann Clin Biochem. 1999;36(Pt 1):62-65. [pmid: 10370762].
245 Matorras R, Perteagudo L, Nieto A, et al. Intrauterine growth retardation and plasma fatty acids in the mother and the fetus. Eur J Obstet Gynecol Reprod Biol. 1994;57(3):189-193. [pmid: 7713295].
246 Cetin I, Giovannini N, Alvino G, et al. Intrauterine growth restriction is associated with changes in polyunsaturated fatty acid fetal-maternal relationships. Pediatr Res. 2002;52(5):750-755. [pmid: 12409524].
247 Vilbergsson G, Samsioe G, Wennergren M, et al. Essential fatty acids in pregnancies complicated by intrauterine growth retardation. Int J Gynaecol Obstet. 1991;36(4):277-286. [pmid: 1684761].
248 Jensen C L, Prager T C, Zou Y, et al. Effects of maternal docosahexaenoic acid supplementation on visual function and growth of breast-fed term infants. Lipids. 1999;34(Suppl):S225. [pmid: 10419159].
249 Xiang M, Alfven G, Blennow M, et al. Long-chain polyunsaturated fatty acids in human milk and brain growth during early infancy. Acta Paediatr. 2000;89(2):142-147. [pmid: 10709881].
250 Carlson S E, Rhodes P G, Rao V S, et al. Effect of fish oil supplementation on the n-3 fatty acid content of red blood cell membranes in preterm infants. Pediatr Res. 1987;21(5):507-510. [pmid: 2954026].
251 Koletzko B, Edenhofer S, Lipowsky G, et al. Effects of a low birthweight infant formula containing human milk levels of docosahexaenoic and arachidonic acids. J Pediatr Gastroenterol Nutr. 1995;21(2):200-208. [pmid: 7472907].
252 Lapillonne A, Picaud JC, Chirouze V et al. Supplementation of preterm formulas (PTF) with a low EPA fish oil: Effect on polyunsaturated fatty acids(PUFAS) status and growth. J Pediatr Gastroenterol Nutr 1997; 24(4).
253 Ghebremeskel K, Burns L, Costeloe K, et al. Plasma vitamin A and E in preterm babies fed on breast milk or formula milk with or without long-chain polyunsaturated fatty acids. Int J Vitam Nutr Res. 1999;69(2):83-91. [pmid: 10218144].
254 Bougle D, Denise P, Vimard F, et al. Early neurological and neuropsychological development of the preterm infant and polyunsaturated fatty acids supply. Clin Neurophysiol. 1999;110(8):1363-1370. [pmid: 10454271].
255 Boue C, Combe N, Billeaud C, et al. Nutritional implications of trans fatty acids during perinatal period, in French pregnant women. Lipids, fats and oils: opportunities and responsibilities in the New Century. 2001;8(1):68-72.
256 Groh-Wargo S, Moore J J, Catalano P, et al. Docosahexaenoic acid (DHA) and arachidonic acid (AA) supplementation does not change body composition in preterm (PT) infants. Pediatr Res. 2002;51(4):380A.
257 Koletzko B, Sauerwald U, Keicher U et al. Fatty acid profiles, antioxidant status, and growth of preterm infants fed diets without or with long-chain polyunsaturated fatty acids: A randomized clinical trial. Eur J Nutr 2003; 42(5).
258 Fewtrell M S, Abbott R A, Kennedy K, et al. Randomized, double-blind trial of long-chain polyunsaturated fatty acid supplementation with fish oil and borage oil in preterm infants. J Pediatr. 2004;144(4):471-479. [pmid: 15069395].
259 Martinez F E, Santos M Md, Sieber V M, et al. Growth and nitrogen balance in preterm infants fed formula with long chain polyunsaturated fatty acids. Nutr Res. 1999;19(10):1497-1505.
260 Ponder D L, Innis S M, Benson J D, et al. Docosahexaenoic acid status of term infants fed breast milk or infant formula containing soy oil or corn oil. Pediatr Res. 1992;32(6):683-688. [pmid: 1287559].
261 Decsi T, Koletzko B. Growth, fatty acid composition of plasma lipid classes, and plasma retinol and alpha-tocopherol concentrations in full-term infants fed formula enriched with omega-6 and omega-3 long-chain polyunsaturated fatty acids. Acta Paediatr. 1995;84(7):725-732. [pmid: 7549287].
262 Makrides M, Neumann M, Simmer K, et al. Are long-chain polyunsaturated fatty acids essential nutrients in infancy?[comment]. Lancet. 1995;345(8963):1463-1468. [pmid: 7769900].
263 Innis S M, Akrabawi S S, Diersen-Schade D A, et al. Visual acuity and blood lipids in term infants fed human milk or formulae.[erratum appears in Lipids 1997 Apr;32(4):457]. Lipids. 1997;32(1):63-72. [pmid: 9075195].
264 Jorgensen M H, Holmer G, Lund P, et al. Effect of formula supplemented with docosahexaenoic acid and gamma- linolenic acid on fatty acid status and visual acuity in term infants. J Pediatr Gastroenterol Nutr. 1998;26(4):412-421. [pmid: 9552137].
265 Lucas A, Stafford M, Morley R, et al. Efficacy and safety of long-chain polyunsaturated fatty acid supplementation of infant-formula milk: a randomised trial.[comment]. Lancet. 1999;354(9194):1948-1954. [pmid: 10622297].
266 Makrides M, Neumann M A, Jeffrey B, et al. A randomized trial of different ratios of linoleic to alpha-linolenic acid in the diet of term infants: effects on visual function and growth.[comment]. Am J Clin Nutr. 2000;71(1):120-129. [pmid: 10617956].
267 Lapillonne A. Erythrocyte fatty acid composition in term infants fed human milk or a formula enriched with a low eicosapentanoic acid fish oil for 4 months. Eur J Pediatr. 2000;159(12):49-53. [pmid: 10653329].
268 Morris G, Moorcraft J, Mountjoy A, et al. A novel infant formula milk with added long-chain polyunsaturated fatty acids from single-cell sources: a study of growth, satisfaction and health. Eur J Clin Nutr. 2000;54(12):883-886. [pmid: 11114686].
269 Birch E E, Hoffman D R, Castaneda Y S, et al. A randomized controlled trial of long-chain polyunsaturated fatty acid supplementation of formula in term infants after weaning at 6 wk of age. Am J Clin Nutr. 2002;75(3):570-580. [pmid: 11864865].
270 Hoffman D R, Birch E E, Castaneda Y S, et al. Visual function in breast-fed term infants weaned to formula with or without long-chain polyunsaturates at 4 to 6 months: a randomized clinical trial. J Pediatr. 2003;142(6):669-677. [pmid: 12838196].
271 Innis S M, Gilley J, Werker J. Are human milk long-chain polyunsaturated fatty acids related to visual and neural development in breast-fed term infants?. J Pediatr. 2001;139(4):532-538. [pmid: 11598600].
272 Wezel-Meijler G, van der Knaap M S, Huisman J, et al. Dietary supplementation of long-chain polyunsaturated fatty acids in preterm infants: effects on cerebral maturation. Acta Paediatr. 2002;91(9):942-950. [pmid: 12412870].
273 Fewtrell M S, Morley R, Abbott R A, et al. Double-blind, randomized trial of long-chain polyunsaturated fatty acid supplementation in formula fed to preterm infants. Pediatrics. 2002;110(1):73-82. [pmid: 12093949].
274 Cheruku S R, Montgomery-Downs H E, Farkas S L, et al. Higher maternal plasma docosahexaenoic acid during pregnancy is associated with more mature neonatal sleep-state patterning. Am J Clin Nutr. 2002;76(3):608-613. [pmid: 12198007].
275 Krasevec J M, Jones P J, Cabrera-Hernandez A, et al. Maternal and infant essential fatty acid status in Havana, Cuba. Am J Clin Nutr. 2002;76(4):834-844. [pmid: 12324298].
276 Williams C, Birch E E, Emmett P M, et al. Stereoacuity at age 3.5 y in children born full-term is associated with prenatal and postnatal dietary factors: a report from a population-based cohort study. Am J Clin Nutr. 2001;73(2):316-322. [pmid: 11157330].
277 Carlson S E, Ford A J, Werkman S H, et al. Visual acuity and fatty acid status of term infants fed human milk and formulas with and without docosahexaenoate and arachidonate from egg yolk lecithin. Pediatr Res. 1996;39(5):882-888. [pmid: 8726246].
278 Birch E, Birch D, Hoffman D, et al. Breast-feeding and optimal visual development. J Pediatr Ophthalmol Strabismus. 1993;30(1):33-38. [pmid: 8455123].
279 Leaf A, Gosbell A, McKenzie L, et al. Long chain polyunsaturated fatty acids and visual function in preterm infants. Early Hum Dev. 1996;45(12):35-53. [pmid: 8842638].
280 Makrides M, Simmer K, Goggin M, et al. Erythrocyte docosahexaenoic acid correlates with the visual response of healthy, term infants. Pediatr Res. 1993;33(4 Pt 1):425-427. [pmid: 8479826].
281 Innis S M, Nelson C M, Rioux M F, et al. Development of visual acuity in relation to plasma and erythrocyte omega-6 and omega-3 fatty acids in healthy term gestation infants. Am J Clin Nutr. 1994;60(3):347-352. [pmid: 8074064].
282 Jorgensen M H, Hernell O, Lund P, et al. Visual acuity and erythrocyte docosahexaenoic acid status in breast-fed and formula-fed term infants during the first four months of life. Lipids. 1996;31(1):99-105. [pmid: 8649242].
283 Bistrian B R. Clinical aspects of essential fatty acid metabolism: Jonathan Rhoads Lecture. [Review] [68 refs]. JPEN J Parenter Enteral Nutr. 2003;27(3):168-175. [pmid: 12757109].
284 Agostoni C, Marangoni F, Giovannini M, et al. Prolonged breast-feeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol. 2001;501:137-141. [pmid: 11787675].
285 Ghys A, Bakker E, Hornstra G, et al. Red blood cell and plasma phospholipid arachidonic and docosahexaenoic acid levels at birth and cognitive development at 4 years of age. Early Hum Dev. 2002;69(12):83-90. [pmid: 12324186].
286 Gobel Y, Koletzko B, Bohles H J, et al. Parenteral fat emulsions based on olive and soybean oils: a randomized clinical trial in preterm infants. J Pediatr Gastroenterol Nutr. 2003;37(2):161-167. [pmid: 12883303].
287 McClead R E Jr, Meng H C, Gregory S A, et al. Comparison of the clinical and biochemical effect of increased alpha-linolenic acid in a safflower oil intravenous fat emulsion. J Pediatr Gastroenterol Nutr. 1985;4(2):234-239. [pmid: 2859362].
288 Helland I B, Saugstad O D, Smith L, et al. Similar effects on infants of n-3 and n-6 fatty acids supplementation to pregnant and lactating women. Pediatrics. 2001;108(5):E82. [pmid: 11694666].
289 Carver J D. Advances in nutritional modifications of infant formulas. Breast Milk and Breastfed Infants: Implications for Improving Infant Formula, Cancun, Mexico, May 23 24, 2002. 2003;77(6):1550S-1554S.
290 Malcolm C A, Hamilton R, McCulloch D L, et al. Scotopic electroretinogram in term infants born of mothers supplemented with docosahexaenoic acid during pregnancy. Invest Ophthalmol Vis Sci. 2003;44(8):3685-3691. [pmid: 12882824].
291 Onwude J L, Lilford R J, Hjartardottir H, et al. A randomised double blind placebo controlled trial of fish oil in high risk pregnancy. Br J Obstet Gynaecol. 1995;102(2):95-100. [pmid: 7756226].
292 Bulstra-Ramakers M T, Huisjes H J, Visser G H. The effects of 3g eicosapentaenoic acid daily on recurrence of intrauterine growth retardation and pregnancy induced hypertension. Br J Obstet Gynaecol. 1995;102(2):123-126. [pmid: 7756203].
293 de Groot R H, Hornstra G, van Houwelingen A C, et al. Effect of alpha-linolenic acid supplementation during pregnancy on maternal and neonatal polyunsaturated fatty acid status and pregnancy outcome. Am J Clin Nutr. 2004;79(2):251-260. [pmid: 14749231].
294 Smuts C M, Borod E, Peeples J M, et al. High-DHA eggs: feasibility as a means to enhance circulating DHA in mother and infant. Lipids. 2003;38(4):407-414. [pmid: 12848286].
295 Dunstan J A, Mori T A, Barden A, et al. Effects of n-3 polyunsaturated fatty acid supplementation in pregnancy on maternal and fetal erythrocyte fatty composition. Eur J Clin Nutr. 2004;58(3):429-437. [pmid: 14985680].
296 Smuts C M, Huang M, Mundy D, et al. A randomized trial of docosahexaenoic acid supplementation during the third trimester of pregnancy. Obstet Gynecol. 2003;101(3):469-479. [pmid: 12636950].
297 D'Almeida A, Carter J P, Anatol A, et al. Effects of a combination of evening primrose oil (gamma linolenic acid) and fish oil (eicosapentaenoic + docahexaenoic acid) versus magnesium, and versus placebo in preventing pre-eclampsia. Women Health. 1992;19(23):117-131. [pmid: 1492408].
298 Laivuori H, Hovatta O, Viinikka L, et al. Dietary supplementation with primrose oil or fish oil does not change urinary excretion of prostacyclin and thromboxane metabolites in pre-eclamptic women. Prostaglandins Leukot Essent Fatty Acids. 1993;49(3):691-694. [pmid: 8248275].
299 van der Schouw Y T, Al M D, Hornstra G, et al. Fatty acid composition of serum lipids of mothers and their babies after normal and hypertensive pregnancies. Prostaglandins Leukot Essent Fatty Acids. 1991;44(4):247-252. [pmid: 1815240].
300 Velzing-Aarts F V, van der Klis F R, van der Dijs F P, et al. Umbilical vessels of preeclamptic women have low contents of both n-3 and n-6 long-chain polyunsaturated fatty acids. Am J Clin Nutr. 1999;69(2):293-298. [pmid: 9989695].
301 Williams M A, Zingheim R W, King I B, et al. Omega-3 fatty acids in maternal erythrocytes and risk of preeclampsia. Epidemiology. 1995;6(3):232-237. [pmid: 7619928].
302 Rocquelin G, Tapsoba S, Kiffer J, et al. Human milk fatty acids and growth of infants in Brazzaville (The Congo) and Ouagadougou (Burkina Faso). Public Health Nutr. 2003;6(3):241-248. [pmid: 12740073].
303 Field C J, Thomson C A, Aerde Jv, et al. Lower proportion of CD45R0+ cells and deficient interleukin-10 production by formula-fed infants, compared with human-fed, is corrected with supplementation of long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr. 2000;31(3):291-299. [pmid: 10997375].
304 Uauy R, Hoffman D R. Essential fat requirements of preterm infants. [Review] [46 refs]. Am J Clin Nutr. 2000;71(1 Suppl):245S-250S. [pmid: 10617979].
305 Koletzko B, Edenhofer S, Lipowsky G, et al. Effects of a low birthweight infant formula containing human milk levels of docosahexaenoic and arachidonic acids. J Pediatr Gastroenterol Nutr. 1995;21(2):200-208. [pmid: 7472907].
306 Lapillonne A, Picaud JC, Chirouze V et al. Supplementation of preterm formulas (PTF) with a low EPA fish oil: Effect on polyunsaturated fatty acids(PUFAS) status and growth. J Pediatr Gastroenterol Nutr 1997; 24(4).
307 Vanderhoof J, Gross S, Hegyi T, et al. Evaluation of a long-chain polyunsaturated fatty acid supplemented formula on growth, tolerance, and plasma lipids in preterm infants up to 48 weeks postconceptional age. J Pediatr Gastroenterol Nutr. 1999;29(3):318-326. [pmid: 10467999].
308 Martinez F E, Santos M Md, Sieber V M, et al. Growth and nitrogen balance in preterm infants fed formula with long chain polyunsaturated fatty acids. Nutr Res. 1999;19(10):1497-1505.
309 Woltil H A, van Beusekom C M, Okken-Beukens M, et al. Development of low-birthweight infants at 19 months of age correlates with early intake and status of long-chain polyunsaturated fatty acids. Prostaglandins Leukot Essent Fatty Acids. 1999;61(4):235-241. [pmid: 10574647].
310 O'Connor D L, Hall R, Adamkin D, et al. Growth and development in preterm infants fed long-chain polyunsaturated fatty acids: a prospective, randomized controlled trial. Pediatrics. 2001;108(2):359-371. [pmid: 11483801].
311 Clandinin M T V. Growth and development of very-low-birth-weight infants (VLBW) is enhanced by formulas supplemented with docosahexaenoic acid (DHA) and arachidonic acid (ARA). J Pediatr Gastroenterol Nutr. 2002;34(4):479.
312 Innis S M, Adamkin D H, Hall R T, et al. Docosahexaenoic acid and arachidonic acid enhance growth with no adverse effects in preterm infants fed formula. J Pediatr. 2002;140(5):547-554. [pmid: 12032520].
313 Groh-Wargo S, Moore J J, Catalano P, et al. Docosahexaenoic acid (DHA) and arachidonic acid (AA) supplementation does not change body composition in preterm (PT) infants. Pediatr Res. 2002;51(4):380A.
314 Koletzko B, Sauerwald U, Keicher U et al. Fatty acid profiles, antioxidant status, and growth of preterm infants fed diets without or with long-chain polyunsaturated fatty acids: A randomized clinical trial. Eur J Nutr 2003; 42(5).
315 Carlson S E, Rhodes P G, Rao V S, et al. Effect of fish oil supplementation on the n-3 fatty acid content of red blood cell membranes in preterm infants. Pediatr Res. 1987;21(5):507-510. [pmid: 2954026].
316 Birch D G, Birch E E, Hoffman D R, et al. Retinal development in very-low-birth-weight infants fed diets differing in omega-3 fatty acids. Invest Ophthalmol Vis Sci. 1992;33(8):2365-2376. [pmid: 1386065].
317 Faldella G, Govoni M, Alessandroni R, et al. Visual evoked potentials and dietary long chain polyunsaturated fatty acids in preterm infants. Arch Dis Child Fetal Neonatal Ed. 1996;75(2):F108-F112. [pmid: 8949693].
318 Ghebremeskel K, Burns L, Costeloe K, et al. Plasma vitamin A and E in preterm babies fed on breast milk or formula milk with or without long-chain polyunsaturated fatty acids. Int J Vitam Nutr Res. 1999;69(2):83-91. [pmid: 10218144].
319 Bougle D, Denise P, Vimard F, et al. Early neurological and neuropsychological development of the preterm infant and polyunsaturated fatty acids supply. Clin Neurophysiol. 1999;110(8):1363-1370. [pmid: 10454271].
320 Field C J, Thomson C A, Aerde Jv, et al. Lower proportion of CD45R0+ cells and deficient interleukin-10 production by formula-fed infants, compared with human-fed, is corrected with supplementation of long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr. 2000;31(3):291-299. [pmid: 10997375].
321 Fewtrell M S, Morley R, Abbott R A, et al. Double-blind, randomized trial of long-chain polyunsaturated fatty acid supplementation in formula fed to preterm infants. Pediatrics. 2002;110(1):73-82. [pmid: 12093949].
322 Fewtrell M S, Abbott R A, Kennedy K, et al. Randomized, double-blind trial of long-chain polyunsaturated fatty acid supplementation with fish oil and borage oil in preterm infants. J Pediatr. 2004;144(4):471-479. [pmid: 15069395].
323 Griffin ME, Brown PB, Grant AL. The dietary lysine requirement of juvenile hybrid striped bass. J Nutr 1992; 122(6).
324 Decsi T, Koletzko B. Growth, fatty acid composition of plasma lipid classes, and plasma retinol and alpha-tocopherol concentrations in full-term infants fed formula enriched with omega-6 and omega-3 long-chain polyunsaturated fatty acids. Acta Paediatr. 1995;84(7):725-732. [pmid: 7549287].
325 Jensen C L, Prager T C, Fraley J K, et al. Effect of dietary linoleic/alpha-linolenic acid ratio on growth and visual function of term infants.[comment]. J Pediatr. 1997;131(2):200-209. [pmid: 9290604].
326 Innis S M, Akrabawi S S, Diersen-Schade D A, et al. Visual acuity and blood lipids in term infants fed human milk or formulae.[erratum appears in Lipids 1997 Apr;32(4):457]. Lipids. 1997;32(1):63-72. [pmid: 9075195].
327 Auestad N, Montalto M B, Hall R T, et al. Visual acuity, erythrocyte fatty acid composition, and growth in term infants fed formulas with long chain polyunsaturated fatty acids for one year. Ross Pediatric Lipid Study. Pediatr Res. 1997;41(1):1-10. [pmid: 8979282].
328 Morris G, Moorcraft J, Mountjoy A, et al. A novel infant formula milk with added long-chain polyunsaturated fatty acids from single-cell sources: a study of growth, satisfaction and health. Eur J Clin Nutr. 2000;54(12):883-886. [pmid: 11114686].
329 Auestad N, Halter R, Hall R T, et al. Growth and development in term infants fed long-chain polyunsaturated fatty acids: a double-masked, randomized, parallel, prospective, multivariate study. Pediatrics. 2001;108(2):372-381. [pmid: 11483802].
330 Ponder D L, Innis S M, Benson J D, et al. Docosahexaenoic acid status of term infants fed breast milk or infant formula containing soy oil or corn oil. Pediatr Res. 1992;32(6):683-688. [pmid: 1287559].
331 Jorgensen M H, Holmer G, Lund P, et al. Effect of formula supplemented with docosahexaenoic acid and gamma- linolenic acid on fatty acid status and visual acuity in term infants. J Pediatr Gastroenterol Nutr. 1998;26(4):412-421. [pmid: 9552137].
332 Lapillonne A. Erythrocyte fatty acid composition in term infants fed human milk or a formula enriched with a low eicosapentanoic acid fish oil for 4 months. Eur J Pediatr. 2000;159(12):49-53. [pmid: 10653329].
333 Willatts P, Forsyth J S, DiModugno M K, et al. Effect of long-chain polyunsaturated fatty acids in infant formula on problem solving at 10 months of age. Lancet British edition. 1998;352(9129):688-691.
334 Hoffman D R, Birch E E, Castaneda Y S, et al. Visual function in breast-fed term infants weaned to formula with or without long-chain polyunsaturates at 4 to 6 months: a randomized clinical trial. J Pediatr. 2003;142(6):669-677. [pmid: 12838196].
335 Birch E E, Hoffman D R, Castaneda Y S, et al. A randomized controlled trial of long-chain polyunsaturated fatty acid supplementation of formula in term infants after weaning at 6 wk of age. Am J Clin Nutr. 2002;75(3):570-580. [pmid: 11864865].
336 Gibson R A, Neumann M A, Makrides M. Effect of increasing breast milk docosahexaenoic acid on plasma and erythrocyte phospholipid fatty acids and neural indices of exclusively breast fed infants. Eur J Clin Nutr. 1997;51(9):578-584. [pmid: 9306083].
337 Agostoni C, Marangoni F, Giovannini M, et al. Prolonged breast-feeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol. 2001;501:137-141. [pmid: 11787675].
338 Cheruku S R, Montgomery-Downs H E, Farkas S L, et al. Higher maternal plasma docosahexaenoic acid during pregnancy is associated with more mature neonatal sleep-state patterning. Am J Clin Nutr. 2002;76(3):608-613. [pmid: 12198007].
339 Avon Longitudinal Study of Pregnancy and Childhood (ALSPAC) Web site. 2005.
340 Jensen C L, Prager T C, Zou Y, et al. Effects of maternal docosahexaenoic acid supplementation on visual function and growth of breast-fed term infants. Lipids. 1999;34(Suppl):S225. [pmid: 10419159].
341 Adewusi S R, Orisadare B O, Oke O L. Studies on weaning diets in Nigeria: 2 protein sources. Plant Foods Hum Nutr. 1992;42(2):183-192. [pmid: 1574484].
342 Khoshoo V, Brown S. Gastric emptying of two whey-based formulas of different energy density and its clinical implication in children with volume intolerance. Eur J Clin Nutr. 2002;56(7):656-658. [pmid: 12080406].
343 Christian P, West K P J, Khatry S K, et al. Night blindness of pregnancy in rural Nepal - nutritional and health risks. Int J Epidemiol. 1998;27(2):231-237. [pmid: 9602403].
344 Williams J. Two enteric coated microspheres in cystic fibrosis. Arch Dis Child. 1990;65(6):594-597. [pmid: 2198848].
345 Werkman S H, Carlson S E. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until nine months. Lipids. 1996;31(1):91-97. [pmid: 8649241].
346 Elias S L, Innis S M. Infant plasma trans, n-6, and n-3 fatty acids and conjugated linoleic acids are related to maternal plasma fatty acids, length of gestation, and birth weight and length.[comment]. Am J Clin Nutr. 2001;73(4):807-814. [pmid: 11273857].
347 Staessen L, De Bacquer D, De Henauw S, et al. Fatty acid composition of the Belgian diet: estimates derived from the Belgian Interuniversity Research on Nutrition and Health. Ann Nutr Metab. 1998;42(3):151-159. [pmid: 9657459].
348 Ollis T E, Meyer B J, Howe P R. Australian food sources and intakes of omega-6 and omega-3 polyunsaturated fatty acids. Ann Nutr Metab. 1999;43(6):346-355. [pmid: 10725768].
349 Simmer K. Longchain polyunsaturated fatty acid supplementation in preterm infants. [Review][16 refs]. Cochrane Database Syst Rev 2000;(2):CD000375.
350 Simmer K. Longchain polyunsaturated fatty acid supplementation in infants born at term. Cochrane Database Syst Rev 2003; 3.
351 SanGiovanni J P, Parra-Cabrera S, Colditz G A, et al. Meta-analysis of dietary essential fatty acids and long-chain polyunsaturated fatty acids as they relate to visual resolution acuity in healthy preterm infants. Pediatrics. 2000;105(6):1292-1298. [pmid: 10835071].
352 Baker P N. Possible dietary measures in the prevention of pre-eclampsia and eclampsia. [Review] [73 refs]. Baillieres Clin Obstet Gynaecol. 1995;9(3):497-507. [pmid: 8846552].
353 SanGiovanni J P, Berkey C S, Dwyer J T, et al. Dietary essential fatty acids, long-chain polyunsaturated fatty acids, and visual resolution acuity in healthy fullterm infants: a systematic review. Early Hum Dev. 2000;57(3):165-188. [pmid: 10742608].
354 Kaufman AS, Kaufman NL. Kaufman Assessment Battery for Children. Circle Pines, MN: American Guidance Service, 1983.
355 Su H M, Huang M C, Saad N M, et al. Fetal baboons convert 18:3n-3 to 22:6n-3 in vivo. A stable isotope tracer study. J Lipid Res. 2001;42(4):581-586. [pmid: 11290830].
356 Jacobson S W. Assessment of long-chain polyunsaturated fatty acid nutritional supplementation on infant neurobehavioral development and visual acuity. Lipids. 1999;34(2):151-160. [pmid: 10102241].
357 Carlson S E, Neuringer M. Polyunsaturated fatty acid status and neurodevelopment: a summary and critical analysis of the literature. Lipids. 1999;34(2):171-178. [pmid: 10102243].