# Acknowledgments

The authors would like to thank numerous individuals for their support of the present project: our collaborators at SC-RAND and Tufts-NEMC EPCs; Isabella Steffensen and Christine Murray for their ability to convey with words, tables and figures what it is we did and found; for their expert and timely translation of articles; Herb Woolf for responding with substance to our request of industry for evidence; Peter O'Blenis for assuring that our software would adapt and grow as quickly as the project requirements shifted and expanded; Mary Fewtrell; Sjurdur Frodi Olsen; Maria Makrides; Eileen Birch; Susan Carlson for timely responded to our requests to clarify their research; Khai Tran and Maia Miguelez, PhD for providing input on the data abstraction forms; Nancy Santesso for helping on the development of the search strategy; Raymond Daniel for helping to retrieve the hard copies of the studies, Manijeh Hamifard for helping on the data abstraction and Chantelle Garritty for coordinating the project.