# Results

## Results of Literature Search

Regardless of its source, the progress of each bibliographic record through the stages of the systematic review is illustrated in the modified QUOROM flow chart (Appendix D *). Ideally, a record included an abstract and key words, in addition to a citation. When a citation was discovered, for example, through a manual search of a reference list, its complete bibliographic record was sought (e.g., PubMed®) and then entered into the first level of relevance screening.

* Appendices and Evidence tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/o3mchtp.htmhttp://www.ahrq.gov/clinic/tp/o3mchtp.htm

Of the 2,049 records entered into the initial screening for relevance, 1,579 were excluded. Reflecting the specific eligibility criteria, the reasons for exclusion were: a. did not involve human participants (n=301); b. did not involve omega-3 FAs as an exposure/intervention (n=827); c. the purpose of the exposure/intervention was not for the assessment of child or maternal health outcomes (n=253); and, d. not a primary study (e.g., a review; n=198). All of the remaining 470 reports were then retrieved and subjected to a more detailed relevance assessment. The second relevance screening then excluded 279 reports for the following reasons: a. did not involve human participants (n=15); b. did not involve omega-3 FAs as an exposure/intervention (n=101); c. the purpose of the exposure/intervention did not concern maternal or childhood health outcomes (n=69); and, d. not a primary study (e.g., a review; n=76). There were an additional number of reports not retrieved at this level (n=18). The third relevance screening took into the account the level of evidence appropriate to answer each question. A list of excluded due to level of evidence (i.e., observational studies) studies for each topic is included in the Appendix F. Of the 191 reports that made it to this level of screening, 74 were excluded. Hence, in total, 117 reports, describing 89 unique studies, were deemed relevant for the systematic review, with 20 studies each described by more than one report and three reports describing more than one unique study.

The 20 unique studies reported by more than one report were: Agostoni et al. ^176^ (Agostoni et al. ^177,^ ^178^ ), Al et al. 1995 ^179^ (Al et al. ^180^ ), Auestad et al., ^104^ (Scott et al. ^104^ , Auestad et al. ^181^ ), Birch et al. ^182^ (Birch et al., ^183^ Hoffman et al. ^184^ ), Carlson et al. ^185^ (Werkman et al., ^186^ Carlson et al. ^187–190^ ), Carlson et al. ^191^ (Carlson et al. ^192^ ), Clandinin et al. ^193^ (secondary reports ^194,^ ^195^ ), de Groot et al., ^196^ (de Groot et al. ^197^ ), Faldella et al. ^198^ (Faldella et al. ^199^ ), Helland et al., ^141^ (Helland et al. ^200^ ), Innis et al. ^201^ (Diersen-Schade et al. ^202^ ), Jensen et al. ^203^ (Voigt et al. ^204^ ), Makrides et al. ^205^ (secondary report ^206^ ), O'Connor et al. ^207^ (secondary report ^208^ ), Olsen et al. ^209^ (Olsen et al., ^210^ Salvig et al. ^211^ ), Uauy et al. ^212^ (Uauy et al., ^213^ Hoffman et al., ^214,^ ^215^ Birch et al., ^216^ Uauy et al., ^217^ ), Vanderhoof et al. ^218^ (Vanderhoof et al. ^219,^ ^220^ ), Vilbergsson et al. ^221^ (secondary report ^222^ ), Willatts et al. ^223^ (secondary report ^224^ ), Woltil et al. ^225^ (secondary report ^226^ ).

Auestad et al. ^227^ that included two uniques studies as well as Birch et al. ^228^ Olsen et al. reported 6 unique trials. ^31^

## Report and Study Design Characteristics of Included Studies

Of the 117 relevant reports describing 89 unique studies, there were 63 randomized controlled trials (RCTs) and 26 observational studies across all the key questions. As an overview, the number of included studies investigating each question are described below, distinguishing the reports by population type (maternal, preterm or term infants), by intake of omega-3 FA supplements, or by research design. Since a given study may address more than one question, some studies may be described for more than one question.

Only one study required translation from German to English. ^229^

Fifteen uniques studies investigated the influence of omega-3 FAs during pregnancy on the duration of gestation. ^141,^ ^196,^ ^209,^ ^230,^ ^231,^ ^231–235^ All reports were RCTs since we had decided to exclude other research designs if enough well-conducted RCTs were identified. Eight RCTs evaluated the question regarding the influence of maternal intake of omega-3 FA during pregnancy on the incidence of gestational hypertension (GHT), pre-eclampsia or eclampsia, ^209,^ ^230,^ ^234,^ ^236–238^ whereas, 14 RCTs assessed the outcome of incidence of infants small for gestational age (SGA). ^141,^ ^196,^ ^209,^ ^230–236,^ ^238^

Regarding the question of the association between the duration of gestation in women with or without a history of a previous preterm birth with the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy, four studies were identified—one RCT, ^234^ one case-control study, ^239^ one single prospective cohort study, ^240^ and one cross-sectional study. ^241^ Five observational studies addressed the question of the association between maternal biomarkers and the incidence of GHT, pre-eclampsia or eclampsia—one was a prospective cohort study ^179^ and four were of cross-sectional design. ^229,^ ^242–244^ Whereas, one RCT, ^196^ two case-control studies, ^245,^ ^246^ one single prospective cohort study ^240^ and two cross-sectional studies ^241,^ ^247^ were identified that addressed the possible association between the incidence of SGA infants and the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy.

No studies were identified across all the child outcomes (i.e., growth patterns, neurocognitive development and visual function) regarding the influence of the intake of omega-3 FA from sources other than human milk, or infant formula.

Only one RCT was identified to answer the question of maternal intake of omega-3 FA during pregnancy and its influence of the growth pattern in term and preterm infants. ^141^ One RCT, ^248^ one prospective cohort study, ^249^ and one cross-sectional study addressed the question of the influence of omega-3 FA content of human milk, with or without known maternal intake, on growth patterns in term infants. No studies were identified that addressed this question in the preterm population. Twenty RCTs investigated the influence of omega-3 FA content in formula, with or without human milk intake, on the growth patterns in preterm infants, ^185,^ ^193,^ ^198,^ ^201,^ ^207,^ ^212,^ ^218,^ ^225,^ ^250–259^ whereas, 18 RCTs were conducted in term infants. ^104,^ ^182,^ ^203,^ ^205,^ ^223,^ ^227,^ ^260–270^

No studies were identified regarding the association between the omega-3 or omega-6/omega-3 FA content of maternal or fetal biomarkers during pregnancy and the growth patterns of term or preterm infants. However, a total of 12 studies addressed the question of child biomarkers, of which five RCTs included a preterm population of infants, ^185,^ ^191,^ ^201,^ ^207,^ ^212^ and five RCTs ^143,^ ^203,^ ^205,^ ^262,^ ^263^ and one prospective single cohort study ^271^ included a term population of infants; the Woltil et al. study, which was deliberately described only in the preterm section of this question, selected a group of very low birth weight (VLBW) preterm and term infants. ^225^

Only one RCT was identified to answer the question of maternal intake of omega-3 FA during pregnancy and its influence on the neurological development in term and preterm infants. ^141^ One RCT ^138^ and one prospective cohort study evaluated the influence of omega-3 FA content of human milk, with or without known maternal intake, on the neurological development in term infants. No studies were identified in the preterm population for this particular question. Six RCTs investigated the influence of omega-3 FA content in formula, with or without human milk intake, on the neurological development outcomes in preterm infants, ^193,^ ^207,^ ^254,^ ^270,^ ^272,^ ^273^ whereas, eight RCTs were conducted in term infants. ^104,^ ^176,^ ^182,^ ^203,^ ^205,^ ^227,^ ^227,^ ^265^

One cross-sectional study conducted in the United States assessed the association between maternal omega-3 FA content during pregnancy and the neurological development of the infants. ^274^ No studies were identified to assess the association between the neurological develoment in term or preterm infants and the omega-3 or omega-6/omega-3 FA content of fetal biomarkers during pregnancy. However, four RCTs ^176,^ ^182,^ ^203,^ ^205^ and one prospective cohort study ^271^ investigated this association, but in child biomarkers.

One RCT ^235^ and one cross-sectional study ^275^ evaluated the question of maternal intake of omega-3 FA during pregnancy and its influence on the visual function in term and preterm infants. Two RCTs, ^138,^ ^248^ one prospective cohort ^276^ and one cross-sectional study ^140^ evaluated the influence of omega-3 FA content of human milk, with or without known maternal intake, on the visual function in term infants. No studies were identified in the preterm population for this particular question. Nine unique RCTs investigated the influence of omega-3 FA content in formula, with or without human milk intake, on visual function outcomes in preterm infants, ^185,^ ^191,^ ^198,^ ^201,^ ^207,^ ^212,^ ^251,^ ^254,^ ^272^ whereas, 13 RCTs were conducted in term infants. ^104,^ ^182,^ ^203,^ ^205,^ ^227,^ ^262–264,^ ^266,^ ^269,^ ^270,^ ^277^

One cross-sectional study assessed the association between maternal omega-3 FA content during pregnancy and the visual function of the infants. ^275^ No studies were identified to assess the association between visual function in term or preterm infants and the omega-3 or omega-6/omega-3 FA content of fetal biomarkers during pregnancy. However, 21 studies investigated this association in child biomarkers. Five studies included a preterm population, ^185,^ ^198,^ ^212,^ ^278,^ ^279^ whereas, 16 studies included term infants. Of five studies in the preterm group, three were RCTs ^185,^ ^198,^ ^212^ and two were cross-sectional studies. ^278,^ ^279^ Of the 16 term infant studies, nine were RCTs ^138,^ ^182,^ ^203,^ ^248,^ ^262–264,^ ^269,^ ^270^ and seven were observational studies. ^140,^ ^271,^ ^275,^ ^278,^ ^280–282^

One RCT ^283^ evaluated the question of maternal intake of omega-3 FA during pregnancy and its influence on the cognitive development outcomes in term and preterm infants. One RCT ^138^ and one single prospective cohort study ^284^ evaluated the influence of omega-3 FA content of human milk, with or without known maternal intake, on the cognitive development of term infants. No studies evaluated this outcome in preterm infants.

Six RCTs investigated the influence of omega-3 FA content in formula, with or without human milk intake, on the cognitive develoment in preterm infants, ^185,^ ^193,^ ^207,^ ^258,^ ^272,^ ^273^ while eight RCTs were conducted in term infants. ^104,^ ^182,^ ^203,^ ^205,^ ^223,^ ^227,^ ^265^ No studies were identified that evaluated the association between the omega-3 FA content of maternal or fetal biomarkers during pregnancy and the cognitive development outcomes. However, six studies addressed the question of child biomarkers. Four studies were RCTs ^138,^ ^182,^ ^203,^ ^205^ and two were single prospective cohort studies. ^271,^ ^285^

All of the RCT's were evaluated for safety data. In addition, two other RCTs, although not providing efficacy data, did provide safety data and hence were also evaluated. ^286,^ ^287^

The remainder of this chapter is organized by group of outcomes (pregnancy, growth, neurological, visual and cognitive), with the evidence addressing each of the key questions related to the type of intake, where at least one study was identified. Safety data is presented last. A table describing the composition of the interventional infant formulas used across the trials was added to Appendix G *. We begin with pregnancy outcomes.

## Pregnancy Outcomes

### What is the Evidence That Intake of Omega-3 Fatty Acids Influences the Duration of Gestation in Women With or Without a History of a Previous Preterm Birth (Gestational Duration Less Than 37 Weeks)?

Fifteen RCTs met eligibility criteria for investigating a possible influence of maternal intake of omega-3 FA supplementation on the duration of gestation. ^141,^ ^196,^ ^209,^ ^230,^ ^231,^ ^231–235^ The studies were published between 1992 and 2004 (see Summary Tables 1 to 3).

#### Overview of relevant studies

Olsen et al. investigated the effect of n-3 LCPUFA supplementation given as fish oil in 533 women with singleton pregnancies in their 30^th^ week of pregnancy (mean age=29 [18–44] years, smokers [31.2%], primiparae [59%]) on pregnancy duration. ^209^ The women were randomally assigned to one of three three diet regimens: daily intake of four 1 g capsules of fish oil (Pikasol) containing EPA (32 % by weight [wt%]) and DHA (23wt%) corresponding to 2.7 g omega-3 FA daily intake; four 1 g capsules of olive oil daily each containing oleic acid (72wt%) and LA (12wt%); or, no supplement. ^209^ (Summary Table 1)

Bulstra-Ramakers et al. investigated the effect of dietary supplementation with EPA on the incidence rate of premature deliveries and GHT in 68 pregnant women (68 completed the study) with or without a previous history of prematurity or GHT. ^238^ The intervention consisted of EPA capsules (each containing a mixture of 0.25 g EPA and DHA) in a daily dose of 3 g of EPA (four capsules three times per day). The placebo capsules, which were similar to the EPA capsules in appearance, smell, and taste, contained coconut oil. The interventions started between 12 and 14 weeks of GA. ^238^ (Summary Table 1)

Onwude et al. conducted an intention-to-treat (ITT) RCT to evaluate the effect of omega-3 FA (EPA/DHA) on the occurrence of proteinuric and nonproteinuric gestational hypertension (GHT) and asymmetrical intrauterine growth retardation (IUGR) in 233 pregnant women (232 completed the study; age range=16–40 years; mean gestational age (GA) at study entry=24 [18–32] weeks) at high-risk for developing these disorders. ^233^ GA was a secondary outcome measure for this study. The participants study were categorized as being multigravida, a history of one or more small babies (n=68), history of proteinuric or nonproteinuric GHT (n=76), history of unexplained stillbirth (n=16), and primigravida with abnormal uterine arcuate artery Doppler blood flow at 24 weeks GA (n=72). Participants were randomized to receive either 2.7 g MaxEpa daily containing 180 mg EPA and 120 mg DHA per capsule or matching air-filled capsules. The women were instructed to take nine capsules each day until the 38^th^ week of pregnancy. ^233^ (Summary Table 1)

Olsen et al., ^230^ in six multicenter RCTs including 19 hospitals, examined the preventative (prophylactic) and therapeutic effects of dietary n-3 FAs on pre-term delivery, IUGR and GHT in women with an increased risk for these clinical outcomes. Four prophylactic trials enrolled women after 16 weeks of GA with an uncomplicated pregnancy who had experienced previous pre-term delivery (n=232), IUGR (n=280), or GHT (n=386) and women who were currently pregnant with twins (n=579).

The two therapeutic trials enrolled women with threatening preeclampsia (n=79) or suspected IUGR (n=63). Participants were randomly assigned to receive fish oil (Pikasol: EPA [32wt%] and DHA [23wt%]) or olive oil in identical-looking capsules from approximately 20 weeks (prophylactic trials) or 33 weeks (therapeutic trials) until delivery. Treatment with fish oil corresponded to 1.3 g EPA and 0.9 g DHA daily intake for the prophylactic group and 2.9 g/d EPA and 2.1 g/d DHA for the therapeutic group. (Summary Table 2 to 3)

Helland et al. randomly assigned 590 (341 completers) healthy, nulli- or primiparous women in weeks 17 to 19 of pregnancy to receive either 10 mL/day of cod liver oil (containing 1,183 mg DHA, 112 mg EPA and 27.5 mg AA) or 10 mL/day of corn oil (containing only 8.3 mg DHA) until delivery. ^141^ The study evaluated GA as a primary outcome. ^141^ (Summary Table 4)

Smuts et al. randomized 347 women in their third trimester of pregnancy (350 pregnancies; three women got pregnant twice during the study), who were supplied with DHA-enriched eggs (mean of 133±15 mg of DHA per egg) or ordinary eggs (mean of 33±11 mg of DHA per egg), and assessed GA and birth weight as primary outcomes (291 completed the study). ^234^ The study also assessed the risk of preeclampsia/eclampsia. The mean number of consumed eggs was 6.8±4.6 per week for the group consuming high-DHA eggs and 7.7±5.6 for the group consuming ordinary eggs. ^234^ (Summary Table 4)

The second Smuts et al. study monitored the safety of consuming high-DHA hen eggs compared with ordinary eggs with respect to pregnancy outcomes as well as infant anthropometric parameters. ^232^ Fifty-two, mostly African-American women, in their third trimester of pregnancy were randomized to the two diet groups: 25 to the regular-egg group (mean daily DHA intake was 35.1±13.2 mg) and 27 to the high-DHA egg group (mean daily DHA intake was 183.9±71.4 mg). Another 21 pregnant women were not randomized and were not given supplementary eggs (low-egg intake group with a mean daily DHA intake 10.8±4.0 mg). ^232^ (Summary Table 4).

Malcolm et al. ^235^ investigated the duration of gestation in healthy pregnant women (ages 17–36 years) that received fish oil capsule supplements from a mean of 15.4 wk gestation until delivery (Marinol D40, 100 mg DHA per capsule) compared with sunflower oil capsules. ^235^ (Summary Table 5)

Dunstan et al. examined the effect of fish oil supplementation on maternal and neonatal FA status. ^231^ The study also investigated if the fish oil supplementation to the diet of pregnant women had any effect on the duration of pregnancy and the size of their infants at birth (birth weight, length, and head circumference [HC]). The study recruited 98 healthy non-smoking pregnant women (83 completed the study); 58% of the women had a known history of allergic rhinitis and 40% had a history of asthma. Participants were randomly assigned to receive their usual diet supplemented with either 4 g/day fish oil (1.1 g EPA and 2.2 g DHA per day) or olive oil capsules, from GA of 20 weeks until delivery. ^231^ (Summary Table 5)

de Groot et al. conducted a double-blind RCT in 79 pregnant women (58 completed the study) who were randomly assigned to receive at least 25 g/day of either an ALA-enriched, high-LA margarine (experimental group) or a high-LA margarine without ALA (control group), from week 14 of pregnancy until delivery. Subjects in the experimental group consumed 9.02 g LA and 2.82 g ALA daily, whereas, women in the control group received 10.94 g LA and 0.03 g ALA daily. One of the outcomes evaluated was the GA of the infant. ^196^ (Summary Table 5)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. Only the study of Olsen et al. had more than two study groups. ^209^ Countries where the studies were conducted included the United States, ^232,^ ^234^ the United Kingdom, ^233,^ ^235^ The Netherlands, ^196,^ ^238^ Australia, ^231^ Denmark ^209^ and Norway. ^141^ One multicenter study involved six trials conducted in 19 centers in Denmark, Scotland, Sweden, England, The Netherlands, Norway, Belgium and Russia. ^230^

Both of the studies by Smuts et al. ^232,^ ^234^ were financially supported by Market Biosciences Boulder Corporation (former Omega Teach Inc.), Boulder, Colorado. The study by Onwude et al. ^233^ was sponsored by Yorkshire Region Locally Organized Research, Glaxo (Leeds) and Seven Seas (Hull). Olsen et al.'s studies ^230^ were funded by Conserted Action and PECO programmes of European Comission and the Danish National Research Foundation. The study of de Groot et al. ^196^ was supported by Unilever Research and Development (Vlaardingen, Netherlands). Dunstan et al.'s ^231^ was funded by the NH and MRC and Raine Medical Research Foundation, Australia. The other study by Olsen et al. ^209^ was supported by the Danish Medical Research Council, Sygekassernes Helsefond, Weman's Legat and Michaelsen Fonden. The study by Helland et al. ^141^ was financed by Peter Moller, Avd. Orkla ASA and “Aktieselskabet Freia Chocoladefabriks Medicinske Fond.” Malcolm et al. was supported by the Chief Scientist's Office, Scottish Office Health Department. ^235^ Finally, Bulstra-Ramakers et al. failed to provide this information. ^238^

Population characteristics. There was a total number of 3,686 pregnant women enrolled across the fifteen trials. The sample size varied from as low as 37 ^232^ to 590 ^141^ women. However, Helland et al. analysed only the patients who completed the study (n=341 of 590, 57%). ^288^ The mean age-range of study participants across the eight studies was 19.9 (SD=4.1) years to 32.9 (SD=14.6) years. Participants in both of the Smuts et al. trials ^232,^ ^234^ tended to be younger (mean age range for high-DHA egg group=19.9 [SD=4.1] to 21.7 years; mean age range for placebo group=21.6 [SD=4.2] years to 24.8 [SD=7.8] years) than the participants in the rest of the studies (mean age range for treatment groups=27.6 [SD=3.2] years, and 32.9 [SD=14.6] years for the placebo groups). ^141,^ ^196,^ ^209,^ ^230,^ ^231,^ ^233^ Two trials did not provide this information. ^235,^ ^238^

A thorough description of both inclusion and exclusion criteria were given in all trials. Information about racial/ethnic backgrounds were given in three of the 15 studies. ^196,^ ^232,^ ^234^ Study participants in two trials were predominantly of African-American descent, comprising 79% and 73% of participants in the ordinary egg groups, and 83% and 73% of participants in the high-DHA egg groups, respectively. ^232,^ ^234^ Only White participants were recruited in the Groot et al. study. ^196^

The exact duration of maternal dietary intervention during pregnancy and/or breastfeeding was reported in all but two studies, ^209,^ ^233^ and ranged from 5 weeks ^230^ to 8 months. ^141^ In most of the studies, LCPUFA supplementation was prescribed in the second trimester of pregnancy. ^141,^ ^196,^ ^231,^ ^233,^ ^235,^ ^238^ In three studies, PUFA supplementation was administered from the third trimester until delivery. ^209,^ ^232,^ ^234^ There was no study where participants were randomized from the first trimester. In one of the studies of Olsen et al., four prophylactic groups of pregnant women were randomized from gestational week 20, whereas, in the therapeutic trials women were randomized around gestational week 33. ^230^ Detailed information about the duration of the LCPUFA supplementation is provided in the Evidence Tables (Appendix E *). Maternal social status, defined as years of education, was determined in two studies. ^141,^ ^196^

Information regarding maternal smoking history and/or smoking during pregnancy was provided in eleven studies. ^141,^ ^196,^ ^209,^ ^230,^ ^233,^ ^234^ Alcohol consumption at 14 weeks of pregnancy was reported in one study. ^196^

In the majority of RCTs, there was no evidence that randomization failed to produce comparable groups in terms of previous obstetric history, socioeconomic status, dietary intake of fish, smoking habits, alcohol intake, body mass index and GA. ^141,^ ^209,^ ^231,^ ^234,^ ^235,^ ^289^ Onwude et al. showed that significantly more women were current smokers at enrollment in the treatment group than in the placebo group. ^233^ Smuts et al. reported that women assigned to consume ordinary eggs were significantly older than those in the high-DHA egg group. ^232^ Olsen et al. reported that in women with suspected IUGR, those in the placebo group had significantly higher GA after randomization. ^230^

Intervention/exposure characteristics. Across the 15 studies, the sources of omega-3 LCPUFA were identified as being either from natural feeding sources, such as eggs, fish and margarines, or from manufactured medical supplementations, such as capsules containing fish oil. Eggs as a source of omega-3 FA were used in two studies ^232,^ ^234^ and margarine, containing different amounts of LA and ALA, was used in one study. ^196^

Gelatin capsules containing a fish oil were utilized in 11 studies. In most of the studies, LCPUFA supplementation was prescribed in the second trimester of pregnancy. ^141,^ ^196,^ ^231,^ ^233,^ ^235,^ ^238^ In three studies, PUFA supplementation was administered from the third trimester until delivery. ^209,^ ^232,^ ^234^ There were no studies where participants were randomized from the first trimester. In one of the studies of Olsen et al., four prophylactic groups of pregnant women were randomized from gestational week 20, whereas, in the therapeutic trials women were randomized around gestational week 33. ^230^

Detailed information about the duration of the LCPUFA supplementation ^209,^ ^230,^ ^231,^ ^233,^ ^235,^ ^238^ is provided in the Evidence Tables (Appendix E). Helland et al. failed to report the manner in which study participants received their oil supplementation; ^141^ however, the investigators were the only ones to identify the exact sources of dietary FAs (i.e., cod liver oil and corn oil as the placebo). The daily amount of omega-3 LCPUFA intake, as well as the start and duration of intake, varied across the studies.

Pregnant women in the Bulstra-Ramakers et al. study received four capsules containing 0.25 mg EPA or placebo (coconut oil) three times daily. The EPA capsules contained a mixture of 3 g EPA and DHA. Both capsules were similar in appearance, smell and taste. ^238^

The two Smuts et al. studies ^232,^ ^234^ used similar regimens of FA supplementation for the high-DHA eggs and the ordinary egg groups. Daily DHA intake was reported to be 183.9 (SD=71.4) mg in the high-DHA diet and 35.1 (SD=13.2) mg for placebo in the one study ^232^ and 133 (SD=15) mg and 33 (SD=11) mg, respectively, in the other Smut et al. study. ^234^ Women in both studies were randomized to the different dietary groups in their third trimester of pregnancy (24 to 28 weeks), for a mean duration of supplementation of approximately 13 weeks. ^232,^ ^234^

de Groot et al. randomized a sample of women to receive margarine containing different amounts of LA and ALA from week 14 of GA until delivery. ^196^ The experimental group received 9.02 g LA and 2.82 g ALA per day, whereas, the control group received 10.94 g LA and 0.03 g ALA daily. ^196^

Pregnant women in the Onwude et al. study were randomized to receive either fish oil or placebo. ^233^ Women were allocated to treatment groups at a very wide range of GA, ranging from 18 to 32 weeks (mean of 24 weeks). Hence, the time of exposure to the intervention was not equal for the study participants. Women in this study were instructed to take nine capsules daily, each containing either 180 mg EPA and 120 mg DHA (treatment group), or air (placebo group); timing of the intake of the nine capsules was left to the participants. ^233^

The patients in the Olsen et al. study received fish oil (Pikasol containing EPA [32wt%] and DHA [23wt%]) or olive oil as placebo (oleic acid [72wt%] and ALA [12wt%]), provided in 1 g identical-looking gelatine capsules, but which were not identical in taste. ^230^ In the four prophylactic trials, four capsules of either oil were given per day, while in the two therapeutic trials, nine capsules were given per day. In the prophylactic trials women were randomized around gestational week 20, whereas, in the therapeutic trials women were randomized around gestational week 33. The same sources of intervention with the same regimen were used in the other study of Olsen et al. ^209^

The pregnant women in the study of Malcolm et al. received two fish oil capsules, rich in DHA (Marinol D40, 100 mg DHA per capsule, R.P. Scherer Ltd, Swindon, UK) per day or identical sunflower oil placebo capsules without DHA or ALA. ^235^ Maternal diet, including fish intake, was assessed by interview at 15 and 28 weeks of pregnancy and delivery. ^235^

The 98 women with a history of rhinitis or asthma in the Dunstan et al. study were randomized to receive either 4 g/day of fish oil or olive oil in capsules, as a supplement to their usual diet from 20 weeks gestation until delivery, when supplementation was ceased. ^231^ Women in the fish oil group consumed about 1.1 g EPA and 2.2 g DHA daily. All capsules contained α-tocopherol (3–4 mg/g oil) as an antioxidant. ^231^

Helland et al. randomly assigned 590 study participants to either a treatment group (10 mL cod liver oil/day; Peter Moller, Avd Orkla, Oslo, Norway) or a placebo group (10 mL corn oil/day). ^141^ Women in the cod liver oil group consumed 1,183 mg DHA, 803 mg EPA and 27.5 mg AA daily compared with 8.3 mg DHA in the placebo group. Randomization started at 17 to 19 weeks of gestation and supplementation continued until approximately 3 months after delivery, for a total of approximately 8 months of exposure. ^141^

Dietary intake information was not well documented in all studies. There was no clear data to suggest that all eight studies were equally able to eliminate the possible confounding influence of having unequal amounts of calories (i.e., as energy) provided to their different study groups. Information about caloric balance of food intake among the study groups was reported in only one RCT. ^141^ The daily energy intake (expressed as MJ/day) of participants in the Helland et al. study was similar among the two diet groups and varied from 8.2 (SD=2.0) MJ/day at week 18 of pregnancy to 8.7 (SD=2.3) MJ/day at week 35 of pregnancy. ^141^

None of the study investigators made an effort to deodorize the LCPUFA supplementation. In the study by Smuts et al., attempts were made to maintain blinding by conducting their own sensory test with clinic nurses who were blinded to the egg source. All of the nurses felt that the omega-3-fortified eggs looked and tasted like the non-enriched eggs. ^232^

Attempts to optimize and assess the compliance of the study participants were made in twelve trials. ^141,^ ^196,^ ^209,^ ^230,^ ^232,^ ^233,^ ^235^ In all of these studies, women were asked to fill a food-frequency questionnaire indicating the exact amount of assigned dietary supplement consumed, followed by conversion of this information into dietary intake using either a computer program ^196^ or simple percentage calculations. ^209,^ ^230,^ ^233^ Smuts et al. utilized phone interviews with the women since few participants were compliant with the request to keep written records of their food intake. ^232^

The manufacturer of the omega-3 intervention was reported in seven trials. ^141,^ ^196,^ ^209,^ ^231,^ ^232,^ ^235^ Purity data on the exposures used were not provided in any of the 15 studies. In five of seven studies that evaluated the FA content of biomarkers, appropriate methods to extract, prepare, store or analyze lipids were described. ^196,^ ^231,^ ^232,^ ^234^ Helland et al. gave little information about the details of blood FA composition analysis. ^141^ None of the trials reported details as to whether, or how, the presence of methylmercury was tested or eliminated from the omega-3 FA exposure when fish oil was the source. ^31,^ ^41,^ ^290^

Cointervention characteristics. Three studies reported the use and/or LCPUFA content of additional vitamin and mineral supplements taken by the pregnant participants. ^141,^ ^231,^ ^234^ Smuts et al. reported that prenatal vitamin use in ordinary and high-DHA groups was 83.2% and 84.6%, respectively. ^234^ Helland et al. reported that the amount of fat-soluble vitamins was identical between the two oil groups i.e., 117 μg/mL vitamin A; 1 μg/mL vitamin D; and, 1.4 μg/mL of dl-α-tocopherol. ^141^ Dunstan et al. used α-tocopherol as an antioxidant to stabilize omega-3 FAs. ^231^ No studies reported the prestudy medication use by either pregnant or breastfeeding mothers. On-study antihypertensive therapy to treat GHT was used in one of the Olsen et al. studies. ^230^

Outcome characteristics. Fourteen studies addressed the question of whether or not omega-3 FA supplementation affects the duration of gestation (gestational age as mean±SD). Preterm delivery rate was assessed in 11 trials. ^41,^ ^230,^ ^232,^ ^234,^ ^291,^ ^292^ However, three more studies reported the number of premature deliveries excluded from the analysis (reported as dropouts). ^288,^ ^290,^ ^293^ The use of ultrasound in the second trimester of pregnancy to determine GA was reported in four studies. ^209,^ ^230,^ ^233,^ ^234^ If the ultrasound measurement was not available, the length of gestation was estimated from the date of last normal menstrual period. ^209,^ ^230^ In seven studies, preterm delivery was defined as delivery at an estimated GA of less than 37 weeks. ^230,^ ^234^

Study quality and applicability. The 15 RCTs received a mean Jadad total quality score of 2.8, approaching a good internal validity (Summary Matrix 1). Two trials received a score of 5, ^233,^ ^238^ the trial of Helland et al. received a score of 4, ^141^ four trials received a score of 3, ^196,^ ^231,^ ^234,^ ^235^ and eight reports received a score of 2. ^209,^ ^230,^ ^232^

Randomization method was not clearly reported in four trials, ^290,^ ^293–295^ eight trials were not double-blinded, ^31,^ ^41,^ ^296^ while double-bliniding method was not reported across five trials. ^288,^ ^290,^ ^293–295^ Reasons for dropouts were not reported across eight trials. ^31,^ ^41,^ ^294^

#### Qualitative synthesis of individual study results

Ten studies evaluating the influence of LCPUFA supplementation on the duration of gestation, did not find any beneficial effect of omega-3 FAs over their comparators. ^141,^ ^196,^ ^230–235^ Conversely, the other four studies found that dietary modifications by LCPUFA significantly prolonged the duration of gestation. ^209,^ ^230^ However, the population characteristics, as well as the interventions, were different across these studies. The preterm delivery trial of Olsen et al. found a significantly increased mean duration of gestation in the treatment group (fish oil) of mothers with a preterm delivery in a previous pregnancy compared with mothers in the placebo group. ^230^ Preterm delivery rate was not affected by omega-3 FA supplementation during pregnancy and was not statistically different in randomized groups in ten trials that evaluated this outcome. ^31,^ ^209,^ ^233,^ ^234,^ ^238^ Smuts et al. on the other hand, observed that 5.6% of women in the high-DHA group had a premature delivery compared with 25% in the control group (no statistical significance was reported). ^232^

Dunstan et al. did not find any statistically significant relationship between GA and neonatal RBC DHA, EPA, and AA content. ^231^ Contrary to these findings, Smuts et al. ^234^ observed a statistically significant positive correlation between infant RBC DHA content at delivery and GA in the treatment group, whereas, maternal RBC phospholipid DHA content at the time of delivery was not significantly correlated with GA in either the treatment or placebo groups. ^231^ Malcolm et al. measured umbilical cord plasma DHA levels in infants of supplemented mothers and observed that the duration of gestation was significantly greater in infants in the upper quartile for cord blood DHA compared with infants in the lower quartile. However, gestational length did not differ based on quartiles of umbilical cord RBC DHA. ^235^

#### Quantitative synthesis

Meta-analysis was performed for incidence of premature deliveries, given that represents the most clinically relevant. Eleven of 15 trials reported this particular outcome. Eight of ten compared the use of DHA+EPA capsules intake with olive oil (control group). ^31,^ ^41,^ ^291^ Olsen et al. 2000 reported the pooled data of six different RCTs, including pregnant women with different risk for prematurity. ^31^ Five of eight trials provided the intervention from the second trimester (week 22) until delivery, ^31,^ ^291^ and three trials from week 30–33 until delivery (3rd Trimester). ^31,^ ^41^ Subgroup analysis (by risk of prematurity) was not possible for this outcome given the lack of individual data from Olsen et al. 2000. ^31^

Two studies by Smuts et al. comparing the use of eggs with high DHA content (mean 133 mg DHA per egg) ^296^ or 12 high-DHA hen eggs (135 mg DHA/egg) ^294^ with ordinary eggs (low DHA content: 18–33 mg DHA/egg) ^294,^ ^296^ from the second trimester to delivery reported the incidence of premature delivery as an outcome.

Two other studies compared the use of EPA alone ^292^ or DHA+AA (from cod oil) ^288^ with control, yet pooling was not possible due to the difference in omega-3 FA content.

Meta-analyses for incidence of prematurity were performed by using a random effect model for odds ratio.

Figure 1. Meta-analysis of studies comparing intake of DHA+EPA vs. control

From eight RCTs, the incidence of premature deliveries did not differ significantly between groups, OR: 0.88 (95% CI: 0.62–1.25), p=0.47.

Figure 2. Meta-analysis of studies comparing intake of DHA vs. control

Smuts et al 2003-1 ^296^ and Smuts et al. 2003-2. ^294^

From two RCTs, ^294,^ ^296^ the incidence of premature deliveries did not differ significantly between groups, OR: 0.53 (95% CI: 0.13–2.29), p=0.40.

#### Impact of covariates and confounders

Olsen et al. adjusted the duration of gestation for fish consumption, as well as for compliance to the oil supplementation. ^209^ Differences between groups in the average duration of gestation were significantly correlated with increasing fish consumption, with the mean length of gestation highest in the fish-oil group and lowest in the olive-oil group. The difference between fish oil and olive oil was nonstatistically significant between compliers and noncompliers. ^209^

Helland et al. adjusted the duration of gestation for the concentration of DHA in umbilical plasma phospholipids and reported that neonates with high concentration of DHA in umbilical plasma phospholipids (upper quartile) had longer gestational length than neonates with low concentration. ^141^

Onwude et al. stratified the results by use of tobacco, failing to observe a difference between groups. ^233^

Smuts et al. adjusted the results by smoking status, maternal BMI and number of prior pregnancies. ^234^ The duration of gestation was significantly longer in the high-DHA egg group in the nonsmoking women, and when adjusted by maternal BMI and parity. ^234^

The power analysis was reported in nine trials, ^31,^ ^288,^ ^292,^ ^296^ while the intention-to -treat analysis approach was reported in six trials from the same author. ^31^

### What is the Evidence That Maternal Intake of Omega-3 Fatty Acids Influences the Incidence of Preeclampsia, Eclampsia or Gestational Hypertension?

Eight unique studies met the eligibility criteria for investigating the effect of dietary supplementation of omega-3 FAs on the incidence of GHT, preeclampsia, or eclampsia, in pregnant women. All eight studies were parallel RCTs published between 1992 and 2003. Olsen et al. ^230^ reported two unique trials relevant to this question—the “Twins trial” (twins in the current pregnancy) and “Earl-PIH” trial (women who had GHT in an earlier pregnancy). Of the eight RCTs, seven were double-blind. ^209,^ ^230,^ ^233,^ ^234,^ ^236,^ ^238^ Of these, one trial was partially double-blind. ^236^ The overview of five trials was summarized in the question of duration of gestation (see key question: Duration of Gestation.). (Summary Tables 6–7)

#### Overview of relevant studies

D'Almeida et al. evaluated the effect of dietary supplementation with fish oil in preventing preeclampsia in pregnant primiparous and multiparous women with GA of less than 4 months. ^236^

The study participants (n=150; age range: 14–40 years) were randomized to receive eight capsules per day of either a mixture of evening primrose oil and fish oil (containing gamma-linolenic acid [GLA] 37 mg, EPA [18 mg] and DHA [10 mg]) or magnesium oxide (2 tablets/2 × 500 mg/day) or placebo (olive oil), for 6 months. The main study outcome was the cumulative incidence rate of preeclampsia (complete triad of hypertension, edema, and proteinuria). Other study outcomes were individual cumulative incidence rates of GHT, edema, and proteinuria. ^236^ (Summary Table 6)

The trial of Laivuori et al. investigated the influence of dietary supplementation with fish oil on the urinary excretion of antiaggregatory prostacyclin (PGI2) and proaggregatory thromboxane (TXA2) metabolites in women with preeclampsia. Of 18 women enrolled, 12 completed the study (mean age: 31 [range 23–40] years; parous: 50%; mean GA: 33 [range 26–37] weeks). ^237^ Changes in clinical signs of preeclampsia such as blood pressure (BP), proteinuria, and edema were also examined. Participants were randomized to receive 10 capsules per day of either Preglandin (containing 375 mg LA and 45 mg GLA), MaxEPA (containing 180 mg EPA, 120 mg DHA and 680 mg of other fish oils) or placebo (containing 500 mg maize oil and 500 mg olive oil). ^237^ (Summary Table 6)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. Of the eight RCTs, seven were double-blinded studies ^209,^ ^230,^ ^233,^ ^234,^ ^236,^ ^238^ of which, one was partially double-blind. ^236^ For one study, ^237^ it was not clear whether the study authors used a single or double-blind design. Authors of all eight trials reported inclusion criteria. Of the eight trials, two trials failed to report their exclusion criteria. ^236,^ ^237^ Three trials ^209,^ ^236,^ ^237^ had three arms and the remaining five trials ^230,^ ^233,^ ^234,^ ^238^ had two arms. All arms in the three-arm trials were randomized.

The studies were conducted in the following countries: the Republic of Angola, ^236^ Finland, ^237^ the Netherlands, ^230,^ ^238^ England, ^230,^ ^233^ Denmark, ^209,^ ^230^ Norway, ^230^ Russia, ^230^ and, the U.S. ^234^ All but two studies ^237,^ ^238^ reported their funding source. These included: Efamol, Ltd; ^236^ Yorkshire Region Locally Organized Research, GLAXO (Leeds) and Seven Seas (Hull); ^233^ Danish Medical Research, Sygekassernes Helsefond, Weiman's Legat and Michaelsen Fonden; ^209^ Concerted Action and PECO programmes of the European Commission and the Danish National Research Foundation; ^230^ and, Martek Biosciences Boulder Corporation (formerly OmegaTech, Inc). ^234^

Population characteristics. The total number of enrolled pregnant women across the included studies was 2,335 and ranged from 18 ^237^ to 579 ^230^ participants.

In general, participants included in most of the trials were healthy, with uncomplicated pregnancies. Patients in the Laivuori et al. trial were diagnosed with preeclampsia (GHT and protein in urine >0.5 g/d). ^237^ The study sample in another trial consisted of healthy women with previous history of anemia (27%), sickle-cell disease (34%), malaria (67%), or GHT (21%). ^236^ Four trials ^230,^ ^233,^ ^236,^ ^238^ included pregnant women who had a history of GHT. In three trials, ^230,^ ^233,^ ^238^ a previous episode of GHT was defined by a diastolic BP ≥90 mm Hg ^233,^ ^238^ or >100 mm Hg. ^230^ The proportion of women with a previous history of GHT in the four trials ranged from 21% ^236^ to 100% ^230^ of participants. The between-arm proportions of women with a previous history of GHT were not similar in the study of Bulstra-Ramakers et al. (75% vs 48.4%). ^238^ In another trial, the distribution of women with a previous history of GHT between the two randomized arms was more balanced (31.8% vs. 33.6%). ^233^

The age of the study participants was not reported in one study. ^238^ In the remaining studies, the age ranged from 14 ^236^ to 40 years. ^233,^ ^236,^ ^237^ The approximate mean age values across the trials ^209,^ ^230,^ ^233,^ ^234,^ ^237^ ranged from 26.5 ^233^ to 31.0 years, ^237^ and were similarly distributed across the treatment groups.

The women's baseline mean diastolic BP across the trials ^209,^ ^230,^ ^233,^ ^234^ ranged from 64 ^234^ to 74 mm Hg. ^230^ In these trials, the mean values of diastolic BP were similar across the randomized arms. The baseline mean (arm-specific) systolic BP was reported only in two studies, ^209,^ ^234^ and ranged from 111 ^234^ to 124 mm Hg. ^209^ In both trials, the randomized arms had similar mean values of systolic BP.

All trials reported the GA of the study participants at enrollment, randomization and start of intervention. The women's GA at enrollment and randomization across the trials, ranged from 16 ^209,^ ^236^ to 37 weeks. ^237^ The range of GA was reported in four trials. ^233,^ ^234,^ ^237,^ ^238^ The arm-specific mean GA (SD) was reported in five studies, ^230,^ ^233,^ ^234,^ ^237^ which was distributed evenly across the randomized arms. Three trials included only parous women (those with previous live births). ^230,^ ^233,^ ^238^

The proportion of parous women across the remaining trials ranged from 48.5% ^230^ to 67.8% ^209^ of participants and were similar across the study arms. Five studies reported on maternal tobacco smoking. ^209,^ ^230,^ ^233,^ ^234^ The proportion of tobacco smokers ranged from 22% ^230^ to 32% ^209,^ ^230,^ ^233^ of participants. In three trials, ^209,^ ^230,^ ^234^ the arm-specific distributions of smokers were more or less comparable. However, in two other trials, ^230,^ ^233^ the proportions of smokers across the randomized arms were not as similar—in the Onwude et al. trial, ^233^ 42% of participants in the fish oil arm were smokers compared with 32% in the placebo arm; in the Olsen et al. “Earl-PIH” trial, 19.1% of participants in the fish oil arm were smokers compared with 24.2% in the placebo arm. ^230^

The trials excluded subjects who had diabetes, ^230,^ ^233,^ ^234,^ ^238^ systemic lupus erythematosus, ^234,^ ^238^ chronic hypertension, ^233,^ ^234^ placental abruption, ^209,^ ^230,^ ^233^ asthma, ^233^ severe fetal malformation, ^230^ drug and/or alcohol abuse, ^230^ regular intake of fish oil, ^196,^ ^209,^ ^230,^ ^231^ allergy to fish oil, ^209^ chronic illness (cardiovascular, cancer, renal, psychiatric, or neurological disorder) and a serious infectious disease (hepatitis). ^234^ Regular users of prostaglandin inhibitors were also excluded. ^209^

Intervention/exposure characteristics. In all but one study, ^234^ the experimental intervention was dietary supplementation with omega-3 FA-enriched capsules. In the study by Smuts et al., ^234^ women were assigned to receive omega-3-enriched eggs. The daily number of assigned capsules across the trials varied from 4 ^209,^ ^230^ to 12. ^238^ Five trials ^209,^ ^230,^ ^236,^ ^237^ reported fish oil as a primary source of omega-3 FAs (i.e., ALA, LA EPA, DHA). The experimental intervention in most of the trials consisted of the combined supplementation with DHA and EPA. ^209,^ ^230,^ ^233,^ ^236–238^ The enriched eggs in the trial of Smuts et al. provided DHA only. ^234^ In three trials, ^209,^ ^230^ the relative contents of DHA and EPA in each experimental capsule were 23% and 32%, respectively. In two trials, ^233,^ ^237^ each experimental capsule contained 120 mg and 180 mg of DHA and EPA, respectively. In two other trials, ^209,^ ^230^ the absolute amounts of DHA and EPA were 225 mg and 325 mg per experimental capsule, respectively. In one trial, each capsule contained 250 mg of EPA. ^238^

The daily dose of DHA and EPA differed across the studies. The range of daily DHA intake was 0.08 g ^236^ to 1.20 g ^237^ and 0.15 g ^236^ to 3.00 g ^238^ for EPA. Three trials had a control arm with standard intervention such as magnesium oxide tablets (37 mg GLA), ^236^ preglandin capsules (45 mg GLA) ^237^ or olive oil ^209^ , besides the experimental and placebo arms. In seven trials, intervention in the control/placebo arms consisted of capsules with an identical appearance and taste as the experimental capsules. In these trials, placebo capsules contained olive oil, ^209,^ ^230,^ ^236,^ ^237^ maize oil, ^237^ coconut oil, ^238^ or no oil. ^233^ In the trial conducted by Smuts et al., omega-3-enriched eggs contained a mean of 33 [range 22–51] mg of DHA. ^234^

Information about patient compliance (numbers of partially- or non-compliant participants and/or reasons for non-compliance) were reported in six trials. ^209,^ ^230,^ ^233,^ ^234,^ ^238^ The type of analysis performed (i.e., ITT) were reported in three trials. ^230,^ ^233^ All three studies used ITT analyses. Two trials ^236,^ ^237^ did not report any information on the rates and/or reasons of compliance.

The manufacturers of the omega-3 FA-enriched supplemental products in the eight studies were: Efamol Research Institute and Efamol, Ltd (England); ^236^ Orion OY (Finland); ^237^ Lube Ltd. (Denmark); ^209,^ ^230^ and, OmegaTech, Inc. (Bouldwer, CO)/Gold Circle Farms (U.S.). ^234^ Two trials did not report the names of manufacturers who provided the omega-3 FA-enriched capsules. ^233,^ ^238^ The trials had varying lengths of intervention (in weeks) i.e, 24, ^230,^ ^236^ 27, ^238^ 1 to 8, ^237^ 14 to 16 ^233,^ ^234^ and 9. ^209^

Cointervention characteristics. Olsen et al.'s “Earl-PIH” and “Twins” trials allowed 2 mg tocopherol/mL in the fish oil capsules only. ^230^ Only two studies assessed the background diet of participants during the study. ^209,^ ^236^ Olsen et al. used a simple food-frequency questionnaire, reporting the amount of fish consumed before the trial: the low-fish intake group (at most one fish snack per month) to high fish intake (at least four fish meals per month). More than 50% of the women (n=327) were in the middle category of fish intake. ^209^ D'Almeida et al. measured background diet with a 24-hour dietary recall questionnaire. ^236^

Outcome characteristics. The incidence (or recurrence) rate of GHT was the primary outcome investigated in six trials. ^209,^ ^230,^ ^233,^ ^236,^ ^238^ The definition of GHT varied slightly across the trials. Most trials defined GHT as diastolic BP above 90 mm Hg. ^209,^ ^230,^ ^233,^ ^238^ These definitions were based on the number of measurements taken and the time-interval between measurements. One trial ^236^ defined GHT as a rise in diastolic BP of >15 mm Hg, whereas, another study ^238^ defined it as a rise in diastolic BP of >25 mm Hg. D'Almeida et al., defined GHT as a rise in systolic BP >30 mm Hg and/or a rise in diastolic BP >15 mm Hg. ^236^ Since one of the trials of Olsen et al. ^230^ included only pregnant females with a previous history of GHT (BP >100 mm Hg), the outcome of interest was the recurrence (not incidence) rate of GHT (BP >90 mm Hg). Note that, in this trial, the definitions for the previous/prevalent and incident GHT, differed.

Five trials investigated the incidence of preeclampsia. ^209,^ ^230,^ ^234,^ ^236^ Of these, four trials reported the definition of incident preeclampsia. ^209,^ ^230,^ ^236^ D'Almeida et al. defined preeclampsia as the simultaneous occurrence of the clinical triad: GHT, proteinuria, and edema. ^236^ However, in the remaining three trials, ^209,^ ^230^ the definition was restricted to GHT accompanied only by proteinuria (proteins >0.3 g/L). Only D'Almeida et al. ^236^ investigated the incidence of eclampsia which was defined by the simultaneous presence of GHT and two convulsive episodes.

Systolic and/or diastolic BP (measured in mm Hg), as the outcome of interest was assessed in four studies. ^209,^ ^230,^ ^237^ The cumulative incidence rates of proteinuria and edema were explored in two trials. ^236,^ ^237^

Study quality and applicability. The eight RCTs received a mean Jadad total quality score of 2.9, approaching a good internal validity (Summary Matrix 2). The trials conducted by Bulstra-Ramakers et al. and Onwude et al. received a score of 5, ^233,^ ^238^ Smuts et al. received a score of 3, ^234^ and the remaining five reports received a score of 2. ^209,^ ^230,^ ^236,^ ^237^ All reported an adequate randomization method. Six trials were not double-blinded, ^31,^ ^41,^ ^296–298^ and five trials failed to report the reasons for dropouts. ^31,^ ^41,^ ^297,^ ^298^

#### Qualitative synthesis of individual study results

Six trials investigating the effect of omega-3 FA-dietary supplementation on the incidence rate of GHT ^209,^ ^230,^ ^233,^ ^237,^ ^238^ showed a nonstaistically significant difference between-groups in the incidence of GHT. In contrast, D'Almeida et al. observed that women randomized to receive the diet enriched with magnesium oxide had lower incidence rates of GHT compared with those participants in the omega-3 FA-supplemented and placebo groups (4% vs 18% and 26%, respectively; p-value NR).^ 236 ^

Three trials demonstrated an effect of omega-3 FA-dietary supplementation in reducing risk of preeclampsia. ^209,^ ^230,^ ^234^ The mean number of women who had developed preeclampsia in all study arms was 15 (range from five to 28 women). Although the proportion of women developing preeclampsia tended to be lower in the experimental/omega-3 FA-supplemented arms, ^209,^ ^230,^ ^234^ the statistical power of these trials was too low to detect these differences. Only one trial ^236^ was able to show that women in the fish oil arm had a lower rate of preeclampsia than those in the placebo and magnesium oxide groups. In the D'Almeida et al. study, none of the women in the fish oil and magnesium oxide groups developed severe eclampsia compared with 3/50 (2.1%) patients in the placebo group. ^236^

The findings of Laivuori et al. suggested that dietary supplementation with fish oil did not have any effects on BP, proteinuria, and edema in women with preeclampsia in 12 of 18 women enrolled. ^237^ Findings from trials that measured BP during the follow up, ^209,^ ^230^ suggested that dietary supplementation with omega-3 FAs did not affect the BP of the women i.e., randomized groups had similar BP (systolic and diastolic) readings at follow up.

The cumulative incidence rates of proteinuria and edema were measured in two studies. ^236,^ ^237^ D'Almeida et al. found similar incidence rates of proteinuria in the randomized groups. However, women in the placebo group had a significantly higher rate of edema than those in fish oil/primrose oil and magnesium oxide groups (58% vs 26% and 24%, respectively). ^236^ Three studies reported data on dropouts and withdrawals with different detail. ^233,^ ^234,^ ^238^ The number of non-completers across the trials ranged from 1 ^233^ to 57. ^234^

#### Quantitative synthesis

In total, seven studies were identified by our search that reported on incidence of pre-eclampsia or GHT. After examining the studies for source of oil and duration of supplementation, five studies ^209,^ ^230,^ ^233,^ ^236,^ ^237^ were initially considered for meta-analysis.

Upon further examination, three studies ^209,^ ^236,^ ^237^ were excluded. Lavuiori et al. did not report quantitative outcome data. ^237^ D'Almeida et al. included a population with unique comorbities in a developing-world population. ^236^ Olsen et al. was carried out in a healthy population (i.e., women not at high risk of pre-eclampsia/GHT). ^209^ Thus, two studies ^230,^ ^233^ reporting on the incidence of GHT were available for meta-analysis.

Figure 3. Gestational hypertension incidence

Meta-analysis was performed using a random-effects model for odds ratios (n/N = number of patients with GHT/total sample in each arm).

In two studies, ^230,^ ^233^ , the overall size of the effect was nonstatistically significant between the DHA+EPA and the control groups in the incidence of GHT (OR: 1.07, CI 95%: 0.75; 1.51).

#### Impact of covariates and confounders

None of the included studies reported the use of multivariable techniques such as logistic or Cox regression modeling in order to adjust for the effects of dietary supplementation on the dichotomous outcomes (GHT, preeclampsia/eclampsia). Most of the studies reported having used a Chi-square or Fisher's test. In one study, ^238^ the randomized groups were not balanced with respect to the important prognostic/predictive factor such as a history of previous GHT (i.e., 75% vs 48.4%). The trial conducted by D'Almeida et al. ^236^ did not report the arm-specific proportions of women with a previous history of GHT. It is not clear whether the study authors adjusted the effect of interest for any between-group differences with respect to the proportion of women with GHT.

The power calculation was reported in four trials, ^31,^ ^292,^ ^296^ while the intention-to treat analysis approach was reported in two trials. ^31^

### What is the Evidence that Maternal Intake of Omega-3 Fatty Acids Influences the Incidence of Births of Human Infants Small for Gestational Age?

Fourteen unique studies were identified to answer this question. The studies were parallel RCTs, published between 1994 and 2004. Olsen et al. ^230^ reported four unique trials: “Earl-PD” (women with history of premature delivery); “Earl-IUGR” (women who had IUGR in an earlier pregnancy); “Twins trial” (twins in the current pregnancy); and, “Susp-IUGR” (women suspected of having IUGR <10^th^ percentile [PC] by ultrasonography in the current pregnancy). All the trials were already summarized above, therefore we only included the summary tables (see above key questions: Duration of Gestation. and Preeclampsia, Eclampsia or Gestational Hypertension) (Summary Table 8–10)

#### Overview of Relevant Studies

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. All but one study ^236,^ were double-blind parallel RCTs. The study by D'Almeida et al. was partially blinded. ^236^ All the included studies were published in English scientific journals. Eleven trials had two arms; two studies included a third study group. ^209,^ ^236^ The trials had been conducted in the following countries: South Africa, ^236^ Denmark, ^209^ The Netherlands, ^196,^ ^238^ England, ^233,^ ^235^ Norway, ^141^ the U.S., ^232,^ ^234^ Australia and England. ^231^ Olsen et al. conducted the three hospital-based trials in Denmark, Scotland, Sweden, England, Italy, The Netherlands, Norway, Russia, and Belgium. ^230^ All but one study238 reported their funding sources: Enfamol Ltd.,236 Danish Medical Research Council, Sygekassernes Helsefond, Weiman's Legat & Michaelsen Fonden, ^209^ Yorkshire Region Locally Organized Research, GLAXO (Leeds) and Seven Seas (Hull); ^233^ Concerted Action and PECO programmes of the European Commission and the Danish National Research Foundation; ^230^ Peter Moller Grants, Avd. Orkla ASA and “Aktieselskabet Chocololadefabrils Medicinske Fond; ^141^ Scottish Office Health Department; ^235^ Martek Biosciences Boulder Corporation (formerly OmegaTech, Inc.); ^232,^ ^234^ Unilever Research and Development (Vlaardingen, Netherlands); ^196^ and, NH & MRC and Raine Medical Research Foundation (Australia). ^231^

Population characteristics. The total number of enrolled pregnant women across the 10 trials was 3,404 and ranged from 60 ^235^ to 590 ^141^ participants. Helland et al. had a high rate of dropouts, leaving 341 women in the final analysis (57%). ^288^

The age distribution of participants was reported in all but two trials. ^235,^ ^238^ The age of women across these studies ranged from 14 ^236^ to 40 years. ^233^ Smuts et al. studied the youngest population of women with about 50% of participants aged between 16 and 21 years. ^234^ Whereas, in the study by Bulstra-Ramakers et al., more than 50% of the women were between 20 and 29 years old. ^233^ The age distribution across the study arms was not statistically different. However, in the Smuts et al. study, ^232^ the experimental arm (omega-3 enriched eggs) consisted of significantly younger women than in the control arm (p <0.05). ^232^

All but one study ^236^ reported both inclusion and exclusion criteria. The 13 trials can be categorized into two groups—those trials investigating the effect of omega-3 dietary supplementation in pregnant women at risk of IUGR, due to a previous history of IUGR, twin pregnancy or history of premature delivery, ^230,^ ^233,^ ^238^ and those trials that included only healthy pregnant women. ^141,^ ^196,^ ^209,^ ^231,^ ^232,^ ^232,^ ^234–236^

The definition of a previous history of IUGR varied across the first group of studies. For example, Bulstra-Ramakers et al. ^238^ defined IUGR as birth weight <10^th^ PC, Onwude et al. ^233^ defined it as birth weight <3^rd^ PC, and Olsen et al. ^230^ as a birth weight <5^th^ PC.

In the second group of studies, women were relatively healthy except in the Dunstan et al. study, ^231^ who reported that 40% and 58% of the women had asthma and allergic rhinitis, respectively. The second group of trials studied multiparous, as well as nulliparous women. The corresponding data on parity were reported in five of the 9 trials. ^141,^ ^196,^ ^209,^ ^231,^ ^234^ The proportion of multiparous women across the studies ranged from 43% ^234^ to 60% ^196^ and with the exception of Smuts et al.'s study (42% vs 32%), were evenly distributed between the study arms. ^141,^ ^196,^ ^231^

The trials excluded women with diabetes, ^230,^ ^233–235,^ ^238^ gestational diabetes, ^232^ systemic lupus erythematosus, ^234,^ ^238^ chronic hypertension, ^196,^ ^233,^ ^234^ GHT, ^232,^ ^235^ placental abruption, ^209,^ ^230,^ ^233,^ ^235^ asthma, ^233^ severe fetal malformation, ^141,^ ^230^ drug/alcohol abuse, ^230^ regular intake of fish oil, ^196,^ ^209,^ ^230,^ ^231^ chronic illness (cardiovascular, cancer, renal, psychiatric, or neurological disorder), ^196,^ ^232,^ ^234^ preeclampsia, ^232,^ ^235^ serious infectious disease (hepatitis), ^141,^ ^234^ serious bleeding episodes, ^209,^ ^235^ allergy to fish ^209,^ ^235^ or use of prostaglandin inhibitors. ^209,^ ^235^ Smuts et al. excluded women who had more than four pregnancies. ^232^ Enrollment in one trial was restricted to non-smoking women. ^231^ Malcolm et al also excluded twin pregnancies. ^235^

Only three trials reported the racial composition of the study population. ^196,^ ^232,^ ^234^ In two trials, ^232,^ ^234^ the majority of women were Black (81.0 and 73.2%, respectively). The third trial included only White women. ^196^ There was no statistically different racial distribution between the study arms among these trials.

Ten studies reported on maternal tobacco smoking. ^141,^ ^196,^ ^209,^ ^230,^ ^231,^ ^233,^ ^234^ The “Earl-IUGR” study by Olsen et al. ^230^ had the highest prevalence of smokers (about 50%). In contrast, the lowest prevalence of smokers (about 19%) was in the study by Helland et al. ^141^ In these trials, the arm-specific distributions of smokers were similar. In their trial, Dunstan et al. included only non-smokers. ^231^

All trials reported the GA of the study participants at enrollment/intervention. In five trials, ^141,^ ^232–234,^ ^238^ GA of women at the start of intervention ranged from 12 weeks ^238^ to 32 weeks. ^233^ For the remaining six trials, the lowest reported value of GA at intervention start was 16 weeks. The between-arm distribution of GA after randomization was reported as not different between-arms in nine trials. ^209,^ ^230,^ ^232–235^

Only three trials reported on alcohol use, ^196,^ ^231,^ ^234^ and in all of them, the distribution of alcohol users was similar between the randomized arms. The years of maternal education was reported in only two trials. ^141,^ ^196^

Intervention/exposure characteristics. In all 14 trials, the experimental intervention was the supplementation of the women's usual diet with omega-3 FA-enriched products. In 10 trials, ^209,^ ^230,^ ^231,^ ^233,^ ^235,^ ^236,^ ^238^ the omega-3 FA supplementation was provided in capsules. The number of assigned capsules given to the women in these trials ranged from 4 ^230^ to 12 per day. ^238^ In two trials, ^232,^ ^234^ women received omega-3 FA-enriched eggs. In 10 studies, the primary source of omega-3 FA supplementation was fish oil. ^141,^ ^209,^ ^230,^ ^231,^ ^233,^ ^235,^ ^236^ In de Groot et al., the source of omega-3 FA supplementation was margarine. ^196^ The experimental intervention in the majority of the trials consisted of the combined supplementation of DHA and EPA. ^141,^ ^209,^ ^230,^ ^231,^ ^233,^ ^238^ Participants in the de Groot et al. trial received dietary supplementation with ALA and LA. ^196^ The supplementation provided to participants in the two Smuts et al. trials was eggs enriched with only DHA. ^232,^ ^234^ D'Almeida et al. used a mixture of evening primrose oil (GLA) and fish oil (DHA+EPA). ^236^

The absolute amount of DHA ranged from 120 ^233^ to 135 mg per capsule (or per egg). ^232,^ ^234^ The study-defined daily dose (in grams) of DHA and EPA varied across the trials. The daily dose of DHA ranged from 0.20 g ^232^ to 2.20 g. ^231^ Whereas, the daily dose of EPA ranged from 0.80 g ^141^ to 3.0 g. ^238^ In the study by de Groot et al., the daily doses of ALA and LA were 2.8 g and 9 g, respectively. ^196^

In most of the studies, intervention for the control group consisted of capsules, ^230,^ ^233,^ ^238^ eggs, ^232,^ ^234^ or margarine ^196^ , with similar appearance and/or taste as those for the experimental intervention. The participants in the control arms received olive oil, ^209,^ ^230,^ ^231^ coconut oil, ^238^ or corn oil. ^141^ Onwude et al.'s control group received airfilled capsules. ^233^

The duration of the intervention was, in general, until delivery. The manufacturers of the omega-3 FA-enriched supplemental products were reported in 12 studies: R P Scherer Ltd. (UK); ^235^ Enfamol Ltd.; ^236^ Lube Ltd. (Denmark); ^209,^ ^230^ Peter Moller, Avd Orkla ASA (Norway); ^141^ OmegaTech, Inc. (Bouldwer, CO)/Gold Circle Farms (U.S.); ^232,^ ^234^ Unilever Research and Development (Vlaardingen, Netherlands); ^196^ and, Ocean Nutrition (Nova Scotia, Canada). ^231^ Two trials did not report the names of the manufacturers. ^233,^ ^238^

The data on compliance (numbers of non-compliant participants and reasons for non-compliance) and type of analysis performed (i.e., ITT) were reported in six trials. ^209,^ ^230,^ ^233^ Five studies used ITT analyses. ^230,^ ^233^ The numbers of non-compliant participants were reported in five studies. ^141,^ ^196,^ ^232,^ ^234,^ ^238^ Dunstan et al. did not report well-documented compliance-related data. ^231^

Cointervention characteristics. Six trials allowed 2 to 4 mg tocopherol/mL in the fish oil capsules. ^209,^ ^230,^ ^231^ de Groot et al.'s margarines also contained vitamins (0.04%). ^196^ In the Helland et al. study, ^141^ the amount of fat-soluble vitamins was identical in the two oils provided to partipants (i.e., 117μg/mL of vitamin A, 1 μg/mL of vitamin D, and 1.4 mg/mL of tocopherol).

Five studies assessed the background diet of participants during the study. ^141,^ ^209,^ ^232,^ ^235,^ ^236^ The studies used either a food-frequency questionnaire or a 24 hour recall questionnaire. ^236^

Outcome characteristics. Of the 14 studies, three looked at the recurrence rate (i.e., percentage, relative risk, or odds ratio) of IUGR. ^230,^ ^233,^ ^238^ Olsen et al., in the “Earl-IUGR” trial, evaluated the incidence of IUGR (not recurrence). ^230^ Twelve trials measured and compared mean birth weight values (in grams) between the randomized arms, adjusted for GA and sex. ^141,^ ^196,^ ^209,^ ^230–235^ The rate of birth (i.e., percentage) of infants weighing <2,500 grams (LBW) was looked at in seven trials. ^230,^ ^232,^ ^234,^ ^236,^ ^238^ The infants' birth length and HC (in cm) between the randomized groups were compared in five trials. ^141,^ ^231,^ ^232,^ ^234,^ ^235^

Study quality and applicability. The 14 RCTs received a mean Jadad total quality score of 2.85, with an average poor internal validity (Summary Matrix 3). The trials conducted by Bulstra-Ramakers et al. and Onwude et al. received a score of 5, ^233,^ ^238^ Helland et al. received a score of 4, ^141^ four trials received a score of 3, ^196,^ ^231,^ ^234,^ ^235^ seven reports received a score of 2. ^209,^ ^230,^ ^236,^ ^294^ Four trials failed to report the randomization method, ^290,^ ^293–295^ seven trials were not double-blinded, ^31,^ ^41,^ ^296,^ ^297^ while Smuts et al. did not provide the method of double-blinding. ^294^ Seven trials did not report the reasons for dropouts. ^31,^ ^41,^ ^294,^ ^297^

#### Qualitative synthesis of individual study results

The three studies investigating the effect of omega-3 FA dietary supplementation on pregnant women with a previous history of IUGR, concluded that the randomized groups did not differ with respect to the recurrence of IUGR (birth weight < 3^rd^ and 10^th^ PC adjusted for GA). ^230,^ ^233,^ ^238^

The between-group difference in the mean birth weight was not significantly different in eight of 12 studies. ^141,^ ^209,^ ^230,^ ^231,^ ^233–235^ However, in three trials, the mean birth weight was significantly higher in the omega-3 FA-supplemented group compared with the group without supplementation. ^196,^ ^230,^ ^232^ In contrast, the “Earl-IUGR” trial found a significantly higher mean birth weight in the olive oil group compared with the fish oil group. ^230^

Regarding birth length, three studies did not find a statistical difference between study arms. ^141,^ ^231,^ ^235^ On the other hand, in the Smuts et al. trial, infants in the high-DHA egg group had a significantly higher birth length compared with those in the ordinary egg group. ^234^ HC at birth was similar in both groups across four trials. ^141,^ ^231,^ ^234,^ ^235^

Results of five trials showed that omega-3 FA supplementation did not influence the incidence rate of LBW infants from pregnant women with or without a history of previous IUGR. ^230,^ ^234,^ ^238^ In the trial conducted by Smuts et al., no LBW infants were born to women receiving omega-3 FA supplementation, and the incidence rate of LBW infants born to women in the control arm was 26%. ^232^ In D'Almeida et al., the percentage of infants born weighing <2,000 g was noticeable lower in the omega-3 FA supplemented group compared with the other two groups (placebo: 3.3%, magnesium: 4.7%, fish oil+primrose oil: 1.4%); however, no p-value was reported.

Only one study evaluated the association between maternal biomarkers with this clinical outcome. ^196^ de Groot et al. found a positive correlation between maternal plasma and RBC DHA and birth weight, when controlled for birth order. This difference was nonsignificant at delivery. There was also a statistically positive correlation between the total estimated DHA intake and birth weight. However, this study provided ALA and LA as supplementation. ^196^

Seven studies reported data on dropouts/withdrawals, albeit with different detail. ^141,^ ^196,^ ^209,^ ^231,^ ^234,^ ^235,^ ^238^ The most frequent reasons for study drop-out were: discomfort in consuming fish oil or margarine; lack of compliance; refusal to participate because it was time consuming; morning sickness; and/or, nausea. The number of non-completers across the trials ranged from 1 ^233^ to 57. ^234^

#### Quantitative synthesis

After examining the studies for source of oil and duration of supplementation, seven trials ^209,^ ^230,^ ^231,^ ^233,^ ^238^ were initially considered for meta-analysis. For Olsen et al. data from only three of six trials was considered (DHA+EPA vs. control): prophylactic EARL-IUGR trial, therapeutic Susp-IUGR trial, and prophylactic Twins trial. ^230^ Olsen et al. ^209^ and Dunstan et al. ^231^ were carried in a healthy population (i.e. women without previous history of high risk pregnancy). Thus five trials ^230,^ ^233,^ ^238^ were considered for meta-analysis.

For the birth weight outcome, data from the Susp-IUGR trial ^230^ could not be included since it was reported as birth weight adjusted for GA, unlike the other studies. Bustra-Ramakers et al. ^238^ did not report birth weight. Thus three trials ^230,^ ^233^ were available for meta-analysis.

For the intra-uterine growth retardation (IUGR) outcome, the therapeutic trial Susp-IUGR ^230^ could not be included since it did not report IUGR outcomes. Thus four trials ^230,^ ^233,^ ^238^ were available for meta-analysis.

Figure 4. Birth weight (grams)

Meta-analysis was performed using the random effects weighted mean difference. For the Onwude et al. study' ^233^ the standard deviations in the two study groups were not reported, however, a 95% confidence interval for the difference in means was reported. We assumed the standard deviations were the same in both groups, and computed the standard deviation from the confidence interval.

In two studies, ^230,^ ^233^ the overall size of the effect in the mean birth weight did not reach statistical significance (weight mean difference: -61.51, CI 95%: -256.21; 133.18).

Figure 5. Incidence of intra-uterine growth retardation (IUGR)

Meta-analysis was performed using a random-effects model for odds ratios.

In three studies, ^230,^ ^233,^ ^238^ the overall size of the effect on the incidence of IUGR between DHA+EPA and control groups was nonstatistically significant (OR: 1.14, CI 95%: 0.79; 1.64).

#### Impact of covariates and confounders

The observed between-group differences in birth weight in three studies, ^209,^ ^230,^ ^232^ were adjusted for potential effect modifiers (i.e., duration of pregnancy, infant's gender, placental weight, maternal age, other characteristics).

Linear regression analysis revealed that the duration of pregnancy was an important predictor (potential confounder) of birth weight. ^230^ The higher birth weight observed in the experimental group compared with the control group was partially due to the effect of duration of pregnancy, which was not evenly distributed between the randomized groups. Once this difference was accounted for, by adjusting for duration of pregnancy, the earlier observed difference in birth weight was attenuated. ^230^ In another study, ^232^ using ANOVA, it was found that birth order was an important predictor of birth weight and length. Smuts et al. used a multiple linear regression to account for effect modifiers by adjusting the effects of interest for race, the number of prior pregnancies, previous premature deliveries, smoking, maternal body mass index (BMI), age, alcohol use, and maternal RBC-DHA levels. ^234^

In the study of Smuts et al., women randomized to receive the diet supplemented with omega-3 FAs (DHA-enriched eggs) were substantially younger compared with those women receiving the diet without this supplementation (regular eggs) (mean age: 19.9 vs 24.8 year, p <0.05). ^232^ The authors did not report any attempt to adjust for the effect of age.

In de Groot et al., ^196^ the observed difference in birth weight was adjusted for the duration of pregnancy. In their “Susp-IUGR” trial, Olsen et al. found that the mean birth weight adjusted for GA at delivery did not differ between the two randomized groups. ^230^

The analysis revealed that the effect estimates for birth weight, length, and HC were strongly influenced by maternal BMI, race, smoking status, and number of pregnancies. The adjustment for the above-mentioned covariates attenuated the earlier observed crude differences in birth weight, length, and HC. In de Groot et al., duration of pregnancy was an influential covariate for the association between the allocation to the experimental intervention and birth weight. ^196^

In two studies, ^232,^ ^238^ the randomized groups were not balanced with respect to the important prognostic/predictive factors such as GHT ^238^ and age. ^232^

None of the studies adjusted the outcomes results for the maternal background diet.

The power calculation was reported in seven trials, ^31,^ ^288,^ ^292,^ ^296^ while the intention-to-treat analysis approach was reported in four trials. ^31^

## Pregnancy Outcomes in Light of Biomarker Data

### What is the Evidence That the Duration of Gestation in Women With or Without a History of a Previous Preterm Birth is Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Maternal Biomarkers During Pregnancy?

Four studies were identified that answered this question. ^234,^ ^239–241^ Smuts et al.'s RCT ^234^ was described above; hence, only the three observational studies will be presented in this section. ^239–241^ The observational studies were published between 1997 to 2001 in English scientific journals. The study by Reece et al. ^239^ was a case-control study, whereas, Elias and Innis was a single prospective cohort study ^240^ and Rump et al. was a cross-sectional study. ^241^ (Summary Table 11)

#### Overview of relevant study characteristics and results

Reece et al. compared blood LCPUFA content of 37 mother-infant pairs with preterm delivery (mean GA 34 weeks) with a group of 34 control full-term mother-infant pairs (mean GA 40 weeks). ^239^ The study was conducted in the U.S. and was supported by the Colorado Agricultural Experiment Station. The study included a sample of preterm and term cases based on the duration of gestation. ^239^ “Preterm delivery” (n=37) was defined as GA of less than 37 weeks, whereas, “term delivery” (n=34) was defined as GA of 37 or more weeks. The patients were excluded if they had a recognized cause of preterm birth (i.e., uterine abnormality, intrauterine infection, substance abuse, multiple gestation, pregnancy-onset hypertension). Exclusions for controls included recognized medical problems, multiple gestations, multiple parity, GHT, and substance abuse. ^239^ Participants were enrolled at 18 weeks of GA and followed until delivery. ^239^

In preterm cases, the maternal blood samples were obtained at delivery, while the control women were sampled at 34 weeks of GA and at delivery. ^239^

The cases were well-matched with the controls in terms of marital status (50% married), race (82% white), financial support (80% public), pre-pregnancy body mass index, maternal infection detected (70% none), type of labor and maternal age. ^239^ Both populations significantly differed in the duration of gestation (mean GA: 40.2 [SD=0.2] weeks vs 33.9 [SD=0.6] weeks), birth weight, length and HC (preterm infants had significantly lower growth parameters at birth than term infants). ^239^

Reece et al. found that the RBC FA content (% total) of LA (omega-6), AA, and DHA was significantly higher in the preterm cases compared with the controls at 34 weeks GA and at term. ^239^ The percent total EPA in RBC in controls at term was significantly higher than both preterm deliveries and 34-week controls. The maternal RBC omega-3/omega-6 ratio content was significantly higher in control term deliveries compared with preterm cases. The maternal plasma percent total LA (omega-6) was significantly increased in the 34-week control and preterm groups compared with the term control group. The plasma percent total LA, AA, EPA was significantly higher in preterm cases compared with term controls. The plasma AA content was increased in 70% of preterm cases compared with control cases at term. ^239^

Elias and Innis determined the association between length of gestation and the maternal plasma concentration of AA and DHA in a cohort of pregnant women (n=84) at 35 weeks of GA. ^240^ The study was conducted in Canada and was supported by the Molly Towell Perinatal Research Foundation and the National Science and Engineering Research Council of Canada. ^240^ The cohort included 60 women at 22 to 24 weeks of GA that were recruited from predelivery registration records and were followed until delivery. An additional 24 pregnant women were recruited from a low-risk delivery unit in Canada. Women with a history of surgical or medical problems that could influence the lipid metabolism or fetal growth were excluded from the study. These included women with more than one fetus, hyperemesis, psychological or social problems, illicit drug or alcohol use, cardiac or renal disease, diabetes, epilepsy, respiratory or rheumatoid conditions, cholestasis, high cholesterol or triglycerides before pregnancy, HIV infection, hepatitis, or tuberculosis. ^240^

The study measured the maternal intake, during pregnancy, of the different FAs through a food-frequency questionnaire designed to collect data on amounts and sources of fat, methods of food preparation, brand names and places of food purchase. ^240^

The outcome measures were the maternal blood content of omega-3 and/or omega-6 FA during pregnancy and its relationship with the duration of gestation, as well as the infant FA blood content. ^240^

Ellis and Innis did not find a significant association between the maternal plasma content of omega-3 and omega-6 FA and the duration of gestation, except for the maternal plasma triglyceride (TGL) AA content that was positively related to the length of gestation. However, this uncontrolled study did not provide the details regarding this association, as well as the fact that all the pregnancies reached term. ^240^

Rump et al. was a cross-sectional study that included a sample of healthy pregnant woman and their term infants. ^241^ It was conducted in the Netherlands and supported by a Hospital, and Nutricia Research. The blood samples were taken at 16 weeks and after delivery. ^241^

The cohort was separated by weight for gestational age groups, SGA (PC <10^th^), AGA (PC >10^th^ and <90^th^) and LGA (PC >90^th^). The groups were comaparable in terms of maternal characteristics like age, height, weight, parity, smoking status, and mode of delivery. ^241^

There was no correlation between the maternal content of PUFA and the birth weight. ^241^

Study quality and applicability. Although they employed different research designs, all the studies were assigned a level III for applicability, and together they received a mean quality score of 6.3.

### What is the Evidence That the Incidence of Preeclampsia, Eclampsia or Gestational Hypertension is Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Maternal Biomarkers During Pregnancy?

Five observational studies were identified that addressed this question. ^179,^ ^229,^ ^242–244^ The studies were published between 1991 and 1999. The trials were included if they selected both preeclamptic and normal pregnant women, and blood samples were drawn before delivery. Three studies used blood samples taken after delivery and hence were excluded from the review. ^299–301^ (Summary Table 12, 13)

Four studies had a cross-sectional design, ^229,^ ^242–244^ whereas, one was a nested case-control study derived from a prospective cohort. ^179^

#### Overview of relevant studies

Wang et al. assessed the association between the plasma levels of omega-6 FA (LA, AA) and omega-3 FA (ALA, EPA, DHA) in a sample of American nonpregnant, normal pregnant and preeclamptic patients (n=30). ^242^ (Summary Table 12)

Craig-Schmidt et al. evaluated the LCPUFA composition of plasma phospholipid in a small sample of American healthy pregnant women compared with women with GHT, preeclampsia and chronic hypertension (n=36). ^243^ (Summary Table 12)

Al et al.'s sample of Dutch healthy pregnant women were compared with pregnant women with GHT in a nested case-control study. The study assessed the plasma FA content during pregnancy in both groups (n=208). ^179^ (Summary Table 12)

Hofmann et al. evaluated the LCPUFA composition of maternal blood in a small sample of German pregnant women with preeclampsia compared with healthy controls (n=30). ^229^ (Summary Table 13)

Shouk et al. compared the LCPUFA plasma content in Egyptian women (mean age 29 [SD=8.2] years, range: 20–40 years) with severe preeclampsia with healthy pregnant subjects during the third trimester. ^244^ (Summary Table 13)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. Of the five observational studies that met eligibility criteria, two studies were conducted in the U.S., ^242,^ ^243^ one was conducted in The Netherlands ^179^ , one in Germany ^229^ and one in Egypt. ^244^ Two studies compared the outcomes in more than two groups, ^242,^ ^243^ whereas, three studies involved only three arms. ^179,^ ^229,^ ^244^

Most studies were published in scientific journals in English, but one required translation from German. ^229^ The funding source was reported in two of five studies. Wang et al. was supported by a pharmaceutical industry (Glaxo, Inc.), ^242^ whereas, Al et al. was funded by Nutricia BV, Zoetermeer, The Netherlands. ^179^

Population characteristics. There were 349 subjects included across the studies. The sample sizes ranged from 30 to 208 patients. Three studies reported the inclusion and exclusion criteria. ^179,^ ^229,^ ^244^

Wang et al. selected three groups of women between 20 and 40 years, normal pregnant patients (n=11), preeclamptic patients (n=9) and nonpregnant female volunteers as controls. All were at term. ^242^ Craig-Schmidt et al. included nulliparous pregnant women (mean age: 21 [SD=6] years). ^243^ The study groups were composed of women with normal pregnancy (n=10), GHT (n=10), preeclampsia (n=10), and chronic hypertension (n=6). ^243^

Al et al. selected, from the prospective cohort of healthy pregnant women (GA <16 wks), a group of women with GHT and matched them with a group of healthy pregnant patients. ^179^ Hofmann et al. ^229^ and Shouk et al. ^244^ compared a group of women with preeclampsia with a healthy pregnant control group, although Shouk et al.'s patients had a severe preeclamsia in the third trimester.

Shouk et al. did not provide a definition for preeclampsia. ^244^ In general, preeclampsia was defined as as BP greater than 140/90 mm Hg measured on two occasions, 6 hours apart starting from the 20^th^ week of GA. Proteinuria was defined as greater than 300 mg urinary protein per 24 h; preeclampsia was the combination of hypertension and proteinuria with or without edema. ^179,^ ^229,^ ^242,^ ^243^

Wang et al. ^242^ and Craig-Schmidt et al. ^243^ failed to provide information about the between-group difference in terms of population characteristics (i.e., maternal age, GA, parity, education, smoking status, etc.) at baseline or before the study. Al et al. did not find a significant difference between groups in maternal age, number of nulliparous women, percentage of smoking women, or number of infants small for gestational age (SGA) at term. ^179^ There was a significant difference between groups in diastolic BP at entry (GHT higher than control), maximum diastolic BP (GHT >control), GA at delivery (GHT < control), birth weight (GHT < control), and APGAR score at 5 min (GHT < control). ^179^ Control of selection bias was achieved by measuring the FA content of pregnant women (at 16 weeks GA) who decided not to participate in the trial. ^179^

Hofmann et al.'s study groups were well-matched for maternal age, BMI, GA, serum creatinine, blood glucose and hematocrit. Blood pressure was significantly higher in the preeclamptic women. ^229^ Similarly, Shouk et al.'s patients were well-matched for age, parity and GA. ^244^

Regarding the medications and/or treatments allowed before study entry, Wang et al. ^242^ and Hofmann et al.'s ^229^ preeclamptic women did not receive aspirin. The rest of the studies did not report the use of medication in their patients.

Hofmann et al. and Shouk et al. included patients without other comorbid conditions. ^229,^ ^244^ The remainig three studies did not provide this information. ^179,^ ^242,^ ^243^

Intervention/exposure characteristics. Groups in the study by Al et al. did not differ in their nutrient intake during pregnancy. ^179^ None of the identified studies described the nature of the nutritional intake, including the use of supplements or any other substance that could alter the lipid content in maternal blood biomarkers.

Outcome characteristics. All studies examined the omega-3 and omega-6 FA content in plasma of maternal blood from preeclamptic women compared with healthy controls.

Study quality and applicability. The total quality score across the studies was 6.2, however the applicability level was III.

#### Qualitative synthesis of individual study results

Wang et al. found that the total PUFA, LA (omega-6), ALA (omega-3) and EPA content in plasma (mg/L, mean) of normal pregnant women was significantly higher than in the preeclamptic patients. ^242^ There was a nonsignificant difference between groups in the content of AA and DHA in plasma. However, there was a significantly higher content of EPA and DHA in normal pregnant women compared with nonpregnant. ^242^

Craig-Schmidt et al. did not observe a significant difference between groups in saturated, monosaturated and PUFAs, or in the content of omega-6 or omega-3 FA (mg/L and % of total FA) between women with normal pregnancies and women with GHT, preeclamsia or chronic hypertension. ^243^ The women with chronic hypertension had a significantly greater AA in plasma phospholipid compared with the other three groups. There was a nonsignificant difference in plasma phospholipid EPA concentrations among the groups, as well as in the AA/EPA ratio or omega-6/omega-3 ratio at baseline. ^243^

During pregnancy (before 16, at 22 and 32 weeks GA) no significant differences in the absolute FA composition (mg/L and % total FA) of maternal plasma phospholipid were observed between groups in the Al et al. study. ^179^ After delivery, however, the amount of ALA (omega-3) was significantly lower in the GHT women compared with women who had normal pregnancies. After correction for differences in GA between groups, significantly higher levels of DHA were observed in umbilical plasma of the GHT compared with controls. ^179^ When the GHT women were stratified by severity of hypertension, patients with severe GHT (diatolic BP >105 mmHg) (n=17), 12 of which had proteinuria, had a mean GA and mean infant birth weight that were significantly lower than those in the group with mild GHT (diastolic BP <105 mmHg). During gestation and after delivery, no significant differences were observed in the maternal FA composition of women with severe GHT compared with those with mild GHT. ^179^

Hofmann et al. found that the total amount of FA in plasma triglycerides during pregnancy were significantly higher in the preeclamptic group compared with the healthy control group. The difference disappeared on the 5th day after delivery. ^229^ The AA content in plasma triglycerides did not differ between groups during pregnancy. On the other hand, the LA (omega-6) and DHA (omega-3) content in this blood fraction were significantly lower in the preeclamptic women compared with the controls. The LA and AA (omega-6) concentration in plasma phospholipid were not significantly different between groups, however, the DHA plasma phospholipid content was significantly lower in preeclamptic women. ^229^

Shouk et al. observed that the AA in plasma (mcg/L) was significantly higher in preeclamptic women. LA and ALA (omega-3) content did not differ between groups. ^244^

### What is the Evidence That the Incidence of Births of Human Infants Small for Gestational Age is Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Maternal Biomarkers During Pregnancy?

Five observational studies were identified that addressed the possible association between the incidence of SGA infants and the omega-3 or omega-6/omega-3 FA content of maternal biomarkers during pregnancy. ^240,^ ^241,^ ^245–247^ Two were cross-sectional studies, ^241,^ ^247^ two were case-control studies ^245,^ ^246^ and one was a single prospective cohort. ^240^ Studies were published between 1991 and 2002. (Summary Table 14, 15)

#### Overview of relevant studies

Vilbergsson et al. assessed the association between LCPUFAs of pregnant women considered to be at an increased risk for IUGR and the incidence of SGA deliveries. ^247^ Investigators recruited 28 eligible women at week 33 or 34 of pregnancy who were considered as high risk for SGA delivery after thorough evaluation using a special risk scoring system, ultrasonographic measurements of fetuses' growth parameters, nonstress test, and biophysical profile following regular monitoring. Twenty pregnant women with no risk factors were enrolled into the study as a control group. ^247^ (Summary Table 14)

Matorras et al., in a case-control intrapartum study, analyzed the relationship between maternal plasma LCPUFAs and IUGR in an apparently well-nourished population of pregnant women in the second stage of labor. ^245^

The study population consisted of 23 women in labor whose infants had prenatally-suspected IUGR and were at term delivery and 34 newborn control cases who whose size were appropriate for gestational age (AGA). ^245^ (Summary Table 14)

Elias and Innis determined the association between birth weight and length and the maternal plasma concentration of AA and DHA in a cohort of Canadian pregnant women (n=84) at 35 weeks of GA. ^240^ (Summary Table 15)

Rump et al., in a cross-sectional study, evaluated the relationship between the incidence of term SGA births and observed changes in maternal plasma LCPUFA composition during pregnancy. ^241^ The study population consisted of 81 SGA infants and 505 AGA infants. Maternal plasma FA analysis was performed at study entry (≤16 weeks GA), at delivery, and in cord plasma at birth. (Summary Table 15)

Cetin et al., ^246^ in a case-control study, determined maternal FAs profiles in utero in 11 AGA and in 10 IUGR fetuses from 19 to 39 weeks of gestation and studied the relationship between maternal plasma LCPUFA status and the incidence of SGA. (Summary Table 15)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. The studies were conducted in different countries, including one from Canada, ^240^ and one each from Sweden, ^247^ Spain, ^245^ Italy ^246^ and The Netherlands. ^241^ Four studies reported their funding sources and these included a professional society, university and foundation, ^240,^ ^247^ and government. ^240,^ ^245,^ ^246^

Population characteristics. Four studies selected a small number of participants, ranging from 21 ^246^ to 84. ^240^ Only Rump et al. studied a large sample of infants (n=81 SGA, n=505 AGA, n=41 LGA). ^241^

Four studies presented clearly-defined inclusion and exclusion criteria ^240,^ ^241,^ ^245,^ ^247^ and one study exclusively described exclusion criteria. ^246^ Vilbergsson et al. included only singleton pregnancies and made an effort to equally distribute subjects to groups by age, parity, and dietary intake; maternal diabetes was an exclusion criterion. ^247^ Matorras et al. included term SGA infants with no malformations and chromosomal abnormalities, delivered from a singleton pregnancy, with an accordance between GA (determined by last menstrual period and early ultrasound) and pediatric evaluation using the Dubowitz test. ^245^ Elias and Innis included healthy pregnant women (GA 22–24 weeks), whereas, women with medical or surgical problems that could influence lipid metabolism were not eligible. ^240^ In the study of Rump et al., selection criteria for inclusion/exclusion were GA <16 weeks at entry, diastolic BP <90 mmHg and no signs of cardiovascular, neurologic, renal, or metabolic disorders at the time of recruitment. ^241^ Cetin et al. set the following exclusion criteria for both normal and IUGR pregnancies: subsequent development of gestational diabetes or GHT; abnormal fetus caryotype; or, malformation at birth. ^246^

The mean GA was reported in all of the five studies. The mean GA for the entire SGA group of infants ranged from 36 ^247^ to 40.6 weeks. ^241^ Statistically significant differences in GA between the SGA/IUGR and AGA groups were reported in two studies. ^246,^ ^247^ In the remaining three studies, the SGA/IUGR cohort and AGA controls were of similar age at birth. ^241,^ ^245,^ ^246^

Definition of IUGR and/or SGA was given in four studies. ^241,^ ^245–247^ Cetin et al. ^246^ and Matorras et al. ^245^ established IUGR by performing ultrasonographic examination measuring fetal biparietal diameter and/or abdominal circumference, which had to be under the 10^th^ PC of reference values for fetuses of a similar age. In the study of Cetin et al., growth retardation was confirmed at birth if the neonatal weight was below the 10^th^ PC according to standards for birth and weight and GA. ^246^ Rump et al. ^241^ classified infants as SGA if their birth weight was ≤10^th^ PC of reference values, whereas Vilbergsson et al. ^247^ defined SGA as an infant birth weight two standard deviations below the mean when compared with a standard growth chart.

No authors explicitly stated the racial/ethnic background of the study participants, yet it is likely that Caucasian/Europeans were represented as a majority in all of these studies.

Information regarding maternal smoking history and/or smoking during pregnancy was available in two studies and even though there was a higher proportion of smokers in the SGA/IUGR group than in control group, the difference did not reach statistical significance. ^241,^ ^245^ Vilbergsson et al reported that the control group contained no smokers and in the group at risk for IUGR, there were no differences between smokers and nonsmokers with respect to clinical characteristics or FAs results. ^247^ Alcohol consumption during pregnancy was not reported in any of the five studies.

None of the studies reported the use of medication and/or supplements before study entry or any comorbid conditions in newborn babies. Maternal characteristics such as parity, and age, height, weight at study entry, were similar between study groups in three studies. ^241,^ ^246,^ ^247^ However, in the study of Matorras et al., ^245^ IUGR mothers had lower height, pregestational weight and weight increase during pregnancy than mothers in the control group.

Only one study reported the mean maternal energy intake during pregnancy, which was similar between control and IUGR groups. ^245^ The same study evaluated socioeconomic levels of study population and reported that twice as many women with IUGR pregnancies belonged to low socioeconomic strata. The description of lipid extraction and biochemical analysis was adequate in all but one study. ^247^

Outcome characteristics. The main outcome evaluated in these observational studies was incidence of births of SGA infants and its relation to either the absolute or relative amount of maternal plasma FA concentrations during pregnancy. Information regarding the timing of the maternal plasma LCPUFA analysis was reported in all but one study. ^247^

In the study of Vilbergsson et al., maternal blood samples were drawn in the 34^th^ and 37^th^ week of pregnancy, at delivery, and at 4 days postpartum. This study measured the plasma content in phospholipids (lecitin) of LCPUFA (mol %). ^247^ Cetin et al. reported that maternal sample collection and analysis were done at 28.2±8.0 weeks GA in the AGA control group and at 28.6±4.3 weeks GA in IUGR group. The plasma PUFA were measured in mcg/ml and % weight of total FA. ^246^ In the study of Rump et al., maternal venous blood samples were collected at 11±3 weeks GA. The plasma FA were measured in % weight of total FA. ^241^ Matorras et al. obtained maternal blood samples during the second stage of labor. The plasma FA were measured in % weight of total FA ^245^ The correlation between maternal plasma FA composition and the main outcomes was calculated using Pearson's correlation coefficient, following the standard criteria of applicability, ^245^ linear regression analysis, ^246^ and simple and multiple regression models. ^241,^ ^247^ Elias and Innis assessed the association between maternal plasma PUFA and the birth weight and length of infants. The plasma FA were measured in % weight of total FA. ^240^

Study quality and applicability. Although they employed different research designs, all the studies were assigned a level of applicability of III and together, received a mean quality score of 7.2.

#### Qualitative synthesis of individual study results

Vibergsson et al. ^247^ found that in a subgroup of SGA participants, maternal plasma DHA and AA concentrations were significantly lower than those in a control group at 34 weeks GA as well as at delivery. The study results of both Matorras et al. ^245^ and Cetin et al. ^246^ were similar. In the Spanish case-control study, Matorras et al. revealed that maternal plasma EPA concentrations expressed in percentage values of total amount of plasma FAs, were significantly increased in IUGR mothers compared with controls at delivery. ^245^ Conversely, there were no differences in percentage values nor in absolute values in the other FAs analyzed in newborn infants. ^245^ Cetin et al. observed significantly higher maternal plasma EPA in the IUGR group compared with the normal control group in the third trimester of pregnancy. ^246^

Rump et al. found that observed changes in maternal plasma LCPUFA concentrations (% wt FA) were related to the size of the infants. ^241^ Significantly bigger decreases in plasma concentrations of AA and DHA were noted in mothers of AGA control infants compared with mothers of the SGA group, whereas, the largest reduction in the fraction of linoleic acid was found in the mothers of SGA infants. No cross-sectional association was found between maternal FA concentrations and infant size at birth at study entry or at delivery, as well as between maternal plasma FA concentrations and the total duration of gestation.

Elias and Innis observed that the maternal plasma TGL AA, but not phospholipid or cholesteryl ester AA, was positively related to infant birth weight and length (p<0.01). No other correlations were found between maternal plasma omega-3 or omega-6 FAs and these variables. ^240^

## Growth Pattern Outcomes

### What is the Evidence That Maternal Intake of Omega-3 Fatty Acids During Pregnancy Influences Growth Patterns in Term or Preterm Human Infants?

One RCT, published in 2002, was identified to answer this question. ^141^ Helland et al. ^141,^ ^200^ had two publications related to the same study population, yet this review will refer only to the earlier one. ^141^ (Summary Table 16)

#### Overview of relevant study characteristics and results

Helland et al., ^141^ has been described in detail in the Pregnancy Outcomes section. A summary and the results relating to the current question are discussed here.

Helland et al. assessed the gestational length, birth weight, and neurologic and cognitive outcomes in a sample of infants born of healthy pregnant women. Participants were randomized to receive either cod liver oil (1,183 mg/10 mL DHA, 803 mg EPA, 27.5 mg AA) or corn oil (LA and ALA) from week 18 of pregnancy to 3 months post delivery. ^141^

The participants (n=590 enrolled) were included if they were healthy, with single pregnancies, between 19 and 35 years of age, and intended to breastfeed their infant. They should not have taken any supplements of omega-3 FA earlier in the pregnancy. The exclusion criteria were premature births, birth asphyxia, infections, and anomalies in the infants that required special attention. ^141^ Infant growth patterns (i.e., weight, length and HC) were measured at birth, 6 weeks and 3, 6, 9 and 12 months. Helland et al. had a high rate of dropouts, leaving 341 women in the final analysis (57%). ^288^

The groups did not differ significantly in weight, length and HC at any time point during the study. ^141^

No correlation was found between these parameters and infant plasma biomarkers.

Study quality and applicability. The Jadad total quality score was 4 (did not report double-blinding method) and the allocation concealment was unclear in the report. The applicability level was III.

### What is the Evidence That the Omega-3 Fatty Acid Content of Maternal Breast Milk, With or Without Known Maternal Intake of Omega-3 Fatty Acids, Influences Growth Patterns in Term or Preterm Human Infants?

One RCT and two observational studies published between 1999 and 2003 met eligibility criteria regarding the influence of maternal milk intake on growth patterns. ^248,^ ^249,^ ^302^ Jensen et al. was a double-blind RCT, ^248^ Xiang et al. was a single prospective cohort study ^249^ and Rocquelin et al. was a cross-sectional study. ^302^ Helland et al.'s RCT (see above and Summary Table 16) also addressed this question since the mothers of the infants included in the study breastfed their infants while taking PUFA supplementation. ^141^

#### Overview of relevant study characteristics and results

Jensen et al. investigated the effect of DHA supplementation in lactating women on the visual function and growth of their infants. ^248^ Mothers were assigned randomily to receive 200 to 250 mg DHA per day as either algal DHA (n=42), refined high-DHA fish oil (n=42) or placebo (n=42), for 120 days after delivery. Infant characteristics, as well as maternal characteristics, were not described in this abstract. ^248^ The study showed no differences between the three diet groups in the weight, length or HC of the infants at 120 and 240 days. ^248^

Xiang et al. evaluated the growth patterns in a random sample of healthy mother-term infant pairs (n=19) at 1 and 3 months of age. The infants were exclusively breastfed during the study period. ^249^ Rocquelin et al. investigated the role of human milk LCPUFAs in term infant growth in two African suburban random samples of nursing mothers and their 5 month old infants. ^302^

Xiang et al. was conducted in Sweden and was supported by the Wenner-Gren Centre Foundation. ^249^ Rocquelin et al. was conducted in in The Congo and Burkina Faso (Africa), and supported partly by the Institut National de la Recherceh Agronomique. ^302^

Xiang et al. did not report the inclusion and exclusion criteria, yet described the included sample as mother-infant pairs without acute or chronic conditions. The infants were exclusively breastfed during the 3 months of the study. The mothers registered the total intake of food and fluid, and a 3-day dietary record was obtained; however, the LCPUFA content was not measured. The maternal milk FA composition was measured at each visit. ^249^

Rocquelin et al. conducted a survey in two random samples of nursing mothers and their 5-month old infants born at term—102 participants in Congo and 101 in Burkina Faso. ^302^ The report failed to describe the inclusion and exclusion criteria. The dietary habits of the mothers was established using a Food-frequency questionnaire. The outcomes measured were the growth patterns (weight and height from birth to 5 months of age). ^302^ The maternal age, height, BMI, and maternal occupation did not differ significantly between both locations, however, maternal education was significantly superior in participants in Congo compared with those in Burkina Faso. The characteristics of the participants' homes (i.e., electricity, refrigerator, private water supply, private toilets, radio set, TV set) were significantly different between cities. ^302^

The feeding practices of the mothers were measured in each location. None of the infants were exclusively breastfed. All the infants in Burkina Faso were receiving extra fluids (e.g. water or juice) compared with 51% of Congo infants. However, the Burkina Faso infants had a significantly higher proportion of predominance of breast feeding and exclusion of solid foods. The LCPUFA content in breast milk and foods given to the infants were measured at both sites. The breast milk fat content was slightly lower in mothers in Congo. The content of omega-6 FA in the human milk of women in Burkina Faso was significantly higher than in Congo, yet it provided significantly lower (half) concentrations of omega-3 FA. Consequently, the LA omega-6/ALA omega-3 ratio and the LC omega-6/LC omega-3 ratio were 4.3 and 4.5 times higher, respectively, in Burkina Faso than in Congo.

The fat and PUFA concentrations in flours fed as gruels were predominantly from corn and millet. In Burkina Faso, infants also received commercial infant formula (Cerelac) containing LA (800 mg/100g), ALA (29 mg/100g) (i.e., LA/ALA=28.0). In Congo, the FA content was LA 1,080 mg/100g, ALA 73 g/100g (i.e., LA/ALA=14.8). ^302^

In the Xiang et al. study, the LC PUFAs fraction (13.5% of total FA) in human milk (LA and ALA) increased significantly during the 3 months of lactation, whereas, DHA decreased significantly but not the EPA maternal milk content. ^249^ The ratio of AA to DHA in the mother's milk correlated positively with the infants' rate of increase of HC at 1 month and 3 months of age, as well as with the gain in estimated brain weight at 1 and 3 months of age. No relations were found between HC or estimated brain weight and LA, ALA, AA or DHA content in human milk. ^249^

Infants in Rocquelin et al.'s study did not differ in gender, percentage of LBW (<2,500 g), birth weight or length, between the two sites. ^302^ However, the infants in Congo were significantly younger than in Burkina Faso. The weight-for-age and weight-for height z-scores and weight gain (in grams) were significantly lower in infants in Burkina Faso than in those in Congo.

When comparing the anthropometric data (birth weight, age, weight gain) of predominantly breastfed to complementary fed infants in Burkina Faso, no differences between groups were detected. Since both populations were extremely different, the analysis of the relationship between the FA content in breast milk and anthropometric data between cities was excluded from the review. ^302^

Study quality and applicability. Jensen et al. was not assessed by Jadad scale give that it was an abstract. ^248^ Both observational studies had a mean total quality score of 5, and a level of applicability of III. ^249,^ ^302^

### What is the Evidence That the Omega-3 Fatty Acid Content of Infant Formula Influences Growth Patterns in Term or Preterm Human Infants?

### What is the Evidence That the Omega-3 Fatty Acid Content of Maternal Breast Milk, With or Without Known Maternal Intake of Omega-3 Fatty Acids, and Together With the Omega-3 Fatty Acid Content of Infant Formula, Influences Growth Patterns in Term or Preterm Human Infants?

### Infant Formula Intake—Preterm Infants

Twenty double-blinded RCTs met eligibility criteria for investigating a possible effectiveness of omega-3 fatty acid content of infant formula on growth patterns in preterm infants. Studies were published between 1987 and 2004. (Summary Tables 18–21)

#### Overview of relevant studies

All of the included studies assessed the effect of omega-3 FA content of infant formula on growth patterns in preterm human infants. One study evaluated the effect of maternal breastfeeding together with the intake of omega-3 FA supplemented formula on growth patterns in preterm infants, as well as the effect of omega-3 FA content of infant formula on growth parameters. ^253^ With the exception of the three Carlson et al. studies, ^185,^ ^191,^ ^250^ as well as the studies of Clandinin et al., ^193^ Groh-Wargo et al. ^256^ and Fewtrell et al., ^258^ all studies included a non-randomized group of breastfed infants that served as a reference standard.

Carlson et al. conducted a study involving 61 preterm infants (<1500 g) with no major congenital abnormalities and major medical conditions. ^250^ The infants were randomized to receive either preterm control formula (Similac Special care, or Enfamil Premature) or fish oil supplemented infant preterm formula for 4 weeks. (Summary Table 18)

In another study by Carlson et al., 79 preterm, premature infants weighed less than 1400 g were randomly assigned to receive either control or marine oil-enriched preterm infant formulas (DHA [0.2wt%], EPA [0.3wt%]), followed by term placebo and experimental formulas (DHA [0.2wt%], EPA [0.3wt%]) for up to 57 weeks postconceptional age (PCA). ^185^ (Summary Table 18)

Koletzko et al. compared LCPUFA supplemented preterm formula containing DHA (0.3wt%), EPA (0.03wt%) and AA (0.05wt%) with a control formula in a small study involving 19 preterm babies with a weight less than 1850 g. ^251^ Infants were followed for a period of 21 days of full enteral feeding. ^251^ (Summary Table 18)

Uauy et al. randomized 60 preterm infants with a birth weight of 1,000 g to 1,500 g and no major neonatal morbidity by the tenth day of life, to receive one of three formulas for 6 months. ^212^ The feeding formulas differed only in the amounts and sources of LCPUFAs—two control formulas contained no added LCPUFAs and had different amount of 18:2 n-3 and 18:2 n-6 FAs, whereas, the experimental formula contained additional LCPUFAs derived from marine oil (DHA [0.35wt%], EPA [0.65wt%] and AA [0.1wt%]). (Summary Table 18)

Carlson et al. enrolled 59 preterm infants with or without bronchopulmonary dysplasia and randomly assigned them to receive standard preterm formula, which contained linolenic acid as 2.5% of total FA (Similac Special Care) or a formula that provided n-3 LCPUFAs from marine oil (DHA [0.2wt%] and EPA [0.06wt%]) but did not differ otherwise from the standard formula. ^191^ Randomization took place between 3 and 5 days of life and formula intake continued for up to 2 months PCA. ^191^ (Summary Table 18)

Faldella et al. recruited 46 preterm infants less than 33 weeks GA with no neurological, visual, acoustic, or gastrointestinal illnesses and randomly assigned them to a formula for preterm infants enriched with marine oil derived LCPUFAs (Preaptamil with Milupan) containing DHA (0.3wt%), EPA (0.05wt%), and AA (0.44wt%) or a traditional formula for preterm infants. ^198^ Feeding regimens continued up to 52 weeks of PCA. ^198^ (Summary Table 18)

Vanderhoof et al. conducted a double-blinded RCT of two formula-fed groups and a parallel reference group of breastfed infants. Medically-stable preterm infants with a birth weight ranging from 750 g to 2000 g were assigned to receive either control preterm formula (Preemie SMA®) or LCP-supplemented Preemie SMA (DHA [0.35wt%], AA [0.5wt%]) for up to 48 weeks PCA. ^218^ (Summary Table 19)

Lapillone et al. evaluated 33 preterm infants appropriate for GA who were randomized to receive either standard preterm formula from inclusion to 40 weeks term corrected age (CA), then a standard term formula until 4 months CA, or preterm formula enriched with the fish oil containing DHA (0.37wt%) and EPA (0.05wt%) until 40 weeks CA and then a term formula supplemented with a fish oil containing DHA (0.45wt%) and EPA (0.09wt%) until 4 months CA. ^252^ A reference group of 10 breastfed infants was also recruited for the trial. ^109^ (Summary Table 19)

Martinez et al. assessed 40 preterm infants (VLBW) who received in a double-blinded fashion either LCPUFA supplemented or control formula for 30 days. A group of 18 breastfed infants served as reference standard. The outcomes were the weight, length and head circumference at 30 days. ^120^ (Summary Table 19)

Woltil et al. conducted a double-blind RCT where preterm newborn babies were allocated to receive two experimental formulas supplemented with evening primrose oil and either a single (DHA [0.20wt%] and EPA [0.17wt%]; n=13) or double dosage (DHA [0.43wt%] and EPA [0.34wt%]; n=16) of purified fish oil, and three control formulas containing different amount of protein and ribonucleotides. ^225^ Dietary intake took place for 6 weeks. Thirty-three infants received their mother's own milk. ^225^ (Summary Table 19)

Ghebremeskel et al. randomized healthy preterm infants with no congenital malformations and metabolic disorders into four feeding groups: (1) breast milk and LCP-enriched formula (0.85±0.25wt% DHA); (2) breast milk and standard formula (0.55±0.25wt% DHA); (3) LCP-supplemented formula (0.30wt% DHA); or, (4) exclusively standard formula. ^253^ Mean duration of an intervention was 11 weeks with a range of 7 to 15 weeks. Twenty exclusively breastfed infants formed a standard reference group. (Summary Table 19)

Bougle et al. conducted a small efficacy study involving healthy, AGA premature infants of less than 34 weeks postmenstrual age, who were randomized into two groups within the first 2 days of enteral feeding—LCP-supplemented (DHA [0.6wt%], EPA [0.1wt%] and AA [0.1wt%]; n=14) or control formula without any LCPUFA supplementation (n=11). ^254^ The end of the study occurred at the expected date of delivery, after babies were fed for at least 1 month on the study diet. ^254^ (Summary Table 20)

Field et al. conducted a double-blind RCT in which 44 medically-stable preterm newborn babies were allocated to receive either preterm formula (Preemie SMA) or the same formula manufactured to contain LCPUFAs (DHA [0.35wt%] and AA [0.49wt%]). ^303^ Feeding of formulas began before day eight of postnatal life and continued until day 42. Seventeen exclusively breastfed infants were included as a reference group. ^303^ (Summary Table 20)

O'Connor et al. randomized 283 preterm infants of less than 33 weeks GA without any congenital abnormalities to one of three formula groups received in-hospital: (1) control; (2) treatment formula with supplemental LCPUFAs derived from fish/fungal oils (0.27±±0.04 g/100g DHA, 0.08±0.01 g/100g EPA, and 0.43±0.02 g/100g AA); or (3) treatment formula with supplemental LCPUFAs derived from egg-triglycerides/fish oils (0.24±0.01 g/100g DHA and 0.41±0.0 g/100g AA). ^207^ After discharge, infants received postdischarge formulas with the same content of AA, but reduced amount of DHA (0.16±0.01 g/100g DHA in fish/fungal oil group and 0.15±0.02 g/100g DHA in egg-triglycerides/fish oil group). The intervention lasted up to 12 months PCA. (Summary Table 20)

Fewtrell et al. recruited 195 preterm infants with no congenital malformations and randomized them to receive either preterm infant formula without additional LCPUFA (Prematil, Milupa) or a supplemented formula (Prematil with Milupan) containing DHA (0.17wt%) and EPA (0.04wt%) from egg lipids. ^273^ All infants were fed and followed for up to 9 months PCA. A group of 88 breastfed infants formed a reference group. ^273^ (Summary Table 20)

Clandinin et al., in a double-blind multicenter RCT, randomized LBW infants to one of three feeding groups: (1) control (n=119); (2) LCP-1 (17mg/100kcal DHA and 34mg/100kcal AA, derived from single cell oils, n=112); or, (3) LCP-2 (17mg/100kcal DHA derived from fish oil and 34mg/100kcal AA, derived from single cell oils, n=130). ^193^ Each group included three formula types: preterm, postdischarge, and term, which investigators chose based on infant needs. Formulas were the infant's sole diet until 57 weeks PCA. ^193^ (Summary Table 20)

Innis et al. conducted a double-blind, multicenter study of 194 healthy premature, VLBW (846 g-1560 g) infants who were randomized to receive either preterm formula with no DHA or AA (control, n=62), DHA (0.15wt% ; n=66) or DHA (0.14wt%) and AA (0.27wt%) (n=66) derived from single cell triglycerides, for at least 28 days and then fed term formula with no LCPUFA supplementations for up to 57 weeks postmenopausal age. ^201^ Ninety breastfed infants served as a reference. ^201^ (Summary Table 21)

Groh-Wargo et al. evaluated the effect of feeding formula supplemented with DHA (0.42wt%) and AA (0.26wt%) derived from fish/fungal oils (LCP-1 group, n=18) or DHA (0.26wt%) and AA (0.26wt%) derived from egg phospholipid/fish oil (LCP-2 group, n=18) on growth parameters of preterm infants at 12 months of CA compared with infants fed unsupplemented formula (control group, n=21). ^256^ Randomization of infants took place within 72 hours of first enteral feeding. ^256^ (Summary Table 21)

Koletzko et al. randomized 30 preterm infants with a stable medical condition and birth weight of less than 1800 g to receive either preterm control formula (n=15) or LCP-supplemented formula (DHA [0.57wt%], EPA [0.13wt%] and AA [0.1wt%]; n=15) within 3 days of established full enteral feeding to 28 days post partum. ^257^ Nineteen breastfed infants formed a reference group. ^257^ (Summary Table 21)

Fewtrell et al. randomly assigned preterm infants with a birth weight less than 2000 g and GA less than 35 weeks to unsupplemented (control group, n=116) or LCPUFA-supplemented formula (treatment group; DHA [0.5wt%], EPA [0.1wt%] and AA [0.04wt%]; n=122) until 9 months PCA. ^258^ (Summary Table 21)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. All studies were parallel RCTs with at least two groups, although the study of Ghebren et al. involved five feeding groups. ^253^

The inclusion/exclusion criteria were described by 11 of 20 studies. ^198,^ ^201,^ ^207,^ ^212,^ ^218,^ ^250,^ ^251,^ ^253,^ ^257,^ ^259,^ ^303^ Only inclusion criteria were reported in four studies ^225,^ ^254,^ ^258,^ ^273^ and only exclusion criteria were reported in two studies. ^185,^ ^191^ Three studies failed to report either inclusion or exclusion criteria. ^193,^ ^252,^ ^256^ Three studies defined maternal substance abuse (cocaine and alcohol) history as exclusion criteria. ^191,^ ^207,^ ^218^ The definition of a preterm infant (<37 weeks GA) was described in eight studies, ^198,^ ^251,^ ^253,^ ^254,^ ^258,^ ^259,^ ^273,^ ^303^ although included preterm infants in these studies were at different GAs. Koletzko et al. ^251^ and Fewtrell et al. ^273^ included infants less than 37 weeks GA, whereas, Field et al. ^303^ evaluated infants born at less than 36 weeks GA, Fewtrell et al. ^258^ at less than 35 weeks GA, Bougle et al. ^254^ at less than 34 weeks GA, and Faldella et al. ^198^ and Ghebremeskel et al. ^253^ at less than 33 weeks GA. Eight studies were typically small, with a mean of 30 participants (range 19–41). ^251–254,^ ^256,^ ^257,^ ^259,^ ^303^ The study duration ranged from 3 weeks to 12 months.

The trials were conducted in various countries, with five undertaken in the U.S., ^183,^ ^185,^ ^191,^ ^212,^ ^218,^ ^250^ three in the U.K. ^253,^ ^258,^ ^273^ and Canada, ^193,^ ^201,^ ^303^ two in France ^252,^ ^254^ and Germany, ^251,^ ^257^ one in Italy, ^198^ one in Brazil, ^259^ and one in The Netherlands. ^225^ One multicenter study was conducted in three countries—the U.S., U.K and Chile. ^207^ Groh-Wargo et al. failed to indicate the country where their study was undertaken. ^256^

The study of Carlson et al. ^250^ was supported by Ross laboratories, Columbus, OH. Another Carlson et al. study was sponsored by Ross Laboratories, Columbus, OH, and the National Eye Institute. ^185^ Koletzko et al. received a grant from Deutsche Forschungsgemeinschaft, Bonn, Germany and Milupa AG, Friedrichsdorf, Germany. ^251^ Uauy et al.'s study was financially supported by the National Institute of Health. ^212^ The Carlson et al. study ^191^ was funded by the National Eye Institute, the National Institute of Child Health and Human Development, and Ross Products Division, Abbott Laboratories, Columbus, OH. Vanderhoof et al.'s study was supported by Wyeth Nutritionals International, Philadelphia, Pennsylvania, U.S.A. ^218^ Martinez et al. was funded by the Brazilian Research Council and Milupa GmbH. ^259^ Woltil et al.'s study was supported by grants from Friesland Nutrition, Leeuwarden, The Netherlands. ^225^ The study of Ghebremeskel et al. was financed by The Christopher H.R. Reeves Charitable Trust and Milupa Plc. ^253^ Field et al.'s study was supported by grants from the Natural Sciences and Engineering Research Council of Canada and the Medical Research Council of Canada, as well as Wyeth-Ayerst Research. ^303^ Fewtrell et al.'s study was funded by Numico Research BV (Wageningen, The Netherlands). ^273^ Clandinin et al.'s ^193^ and Innis et al.'s ^201^ studies were financed by grants from Mead Johnson & Company. The Groh-Wargo et al. study was supported by Abott Laboratoris, Columbus and GCRC NIH. ^256^ Koletzko et al.'s study was sponsored by Deutsche Forschungsgemeinschaft, Bonn, Germany, Nestec S.A., Vevey, Switzerland and Nestle Alete GmbH, Munchen, Germany. ^257^ Fewtrell et al.'s study was supported by grant from H.J. Heinz Company, Ltd, Hayes, Middlesex, U.K. ^258^ Four trials did not provide information concerning their funding source. ^198,^ ^207,^ ^252,^ ^254^

In general, six studies ^193,^ ^201,^ ^218,^ ^225,^ ^250,^ ^258^ were granted only by pharmaceutical companies, six studies ^185,^ ^191,^ ^251,^ ^256,^ ^257,^ ^303^ by both pharmaceutical and governmental fundings, two studies ^212,^ ^273^ by only governmental sources, and one study ^253^ partly by private and pharmaceutical sources.

Pre-study sample size calculation to reach statistical significance and power was performed in seven studies. ^191,^ ^201,^ ^207,^ ^212,^ ^218,^ ^258,^ ^273^

Population characteristics. A total of 2,650 preterm infants were enrolled across 20 RCTs. The total number of infants that completed the trials could not be calculated since six of the studies failed to report these data, providing only the number of infants who entered the trial. ^193,^ ^218,^ ^225,^ ^252,^ ^256,^ ^259^

Eligibility criteria varied broadly across studies. Most importantly, body mass of recruited preterm infants, GA, and age at study enrollment, differed substantially from trial to trial. Some investigators randomized very small preterm infants (i.e., weighing less than 1,400 g to 1,500 g), ^185,^ ^201,^ ^212,^ ^250,^ ^259^ whereas, other authors broadened their criteria to include preterm infants with a birth weight ranging from 2,000 g to 2,500 g. ^218,^ ^225,^ ^258^ Six studies failed to report predefined eligibility criteria regarding infant's weight. ^191,^ ^198,^ ^253,^ ^254,^ ^256,^ ^303^

The gender distribution of randomized infants was reported in ten studies. ^191,^ ^207,^ ^212,^ ^218,^ ^225,^ ^257–259,^ ^273,^ ^304^ In eight of these studies, male infants constituted the majority of participants, although the gender ratio of infants among different diet groups were evenly distributed in all of these studies.

The racial/ethnic background of study participants were described in only four trials. ^191,^ ^207,^ ^212,^ ^218^ In two studies, ^191,^ ^212^ the majority of infants were Black, accounting for 60% and 83% of study population, respectively. In the two other trials, ^207,^ ^218^ White infants comprised the majority of study participants accounting for 58% and 70% of participants, respectively.

Different variables were used to demonstrate family sociodemographic status in the studies (e.g., maternal education, social class, professional qualification, home inventory score, maternal WAIS-R raw vocabulary score). Maternal social status was determined in two studies, ^258,^ ^273^ whereas, information about maternal education or maternal professional qualification was given in three trials. ^207,^ ^258,^ ^273^ O'Connor et al. measured and compared the quality and quantity of stimulation and support available to a child in the home environment in different groups by means of a HOME inventory score. Maternal intelligence was assessed by administering a WAIS-R raw vocabulary score. ^207^ There were no differences in sociodemographic variables among the study groups of randomized infants in all of these studies with the exception of HOME inventory scores, which were better in the control group than in both treatment groups. ^207^ Mothers of infants in the reference breastfed group had a more prestigious social score and attained a higher level of professional qualification compared with mothers of formula-fed infants. ^273^

Only one study reported on maternal smoking during pregnancy and postnatal smoking in the home. ^207^

Intervention/exposure characteristics. Only one of 20 reviewed studies reported the exact amount of supplementary LCPUFAs consumed per day by the preterm infants. ^225^ Woltil et al. ^225^ assigned preterm infants to two LCPUFA-supplemented feeding groups with different anounts of DHA—group LCP-1 consumed 23.3±9.9 mg/kg/day DHA, whereas group LCP-2 consumed 13.3 to 41.8 mg/kg/day DHA. The rest of the studies failed to indicate daily consumption of omega-3 FAs by feeding infants. In all studies, formula-fed infants received preterm formula and depending on the ultimate interest of the research project, went to either post-discharge or term formula. In fourteen studies, the effect of only preterm formulas with supplemented LCPUFAs on growth indices of preterm infants were assessed. ^191,^ ^193,^ ^198,^ ^212,^ ^218,^ ^225,^ ^250,^ ^251,^ ^253,^ ^254,^ ^257,^ ^259,^ ^273,^ ^303^ In six studies, infants continued to receive a formula designed for term infants (with or without LCP supplementation) according to their original assignments, and their effect on each child's growth was further estimated. ^185,^ ^201,^ ^207,^ ^252,^ ^256,^ ^258^

Preterm infants were eligible to enter the study after they attained full enteral feeding without intravenous support. The minimum amount of formula-intake required in order to be considered fully enteral-fed differed across the trials. In two studies infants became eligible to enroll when they received at least 130 mL/kg/day of a preterm formula. ^251,^ ^257^ Carlson et al. allowed preterm infants to enroll in the study after they had reached intakes of nutrient-enriched formula of at least 60 kcal/kg/day, ^250^ whereas, Carlson et al. established criteria for enrollment of more than 110 kcal/kg/day. ^185^ Enteral feeding of at least 70 to 120 kcal/kg/day was required in the trial of Uauy et al.; ^212^ Carlson et al. required an intake of at least 100 kcal/kg/day. ^191^ Vanderhoof et al. specified an intake of 145 mL/kg/day, ^218^ whereas, Woltil et al. required an intake of 80 kcal/kg/day. ^225^ In the Martinez et al. study, an intake of 112 kcal/kg/day was indicated ^259^ and Innis et al. specified an intake of at least 90 kcal/kg/day. ^201^ Eight studies failed to report a minimum daily food or caloric intake required for preterm infants. ^198,^ ^207,^ ^253,^ ^254,^ ^256,^ ^258,^ ^273,^ ^303^

Only two studies reported as part of the protocol that the volume of formula consumed, i.e., calculated as the difference in the volume of formula in the bottle at the start and end of the feed, was recorded. ^185,^ ^225^ Daily intake of formula did not differ in the three feeding groups of Woltil et al. (171 [SD=21] mL/kg vs 172 [SD=17] mL/kg vs 176 [SD=17] mL/kg). ^225^ In a study of Carlson et al., ^185^ all except one infant consumed at least 720 g of formula per day through 79 weeks PCA. Duration of formula feeding ranged from 3 weeks ^251^ to 12 months CA. ^207,^ ^256^

The sources of omega-3 FA intervention varied across the RCTs. Three trials described the source of LCPUFA supplementation as purely fish oil. ^225,^ ^250,^ ^252^ The specific type of fish from which fish oil exposures were derived was described in only one study. ^258^ O'Connor et al. ^207^ and Groh-Wargo et al. ^256^ used a treatment formula with omega-3 FAs derived from fish and fungal oils, whereas, Fewtrell et al. ^258^ supplemented a treatment formula with a combination of DHA derived from fish oil and AA derived from borage oil. The remaining studies employed either single cell sources of FAs, ^193,^ ^201,^ ^218,^ ^303^ marine oils, ^185,^ ^191,^ ^212^ egg phospholipids with primrose oil, ^253,^ ^259,^ ^273^ or a combination of egg triglyceride and fish oil sources. ^207,^ ^256,^ ^257^ The sources of supplemental LC PUFAs were not reported in three trials. ^198,^ ^251,^ ^254^

The type of omega-3 FA employed in four studies included a combination of DHA and EPA; ^185,^ ^191,^ ^225,^ ^252^ DHA alone was used in one trial. ^201^ Supplementation of formulas with omega-6 FA AA was reported in 12 studies. ^193,^ ^198,^ ^201,^ ^207,^ ^213,^ ^218,^ ^253,^ ^254,^ ^256,^ ^258,^ ^273,^ ^303^

Seven studies failed to report the name of feeding formulas, although all of them indicated the manufacturers of the product. ^185,^ ^193,^ ^212,^ ^225,^ ^252,^ ^254,^ ^256^ The brands of formulas employed in the rest of the studies were: Enfamil Premature (Mead Johnson Nutritionals, Evansville, Ind); ^201,^ ^250^ Similac Special Care (Ross Laboratories, Columbus, OH); ^191,^ ^207,^ ^250^ Prematil with Mipupan (Milupa, AG, Friedrichsdorf, Germany); ^198,^ ^251,^ ^253,^ ^259,^ ^273^ SMA “Preemie” (Wyeth-Ayerst Laboratories, Randor, Philadelphia, PA); ^218,^ ^250,^ ^303^ Alprem (Nestle, Vevey, Switzerland); ^257^ OsterPrem with LCPUFA (Heinz Co, Ltd, Hayes, Middlesex, U.K.); ^258^ NeoSure (Ross Product Division, Columbus, OH, USA); ^207^ and, Farley's PreCare with LCPUFA (Heinz Co, Ltd, Hayes, Middlesex, U.K.) were used as a term formulas after hospital discharge. Five studies indicated the manufacturer of at least one omega-3 FA product used in their study. ^201,^ ^212,^ ^218,^ ^250,^ ^303^ In three of these trials supplemented LCPUFAs were manufactured and supplied by Market Biosciences Corporation (Columbia, MD, USA), ^201,^ ^218,^ ^303^ whereas, in two other studies omega-3 FAs were produced by MaxEPA, R.P. Scherer, Troy, MI ^250^ and Zapata-Haynie Co., Reedville, Va. ^212^ Only one study reported on the purity of their omega-3 FA exposure. ^225^

Formula was the only source of alimentation in 14 studies and no solid foods were introduced during the entire trial period. ^185,^ ^191,^ ^193,^ ^198,^ ^201,^ ^218,^ ^225,^ ^250,^ ^251,^ ^253,^ ^254,^ ^257,^ ^259,^ ^303^ Only one study reported the time of introduction of solid foods—Uauy et al. ^212^ permitted cereals, fruit juices, or fruits at 4 months of CA in both study groups. Fewtrell et al., ^273^ Groh-Wargo et al., ^256^ Fewtrell et al., ^258^ and O'Connor et al. ^207^ did not report of any solid food introduction to infants even though their study durations were up to 9 and 12 months CA.

Information about caloric balance of feeding formulas was reported in eight RCTs. ^185,^ ^191,^ ^201,^ ^212,^ ^225,^ ^254,^ ^259,^ ^273^ Nutritional and energy intake were similar between randomized groups throughout the study period in the majority of trials. However, Carlson et al. reported that the mean energy intake from formula was not affected by dietary assignment or gender at 48 and 57 weeks PCA; however, at 68 weeks PCA, infants consuming the marine oil-supplemented formula had significantly higher energy intake from formula compared with infants fed standard formula. ^185^

Only three RCTs ^212,^ ^258,^ ^273^ mentioned that study treatment formulas were indistinguishable in appearance and odor. Uauy et al. also reported that supplemental marine oil was winterized and stabilized. ^212^

Cointervention characteristics. Six studies reported the content of vitamin and mineral supplements of feeding formulas or multivitamin preparations taken by preterm infants. ^191,^ ^207,^ ^212,^ ^251,^ ^253,^ ^303^ All of these formulas or oral vitamin supplements provided alpha-tocopherol ranging from 4.5 mg/day ^303^ to 15 mg/day. ^253^ Ghebremeskel et al. used a formula also supplemented with 0.22 μmol/100 mL vitamin A. ^253^ The formula used by O'Connor et al. ^207^ was supplemented with 0.60 mg/L vitamin A and 0.50 mg/L beta-carotene, and Field et al. added 1200 U/day vitamin D to their infant formulas. ^303^

Due to the physical immaturity of LBW preterm infants, many of the newborns required pre- or on-study medical cointerventions, such as oxygen supply, mechanical ventilation, intravenous nutrition, blood or blood product transfusion, and corticosteroid treatment. The most frequently reported cointervention was oxygen supply or mechanical ventilation and measurements were provided in four studies. ^185,^ ^191,^ ^212,^ ^258^ Carlson et al. ^191^ allowed a significant subgroup of patients (n=23) who continued to require supplemental oxygen for 28 days and had lung changes on X-ray characteristic of bronchopulmonary dysplasia, to remain in the study. Two studies reported use of blood or blood products. ^212,^ ^303^ Uauy et al. described that only five preterm infants required blood transfusion after random assignment, and all transfusions were given at least 2 weeks before blood sampling. ^212^

In the study of Field et al., two infants received an intravenous bolus of albumin on day 2 of life. ^303^ Some investigators set strict inclusion criteria for infants requiring additional medical treatment. Vanderhoof et al., for example, excluded preterm infants with consistent requirements for oxygen at 36 weeks PCA and administration of more than a 5-day course of corticosteroids. ^218^ In studies of Koletzko et al. ^251^ and Koletzko et al., ^257^ infants requiring artificial ventilation or an oxygen supply with FiO_2_ >0.3 at the time of enrollment were excluded. Uauy et al. reported that no infants had used a ventilator after day 5 or for more than 3 days. ^212^ None of the participants received corticosteroids, red blood cells and plasma transfusions or intravenous lipid emulsions beyond day 8 of life in the Field et al. trial. ^303^ However, none of these studies reported how many newborn babies received cointerventional measures below the set limit.

Outcome characteristics. Of 20 trials, 12 assessed the growth parameters as primary outcomes ^123,^ ^150,^ ^305–314^ while the remaining eight trials evaluated them as a secondary outcome or part of the safety profile. Thirteen included RCTs employed infants' weight, length, and HC as main outcome measures for growth. ^185,^ ^191,^ ^193,^ ^201,^ ^212,^ ^218,^ ^251,^ ^253,^ ^254,^ ^257,^ ^259,^ ^273,^ ^303^ Two trials (abstracts) did not specify the growth indices evaluated, rather they described changes in growth parameters. ^252,^ ^256^ Carlson et al. evaluated only weight gain from birth to 4 weeks of study period in two randomized dietary groups. ^250^ The rate of gain in weight, length and HC were assessed in five studies. ^198,^ ^207,^ ^225,^ ^254,^ ^258^ Triceps skinfold thickness and subscapular skinfold thickness were measured in two RCTs. ^212,^ ^259^ Another study evaluated mid-arm circumference, ^218^ another measured weight-to-length ratio, ^201^ and one study used estimated brain weight gain in preterm infants as one of the growth outcomes. ^225^

Study quality and applicability. Seventeen (of twenty) RCTs received a mean Jadad total quality score of 2.64, indicating a poor internal validity (Summary Matrix 9). Three abstracts were not quality assessed. ^306,^ ^311,^ ^313^ The trials conducted by Fewtrell et al. received a score of 5, ^258,^ ^273^ Carlson et al. and Vanderhoof et al. received a score of 4, ^185,^ ^218^ five trials received a score of 3, ^191,^ ^201,^ ^207,^ ^254,^ ^257^ four reports received a score of 2, ^212,^ ^250,^ ^251,^ ^253^ and four received a score of 1. ^198,^ ^225,^ ^259,^ ^303^ Eleven trials failed to report the method of randomization, ^123,^ ^305,^ ^309,^ ^312,^ ^314–320^ while one study reported an inappropriate method of randomization. ^308^ Seven trials were unblinded, ^309,^ ^310,^ ^315–318,^ ^320^ seven trials failed to report the double-blinding method, ^123,^ ^150,^ ^305,^ ^308,^ ^312,^ ^314,^ ^319^ and six trials did not report the reasons for dropouts. ^305,^ ^307–309,^ ^317,^ ^320^

#### Qualitative synthesis of individual study results

The most frequently investigated outcomes across the reviewed studies were infant weight, length, and HC. Weight and/or weight gain was evaluated in all trials, and infant's length and/or length gain was evaluated in all but one ^250^ trial. The majority of the studies did not find any statistically significant difference between randomized groups regarding these two parameters at different time points. Carlson et al., ^250^ who randomized preterm infants to receive either preterm control formula or MaxEPA supplemented infant preterm formula for 4 weeks, did not find any better weight and length gain in the treatment group. Similar results were obtained at 3 weeks in the study of Koletzko et al., ^251^ at 3, 9, 17, and 26 weeks in the study of Uauy et al., ^212^ at 52 weeks PCA in the Faldella et al. study, ^198^ at 92 weeks PCA in the Vanderhoof et al. study, ^218^ at 4 months of CA according to Lapillonne et al., ^252^ a mean of 11 weeks according to Ghebremeskel et al., ^253^ at 1 month in three studies., ^225,^ ^254,^ ^259^ , at 8 weeks, 4, and 12 months CA in the study of O'Connor et al., ^207^ at 40 and 57 weeks postmenstrual ages in Clandinin et al., ^193^ at 12 months CA according to Groh-Wargo et al., ^256^ and at 28 days of age in the study by Koletzko et al. ^257^

Three studies revealed statistically significant weight and length gain in LCPUFA-supplemented diet groups compared with placebo. ^193,^ ^201,^ ^258^

Clandinin et al. randomized LBW infants to one of three feeding groups: (1) control LCP-1 (DHA [17mg/100kcal] and AA [34mg/100kcal] derived from single cell oils); (2) LCP-2 (DHA [17mg/100kcal] derived from fish oil); or, (3) AA (34mg/100kcal, derived from single cell oils). ^193^ The study found a significantly higher weight in the LCP-1 group of infants compared with infants in in the placebo group at 66 weeks to 118 weeks postmenstrual ages. In addition, infants in the LCP-1 group were significantly longer than infants in the LCP-2 or placebo groups at 79 to 92 weeks postmenstrual ages. ^193^

Innis et al., who randomly assigned VLBW (846g-1560g) infants to receive either preterm control formula (no DHA or AA), preterm formula containing only DHA (0.15wt%; DHA group) or DHA+AA formula (DHA [0.14wt%] and AA [0.27wt%]; DHA+AA group), found significantly higher body weight, length and weight-to-length ratio in infants in the DHA+AA group compared with those in the DHA formula group, and significantly higher body weight and weight-to-length ratio in DHA+AA group compared with those in the control group at 48 weeks postmenstrual age. ^201^ Moreover, infants fed the DHA+AA formula gained weight significantly faster during premature formula feeding than infants fed the control formula. The rate of weight gain of infants fed the formula with DHA was not different from that of infants fed the control formula or the formula with DHA+AA. ^201^

The study of Fewtrell et al. involving preterm infants with a birth weight less than 2,000 g and GA less than 35 weeks, found a significantly greater increase in weight and length of infants in the LCPUFA-supplemented formula group (DHA [0.5wt%], EPA [0.1wt%], and AA [0.04wt%]) compared with infants fed unsupplemented control formula at 9 months CA. ^258^

Contrary to these findings, three trials revealed statistically significant weight and length gain in infants in the placebo group compared with the LCPUFA-supplemented group, suggesting that omega-3 LCPUFA can have a negative effect on growth of very-low-birth infants. ^185,^ ^191,^ ^273^

The trial of Carlson et al. ^185^ that compared growth parameters in preterm, premature infants weighed less than 1400 g fed marine oil-enriched preterm infant formula with infants in a placebo group, found that by 40 weeks and continuing throughout infancy (i.e., up to 93 weeks PCA), infants supplemented with marine oil had significantly lower normalized weight, length, HC and weight-to-length ratio than those receiving standard formula. ^185^

Carlson et al. randomly assigned preterm infants with or without bronchopulmonary dysplasia to receive standard preterm formula, or a formula that provided n-3 LCPUFAs from marine oil (DHA [0.2wt%] and EPA [0.06wt%]). ^191^ The investigators reported that n-3 LCPUFA-supplemented infants weighed significantly less than placebo group babies both at 6 and 9 months post term and had significantly lower weight-to-length ratios at 2, 6, 9, and 12 months post term. ^191^

Fewtrell et al observed that at 9 and 18 months CA, treatment formula infants were significantly lighter and shorter than control group babies. This weight difference was present in both boys and girls, and it remained significant at 18 months after adjusting for parental smoking, social class, and level of maternal education. ^273^

In the three studies where a weight and length gain benefit was observed in LCPUFA supplemented formula fed infants, ^193,^ ^201,^ ^258^ investigators used experimental formulas containing AA. Conversely, in trials that showed a decrease in weight, ^185,^ ^191,^ ^273^ length, ^185,^ ^191,^ ^273^ and HC ^185,^ ^191^ in infants fed LCPUFA-supplemented formula, the formula did not contain AA. It can be assumed that the growth benefit in preterm infants might be attributed to supplemented AA, and omega-3 FAs negatively affect infant weight gain.

Infant HC and/or HC gain was evaluated in all but two trials. ^193,^ ^250^ Most of the studies did not find any statistically significant difference between randomized groups regarding this parameter at different time point. Only two studies ^185,^ ^191^ reported a significantly lower HC in the omega-3 FA supplemented group compared with the placebo group at 40 to 93 weeks PCA ^185^ and at 6 and 9 months post term. ^191^ None of the studies revealed any benefit of LCPUFA supplementation regarding the HC gain of premature infants.

Other growth outcomes assessed were triceps skinfold thickness, subscapular skinfold thickness, and mid-arm circumference. Uauy et al. did not find any statistically significant difference in triceps skinfold thickness and subscapular skinfold thickness among the randomized study groups at 3, 9, 17, and 26 weeks. ^212^ Martinez et al. had the same result at 30 days. ^259^ Vanderhoof et al. did not find a statistically significant difference in mid-arm circumference between study groups, although this parameter was significantly lower in the breastfed group. ^218^

Carlson et al. found that the weight and length z-scores were positively correlated with the plasma and RBC AA content at 2, 4, 5, 6, 9, and 12 months of age. However, HC was positively correlated at 2 and 4 months of age only. ^185^ Uauy et al. found that the length z-score at 57 weeks of PCA was negatively correlated with the RBC AA at 57 weeks PCA. ^212^

The other Carlson et al. study reported a negative correlation between the weight-for-length z-score and the RBC PE DHA at 5 months of age, whereas, there was a positive correlation between length and RBC PC AA at 5 months. ^191^ Innis et al. observed a positive correlation between the rate of weight gain and the RBC PE AA at 28 days (end of feeding), as well as the weight and length. ^201^ Woltil et al. found a significantly positive correlation between the weight, length and HC gain and the plasma and RBC DHA content at 1 month of age. ^225^

Finally, O'Connor et al. found a significantly postive correlation between the rate of weight gain, weight (mean) and length (mean) and the RBC AA at 1 month of age. ^207^

#### Quantitative synthesis

The outcomes considered for meta-analysis for growth development were weight, height and HC at 4 and 12 months. These end-points were selected given that the intervention with supplemented formula was exclusively administered until 4 months and 12 months (as a longterm followup measure), yet with the possible confounder factor of the background diet. Outcome results were available for more than one study at six different end-points in time: CA 4, 6, 9, 11, 12, and 18 months in 19 studies.

At 4 months CA, outcomes were available for four studies. ^185,^ ^191,^ ^201,^ ^207^ Carlson et al. ^185^ provided growth z-scores with standard deviation in a figure, and reported absolute growth data (by sex) in a table but without any measure of variability. In another report by Carlson et al. ^191^ supplementation only continued to 2 months CA. Innis et al. ^201^ did not report HC data on the grounds that results were not found to be statistically significant. We were thus able to combine weight and length results from Innis et al. and O'Connor et al. ^201,^ ^207^ Both trials assessed these outcomes as primary outcomes.

At 12 months CA, outcomes were available for three studies. ^185,^ ^191,^ ^207^ Supplementation in Carlson et al. ^191^ only continued until 2 months CA.

Supplementation in Carlson et al. ^185^ continued only until 9 months CA. In addition, Carlson et al. ^185^ provided growth z-scores with SD in a figure, and absolute growth data (by sex and without any measure of variability) in a table. We were thus unable to combine any results.

Figure 6. Child pre-term growth 4 months DHA+AA vs. control

Meta-analysis was performed using the random effects weighted mean difference.

The mean weight difference (WMD) in weight (kg) and length (cm) at 4 months (DHA+AA vs. control) in two studies ^201,^ ^207^ were nonstatistically significant. For weight: WMD: 0.04, CI 95%: -0.30; 0.38. For length: WMD: 0.09, CI 95%: -0.62; 0.80.

#### Impact of covariates and confounders

In the majority of the RCTs there was no evidence that randomization failed to produce comparable groups with the exception of scores on the HOME Inventory. ^268^ In the study of O'Connor et al., ^268^ HOME Inventory scores were higher (better) in infants weighing less than 1,250 g randomized to the control group than those randomized to the fish/fungal oil group. HOME Inventory scores were lower in infants in the more than 1,250 g birth weight stratum randomized to the egg-TG/fish oil group compared with scores in the control and fish/fungal oil groups. ^268^

Carlson et al. used a multiple regression analysis to control for potential effect modifiers such as maternal height, marine oil supplementation, and birth order. ^185^ Length achieved at 12 months of age was positively associated with maternal height, but negatively associated with marine oil supplementation. Weight was negatively associated with both birth and marine oil supplementation. ^185^

Fewtrell et al. controlled the growth changes for covariates like gender, center, parental smoking, social class and level of maternal education. ^273^

Differences in weight and length at 18 months post-term remained after adjusting for parental smoking, social class and level of maternal education. ^273^ There were no differences in HC between groups. The growth differences were greater in one center than the other, however, there was no interaction between center and growth patterns. ^273^ O'Connor et al. observed that the females in the DHA+AA (egg-TG/fish) group had a greater mean HC gain from day 1 to term CA compared with the females in the other groups. ^207^

The power calculation was reported in eight trials, ^123,^ ^307,^ ^310,^ ^312,^ ^315,^ ^316,^ ^321,^ ^322^ while the intention-to-treat analysis approach was reported in only three studies. ^310,^ ^321,^ ^322^

### Infant Formula Intake—Term Infants

Eighteen double-blinded RCTs met eligibility criteria for addressing the question relating to the possible effectiveness of formula intake enriched with omega-3 FA on growth patterns in term infants. ^104,^ ^182,^ ^203,^ ^205,^ ^223,^ ^227,^ ^260–270^

Auestad et al. included two unique trials in one report. ^227^ The studies were published between 1992 and 2004. (Summary Tables 22–24)

#### Overview of relevant studies

Ponder et al. conducted a small efficacy study involving 25 full-term, healthy infants who were randomized to receive either soy-based (Similac with Iron 20 ready-to-feed) or corn oil-based (Similac with Iron 20 powder) formulas for 8 weeks. ^260^ None of the formulas contained either DHA, EPA, or AA supplementations and their FA composition differed primarily in the percentage of ALA (omega-3) and ratio of LA (omega-6)/ALA (omega-3) The outcomes were the mean weight, length and HC at 3 days, 4 and 8 weeks of age. ^260^ (Summary Table 22)

Decsi et al. randomly assigned 22 term infants to receive either conventional infant formula (Pre-Aptamil, placebo group) or the same formula enriched with egg lipids and evening primrose oil (Pre-Aptamil with Milupan, LCP-F group). ^261^ All infants were fed ad libitum throughout the study but investigators failed to report the duration of interventions in both groups. The outcomes were the change in weight, length and HC at 4 months. ^261^ (Summary Table 22)

Makrides et al. compared fish oil and evening primrose oil derived LCPUFA-supplemented formula with placebo formula in a double-blinded RCT involving 89 healthy full-term infants. ^262^ Infants were fed for 30 weeks and growth parameters were measured and compared at 6, 16, and 30 weeks. ^262^ (Summary Table 22)

Jensen et al. randomly assigned 80 healthy term infants to receive one of four formulas as his/her sole source of nutrition from birth to 120 days of age. ^203^ LA comprised 15.6% to 17.6% of the total FAs of all formulas. The ALA content was 0.4%, 1%, 1.7%, and 3.2% of total FAs, and LA/ALA ratios were 44, 18.2, 9.7, and 4.8, respectively.

The outcomes assessed were the growth patterns at 4 and 8 months of age and the correlation with infant biomarkers. ^203^ (Summary Table 22)

Innis et al. conducted a 3-month multicenter RCT at seven different centres in the U.S. and Canada involving 139 term infants who were randomized to receive one of two cow milk-protein based formulas (Mead Johnson Nutritionals), which differed only in FA composition and blend (18.0% LA, 1.9% ALA, with LA/ALA ratio of 9.5:1 vs 34.2% LA, 4.7% ALA, with an LA/ALA ratio of 7.3:1). ^263^ Neither formula had any detectable DHA, EPA, or AA. ^263^ (Summary Table 22)

Auestad et al. randomized 134 term, healthy infants to receive one of three formulas from less than 7 days of age to 12 months. ^104^ The feeding formulas differed only in the amounts and sources of LCPUFAs: (1) the control formula contained no added LCP FAs; (2) formula containing AA (0.43wt%) and DHA (0.12wt%) from egg yolk phospholipids; and, (3) formula providing DHA (0.2wt%) from a high-DHA, low-EPA tuna fish oil with a ratio of DHA to EPA of 4:1. ^104^ (Summary Table 22)

Jorgensen et al. included 39 formula-fed infants randomized to receive one of the three formulas for at least 3 months: (1) formula with DHA (0.3wt%) and EPA (0.4wt%) derived from fish oil (DHAF group); (2) formula with DHA (0.3wt%) and EPA (0.4wt%) derived from fish oil, and GLA (0.5wt%) derived from borage oil (DHAGF group); and,(3) control formula with no supplemented LCPUFA. The outcomes were the growth patterns at 1, 2, and 4 months of age. ^264^ (Summary Table 23)

Birch et al. enrolled 79 exclusively formula-fed infants and randomized them to receive one of the three formulas from birth to 17 weeks of age. Study diets were Enfamil with iron (control group), Enfamil with iron supplemented with DHA (0.35wt%, DHA group), and Enfamil with iron supplemented with DHA (0.36wt%) and AA (0.72wt%). ^182^ Treatment formulas contained single cell oils, specifically DHASCO® and ARASCO® (Market Biosciences, Columbia, MD). An exclusively breastfed reference group included 29 infants. ^182^ (Summary Table 23)

Willatts et al. randomized English term infants to receive LCPUFA (DHA 0.15–0.25 g/10 g fat + AA 0.30–0.40 g/100 g fat) supplemented formula or standard formula during 4 months. ^223^ The outcome evaluated was the growth patterns at 3 months of age. ^223^ (Summary Table 23)

Makrides et al. conducted a double-blinded RCT of three formula-fed groups and a parallel reference group of breastfed infants. ^205^ The study formulas contained (1) DHA (0.34wt%) and AA (0.34wt%) from egg phospholipid (DHA+AA group, n=28): (2) DHA (0.35wt%) and EPA (0.10wt%) derived from tuna fish oil (DHA group, n=27), and (3) placebo formula (n=28) with no LCPUFA supplementation. Formulas were given to the infants for 12 months. A reference group of 33 breastfed infants was also recruited for the trial. ^205^ (Summary Table 23)

Lucas et al. evaluated the effect of feeding formula supplemented with DHA (0.32wt%), EPA (0.01wt%) and AA (0.30wt%) derived from purified egg phospholipid (LCPUFA group, n=154) compared with unsupplemented formula (control group, n=155) on growth parameters of infants at 18 months of age. ^265^ Randomization of infants took place during the first week after delivery. One hundred and thirty-eight breastfed infants also were recruited as a reference group. ^265^ (Summary Table 23)

Makrides et al. conducted a double-blind RCT of newborn babies allocated to receive formula with an LA/ALA of either 10:1 (16.9/1.7, n=36) or 5:1 (16.3/3.3, n=37) from near birth to 34 weeks of age. ^266^ Increased ALA was attained by replacing soy oil with low-erucic acid canola oil. A parallel group of 103 breastfed infants was also recruited. ^266^ (Summary Table 23)

Lapillone et al.'s group of 24 infants were randomly assigned to received a placebo or a LCPUFA-enriched formula (DHA [0.31wt%], EPA [0.08wt%] and AA [0.03wt%] derived from high DHA/low EPA fish oil, ROPUFA® “30” n-3 INF oil, Roche, Basel, Switzerland) from the third day of life until 4 months of age. ^267^ A non randomized group of 13 breastfed infants was also included. ^267^ (Summary Table 24)

Morris et al. randomized 140 healthy, full-term infants to receive either standard formula milk with no LCPUFA supplements (control group) or milk with added DHA (0.2wt%) and AA (0.4wt%) (trial group). ^268^ Participants remained on these formulas for 12 weeks. Anthropometric measurements were taken at recruitment, 6 weeks, 3 months, 6 months, and 1 year. ^268^ (Summary Table 24)

Auestad et al.'s first trial compared the visual function of healthy term infants exclusively fed (1) formula with either DHA (0.14wt%) and AA (0.45wt%) derived from egg triglycerides, (2) formula with DHA (0.13wt%), EPA (<0.04wt%) and AA (0.46wt%), derived from fish and fungal oils, or (3) formula with no LCPUFAs (control group), from less than 9 days to 12 months. ^227^ (Summary Table 24)

Auestad et al.'s second trial included a sample of healthy term infants who were exclusively breastfed for 3 months and then weaned to formula. ^227^ Infants were randomized to receive a control formula and a DHA +AA supplemented formula derived from egg-triglycerides within 11 days of birth and exclusively breastfed for 3 months. Study formulas were not provided nor fed until after 3 months of exclusive breastfeeding. ^227^ (Summary Table 24)

Birch et al. evaluated the effect of feeding DHA+AA supplemented formula (Enfamil with iron containing DHA [0.36 wt%] and AA [0.72 wt%], derived from single-cell oils, n=32) or unsupplemented formula (control formula, Enfamil with iron, n=33) from week 7 of life to 52 weeks of age, on growth parameters measured at 6, 17, 26, and 52 weeks of age. ^269^ (Summary Table 24)

Hoffman et al. evaluated the effect of feeding previously breastfed infants with DHA+AA supplemented (DHA 0.36 wt%, AA 0.72 wt%) or unsupplemented formula from 4 to 6 months of age (after weaned from breastfeeding) to 12 months of age on growth patterns at 4, 6, 9 and 12 months of age. ^270^ (Summary Table 24)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. All studies were parallel RCTs with at least two groups. All the studies evaluated the effect of omega-3 FA supplementations on infant growth. Auestad et al. also evaluated the effect of maternal breastfeeding together with omega-3 FA supplemented formula intake in term infants on growth pattern. ^227^ Eleven of 18 studies also included a non-randomized group of breastfed infants that served as a reference standard. ^104,^ ^182,^ ^205,^ ^227,^ ^260,^ ^262–267^

The trials were conducted in various countries, with eight undertaken in the U.S., ^104,^ ^182,^ ^203,^ ^227,^ ^260,^ ^269,^ ^270^ three in Australia, ^205,^ ^262,^ ^266^ three in the U.K. ^223,^ ^265,^ ^268^ and one each in Denmark, ^264^ , France, ^267^ and Hungary. ^261^ The only multicenter study was conducted in the U.S. and Canada by Innis et al. ^263^ Ponder et al.'s study was supported by Ross Laboratories, Columbus, OH. ^260^ Decsi et al.'s study was sponsored by Deutsche Forschungsgemeinschaft, Bonn, Germany and Milupa Austria, Puch, Austria. ^261^ Makrides et al. received grants from Channel 7 Children's Medical Research Foundation, Nestle Australia, Scotia Pharmaceuticals, U.K. and the Flinders Medical Center Research Foundation. ^262^ Jensen et al.'s study was financially supported by the U.S. Department of Agriculture, Agricultural Research Service, Mead-Johnson Nutritional Group, The Foundation Fighting Blindness, Research to Prevent Blindness, Inc. and Retina Research Foundation. ^203^ The Innis et al. study was funded by Mead Johnson Research Center, Evansville, IN. ^263^ Auestad et al.'s study was supported by Ross Products Division, Abbott Laboratories. ^104^ Makrides et al.'s was supported by Wyeth Nutritionals International, USA the Australian National Health and Medical Research Council, and the MS McLeod Research Trust. ^266^ The study by Birch et al. was financed by the National Institutes of Health and Mead Johnson Nutritionals Research, Evansville, IN. ^182^ The second Makrides et al. study was funded by Nestec Ltd, Swirzerland and the Australian National Health and Medical Research Council. ^205^ Jorgensen et al.'s study was supported by grants from the Food Technology Research and Development Program (FOTEK), BASF Health and Nutrition, Denmark, and the Swedish Medical Research Council. ^264^ Lucas et al.'s was funded by Nestec Ltd (Switzerland). ^265^ Both of Auestad et al.'s trials were supported by Ross Products Division, Abott Laboratoris, Columbus, OH. ^227^ The Lappilonne et al. study was supported by Bledina sa., Villefranche, France. ^267^ Birch et al. and Hoffman et al. were supported by the NIH. ^269,^ ^270^ Only one trial conducted in U.K. did not provide information concerning its funding source. ^268^ Willatts et al. was supported by Milupa Ltd. ^223^

In general, eight studies were funded by grants only from pharmaceutical companies, ^223,^ ^227,^ ^260,^ ^263,^ ^265,^ ^265,^ ^267^ seven studies were funded by both pharmaceutical and governmental agencies, ^104,^ ^182,^ ^203,^ ^205,^ ^261,^ ^262,^ ^264^ two trials were funded by governmental sources alone, ^269,^ ^270^ and one study was funded partly by private, pharmaceutical and governmental sources. ^266^

The pre-study sample size calculation to reach statistical significance and power was done in nine studies. ^182,^ ^205,^ ^223,^ ^227,^ ^262,^ ^265,^ ^269,^ ^270^

Population characteristics. The total number of enrolled children across the 18 RCTs was not possible to calculate because two investigators ^104,^ ^260^ failed to report this data providing only the number of infants who finished the study. The sample sizes ranged from 22 ^261^ to 447. ^265^

The percentage of male randomized infants was reported in five studies ^205,^ ^264,^ ^265,^ ^269,^ ^323^ and ranged from 42% to 64% of the infant cohort. The male/female ratio was reported in six studies. ^104,^ ^182,^ ^203,^ ^262,^ ^266,^ ^268^ The gender ratio of infants among different diet groups was evenly distributed in all of these studies.

In five studies most of the participants were White, accounting for 75% to 93% of the study population. ^104,^ ^182,^ ^227,^ ^269,^ ^270^ Only one trial reported that Black infants comprised the majority of the study participants. ^203^ Auestad et al.'s racial distribution of infants among the groups was not equal, for example, the breastfed group included significantly more White infants than the placebo group and the treatment groups. ^104^ In two studies, participants were only White. ^205,^ ^266^ No information about the ethic/racial background of participants was provided in the remaining trials.

The inclusion and exclusion criteria were described in twelve studies. ^104,^ ^182,^ ^205,^ ^227,^ ^262–264,^ ^266,^ ^267,^ ^269,^ ^270^ Only inclusion criteria were reported in one study. ^203^ Four studies failed to report either inclusion or exclusion criteria. ^223,^ ^260,^ ^261,^ ^268^ Lapillonne et al. defined maternal cocaine and alcohol abuse history as exclusion criteria. ^267^

The definition of a term infant (at least 37 weeks GA) was described in 11 studies ^104,^ ^223,^ ^227,^ ^260,^ ^262,^ ^263,^ ^265,^ ^266,^ ^269,^ ^270^ The study duration ranged from 8 weeks to 24 months, with a mean interventional length of 27.5 weeks (range 8–52 weeks). Only one trial did not report the length of dietary intervention. ^261^

Different variables were used to demonstrate the family socioconomic status across the studies (i.e., maternal education, paternal education, social score, social status of income earner, marital status). Maternal social status was determined in seven studies, ^205,^ ^227,^ ^262,^ ^265,^ ^268,^ ^270^ whereas, information about maternal and/or paternal education and/or maternal marital status was given in six trials. ^182,^ ^205,^ ^227,^ ^265,^ ^269^ Makrides et al. assessed parental education scores, as well as parental social scores in two randomized study groups. ^266^

There were no differences in sociodemographic variables among the study groups of randomized infants in all of these studies. Mothers of infants in the reference breastfed group had a more prestigious social score, and attained a higher level of education compared with mothers of formula-fed infants. ^205,^ ^227,^ ^262^ Hoffman et al. found that maternal education was better in the LC PUFA supplemented group at baseline. ^270^ There was missing data about maternal smoking history before and during pregnancy in eleven studies. ^104,^ ^182,^ ^203,^ ^223,^ ^262–265,^ ^267,^ ^269,^ ^270^ In studies that reported information about maternal smoking history, there was a tendency for less maternal smoking during pregnancy and/or lactation among the mothers of breastfed infants compared with formula-fed groups. ^205,^ ^227,^ ^266^

Intervention/exposure characteristics. Only four studies reported as part of the protocol that the volume of formula consumed, calculated as the difference in the volume of formula in the bottle at the start and end of the feed, was recorded. ^203,^ ^261,^ ^265,^ ^268^ Nonetheless, most of the authors failed to report the daily amount of formulas consumed by infants in the different feeding groups. Only Decsi et al. reported that daily formula intakes were between 120 mL/kg and 150 mL/kg and did not differ between the feeding groups. ^261^

The duration of formula intake was not reported only in the study of Decsi et al. ^261^ In the remaining trials, the formula intake duration ranged from 8 weeks ^260^ to 12 months. ^104,^ ^205,^ ^227^

The sources of omega-3 FA intervention varied across the 18 RCTs. Six trials described the source as fish oil. ^104,^ ^205,^ ^227,^ ^264,^ ^267^ Makrides et al. supplemented a standard formula with a combination of DHA derived from fish oil and AA derived from primrose oil. ^262^ The specific type of fish from which the fish oil exposures were derived were described in two studies. ^104,^ ^205^ The remaining studies employed either single cell sources of FA, ^182,^ ^268–270^ solely vegetable sources of FA, ^203,^ ^223,^ ^260,^ ^261,^ ^263,^ ^266^ egg phospholipids, ^196,^ ^265^ or at least one of the feeding formulas containing FA from vegetable or egg sources. ^104,^ ^205,^ ^227,^ ^264^ Decsi et al. used a formula enriched with both egg lipids and primrose oil to achieve a higher levels of omega-3 and omega-6 FA. ^261^

In 10 studies, the type of omega-3 FA employed included a combination of DHA and EPA. ^205,^ ^223,^ ^227,^ ^261,^ ^262,^ ^264,^ ^265,^ ^267,^ ^270^ In four trials DHA was used alone; ^104,^ ^182,^ ^268,^ ^269^ ALA was used alone also in four trials. ^203,^ ^260,^ ^263,^ ^266^ Supplementation of formulas with the omega-6 FA AA was reported in seven trials. ^104,^ ^182,^ ^205,^ ^227,^ ^265,^ ^269^

Nine studies failed to report the name of the intervention formulas. ^104,^ ^205,^ ^227,^ ^264–268^ In the rest of the studies, the brands of the employed formulas were: Enfamil (Mead Johnson Nutritionals, Evansville, Ind); ^182,^ ^203,^ ^263,^ ^269,^ ^270^ Similac with iron (Ross Laboratories, Columbus, OH); ^260^ Aptamil (Milupa Ltd.); ^223^ and Pre-Aptamil (Puch/Salzburg, Austria). ^261^ Eight trials indicated the manufacturer of at least one omega-3 FA product used in their study. ^182,^ ^223,^ ^227,^ ^265,^ ^267,^ ^269,^ ^270^ None of the studies reported on the purity of their omega-3 FA exposure.

Study infants were placed on the study formulas within the first week of life in most of the studies. ^104,^ ^182,^ ^205,^ ^223,^ ^260,^ ^261,^ ^265–268^ Study formulas were started within the first month of life in four studies, ^203,^ ^227,^ ^263,^ ^264^ from the beginning of week 7 in the Birch et al. study, ^269^ 1 month after delivery in the study of Jorgensen et al., ^264^ and in the second Auestad et al. trial, infants received the formula after 3 months of being exclusively breastfed. ^227^ One trial failed to report information on the exact time of participants' enrollment into the study. ^262^ Hoffman et al.' infants were breastfed for at least 4 to 6 months and then were randomized to the study formulas until 12 months of age. ^270^

Formula was the only source of alimentation in three studies and no solid foods were introduced during the entire trial period. ^203,^ ^260,^ ^263^ Innis et al. specified that an infant would be withdrawn from the study if more than 10% of dietary energy came from sources other than assigned formula for 5 days or more. ^263^ Decsi et al. permitted fruit juices at 2 months of age and solid food beginning at 3 months of age in both study groups. ^261^ In eight studies, introduction of solid foods was permitted after 4 months of age. ^104,^ ^205,^ ^227,^ ^262,^ ^266,^ ^267,^ ^270^ Both Birch et al. trials did not permit the introduction of any solid food until 17 weeks of age. ^182,^ ^269^ Lucas et al. reported that the mean age of first introduction of any solid food did not differ between those fed LCPUFA and those fed control formula. ^265^ Two trials failed to report if any solid food was permitted at all. ^223,^ ^268^

Information about caloric balance of feeding formulas was reported in seven RCTs. ^104,^ ^182,^ ^227,^ ^265,^ ^269,^ ^270^ Only Auestad et al. mentioned that the study formulas were indistinguishable in appearance and odor. ^227^

Cointervention characteristics. Three studies reported the content of vitamin and mineral supplements of feeding formulas and oils taken by pregnant or lactating women. ^182,^ ^261,^ ^264^ In Ponder et al., no vitamins or mineral supplementations were given to the infants fed formula, whereas, breastfed infants received routine vitamin D supplementation. ^260^ Only Jorgensen et al. reported about the use of preventive measures such as microencapsulation of fish and borage oils and addition of corn starch to avoid oxidation and to allow homogenization with the formula powder. ^264^ Toxicology studies for supplemented oils were done only in one study. ^182^

Outcome characteristics. Nine (of 20) trials evaluated the growth parameters as primary outcomes, ^120,^ ^151,^ ^324–329^ while the remaining 11 trials assessed these outcomes as secondary outcomes. All included RCTs employed the weight, length, and HC of infants as main outcome measures for growth. The rate of gains in weight, length and HC were assessed in three studies. ^261,^ ^264,^ ^266^ Triceps skinfold thickness was measured in five RCTs ^182,^ ^203,^ ^223,^ ^268,^ ^269^ Subscapular skinfold thickness was assessed in five studies. ^182,^ ^203,^ ^265,^ ^268,^ ^269^ Two studies evaluated mid-arm circumference as one of the growth outcomes. ^265,^ ^268^

Study quality and applicability. The 18 RCTs received a mean Jadad total quality score of 3.2, with good internal validity (Summary Matrix 10). Seven trials received a score of 5, ^182,^ ^205,^ ^265,^ ^266,^ ^269,^ ^329^ four received a score of 3, ^104,^ ^223,^ ^268,^ ^270^ four reports received a score of 2, ^203,^ ^262–264^ and three received a score of 1. ^260,^ ^261,^ ^267^ Seven trials failed to report the randomization method, ^125,^ ^324,^ ^325,^ ^328,^ ^330–332^ nine were unblinded, ^125,^ ^324–327,^ ^330,^ ^332–334^ two failed to report the method of double-blinidng, ^328,^ ^331^ and five trials did not describe the reasons for dropouts. ^324,^ ^326,^ ^330–332^

#### Qualitative synthesis of individual study results

The most frequently investigated outcomes across the included studies were infant weight, length, and HC, expressed as mean (SD), normalized z-score or gain over time.

Most of the studies failed to find a statistical difference between groups in the growth patterns at any time point. However, some differences were detected in five trials.

Only the study of Lapillonne et al. found that infants' HC at 4 months in the placebo group was significantly larger than that in both breast and treatment formula groups. ^267^

Infant length and weight were not statistically different among the three feeding groups. ^267^ Makrides et al., who compared growth parameters among three randomized groups, did not find statistically significant differences in weight, length, or HC at any age up to 2 years, even after adjusting for gender, GA, and postnatal age at assessment. ^205^ When growth parameters were compared between the two treatment formula and the breastfed infant groups, investigators found that breastfed babies were significantly shorter and lighter than infants in the DHA+AA and DHA+EPA groups at 34 weeks and 12 months of age. These differences did not reach statistical significance at 2 years of age. ^205^

Decsi et al., who randomized two groups of infants to receive either placebo or treatment formula, did not find a statistically significant difference between the groups regarding gain of weight, length, or HC at 4 months of age. ^261^

The Makrides et at. study, which compared growth parameters in two randomized groups receiving placebo and treatment formulas, did not find any statistically significant difference in weight, length, or HC at 30 weeks of age. ^262^

Three out of four RCTs describing the use of ALA as a source of omega-3 FAs, failed to find any significant difference in growth parameters among the randomized groups receiving either placebo or treatment formula(s). The weight, length, and HC of infants were similar at 4 and 8 weeks of age in the study of Ponder et al., ^260^ at 6, 16, and 34 weeks of age in the study of Makrides et al. ^266^ and at 3 months of age in the Innis et al. study. ^263^ Only one trial showed significantly lower weight at 120 days of age in the group of infants receiving the highest ALA intake, or the lowest LA/ALA ratio (LA [15.6wt%] and ALA [3.2wt%]), compared with the group receiving the lowest ALA, or highest LA/ALA ratio (LA [17.6wt%] and ALA [0.4wt%]). ^203^ These results were obtained after adjusting for differences in birth weight, gender, and ethnicity. In Makrides et al.'s study, where newborn babies were randomized to receive formula with an LA:ALA of either 10:1 or 5:1, there were no significant differences in weight, length, and HC gain between the two groups, although breastfed infants had significantly lower weight and length gain at 16 and 34 weeks of age than infants in the two formula fed groups. ^266^

Other growth outcomes assessed were triceps skinfold thickness, subscapular skinfold thickness, and mid-arm circumference. Five studies did not find a significant difference between groups in triceps skinfold thickness and subscapular skinfold thickness among the randomized study groups at any time point. ^182,^ ^203,^ ^223,^ ^265,^ ^269^ Morris et al. randomized infants to receive either standard formula or the treatment formula with added DHA and found that subscapular skinfold thickness at 6 weeks and 3 months of age was significantly higher in the control group compared with the trial group, althought these differences were not evident at 6 months or at 1 year of age. ^268^

Four studies measured the correlation between the plasma or RBC PUFAs and growth outcomes. ^203,^ ^205,^ ^262,^ ^263^ Two studies did not find a significant correlation between the omega-3 FA in plasma or RBC and the weight. ^203,^ ^262^ However, Jensen et al. observed a significant positive correlation between weight at 4 months and the plasma AA content at the same time. ^203^ Innis et al., on the contrary, did not find a correlation between growth patterns and the plasma and RBC AA content in term infants. ^263^

Makrides et al. found a significantly negative correlation between plasma DHA at 16 weeks and weight at 12 and 24 months of age. ^205^

#### Quantitative synthesis

At 4 months of age, growth pattern outcomes were noted in 13 studies. However, only four studies included treatment groups of both DHA+AA and placebo. ^104,^ ^182,^ ^205,^ ^227^ For Auestad et al.'s first study, ^227^ data on weight, length, and HC could not be extracted; although partially reported in the text for statistically significant differences, the sample sizes were not given, and the weight gains were reported in grams/day. The figure provided growth data by sex at different follow-up times, but no sample sizes were indicated. For the Birch et al. 1998 study, ^182^ standardized weight and length were reported in a boxplot figure using z-scores, thus it was not possible to obtain unstandardized growth measures. This left only two studies for meta-analysis. ^104,^ ^205^ Both trials assessed the growth parameters as primary outcomes.

Figure 7. Child term growth 4 months DHA+AA vs. control

Meta-analysis was performed using the random effects weighted mean difference.

The WMD in the weight (kg) and length (cm) (DHA+AA vs. control) in two studies ^104,^ ^205^ was nonstatistically significant at 4 months. For weight: WMD: -0.06, CI 95%: -0.45; 0.34. For length: WMD: -0.33, CI 95%: -1.07; 0.40.

Figure 8. Meta-analysis: Child term growth 4 months DHA vs. control

Meta-analysis was performed using the random effects weighted mean difference.

The WMD in the weight (kg), length (cm) and HC (cm) (DHA vs. control) in two studies ^104,^ ^205^ was nonstatistically significant at 4 months. For weight: WMD: -0.12, CI 95%: -0.44; 0.20. For length: WMD: -0.43, CI 95%: -1.20; 0.34. For HC: WMD: 0.04, CI 95%: -0.37; 0.46.

Figure 9. Meta-analysis: Child term growth 12 months DHA+AA vs. control

Meta-analysis was performed using the random effects weighted mean difference

The WMD in the weight (kg), length (cm) and HC (cm) (DHA+AA vs. control) in two studies ^104,^ ^205^ was nonstatistically significant at 12 months. For weight: WMD: -0.33, CI 95%: -0.87; 0.21. For length: WMD: -0.37, CI 95%: -1.26; 0.51. For HC: WMD: 0.14, CI 95%: -0.83; 1.12.

Figure 10. Meta-analysis: Child term growth 12 months DHA vs. control

Meta-analysis was performed using the random effects weighted mean difference.

The WMD in the weight (kg), length (cm) and HC (cm) (DHA vs. control) in two studies ^104,^ ^205^ was nonstatistically significant at 12 months. For weight: WMD: -0.33, CI 95%: -0.87; 0.21. For length: WMD: -0.71, CI 95%: -2.18; 0.76. For HC: WMD: -0.04, CI 95%: -0.45; 0.38.

#### Impact of covariates and confounders

In most of the RCTs there was no evidence that randomization failed to produce comparable groups, with the exception of HC. ^268^ In the study of Morris et al., two randomized groups had similar characteristics at recruitment, except for a small difference in mean HC which just reached statistical significance. ^268^ In the study of Jorgensen et al., within the formula groups there was a borderline statistical difference in birth weight in favor of the group supplemented with only DHA. ^264^ Jorgensen et al. ^264^ and Auestad et al. ^227^ also reported that maternal age of infants assigned to breast milk was significantly higher than that in the randomized formula-fed groups. In the study of Auestad et al., infants in the breastfed group also had a higher GA, a smaller percentage of mothers having no postsecondary education, and a smaller prevalence of smoking exposures both in utero and in the houshold. ^227^

Four studies controlled the growth outcomes for potential confounders such as gender, maternal education, center, and socioeconomic status. ^203,^ ^205,^ ^263,^ ^266^ No differences were found after adjusting for these covariates.

The power calculation was reported in eleven trials, ^120,^ ^124,^ ^132,^ ^151,^ ^325,^ ^329,^ ^331,^ ^333–335^ while the intention-to-treat analysis approach was reported in only one study. ^132^

## Growth Pattern Outcomes in Light of Biomarker Data

### What is the Evidence That Term or Preterm Human Infants' Growth Patterns Are Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Child Biomarkers?

A total of 12 studies were identified to address this question. The results of six RCTs of preterm infants were described previously in this section (see key question: Growth Patterns-Preterm Infant Formula Intake), ^185,^ ^191,^ ^201,^ ^207,^ ^212,^ ^225^ as well as the results of four RCTs that included a term population of infants (see key question: Growth Patterns-Term Infant Formula Intake). ^203,^ ^205,^ ^262,^ ^263^ Therefore, two studies will be addressed here—the RCT of Guesnet et al. ^143^ and the prospective single cohort study of Innis et al. ^271^ The studies were published in 1999 and 2001, respectively. A summary of the study characteristics and outcomes relating to the current question are described in this section. (Summary Table 25)

#### Overview of relevant study characteristics and results

Guesnet et al. assessed growth patterns and their correlation with the plasma and RBC PUFA content after the use of three different formulas. Healthy term infants (n=68) were randomized to receive one of three formulas, supplemented with either DHA and EPA (high dose), DHA and EPA (low dose) or unsupplemented, for 6 weeks. ^143^ It also included a group of infants who where breastfed, yet were nonrandomized. The formulas were provided by Gallia 1 (Bledina-sa, Groupe Danone, Villefranche-sur-saone, France). ^143^

This study was conducted in France and supported by the Bledina-sa, Groupe Danon Paris, French Ministry of Cooperation in Mauritius and the University of Mauritius.

Blood samples were collected from umbilical cord at birth and venipuncture at 6 weeks of age. There was no difference between groups in the growth paramenters at 6 weeks of age. ^143^

Innis et al. selected a cohort of 83 term infants who were exclusively breastfed, with birth weights ranging from 2,500 g to 4,500 g. ^271^ The objective of the study was to measure the infant RBC DHA content and its association with visual, neuro or cognitive development. ^271^ Infants were enrolled within 2 weeks of age and to be eligible, their mothers were required to intend to exclusively breastfeed their infant without providing infant formula or cow's milk for at least 3 months and without introducing solid foods for at least the first 4 months after birth. The infants were excluded if they had evidence of metabolic or physical abnormality, or if their mothers had substance abuse, metabolic or physiologic problems, or communicable diseases. ^271^

Only one mother reported taking FA supplements with LA and DHA. The maternal diet was not reported or controlled. Only five mothers reported being smokers during the study. Infant measures of weight, length and HC were correlated with the RBC DHA and AA content at birth, 2, 4, 6, 9 and 12 months of age. ^271^

Multiple linear regression analysis was used to determine the impact of the FA variables on the outcomes. The analysis controlled statistically for the duration of breastfeeding, maternal education, family income, gender, maternal smoking, birth order and birth weight, length and HC. ^271^

Guesnet et al. observed a negative correlation between postnatal gains in length and the EPA concentration at birth in total plasma PL and in RBC PE.

Innis et al. found that the RBC choline phosphoglyceride (CPG) DHA and the ethanolamine phosphoglycerides (EPG) DHA, but not the plasma DHA, were significantly inversely related to infant weight at 6 months of age, but not at 12 months. There was no significant relation between infant blood lipid concentrations of AA and growth at any age. ^271^

Study quality and applicability. Guesnet et al. had a Jadad's total score of 2 (did not report method of randomization and was unblinded) and an unclear allocation concealment. ^143^ Innis et al. had a quality score of 8 and a level of applicability of III. ^271^ (Summary Matrix 11)

## Neurological Development Outcomes

### What is the Evidence That Maternal Intake of Omega-3 Fatty Acids During Pregnancy Influences Neurological Development in Term or Preterm Human Infants?

One RCT, published in 2001, was identified to answer this question. ^141^ Helland et al. had two publications related to the same study population. ^141,^ ^200^ (Summary Table 26)

#### Overview of relevant study characteristics and results

Helland et al., ^141^ has been described in detail in the Pregnancy Outcomes and Growth Pattern Outcomes sections (see key questions: Duration of Gestation, Infants Small for Gestational Age, and Maternal Intake/Growth Patterns). A summary and the results relating to the current question are discussed here.

Helland et al. assessed the gestational length, birth weight, and neurologic and cognitive outcomes in a sample of 590 healthy pregnant women. They were randomized to receive 10 ml of cod liver oil (1,183 mg DHA, 803 mg EPA) or corn oil (LA and ALA) from week 18 of pregnancy to 3 months post delivery. ^141^ They should not have taken any supplements of omega-3 FA earlier during the pregnancy. The exclusion criteria were premature births, birth asphyxia, infections, and anomalies in the infants that required special attention. ^141^ The neurological outcomes assessed was the electroencephalogram (EEG) recordings of the included infants to evaluate brain maturity. EEGs were performed at 1 day of life and repeated at 3 months of age. ^141^ Helland et al. had a high rate of dropouts, leaving 341 women in the final analysis (57%). ^288^

There were no differences between groups in maturity as evaluated from the EEGs, neither at day 1 of life nor at 3 months of age. ^141^

Between neonates with mature (score 1; n=70) and immature EEG scores (score 2 and 3; n=51), there were significant differences in umbilical plasma phospholipid levels of EPA, DPA and DHA at the 2^nd^ day of life. At 3 months, there were no significant differences in plasma phospholipid levels between those with mature and immature EEGs. ^141^

Study quality and applicability. Helland et al. received a Jadad total quality score of 4 (did not report method of double-blinding), indicating good internal validity. However, the allocation concealment was unclear. The applicability was scored with III, since the Norwegian population has a significantly higher intake of LCPUFA from marine sources compared to the Nort American population.

### What is the Evidence That the Omega-3 Fatty Acid Content of Maternal Breast Milk, With or Without Known Maternal Intake of Omega-3 Fatty Acids, Influences Neurological Development in Term or Preterm Human Infants?

One RCT and one single prospective cohort study were identified. ^138,^ ^284^ They were published between 1997 and 2001. (Summary Table 27)

#### Overview of relevant study characteristics and results

Gibson et al. was a double-blind RCT that investigated the effect of maternal intake of omega-3 FAs on breastfed infant's neurological and visual function outcomes in Australia. ^138^ This study included mothers of term infants (>37 weeks of GA) who intended to breast feed for at least 12 weeks (n=52, means age: 30 [SD=4] years). These mothers were randomized to receive one of five doses of a DHA-rich algal oil (0, 0.2, 0.4, 0.9, 1.3 g DHA/day; DHASCO, Market Biosciences, MD, U.S.) between day 5 and week 12 postpartum. The oil contained 43% DHA, 1% omega-6 PUFA, 38% saturates and 18% monosaturates. Infants who were exclusively breastfed for 12 weeks were assessed. Infants (n=20) were healthy, appropriate weight for GA, and had Apgar scores greater than 7 at 5 minutes. ^138^

Infant's visual function was assessed using visual evoked potentials (VEP) (logMAR) at 12 and 16 weeks of life. ^138^ Global development (Bayley's Scales of Infant development) was assessed at 1 and 2 years of age. From Bayley Scales of Infant Development, the psychomotor developmental index (PDI) was derived. PDI assesses the control of gross and fine muscle groups, including walking, running, jumping, comprehension, use of writing implements, and imitation of hand movements. Mothers were from middle class families and completed year 12 of education. The five groups were compared in terms of maternal age, maternal BMI, GA, infant gender, birth weight, birth length, birth HC, Apgar score, siblings, maternal social score, smoking, education, home stimulation, and length of breast feeding, at baseline. There was a predominance of boys in the group that received the highest dose of DHA. ^138^

Agostoni et al. evaluated the neurodevelopmental indices at 1 year of age in a single prospective cohort of term infants (n=44; 54.5% males) who were exclusively breastfed for at least 3 months in Italy. ^284^ The children received breast milk for at least 3 months, after which weaning foods were introduced to all infants. Infants underwent clinical examination at 0, 1, 3, 6, 9 and 12 months of age. ^284^

The mother's milk lipid composition was determined at each time-point. The day before, the control pooled milk was collected from all feedings over 24 hours. There was a progressive reduction of the number of breastfed infants to n=29 at 6 months, n=17 at 9 months and n=10 at 1 year. ^284^

The mean PDI score was similar in infants between dietary groups at 1 and 2 years of age in Gibson et al. study. ^138^ There were no associations with any sociodemographic variables at 1 year. The only association at 2 years of age was between PDI and the level of education of the partner (r ^ 2 ^=0.10; adjusted r ^ 2 ^=0.08, p<0.05). ^138^

In Agostoni et al., the mean PDI in 1-year old infants, was 92 (SD=11.3). ^284^ After correcting for potential confounders such us parity and mother's characteristics (i.e., age, education, smoking habits), breast feeding for 6 months or longer was not significantly correlated to the mean PDI result compared with subjects breastfed for 3 to 6 months (n=15). ^284^ Associations between PDI and milk fat content and composition were measured with a multiple regression analysis. There was no correlation between PDI and the milk fat content at any time-point. ^284^

Study quality and applicability. Gibson et al. obtained a Jadad total quality score of 3 (did not report methods of randomization and double-blinding), indicating sound internal validity. ^336^ However, the allocation concealment was unclear. The applicability level was II for Gibson et al. and III for Agostoni et al. ^337^

### What is the Evidence That the Omega-3 Fatty Acid Content of Infant Formula Influences Neurological Development in Term or Preterm Human Infants?

### What is the Evidence That the Omega-3 Fatty Acid Content of Maternal Breast Milk, With or Without Known Maternal Intake of Omega-3 Fatty Acids, and Together With the Omega-3 Fatty Acid Content of Infant Formula, Influences Neurological Development in Term or Preterm Human Infants?

### Infant Formula Intake—Preterm Infants

Six RCTs, published between 1999 and 2004, met eligibility criteria. ^193,^ ^207,^ ^254,^ ^258,^ ^272,^ ^273^ Five trials were summarized in the Growth Pattern Outcomes section (see key question: Growth Patterns-Preterm Infants Formula Intake). ^310,^ ^311,^ ^319,^ ^321,^ ^322^ (Summary Table 28)

#### Overview of relevant studies

van Wezel-Meijler et al. studied the influence of supplemented formula with DHA and AA on brain maturation in preterm infants and investigated parameters of functional brain development, including cognitive development. ^272^ (Summary Table 36)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. Six parallel RCTs involving preterm infants were identified to address these questions. ^193,^ ^207,^ ^254^ ^258,^ ^272,^ ^273^ Five of the studies were published in English scientific journals, while one was published as an abstract. ^193^ Bougle et al.'s study was conducted in France, ^254^ both Fewtrell et al.'s studies were conducted in the U.K., ^258,^ ^273^ the van Wezel-Meijler et al. study was located in the Netherlands, ^272^ Clandinin et al.'s study was conducted in Canada, ^193^ and the O'Connor et al. study took place in the United States, United Kingdom and Chile. ^207^

Three studies involved three study arms comparing the use of supplemented and unsupplemented infant formula with the addition of a fourth reference standard group (i.e., human milk). ^193,^ ^207,^ ^254^ Two RCTs compared only two study groups (i.e., formula with or without LCPUFA), ^258,^ ^272^ whereas, another study also included a group using human milk as a reference standard. ^273^

van Wezel-Meijler et al. ^272^ and Fewtrell et al. (2002) ^273^ were supported by a private source (Numico Research). Clandinin et al. was funded by Mead Johnson & Company (pharmaceutical-nutritional company), ^193^ whereas, Fewtrell et al. (2004) ^258^ was supported by H.J. Heinz Company (food company). O'Connor et al. and Bougle et al. did not report their funding source. ^207,^ ^254^

Population characteristics. There were 1,228 preterm infants enrolled across the included studies that were randomized to receive the supplemented or control formulas. The sample sizes ranged from 25 to 470 participants. The mean age of the infants at randomization was not significantly different between study groups across five RCTs. ^207,^ ^254,^ ^258,^ ^272,^ ^273^ Clandinin et al. did not report the age of their infants. ^193^ The GA of the preterm infants was below 37 weeks across five studies, ^207,^ ^254,^ ^258,^ ^272,^ ^273^ except for Clandinin et al. that also included VLBW term infants. ^193^ The between-group difference in GA was not significant across the studies.

In four studies, the proportion of male participants did not differ significantly between randomized groups, ^207,^ ^258,^ ^272,^ ^273^ although two studies did not mention this information in their report. ^193,^ ^254^ The range of males varied between 35% ^272^ to 56%. ^207^

O'Connor et al. was the only one to describe the racial composition of their participants, which was predominantly White. ^207^ The rest of the studies failed to provide the race and/or ethnicity of their subjects.

Other variables like birth weight, proportion of SGA infants, percentage from multiple pregnancies, and Apgar score at birth, were nonstatistically different between groups in O'Connor et al. ^207^ van Wezel-Meijler et al. matched their population by birth weight and proportion of SGA at baseline. ^272^ Infants in both of Fewtrell et al.'s studies were well matched by birth weight and length, proportion of SGA, proportion from multiple pregnancies, and delivery by C-section at baseline. ^258,^ ^273^

Three of six studies analyzed the between-group difference of maternal covariates. O'Connor et al. matched their study groups by maternal age, education, smoking status during pregnancy and in the home, prenatal care, the HOME inventory score and maternal intelligence measured with WAIS-R Raw vocabulary score. ^207^ The HOME Inventory Score was statistically different depending of the birth weight group—in infants <1,250 g, the control group had a higher score than infants in the AA+DHA (fish/fungal) group and in infants >1,250 g, the control group had a higher score than the AA+DHA (egg-TG/fish) group. Finally, the infants with a birth weight higher than 1,250 g in the AA+DHA (fish/fungal) group had a higher score than those in the AA+ DHA (egg-TG/fish) group. ^207^

The inclusion criteria were described in every included study, however, exclusion criteria were not reported in two studies. ^193,^ ^273^

The studies included mostly healthy preterm infants with a defined range of weight drawn from neonatal intensive care units (NICU). Bougle et al. included healthy preterm infants (<34 weeks GA) free of respiratory, metabolic or neurological disease. ^254^ O'Connor et al. selected preterm infants (<33 weeks GA) with a birth weight ranging from 750 g to 1,805 g, including singleton and twin births as well as SGA subjects, that could initiate enteral feeding by the 28^th^ day of life. ^207^ van Wezel-Meijler et al. included premature infants (<34 weeks GA) with birth weight of <1,750 g, normal neurological examination throughout the neonatal period, normal repeated brain ultrasound or showing minor abnormalities such as isolated subependymal haemorrhage and subventricle, with no ventricular dilation, transient periventricular echodensities, without evolution into cysts or any combination of previous findings. ^272^ Infants in the Fewtrell et al. (2002) trial had a GA below 37 weeks and a birth weight of <1,750 g, were free of congenital malformations known to affect neurodevelopment, and whose mothers decided not to breastfeed at 10 days of age. ^273^ Fewtrell et al.'s (2004) preterm infants (GA <35 weeks) with birth weight ≤2,000 g received at least one of their enteral feeds as formula milk during their hospital stay. ^258^ On the other hand, Clandinin et al. included VLBW term and preterm infants after their feeding reached 30 mL/kg/day. ^193^

Three studies excluded infants with serious congenial abnormalities affecting growth and development, major surgery before randomization, perivenricular or intraventricular hemorrhage, maternal incapacity, liquid ventilation asphyxia resulting in severe and permanent neurologic damage, or uncontrolled systemic infection at the time of enrollment. ^207,^ ^258,^ ^272^

The baseline characteristics of the patients in the Bougle et al. study were nonstatistically significant for the electrophysiological studies (i.e., motor and sensory nerve conduction studies, auditory evoked potentials). ^254^

Only three trials measured the blood content of FAs at baseline. ^207,^ ^272^ O'Connor et al. found a nonsignificant difference between groups in the plasma or RBC (lipid fractions) levels of AA and DHA. ^207^ van Wezel-Meijler et al. observed the same finding. ^272^ Bougle et al.'s plasma phospolipid composition of EPA was significantly lower in the low LCPUFA supplemented formula than in the DHA/EPA/AA supplemented formula and human milk. ^254^ However, the RBC content of omega-3 and omega-6 did not differ between groups. The Bougle et al. study was the only one to describe the FA content in human milk i.e., 0.5% (SD 0.1) total FA DHA and ALA (omega-3) plus 0.9% (SD 0.2) total FA AA. ^254^

None of the studies reported the presence of concurrent conditions in the study population and/or the use of medications. However, van Wezel-Meijler et al. reported that 13 patients were excluded from the analyses for the following reasons: necrotizing enterocolitis (n=2, 1 each group); chronic lung disease (n=3; n=2 DHA-AA vs n=1 control); grade 4 retinopathy of prematurity (n=1 AA+DHA); cystic periventricular leucomalacia (n=1 control); and, duration of artificial ventilation at baseline. ^272^ No differences were found between groups. ^272^ None of the studies included information regarding maternal concurrent conditions, medications or background diet, that could be relevant for the infants consuming breast milk.

No other pre-study medications or treatments were mentioned in the included studies. The infants in the O'Connor et al. study were formula and/or human milk fed before study entry, ^207^ whereas, van Wezel-Meijler et al.'s infants received parenteral nutrition using glucose/Vaminolact 6.75%/Intralipid 20% (Kabi-Fresenius, Stockohlm, Sweden) for an average of 12 to 17 days, from 24 hours after birth. ^272^ This parenteral nutrition contained negligible amounts of LCPUFA. Three to 7 days after birth, enteral feeding was introduced using preterm formula (without LCPUFA). Total enteral nutrition was usually achieved within 2 to 3 weeks after birth. ^272^

Intervention/exposure characteristics. The intervention groups in each trial received different types of supplemented infant formula, therefore, each study will be discussed separately.

Bougle et al.'s small sample were randomized to receive a formula with 17.7% total FA of LA (omega-6), AA (0.1%), ALA (omega-3: 1.2%), EPA (0.1%) and DHA (0.6%), for at least 30 days. ^254^

O'Connor et al. randomized their participants to receive one of three study formulas with or without the addition of LCPUFA until term CA. The intra-hospital preterm formula was a modified version of Similac Special Care ready-to-feed (Ross Products Division, Columbus, OH, U.S.) with or without AA- and DHA-enriched oils. At term CA, postdischarge nutrient-enriched formula (modified version of NeoSure powder) with and without the same sources of AA+DHA and/or human milk was given to the infants until 12 months CA. ^207^ The first group received a supplemented formula with fungal and low-EPA fish oil (DHA/EPA ratio: 3.5/1) providing 0.27 g DHA, 0.08 g EPA and 0.43 g AA (per 100 mL) in the Similac Special Care formula and 0.16 g DHA and 0.43 g AA in the NeoSure formula. In the other group, egg-tryglyceride (TG) and low-EPA fish oil provided 0.24 g DHA and 0.41 g AA to the Similac formula, but 0.15 g DHA to NeoSure. The purveyors of the fish, fungal and egg-TG oils were Mochida International (Japan), Suntory Ltd. (Japan) and Eastman Chemicals Co (U.S.), respectively. The duration of the treatment was until 12 months CA. ^207^

In van Wezel-Meijler et al., the neonates were randomized to receive preterm liquid formula supplemented with (4.4 g/100mL fat) a 2/1 ratio of DHA (0.015 g/100mL [0.34% fat]) as DHASCO® oil produced by microalgae (Martek Inc., Columbia, U.S.) and AA (0.031 g/100 mL [0.68% fat] as ARASCO® oil produced by fungi (Martek Inc.). The formula was continued from enrollment until a weight of 3000 g was reached. Subsequently, this group continued with a supplemented term formula (3.5 g/100 mL fat) with a reduced absolute amount of DHA (0.012 g/100 mL; 0.34% fat) and AA (0.025 g/100 mL; 0.70 % fat) until 6 months CA. ^272^

Fewtrell et al. used a LCPUFA-supplemented preterm formula (n=95) (Prematil, Milupan) with fat blended from vegetable oils (palm coconut, soya, sunflower) and milk fat with derivates of LA and ALA sourced from evening primrose oil (GLA) and egg-lipids (AA [0.31 g/100 mL, DHA [017 g/100 mL], EPA [0.04 g/100mL]). Formula was provided as a ready-to-feed form for a mean of 31 days until neonatal unit care discharge. ^273^

Clandinin et al. included two interventional groups. The first group (DAS group) received 17 mg DHA plus 34 mg AA/100 Kcal from single cell oils (SCO) (n=72) as preterm formula (24 Kcal oz), discharge formula (22 Kcal oz) and term formula (20 Kcal oz). The second group (DAF group) received the same formula as the DAS group but with 17 mg DHA/100 Kcal from fish oil and 34 mg AA/100 Kcal from single cell oils (n=90). ^193^

Fewtrell et al.'s study 2004 study used a preterm infant formula supplemented with LCPUFA (OsterPrem with LCPUFA) until the infants were discharged from the NICU. Afterwards, a nutrient-enriched postdischarge formula was used (Farley's PremCare with LCPUFA). The fat was a blend of vegetable oils (high oleic sunflower oil, palmolein, palm kernel oil, and canola oil). LCPUFAs were sourced from borage (starflower) oil (GLA [omega-6] 0.9 g/100 mL) and tuna fish oil (high DHA/EPA ratio: DHA 0.5 g/100 mL, EPA 0.1 g/100 mL, AA: 0.04 g/100 mL). Formula was provided in ready-to-feed form during the hospital stay and in powdered form after discharge up to 9 months after CA. ^258^

The studies compared the interventional formulas with unsupplemented infant formulas that were identical in appearance and smell, ^258,^ ^273^ contained the same proportion of monosaturated and saturated FAs, and given to the infants during the same period of time as the intervention group. Bougle et al. compared the supplemented formula with a LA (omega-6) and ALA (omega-3) enriched formula. ^254^

The studies did not provide information regarding background diet, when introduced, and the purity data the omega-3 supplements. No study report included details as to whether, or how, the presence of methylmercury was tested for, or eliminated from, the omega-3 FA exposure.

Cointervention characteristics. Human milk was the reference standard group, either as a separate arm ^193,^ ^258,^ ^273^ or as part of the formula groups that did not comply with the intervention. ^207^ Bougle et al permitted the use of supplements, which contained dextrines, proteins and minerals during the study period. The patients received daily supplementation with 1,200 IU of vitamin D and 4.5 mg of vitamin E (Uvesterol ADEC). ^254^ Infant preterm and term formulas in the O'Connor et al. study contained beta-carotene and natural vitamin E. ^207^ Participants in both of Fewtrell et al.'s studies received an identical proportion of minerals and vitamins (A,D,E,K) in their formulas. ^258,^ ^273^

Outcome characteristics. Only one study performed electrophysiological studies at baseline and after treatment. ^254^ This study measured the latencies of auditory evoked potentials (BAEP test), motor and sensory nerve conduction studies on the posterior tibial nerve and the flexor hallucis brevis muscle. ^254^

The Bayley's PDI was assessed in five of six studies. ^193,^ ^207,^ ^258,^ ^272,^ ^273^ O'Connor et al.'s average percent of agreement on scoring between site testers and central testers was 93% (range: 73%-100%). ^207^

The first Fewtrell et al. study utilized the Knobloch, Passamanick and Sherrard's Developmental Screening Inventory (five subscales: adaptative, gross motor, fine motor, language and personal-social) to assess neurodevelopment at 9 months, as well as neurologic impairement at 9 and 18 months of followup (diagnosed by examining pediatrician). ^273^

Study quality and applicability. Five RCTs received a mean Jadad total quality score of 4.2, indicating a good internal validity (Summary Matrix 6). One abstract was not assessed. ^311^ Three trials received a score of 5, ^258,^ ^272,^ ^273^ Bougle et al. and O'Connor et al. each received a score of 3. ^207,^ ^254^ Bougle et al. failed to report the method of randomization and double-blinding, ^319^ while O'Connor et al. was unblinded. ^310^

#### Qualitative synthesis of individual study results

The latencies of auditory evoked potentials (i.e., Wave I, Wave III, Wave V and I-V interpeak latency) difference between day 0 and day 30 were not significant in the study of Bougle et al. ^254^ The change in the motor nerve conduction test (m/s) was significantly higher in the group receiving the DHA/EPA/AA-supplemented formula and in the human milk groups, from day 0 to day 30. However, the change in the sensory test (m/s) was nonsignificant during the same period. ^254^

Five studies evaluated Bayley's PDI after the administration of supplemented formula, unsupplemented formula, and/or human milk only (reference standard). ^193,^ ^207,^ ^258,^ ^272,^ ^273^ In O'Connor et al., a statistically significant feeding by birth weight stratum interaction was observed for Bayley PDI (p=0.005) among infants who consumed >80% of their feeding as study formula and/or human milk. ^207^

van Wezel-Meijler et al. observed a statistically significant higher PDI score for the unsupplemented group compared with supplemented formula group, at 3, 6, 12 and 24 months. ^272^ The first Fewtrell et al. study did not find a statistical difference between formula groups at 18 months. Although the human milk group was not randomized, since it was used as reference standard, the PDI was significantly higher in the breastfed group compared with both formula groups. ^273^

Clandinin et al., using ANOVA analysis, found that the control group had a significantly lower PDI score than the formula groups (DAS, DAF) and the human milk group (reference standard). ^193^ The second Fewtrell et al. study showed that there was a nonstatistical diference in Bayley's PDI scores between formula groups at 18 months. ^258^

Fewtrell et al. found that The Knobloch, Passamanick and Sherrard's Developmental Screening Inventory scores (quotient) at 9 months did not differ significantly between the formula groups, whereas, the breastfed group had a significantly higher quotient compared with the formula groups. ^273^ This study also failed to find a difference in neurological impairment between formula groups, at 9 and 18 months of followup. ^273^

Bougle et al.'s cohort of healthy preterm infants had seven dropouts during the study. The main reasons were NEC (n=1) in the human milk group, hydrocephalus in the control formula group (n=5), and transfer to their referring hospital (n=3 human milk group, n=1 control, n=1 supplemented formula group). ^254^

O'Connor et al.'s had 94 withdrawals (80%) at 12 months CA. ^207^ There was no statistical difference in the number of withdrawals between groups. The main reason for withdrawals was symptoms related to feeding intolerance. During the study 6 infants in the control group, 3 in the AA+DHA (fish/fungal) group, 6 in the AA+ DHA (egg-TG/fish) group, and none in the human milk groups, died. None of the infant deaths were related to study feedings. ^207^

There were 13 dropouts in the van Wezel-Meijler et al. study. ^272^ Reasons for withdrawal were: necrotizing enterocolitis; chronic lung disease; grade 4 retinopathy of prematurity; cystic periventricular leucomalacia; change from formula feeding to mother's expressed milk; and, home-to-hospital distance. There were no losses to followup. ^272^

In the first Fewtrell et al. study, six patients randomized to the control formula withdrew from the trial before 3 weeks for the following reasons: early discharge (<3 weeks of age; n=3); necrotizing enterocolitis (n=1); intolerance of feeds (n=1); and, breastfed (n=1). ^273^ Fourteen infants withdrew in the supplemented formula group. Reasons for withdrawal were: early discharge (n=2); necrotizing enterocolitis (n=5); maternal concern (n=2); and, death(n=2). ^273^ There were 14 lost to follow up at 9 months in the control group, whereas, only one infant withdrew in the supplemented formula group and three in the human milk group. There were two deaths in the supplemented formula group and three in the human milk group. ^273^ Clandinin et al. failed to report the dropouts. ^193^ Fewtrell et al.'s reasons for dropouts were: in the control group—abdominal distention (n=1); death due to bronchopulmonary dysplasia at 25 days of age (n=1); and lost to follow up at 18 months (n=21). ^258^ In the supplemented formula group, the reasons for dropouts were: necrotizing enterocolitis (n=1); and, lost to follow up at 18 months (n=15). ^258^

#### Quantitative synthesis

The inclusion criteria for meta-analysis in this population were: 1. Formula with same content of omega-3 FA supplements (e.g., DHA+ AA or DHA alone) compared with a control formula without omega-3 FA; 2. same outcome measure; 3. same follow-up period or timepoint of outcome measure; 4. at least two trials. Only five studies measured the Bayley's Developmental Index (PDI). This outcome was chosen to evaluate the possibility of meta-analysis. However, outcome results were only available for more than one study at two follow-up times: CA 12 months and 18 months. At 12 months CA, outcomes were available for two studies. ^207,^ ^272^ In Wezel-Meijler et al., ^272^ the experimental group received supplemented formula from the first enteral feeding time until 6 months CA. In O'Connor et al., ^207^ however, supplemented formula was used until 12 months CA. We would have combined data at 6 months follow-up, however, this data was not available in O'Connor et al. ^207^ Thus, meta-analysis was not possible for this outcome.

#### Impact of covariates and confounders

O'Connor et al.'s Bayley's PDI score in <1,250 g birth weight infants who strictly followed the feeding protocol was greater in infants fed AA+DHA (egg-TG/fish) than control infants, even after adjusting for a number of covariates including the HOME inventory, maternal WAIS-R, and human milk intake. ^207^ The score did not differ statistically from either the control or AA+DHA (fish/fungal) groups. In an ITT and subgroup population analysis, the percentage of participants who had a significantly delayed motor performance did not differ statistically by study formula group. ^207^

In van Wezel-Meijler et al., after adjusting for birth weight and number of SGA infants, there was no difference in PDI between the groups. ^272^

To explore the possible influence of maturity on the response to LCPUFA supplementation, the first Fewtrell et al. study stratified the cohort by GA (<30 weeks). Infants who had a GA <30 weeks and received LCPUFA supplemented formula, had a Bayley PDI of 5.8 points higher than the control group, although the difference was nonsignificant. ^273^ There were no differences in Bayleys PDI between supplemented and control groups with a GA >30 weeks. ^273^ In this study, there was no significant interaction between formula and duration or volume of formula consumed on later outcome. At 18 months of age, breastfed infants had a significantly higher PDI score than formula groups. This result persisted after adjusting for effect modifiers (social class, level of maternal education, birth order and marital status). ^273^

The second Fewtrell et al. study did not find a significant difference between groups when the PDI scores were adjusted by gender, GA and birth weight. ^258^

The remaining studies did not report on the control for effect modifiers.

The power calculation was reported in three trials, ^310,^ ^321,^ ^322^ while the intention-to-treat analysis approach was reported in both Fewtrell et al.'s trials. ^321,^ ^322^

### Infant Formula Intake—Term Infants

Eight unique parallel design RCTs met eligibility criteria. These trials were published between 1995 and 2003. Seven trials were described in the Growth Pattern Outcomes section (see key question: Growth Patterns-Term Infant Formula Intake). ^124,^ ^132,^ ^151,^ ^325,^ ^327,^ ^329^ (Summary Tables 29–30)

#### Overview of relevant studies

All of the included studies evaluated the influence of supplemental omega-3 FA intake on neurological function of term infants. All but two studies—Birch et al. ^182^ and Jensen et al., ^203^ —included a non-randomized group of breastfed infants that served as a reference standard. Agostoni et al. randomized Italian healthy term infants to receive LCPUFA-(AA+DHA+EPA) supplemented formula or a control formula. The main outcomes were the Brunet-Lézine test (Italian edition) of the graded psychomotor developmental test at 4 months, and the FA composition of venous blood (plasma and RBC PL composition). ^176^ (Summary Table 29)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. All studies were parallel RCTs with at least two arms. Countries where the studies were conducted included the United States, ^104,^ ^182,^ ^203,^ ^227^ Italy, ^176^ Australia, ^205^ and the U.K. ^265^

Agostoni et al. did not report their funding source. ^176^ Auestad et al.'s ^104^ study was supported by Ross Products Division, Abott Laboratoris, Columbus, OH and the U.S. Maternal and Child Health Bereau, Rockville, MD. Lucas et al.'s study was funded by Nestec Ltd (Switzerland). ^265^ The study of Birch et al. was supported by an NIH grant and Mead Johnson Nutritional Center (Evansville, IN). ^183^ Makrides et al.'s study was sponsored by Nestec Ltd (Switzerland), the MS McLeod Research Trust and the Australian National Health and Medical Research Council. ^205^ Both of Auestad et al.'s trials were supported by Ross Products Division, Abott Laboratoris, Columbus, OH. ^227^ The study of Jensen et al. was sponsored by federal funds from the U.S. Department of Agriculture, Agricultural Research Service. ^203^

Population characteristics. Maternal and infant characteristics were analyzed separately. Across the seven RCTs, sample sizes ranged from 60 ^176^ to 447 ^265^ infants. The maternal sample size was provided in only one study. ^265^

The definition of a term infant (at least 37 weeks GA) was described in seven studies. ^104,^ ^176,^ ^182,^ ^205,^ ^227,^ ^265^

Of eight RCTs, the mean GA of randomized infants was reported in six studies and ranged from 39 to 40.3 weeks). ^176,^ ^203,^ ^205,^ ^227^ The percentage of males of randomized infants was reported in five studies and ranged from 46.4% to 52.5% of infants. ^176,^ ^182,^ ^205,^ ^227^

The gender ratio of the infants, among the different diet groups, was evenly distributed in four studies; ^176,^ ^182,^ ^227^ however, in the study of Makrides et al., there was a tendency for proportionally more boys to be enrolled in the group that received the highest dose of DHA. ^205^

The mean age of the infant's mothers across the eight trials was impossible to determine given that the full sample size was not reported in four of the trials. ^104,^ ^182,^ ^203,^ ^205^ Excluding the studies failing to report the mean maternal age, the mean age of participants in the other four studies ranged from 27.0 (SD=5.12) to 32.4 (SD=5.7) years. ^176,^ ^227,^ ^265^ Auestad et al. did not report the age, gender distribution, or racial/ethnic background of either participating women or their children. ^104^

Four studies failed to report the racial/ethnic background of the trial population, ^176,^ ^203,^ ^205,^ ^265^ In four studies, most of the participants were White, accounting for 68.4% to 90.2% of the study population and the distribution of race/ethnicity between the study groups of randomized infants was closely matched ^104,^ ^182,^ ^227^ Different variables were used to demonstrate family sociodemographic status in these studies (i.e., parental education, social score, smoking, marital status, birth order, number of siblings, HOME screening questionnaire score). ^104,^ ^182,^ ^227^

Maternal social status was reported in five studies, ^182,^ ^205,^ ^227,^ ^265^ as well as information about maternal and/or paternal education and/or maternal marital status. There were no differences in sociodemographic variables among the study groups of randomized infants in all these studies.

Five studies failed to provide the maternal smoking history before and during pregnancy. ^104,^ ^176,^ ^182,^ ^203,^ ^265^ The studies that provided information about maternal smoking history, there was a tendency for less maternal smoking during pregnancy among the breastfed infants compared with the formula-fed groups. ^205,^ ^227^

The inclusion/exclusion criteria were described in four of eight studies. ^104,^ ^205,^ ^227^ Only exclusion criteria were reported in two studies. ^104,^ ^265^ All the studies included only healthy term infants.

Intervention/exposure characteristics. Lucas et al. reported that by the protocol, the volume of formula consumed, calculated as the difference in amounts in the bottle at the start and end of the feed, was recorded. ^265^

The duration of formula feeding was reported in all studies and ranged from 3 months ^203^ to 12 months. ^104,^ ^205,^ ^227^ Three studies ^104,^ ^227^ failed to report the name of the infant formulas. Seven trials reported the manufacturer of the omega-3 FA intervention. ^176,^ ^182,^ ^203,^ ^205,^ ^265^ Agostoni et al. used Aptamil with Milupan supplied by Milupa od Friedrichsdorf, Germany. ^176^ Lucas et al. ^265^ and Makrides et al. ^205^ used Nestec formula (Nestec Ltd, Switzerland), and both Birch et al. ^182^ and Jensen et al. ^203^ administered Enfamil, by Mead Johnson Nutritional Center (Evansville, IN). Both Auestad et al. trials used fish oil provided by Mochida International Co, Ltd, Tokyo, Japan and fungal oil by Suntory Ltd., Osaka, Japan; egg-derived trigycerides was provided by Eastman Chemical Co, Kingsport, TN. ^227^

The duration of the intervention in children in four studies ^104,^ ^205,^ ^227^ was 12 months, at least 6 months in Lucas et al., ^265^ and 4 months in three studies. ^176,^ ^182,^ ^203^

In many of the studies, information regarding the time of introduction of solid food, caloric composition of formulas, source of omega-3 FA, micronutrient and vitamin content of formulas as well as presence of omega-3 FA stabilizing antioxidants, and attempts to deodorize any odor, were not clearly reported. Only five studies reported about the time of solid food introduction. ^104,^ ^182,^ ^227,^ ^265^ All the Auestad et al. studies permitted solid foods in all study groups beginning at 4 months of age. ^104,^ ^227^ Birch et al. did not introduce any solid food until 17 weeks of age. ^182^ Lucas et al. reported that the mean age of first introduction of any solid food did not differ between those fed LCPUFA and control formula (12.5 [SD=0.4] vs 11.8 [SD=0.4] weeks). ^265^ Information about caloric balance of feeding formulas was reported in five RCTs. ^176,^ ^182,^ ^227,^ ^265^ Infant formulas provided 670 kcal/L, 2805kJ/L and 670 to 694 kcal/L energy, respectively.

The source of omega-3 FA varied across the trials. Agostoni et al.'s fat blend was derived from palm oil, coconut and palm kernel fats, soybean oil, sunflower oil (parents PUFA), evening primrose oil (GLA) and egg lipids (LCPUFA PL and TGL). ^176^ The content of AA was 0.44 g/100 g fat; EPA 0.05 g and DHA 0.30 g. ^176^ However, the control formula also contained LA (omega-6) and GLA (omega-6). ^176^ Auestad et al. ^104^ described the source of DHA as fish oil in one of the formulas (DHA group) and the source of DHA and AA as egg-derived phospholipids in another formula (DHA+AA group). Not only the sources but the content of the omega-3 FAs were different in this trial: the DHA group contained 0.2wt% of DHA, while the DHA+AA group contained 0.12wt% DHA and 0.43wt% AA. ^104^ Lucas et al. reported the source of LCPUFAs as egg-derived phospholipids and triglyceride fractions (0.32wt% DHA, 0.3wt% AA and 0.01wt% EPA). ^265^

Birch et al. compared two DHA-supplemented (0.35wt% DHA) and DHA+AA-supplemented formulas (0.36wt% DHA and 0.72wt% AA), containing single-cell oils (DHASCO® and ARASCO®; Market Biosciences, Columbia, MD, USA) with a control, LCPUFA-unsupplemented formula. ^183^ Makrides et al.'s study formula contained either no LCPUFAs (placebo) or 0.35wt% DHA from tuna oil or 0.34wt% DHA and 0.34% AA from egg phospholipids fraction. ^205^

The first Auestad et al. trial ^227^ randomized infants to receive a control formula or one of two formulas supplemented with DHA and AA: 1) fish oil and fungal oil containing DHA (0.13wt%), AA (0.46wt%) and EPA (0.04wt%) or 2) egg-derived triglyceride, containing DHA (0.14wt%) and AA (0.45wt%). Only this study mentioned that study formulas were indistinguishable in appearance and odor. ^227^ The second Auestad et al. trial ^227^ randomized the breastfed infants to receive a control formula or the AA+DHA (egg-TG) formula for 12 months. The infants were allowed water ad libitum, solid foods after 4 months and alternate formulas for up to 5 days. ^227^

Jensen et al. randomly and blindly assigned each infant to receive one of four formulas from birth to 120 days of age. ^203^ There were no significant differences among formulas in the content of FAs other than ALA, which ranged from 0.4wt% to 3.2wt%. The LA:ALA ratio ranged from 44 to 4.8. No information was provided by the investigators regarding the delivery method of omega-3 FA exposure or attempts to deodorize the oil supplements.

Cointervention characteristics. Only one study ^265^ reported the content of vitamin and mineral supplements of feeding formulas and oils taken by women. No studies reported the pre-study or on-study medication use by either pregnant or breast feeding mothers or infants.

Outcome characteristics. The most frequently employed outcome assessing infants neurological development was the Bayley Scales of Infant Development, from which were derived a PDI. Two trials ^104,^ ^205^ used Bayley I Scales (1^st^ edition) and five studies employed Bayley II Scales (2^nd^ edition). ^182,^ ^203,^ ^227,^ ^265^ Lucas et al. ^265^ administered two tests to assess infant neurological development: as a primary outcome measure they used Bayley Scales, 2^nd^ edition and as a secondary outcome measure-Knobloch, Passamanik and Sherrards Developmental Screening Inventory at 9 months. The latter test comprises of five scales: adaptive, gross motor, fine motor, language, and personal-social. Agostoni et al. used the Italian edition of the graded psychomotor developmental test by O. Brunet and I. Lezine for French children to rate the global neurodevelopment at 4 and 24 months of age. It explores four developmental areas: posture and gross notor function, adaptation and fine motor function, social reactions and language. This test was statistically validated. ^176^

As for infants neurological development outcome assessment four studies evaluated these indices at 12 months ^203,^ ^227,^ ^327^ , two studies at 18 months, ^182,^ ^265^ whereas in two other studies the assessment has been done at 12 and 24 months. ^205^

Study quality and applicability. The eight RCTs received a mean Jadad total quality score of 4.25, indicating a good internal validity (Summary Matrix 15). Five trials received a score of 5, ^124,^ ^205,^ ^265,^ ^329^ Agostoni et al. received a score of 4, ^176^ Auestad et al. received a score of 3, ^104^ and Jensen et al. received a score of 2. ^203^ Jensen et al. failed to report the method of randomization, ^325^ Auestad et al. 1997 was unblinded, ^327^ and Agostoni et al. did not report the method of double-blinding. ^134^

#### Qualitative synthesis of individual study results

All but one study addressing the issue of child neurological development used Bayley's Developmental Scales (PDI) as a primary outcome measure. ^104,^ ^182,^ ^203,^ ^205,^ ^227,^ ^265^ The included studies did not find a statistically significant difference in PDI between the formula groups at 6, 12, 18 and 24 months of age. Makrides et al. (1997) reported a nonsignificantly difference among the 3 formula arms, ^327^ however when we compared the scores (PDI) between the DHA+AA group versus control formula (see Figure 11 below) the score was favouring significantly the control group. Lucas et al. did not find a significant difference in Bayley PDI at 18 months or in Klobloch, Passamanick and Sherrard's test performance at 9 months between control and LCPUFA groups. ^265^ Birch et al. also measured the developmental ages on the cognitive, language and motor subscales. ^182^ The cognitive and motor subscales were significantly poorer in the control group compared with both supplemented formula groups (DHA+AA and DHA). ^182^ No significant differences were found among diet groups on the language subscale. ^182^ The Behavioral Rating Scale (BRS) did not differ significantly among diet groups at 18 months of age. ^182^ Both of the Auestad et al. trials, with and without human milk, failed to find a significant difference in the BRS among diet groups at 6 and 12 months of age. ^227^

Jensen et al found a statistically significant difference among the study groups in gross motor developmental quotient (GM DQ) index at 12 months of age. ^203^ Group 1 (i.e., lowest ALA intake) and Group 3 (LA/ALA ratio 9.7) had significantly lower mean GM DQ than Group 2 (LA/ALA ratio 18.2) and Group 3 (LA/ALA ratio 4.8). ^203^

Agostoni et al. found that the Brunet Lezine test DQ was significantly higher in the supplemented group compared with the control group at 4 months of age; the difference was, however, not statistically significant at 24 months. ^176^

Four investigators tried to find a correlation between different covariates as well as plasma and/or RBC phospholipid content of omega-3 and omeda-6 LCPUFAs and each neurodevelopmental index. ^176,^ ^182,^ ^203,^ ^205^ Agostoni et al. found that the RBC DHA content at 4 months was positively correlated with the DQ at 4 months but not at 24 months. ^176^

Birch et al. found that PDI and BRS scores at 18 months of age were not significantly correlated with plasma or RBC LA, ALA, AA, EPA, or DHA at 4 months or at 12 months of age. ^182^ The PDI score was negatively correlated with VEP acuity at 4 months of age, i.e. better visual acuity was associated with a better PDI score. ^182^ There was no significant correlation between PDI score at 18 months and FPL acuity at 4 months of age. ^182^ PDI score at 18 months was not correlated with normalized height, weight, or weight-for-length z scores at 4 months.

Jensen et al. found a positive correlation between both PDI and GM DQ scores and the plasma, but not the RBC, phospholipid content of DHA at 120 days of age. ^203^

In the study performed by Makrides et al., the only FA variable to significantly influence the PDI was plasma AA at 1 year of age. ^205^ The same study established significant environmental variables that influenced PDI scores at 1 year—i.e., the assessor, maternal education, number of siblings, and the infant's age at testing. HC, number of siblings, and maternal smoking predicted PDI at 2 years of age, and PDI at 1 year was correlated with PDI at 2 years. ^205^

#### Quantitative synthesis

The outcome measure selected to conduct meta-analysis was the Bayley's Developmental Index at 4 and 12 months of age. All the infants that were followed-up at 12 months, were exclusively breastfed until 4 months of age. At 12 months, outcomes were noted in three studies that were using the same comparators—DHA+AA versus unsupplemented formula. ^104,^ ^205,^ ^227^

Figure 11. Bayley's Developmental Index (PDI)

Meta-analysis was performed using the random effects weighted mean difference (WMD).

The WMD in the Bayley's PDI score at 12 months was nonstatistically significant (WMD: -2.80, CI 95%: -7.43; 1.82). ^104,^ ^205,^ ^227^

#### Impact of covariates and confounders

Most of the RCTs did not reveal enough evidence regarding the comparability of the study groups in terms of infant gender, ethnic/racial distribution, birth characteristics, parental socioeconomic background, education or maternal and/or paternal smoking. Only one study failed to report the baseline characteristics of randomized groups so it was impossible to estimate the impact of potential covariates and confounders on the study results. ^182^ Differences in some characteristics at enrollment were noted between breastfed and formula fed infant groups only.

In the Makrides et al. study, breastfed infants had parents who were less likely to smoke, had attained a higher level of education and had more prestigious social scores compared with formula fed infants. ^205^ Bayley's PDI scores at 12 and 24 months were adjusted for different covariates. The only variables that significantly influenced (regression model) the PDI scores at 12 months were the assessor, maternal education, number of siblings and the infant's age at testing. At 24 months, HC, number of siblings and maternal smoking predicted the PDI. ^205^ Auestad et al. ^227^ reported that maternal age and GA in a breastfed infant group were significantly higher than that in the randomized formula-fed groups. In the same study, infants assigned to breast milk also had a significantly smaller percentage of mothers having no postsecondary education and smaller prevalence of smoking exposures both in utero and in the household. ^227^ In Lucas et al., the results were unaffected when Bayley's score was adjusted for center or observer. ^265^

Jensen et al. used a multiple regression model to adjust the scores for effect modifiers such as birth weight, weight at 120 days of age, chronological age on the assessment day. ^203^ However, none of these variables seemed to affect the results.

The power calculation was reported in seven trials, ^124,^ ^132,^ ^134,^ ^151,^ ^325,^ ^329^ while the intention-to-treat analysis approach was reported in only one study. ^132^

## Neurological Development Outcomes in Light of Biomarker Data

### What is the Evidence That Term or Preterm Human Infants' Neurological Development is Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Maternal Biomarkers During Pregnancy?

One cross-sectional study was identified to answer this question. Cheruku et al. was conducted in the United States and founded by the National Institutes of Health, the US Department of Agriculture, the Donaghue Medical Research Foundation, and the University of Conneticut Research Foundation. ^274^ This study was published in 2002. ^274^ (Summary Table 31)

#### Overview of relevant study characteristics and results

Cheruku et al. assessed the association between the content of LCPUFA in maternal blood and the Central Nervous System (CNS) integrity of their newborns. ^274^

Healthy pregnant women (n=17) were included after their admission for delivery. The exclusion criteria were: women with a history of chronic hypertension, hyperlipidemia, renal or liver disease, heart disease, thyroid disorders, multiple gestations, pregnancy-induced complications (e.g., hypertension, preterm labor, or premature rupture of membranes), treatment during labor with drugs that affect respiration of newborns, or any infant with lower than 4 hours of crib time in the first and second days postpartum. ^274^

The maternal blood samples to measure the plasma FA content were taken at delivery. The CNS integrity was measured using the Motility Monitoring System to record the sleep patterns (i.e., quiet sleep, active sleep, sleep-wake transition, wakefulness, time spent out of the crib) on postpartum day 1 and postpartum day 2. ^274^ Infant sleep patterns are an expression of central integrative control. Multiple mechanisms involving both neural and humoral processes in various regions of the brain interact to produce sleep and wakefulness. Changes in the sleep architecture may be associated with neurologic changes during development and that deviant sleep patterns may be associated with neuroogic deficits. ^338^

Regression analysis used to describe the associations of maternal plasma PL FA concentrations with infant sleep and wake states indicated that, among the omega-6 and omega-3 LCPUFAs, only the omega-3 FAs specially DHA, and the n-6:n-3 ratio showed strong correlations on both postpartum days 1 and 2. ^274^ The following correlations were the most significant among all the statistically significant correlations for this population. On postpartum day 2, maternal DHA was negatively associated with active sleep (AS), AS:QS (quiet sleep) and sleep-wake transition, and positively associated with wakefulness. ^274^ On postpartum day 2, the ratio of n-6:n-3 LCPUFAs in maternal plasma was positively associated with AS, AS:QS and sleep-wake transition and negatively associated to wakefulness. ^274^

On postpartum day 1, the ratio of n-6:n-3 LCPUFAs in maternal plasma was negatively associated with QS and positively associated with arousals in QS.

When the cohort was analyzed by maternal DHA plasma concentration, the high DHA group (>3.0% by wt of total FAs) did not differ significantly from the low DHA group (≤3.0% by wt of total FAs) in terms of maternal age, race, parity, duration of gestation, maternal education, infant birth weight and length, infant HC and Apgar score at 1 and 5 minutes. ^274^ However, infants from mother with high DHA concentrations had significantly less AS and had a lower AS:QS compared with infants of mothers with low DHA concentrations. Furthermore, infants in the high DHA group had significantly less sleep-wake transition and more wakefulness than did infants in the low DHA group on postpartum day 2. ^274^

Study quality and applicability. The quality score was 6 and the applicability level was III.

### What is the Evidence That Term or Preterm Human Infants' Neurological Development is Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Child Biomarkers?

Five studies were identified to answer this question, including four RCTs that were described in the Growth Pattern Outcomes and Neurological Development Outcomes sections (see key questions: Growth Patterns & Neurological Development-Term Infant Formula Intake), ^176,^ ^182,^ ^203,^ ^205^ and a prospective single cohort study published in 2001. ^271^ (Summary Table 32)

#### Overview of relevant study characteristics and results

Innis et al. selected a cohort of 83 Canadian term infants who were exclusively breastfed, with birth weights in the range of 2,500 g to 4,500 g. ^271^ The objective of the study was to measure the infant RBC DHA content and its association with the visual, neurological or cognitive development. ^271^

Innis et al. was funded by the Medical Research Council (MRC) of Canada and Ross Laboratories, OH. ^271^

The infants were enrolled within 2 weeks of age and to be eligible, their mothers were required to intend to breastfeed their infant without providing infant formula or cow's milk for at least 3 months and without introducing solid foods for at least the first 4 months after birth. The infants were excluded if their mothers had substance abuse, metabolic or physiologic problems, communicable diseases, and infants with evidence of metabolic or physical abnormality. ^271^

Only one mother was taking FA supplements with LA and DHA. The maternal diet was not reported or controlled. Only five mothers were smokers during the study. ^271^

The outcome assessed included the Bayley's PDI at 6 and 12 months and its correlation with the RBC DHA and AA content in infants.

Multiple linear regression analysis was used to determine the impact of the FA variables on the outcomes. The analysis controlled statistically for the duration of breast-feeding, maternal education, family income, gender, maternal smoking, birth order and birth weight, length and HC.

No statistically significant relation was found between the infant DHA or AA status (RBC) at 2 months of age and the Bayley's PDI score at 6 and 12 months of age. ^271^

There were 31 dropouts at 12 months due to different reasons, like lost to follow up, fed with formula before 3 months of age, or lack of blood samples.

Study quality and applicability. This study had a quality score of 8 and a level of applicability of II.

## Visual Function Outcomes

### What is the Evidence That Maternal Intake of Omega-3 Fatty Acids During Pregnancy Influences Visual Function in Term or Preterm Human Infants?

#### Overview of relevant study characteristics and results

One double-blinded RCT ^235^ and one cross-sectional study ^275^ evaluated the influence of maternal intake of omega-3 FAs during pregnancy on the visual function. The RCT was conducted in the United Kingdom and was funded by the Scottish Office Health Dept. ^235^ The cross-sectional study was conducted in Cuba and was funded by Canadian International Development Agency. ^275^ (Summary Table 33)

Malcolm et al. ^235^ investigated the photoreceptor function of healthy term infants (mean 279.7 [SD:9.5] days; males 52%) at approximately 1 week of age, whose mothers (ages 17–36 years) received fish oil capsule supplements from a mean of 15.4 wk gestation until delivery (Marinol D40, 100 mg DHA per capsule, R.P. Scherer Ltd, Swindon, UK) compared with infants (279.6 [SD:8.5] days; males 37.9%) whose mothers received sunflower oil capsules from the same time point. Women were excluded if they had had a twin pregnancy, placental abruption, postpartum hemorrhage, allergy to fish products, a thrombophilic tendency, or receiving drugs affecting thrombocyte function. Healthy full-term infants with an Apgar score above 7 and with no visual, medical or developmental disorders were included. The tests used to measure photoreceptor function were intensity-series electroretinogram (ERG) (rod photoreceptor function) and standard maximum combined ERG (mixed rod and cone function). In addition, the b wave amplitudes were fitted to the Naka-Rushton function as another assessment of rod photoreceptor function and the derived log δ was used as a measure of retinal sensitivity. ^235^

Malcolm et al. showed that maternal fish oil supplementation during pregnancy, from a mean of 15.4 weeks gestation to delivery, had no significant effect on retinal function (rod photoreceptor function, rod and cone photoreceptor function, or retinal sensitivity) assessed within the first week of life in healthy term infants. ^235^ There were no differences between the fish oil and placebo groups in the maternal self-selected diets, fish intake, or consumption of DHA-containing dietary supplements at study entry, or in the time period between study entry and delivery (assessed by interview at 15 and 28 weeks gestation, and at delivery).

In addition, the groups did not differ significantly in age, previous obstetric history, socioeconomic status, smoking habits, alcohol intake and exercise patterns. Satisfactory intensity-series ERGs were recorded in 41/60 infants (fish oil, n=22, placebo, n=19), and maximum combined ERGs were recorded in 44/60 infants (fish oil, n=25, placebo, n=19). Regardless of mother's supplementation group, significant correlations were found between retinal sensitivity and cord RBC levels of DHA, AA, omega-6/omega-3 FA and total omega-3 FAs. ^235^

Krasevec et al. evaluated the visual acuity in 2-month old term infants (mean age:40.4 [SD:1.5] weeks; males NR) born to Cuban mothers (mean age 26.8 [SD:4.0] years) who had received a high fat fish diet during pregnancy and breast feeding. ^275^ Included were pregnant women with a history of normal pregnancy, no medical risks affecting FA metabolism (i.e. heart, kidney, hypertensive, gallbladder, or thyroid diseases and gestational or other diabetes), resident of Havana, and a range of age from 17 to 36 years; exclusion criteria were not reported for the mothers. Neither inclusion or exclusion criteria were reported for the infants. ^275^

All Cubans received 227 g of a high fat fish every week through the ration system before and during pregnancy, and a higher amount during breast feeding. Infants were exclusively breastfed (55%), fed a combination breastmilk and bottle-feeding (39%), or not fed any breastmilk (5%). Supplemental milks were fed for an average of 2 to 4 weeks before the 2-month study. Binocular visual acuity was assessed at 2 months of age using the Teller Acuity Cards with acceptable reliability.

Krasevec et al. ^275^ observed that there were no significant correlations between visual acuity and any individual PUFA concentration, ratio of PUFA concentrations or concentrations of groups of PUFAs in the infants' plasma and RBCs, in term infants born to Cuban women who received high fat fish during pregnancy and breast feeding. Fatty acid composition was analyzed in 31/56 infants's plasma and 33/56 infants' RBCs. Infant RBC PUFA contents were compared with values reported in the literature without statistical evaluation. Visual acuity was tested in 54/56 infants. The visual acuity scores for all tested infants were within the 99% prediction limits for 2.5 month old infants. The group mean visual acuity score was within a range of data obtained from full-term, normally developing infants. Mean values for visual acuity were not significantly different between the exclusively breastfed or not exclusively breastfed infants.

Study quality and applicability. Malcom et al.'s Jadad total quality score was 3 (failed to report methods of randomization and double-blinding), indicating a good internal validity. ^235^ The allocation concealment was unclear. Krasevec et al. quality score was of 7.

### What is the Evidence That the Omega-3 Fatty Acid Content of Maternal Breast Milk, With or Without Known Maternal Intake of Omega-3 Fatty Acids, Influences Visual Function in Term or Preterm Human Infants?

Two RCTs and two observational studies published from 1997 to 2001 met eligibility criteria regarding the influence of maternal breast milk intake in term infants. ^138,^ ^140,^ ^248,^ ^276^ Krasevec et al. ^275^ also addressed the issue of maternal intake during breastfeeding and visual function in term infants, and is fully described above (see key question: Maternal Intake/Visual Function). ^275^ No reports were identified in the preterm population. (Summary Table 34, 35)

#### Overview of relevant study characteristics and results

Gibson et al. was a double-blind RCT that investigated the maternal intake effect on breastfed infant's neurological and visual function outcomes in Australia. ^138^ This study included mothers of term infants (>37 weeks of GA) who intended to breast feed for at least 12 weeks (n=52, means age: 30 [SD=4] years). These mothers were randomized to receive one of five doses (0, 0.2, 0.4, 0.9, or 1.3 g DHA/day) of a DHA-rich algal oil (DHASCO, Market Biosciences, MD, US) between day 5 and week 12 postpartum. The oil contained 43% DHA, 1% omega-6 PUFA, 38% saturates and 18% monosaturates. Infants who were exclusively breastfed for 12 weeks were assessed. Infants (n=20) were healthy, appropriate weight for GA, Apgar scores greater than 7 at 5 minutes. ^138^

Infant's visual function using VEP (logMAR) was assessed at 12 and 16 weeks of life, and for global development (Bayley's Scales of Infant development) at 1 and 2 years of age. Mothers were from middle class families and completed year 12 education. The five groups were compared in terms of maternal age, maternal BMI, GA, infant's gender, birth weight, birth length, birth HC, Apgar score, siblings, maternal social score, smoking, education, home stimulation, and length of breast feeding, at baseline. There was a predominance of boys in the group that received the highest dose of DHA. ^138^

Jensen et al. investigated the effect of DHA supplementation in lactating women on the visual function and growth of their infants. ^248^

Mothers were randomaly assigned to receive 200 to 250 mg DHA per day as either algal DHA (n=42), refined high-DHA fish oil (n=42) or placebo (n=42), for 120 days after delivery. Infant characteristics, as well as the maternal characteristics, were not described in this abstract. ^248^

Jorgensen et al. investigated, in a cross-sectional study, whether the variation in milk DHA content between Danish mothers is large enough to cause differences in visual acuity in their healthy term 4-month-old infants, and to evaluate the influence of frequency of fish intake on the DHA level of milk. ^140^ The study included term infants (GA 37–42 weeks) with normal birth weight for GA; uncomplicated pregnancy, delivery, and neonatal period; Apgar score > 8 after 5 minutes; fully breastfed at the time of the examination (i.e., no energy drinks and < 100 mL of formula per day). Infants were excluded if they were SGA (< 10^th^ PC of birth weight), had strabismus, or operation of pyloric stenosis. Seventy infants were enrolled, of which 39 completed the study (mean age: 17.4 [SD=0.7] months; 51% males). ^140^ The study was conducted in Denmark and was supported by the Danish Research and Development Programme for Food Technology (FOTEK), and BASF Health and Nutrition A/S. ^140^

The study by Williams et al. was a population-based cohort study that compared the stereoacuity at age 3.5 years in healthy term children who were breastfed with similar children who had not been breastfed after adjustement for socioeconomic status and maternal diet. ^276^ The study included a random selected subset of children born in the last 6 months of the Avon Longitudinal Study of Pregnancy and Childhood (ALSPAC) enrollment period.

The ALSPAC was a prospective population birth cohorth study. ^339^ Infants were excluded if they had strabismus, reduced vision, high refractive error, preterm infants (GA <37 weeks). ^276^ Williams et al. enrolled 641 children aged a mean of 43.2 (SD=0.6) months (i.e., 3.5 years), of which 435 completed the study period (52.1% males). ^276^ The study was based in the United Kingdom, and was funded by the Medical Reseach Council, the Wellcome Trust, Ministry of Agriculture, Foods and Fisheries, the Departments of Health and Enviroment, the South West Regional Health Authority, the National Eye Research Centre, Cow and Gate, and Milupa. ^276^

Jorgensen et al.'s infants were exclusively breastfed until 14 weeks of age. The median DHA content of the milk was 0.31 wt% of total FAs (range: 0.12–1.20 wt%), AA was 0.30 (SD=0.07) wt% and the content of EPA was 0.39 (SD=0.07) wt%. The study described the details regarding the maternal age, weight gain during pregnancy, Apgar score at 5 minutes, gender, GA, birth weight, length at birth and HC, as well as growth parameters at the time of the examination. ^140^ Jorgensen et al.' mothers did not take any fish oil supplements regularly, however one of the ninemothers that ate fish the day before the milk sample was taken, ate lean fish while the remaining ate fatty fish. ^140^ Outcomes measures were visual acuity, using VEP acuity (expressed in LogMar) in the 4-month infants, and the correlation with the LCPUFA content of maternal breast milk and/or maternal fish intake. ^140^

Williams et al. used different questionnaires to collect information related to the infant's feeding practices from 4 weeks to 6 months of age and at 36 months (3.5 years), as well as other information like socioeconomic status, smoking status, and housing. ^276^ During the study period, no formula milks supplemented with DHA were commercially available in the United Kingdom. ^276^ This study did not report the DHA/AA/EPA FA content in human milk. Williams et al. measured the stereoacuity (peripheral or poor; macular or moderate; foveal or adult) in the 3.5 year-old children. They also measured the possible correlation with the percentage of DHA content of the maternal RBC PL during pregnancy, as well as with the mother's intake of fish oil. ^276^

Both Jorgensen et al.'s and Williams et al.'s studies collected the maternal diet intake using a food-frequency questionnaire, including questions regarding fish intake. ^140,^ ^276^

Gibson et al.'s VEP acuity did not differ significantly between the dietary DHA groups at either 12 or 16 weeks of age, although numbers were limited in each treatment group. VEP acuity (n=19) significantly improved with age (0.83 [SD=0.13 logMAR at 12 weeks vs. 0.73 [SD=0.09] log MAR at 16 weeks, p<0.01). There was no association between VEP acuity and the level of DHA in the breast milk, infant plasma or RBC as well as with any socio-demographic variables. ^138^

Jensen et al. failed to find a statistical difference among groups in VEP latency, sweep VEP acuity or Teller Card acuity at 120 or 240 days of age in term infants. However, transient VEP amplitude was lower in infants of mothers who received the algal DHA supplement than infants in the other two groups at 120 days but not at 240 days of age. There were no significant correlations betweeb the visual function and the milk DHA or infant plasma PL DHA content at 120 days of age. ^248^

Jorgensen et al. observed a significant association between visual acuity of the infant at 4 months of age and the mother's milk DHA. ^140^ , controlling for intake of fatty fish the day before sampling. The visual acuity of infants of mothers who ate fish the day before sampling did not differ from the rest of the group. Neither did AA, EPA, LA and ALA (omega-3) correlate with visual acuity, nor did any of the antropometric data (i.e., GA or age at examination). No association was found between educational level of the mother and visual acuity or educational level and milk DHA. ^140^ In a general linear model, including frequency of consumption of lean and fatty fish, and fatty fish intake the day before sampling, all three variables were associated positively with milk DHA. ^140^

Williams et al., in an univariate analysis, found that breast feeding, greater maternal age, and consumption of oily fish by the mother antenatally or by the child up to the age of 3.5 years were all associated with an increased likelihood of the child having foveal (adult) stereacuity. ^276^ As these variables were interrelated, a multiple logistic regression analysis was used to determine which factors might be independently associated with the child's stereoacuity. The variable most associated with an increased likelihood of foveal as opposed to worse-than-foveal stereoacuity was breast feeding. ^276^ This result was consistent even when it was stratified by age (< or >4 months), compared with a diet without breast milk. A second variable was the mother's intake of oily fish. The mothers who ate oily fish at least once every 2 weeks during pregnancy were more likely to have children who achieved foveal stereoacuity than were the mothers who never ate oily fish (adjusted OR: 1.57; 95%CI: 1.00–2.45). There was no statistical evidence of interaction between the effects on stereoacuity and whether or not the mother ate oily fish, or for breast feeding compared with formula feeding. When only the children whose mothers never breastfed (n=101) were selected, foveal stereoacuity in the children (n=20) was still more likely if the mothers ate oily fish during pregnancy than if they did not, however, the difference was not significant. The correlation between maternal age and children eating oily fish did not reach statistical significance using the multiple regression model. ^276^ There was a correlation between the child's stereoacuity and the antenatal mother's RBC DHA content.

None of the RCTs reported the power calculation or intention-to-treat approach. ^336,^ ^340^

Study quality and applicability. Gibson et al. had a total quality score of 3 (did not report the randomization and double-blind method), indicating a good internal validity. ^336^ However, Jensen et al. could not be assessed given it was an abstract. ^340^ The allocation concealment was unclear in both. The observational studies had a mean quality score of 9.

### What is the Evidence That the Omega-3 Fatty Acid Content of Infant Formula Influences Visual Function in Term or Preterm Human Infants?

### What is the Evidence That the Omega-3 Fatty Acid Content of Maternal Breast Milk, With or Without Known Maternal Intake of Omega-3 Fatty Acids, and Together with the Omega-3 Fatty Acid Content of Infant Formula, Influences Visual Function in Term or Preterm Human Infants?

### Infant Formula Intake - Preterm Infants

Nine unique studies met the eligibility criteria in investigating the effect of omega-3 FAs on visual function in preterm infants. All these studies were parallel design RCTs published between 1992 and 2003. All the studies were summarized in the Growth Pattern Outcomes and Neurological Development Outcomes sections (see key questions Growth Patterns & Neurological Development-Preterm Infant Formula Intake). (Summary Tables 36, 37)

#### Overview of relevant studies

All the included studies evaluated the influence of intake of infant formula, supplemented with omega-3 FAs on visual function (i.e., visual acuity, retinal development, visual behavior and attention) in preterm infants. The effect on visual function in the groups receiving omega-3 FA-supplemented formulas, were compared with the effect in the groups (control) receiving standard infant formulas (without omega-3 FA supplementation) and/or human milk. In five of the nine studies, visual function measured in infants receiving formulas with or without omega-3 FA supplementation was compared with visual function in infants receiving breast milk. ^198,^ ^207,^ ^212,^ ^251,^ ^254^ In all these studies, the breastfed arms were non-randomized and served as reference groups.

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. All nine studies had at least two randomized groups. Three studies involved three randomized groups. ^201,^ ^207,^ ^212^ Of the nine trials, five used non-randomized groups of infants receiving human milk (reference standard). ^198,^ ^207,^ ^212,^ ^251,^ ^254^

The trials had been conducted in the following countries: the United States, ^185,^ ^191,^ ^212^ the Netherlands, ^272^ France, ^254^ Italy, ^198^ and Germany. ^251^ Two trials ^201,^ ^207^ were conducted multinationally in different centers in the United States, United Kingdom, and Chile, ^207^ and in Canada and United States. ^207^ The Birch et al. study was funded by National Eye Institute, National Institute of Child Health and Development, United Cerebral Palsy Research Foundation, and Pediatric Subunit United States Public Health Service grants. ^212^ The Carlson et al. study was supported by National Eye Institute and Ross Laboratories, Columbus, OH. ^185^ Koletzko et al. was funded by Deutsche Forschungsgemeinschaft and Milupa AG, Germany. ^251^ Carlson et al. was supported by National Eye Institute, Ross Products Division, National Institute of Child Health and Development, and Abbott Laboratories. ^191^ O'Connor et al. was supported by Ross Products Division and Abbott Labs. ^207^ van Wezel-Meijler et al. was funded by Numico Research. ^272^ Innis et al. was supported by Mead Johnson Nutritionals. ^201^ Faldella et al.and Bougle et al. did not report their funding source. ^198,^ ^254^

Population characteristics. The total number of enrolled infants, including reference non-randomized breastfed infants, across the nine trials was 1,171 with a range from 27 ^251^ to 470 ^207^ infants.

All nine trials reported the infants' study arm-specific means of GA. The range of study arm-specific mean GA across all trials was 27.0 ^191^ to 33.9 weeks. ^254^ In all nine trials, the GA was relatively evenly distributed amongst the study arms. Four studies did not report the percentage of males (or females) across study groups (randomized as well as reference/breastfed). ^198,^ ^212,^ ^251,^ ^254^ The total percentage of males across the remaining five studies was from 35.5% ^272^ to 53.4%. ^207^ In four studies, the percentage of male infants across the randomized groups was similar. One study failed to report the study arm-specific distribution of sex. ^191^

Racial/ethnical composition was reported only in three studies, ^185,^ ^191,^ ^207^ of which two reported arm-specific percentages of White/Black ^185^ and White/Black/Hispanic/Other infants. ^207^ The race distribution across the randomized groups in these studies was more or less balanced. The remaining one trial reported the race percentage (%White/Black) of the total study sample. ^191^ In two studies by Carlson et al., the majority of participants belonged to the Black race. ^185,^ ^191^ All studies reported the birth weight of the infants.

Six studies reported ranges of birth weight for the entire sample, as well as the arm-specific means of birth weight. ^185,^ ^201,^ ^207,^ ^212,^ ^251,^ ^272^ Two studies reported only arm-specific means of birth weight. ^198,^ ^254^ Birth weight, across the majority of the studies ranged from 750 to 1,850 grams. ^185,^ ^201,^ ^207,^ ^212,^ ^251,^ ^272^ In six studies, birth weight was similarly and evenly distributed across the randomized study arms. ^185,^ ^201,^ ^207,^ ^212,^ ^251,^ ^272^

Of the nine studies, six described both the inclusion and exclusion criteria with enough detail. ^185,^ ^201,^ ^207,^ ^212,^ ^251,^ ^272^ Two trials reported only inclusion or exclusion criteria. ^191,^ ^254^ One trial reported neither inclusion nor exclusion criteria. ^198^

The infants in most of these studies were healthy preterm infants (< 37 weeks GA), free of respiratory or neurological disease, able to receive enteral feeding, had no severe intrauterine growth retardation, and did not require long-term mechanical ventilation or gastrointestinal surgery after birth. The studies excluded infants with risk factors for visual development, congenital abnormalities, retinopathy (> stage 2), intraventricular or periventricular hemorrhage (> grade 2), metabolic abnormalities, or history of maternal drug abuse. The study sample of one trial consisted of 49% infants suffering from bronchopulmonary dysplasia. ^191^

Only three studies reported parental education. ^185,^ ^191,^ ^207^ O'Connor et al. presented only maternal education (in years and earned degrees). ^207^ In this study, randomized formula groups had similar mean duration of maternal education. However, the breastfed arm had a higher mean maternal education compared with the formula groups (breastfed group:15.1 years vs. formula groups:12.9, 13.1, and 12.8 years). In two other trials, years of parental (mother's and father's) education were balanced across the randomized study arms, ^185,^ ^191^ and the number of years of education in these trials ranged from 11.4 to 12.2. Only one study reported percentage of maternal smoking during pregnancy. ^207^ The formula (randomized) groups had strikingly high rates of maternal smoking during pregnancy compared with the breastfed group (formula groups: 28%, 25.4%, 29.3% vs. breastfed group: 4.7%).

Intervention/exposure characteristics. In all nine trials, the study intervention was the assignment of dietary standard infant formulas (preterm/term) with or without the supplemental omega-3 and/or omega-6 LCPUFAs. In six trials, breast milk was the study exposure aside from the randomly assigned intervention (infant formula: with or without the supplementation of omega-3 and/or omega-6 LCPUFA). ^198,^ ^201,^ ^207,^ ^212,^ ^251,^ ^254^

Some of these studies defined breastfed infants as those whose dietary intake of human milk accounted for 75% to 85% of their total dietary intake. ^198,^ ^201,^ ^207,^ ^212^ The amount/content (i.e., mean g/100 g, % of total FAs), type (i.e., ALA, LA, DHA, AA, EPA), and source (i.e., egg-TG, corn-, soy-, marine-, fish-, and/or fungal-oil) of omega-3 and/or omega-6 LCPUFA supplementation differed slightly across the studies. The formula content of DHA supplementation in the experimental arms across the trials ranged from 0.14% ^201^ to 0.60%. ^254^ For the majority of trials, the content of DHA supplementation was confined between 0.20% and 0.35% inclusively. ^185,^ ^191,^ ^198,^ ^207,^ ^212,^ ^251^

Of the nine studies, two did not report the formula content/amount (%) of EPA supplementation in the experimental arms. ^201,^ ^272^ Across the remaining seven trials, the formula content/amount (%) of EPA supplementation in the experimental arms, ranged from 0.03% ^251^ to 0.65%. ^212^ Mostly, the EPA formula content was confined between 0.03% to 0.1%. ^191,^ ^198,^ ^207,^ ^251,^ ^254^

The formula content/amount (%) of ALA supplementation in the experimental arms was reported in seven trials, ^185,^ ^191,^ ^198,^ ^207,^ ^212,^ ^251,^ ^254^ and ranged from 0.20% ^251^ to 3.10%. ^185^ Amongst the studies, the most common source of omega-3 and/or omega-6 LCPUFA supplementation was marine oil. ^185,^ ^191,^ ^341^

In three trials, the sources used for omega-3 and/or omega-6 LCPUFA supplementation were oils derived from the alga and fungus. ^201,^ ^207,^ ^272^ One study used egg-derived triglyceride (egg-TG). ^207^ Two trials did not report the source of omega-3 and/or omega-6 LCPUFA supplementation. ^198,^ ^254^ Birch et al. used corn and soy oils as sources of FA supplementation. ^212^

In almost all studies, the infants were enrolled and assigned to the interventions within ten days after their birth. Only one study reported the rate of formula intake (at least 0.72 L formula/day through 79 weeks PCA. ^185^ The duration of preterm formula intake varied between the studies, ranging from 21 days ^251^ to 12 months. ^207^ Upon reaching the weight of 1,800 g, the infants were switched from preterm to term formulas with or without LCPUFA supplements. ^185,^ ^207^ In one study, standard and supplemented formulas differed from their commercial versions in that the former contained nucleotides, β-carotene, lactose, and α-tocopherol. ^207^

Two studies reported that the assigned study formulas had nutritionally similar content (except for fat composition), and the only difference between them was the composition of omega-3/omega-6 FAs. ^191,^ ^212^ In two trials, the manufacturer of the study formula (Enfamil) was Mead-Johnson Nutritional Group, Evansville, Indiana. ^201,^ ^212^ In other trials, the manufacturer of the study formulas included Milupa AG, Friedrichsdorf, Germany (Preaptamil with Milupan), ^198,^ ^251^ Ross Products Division, Columbus, OH (Similac Special Care), ^191^ and Nutricia, Zoetermeer, The Netherlands (product name not reported). ^272^ None of the studies reported well-documented data on compliance.

The study protocol in the trial by O'Connor et al. did not limit the amount or duration of human milk feeding. Whenever the study infants were being weaned from human milk, the protocol required that the infant be fed the assigned study formula unless there was a medical indication to do otherwise. ^207^

Cointervention characteristics. None of the studies described how the dietary formula intake and background diet was monitored. Three studies reported vitamin intake. ^212,^ ^251,^ ^254^ For example, one trial reported that the study groups were given a daily supplementation of 1,200 IU of vitamin D and 4.5 mg of vitamin E. ^254^ Another trial reported that all infants in the study were given daily multivitamin drops (A, C, and D) and vitamin E (25 IU per day) for 14 days, after feeding was well tolerated. ^212^ In the trial by Koletzko et al., the infants received oral vitamin supplement providing 0.8 mg α-tocopherolacetate/kg body weight. ^251^

Outcome characteristics. Visual acuity parameters (FPL and/or VEP) were evaluated in all the trials. In these studies, FPL was measured by Teller Acuity Card Procedure. ^185,^ ^191,^ ^201,^ ^207,^ ^212,^ ^251,^ ^272^ The FPL values were expressed as means of Log10 (cycles/cm) [SD] and were derived from threshold of the finest grating size identified (cycles/cm), based on the infant's behavior, and the distance between the infant and visual stimulus.

The SD was expressed in octaves (SD of log acuity score/0.301). The VEP values were measured in five studies. ^198,^ ^207,^ ^212,^ ^254,^ ^272^ For the VEP responses, peak-to-peak amplitude (in mvolts) and latency (in msec) for each check size were determined. The VEP acuity (in logMAR) was obtained from linear functions relating amplitude to the logarithm of each check size. Lower LogMAR values indicate better visual acuity.

Two trials reported ERGs. ^198,^ ^212^ The ERGs were reported as latencies and rod/cone ERG amplitudes (Naka-Rushton parameters: log threshold, LogVmax, and log k).

Study quality and applicability. The nine RCTs received a mean Jadad total quality score of 2.9, approaching a good internal validity (Summary Matrix 20). van Wezel-Meijler et al. received a score of 5, ^272^ Carlson et al. received a score of 4, ^185^ four reports received a score of 3, ^191,^ ^201,^ ^207,^ ^254^ two reports received a score of 2, ^212,^ ^251^ and Faldella et al. received a score of 1. ^198^ Six trials failed to report the method of randomization, ^123,^ ^305,^ ^312,^ ^316,^ ^317,^ ^319^ three were unblinded, ^310,^ ^316,^ ^317^ five trials did not decribe the method of double-blinding, ^123,^ ^150,^ ^305,^ ^312,^ ^319^ and two did not report the reasons for dropouts. ^305,^ ^317^

#### Qualitative synthesis of individual study results

The study results regarding the effects of LCPUFA supplementation on visual acuity in healthy preterm infants are not consistent. Five studies observed that preterm infant formula supplemented with LCPUFA is associated with better FLP and/or VEP acuity. ^185,^ ^191,^ ^198,^ ^207,^ ^212^ In contrast, the remaining studies did not observe any relationships between LCPUFA supplementation and the development of visual acuity (FLP and/or VEP). ^201,^ ^251,^ ^254,^ ^272^ In two studies, ERG responses were not statistically significantly different across the formula groups at 52 to 57 weeks postconceptional age (PCA). ^198,^ ^212^

According to study results obtained by Birch et al., ^212^ the soy/marine oil-supplemented formula (DHA+EPA: 1.0 g/100 g) group had a better VEP acuity than the corn oil-based formula (LA: 24.2, ALA: 0.5 g/100g) group at 36 weeks PCA. At 57 weeks PCA, the soy/marine oil-supplemented formula group had a statistically significantly better VEP acuity than the corn oil- and soy-based formula groups. The soy/marine oil-supplemented formula group had a better FPL acuity (of borderline statistical significance) than the corn oil-supplemented formula group at 57 weeks PCA. Statistically significant differences were observed for rod threshold at 36 weeks PCA between the study arms (higher in corn-oil supplemented formula group vs. human milk, soy- or soy/marine-oil supplemented formula groups). The rod ERG responses between the groups were not statistically significantly different at 57 weeks PCA. There was no statistically significant differences for cone ERG parameters between the groups at 36 and 57 weeks postconception. ^212^

Carlson et al. ^185^ found a statistically significant effect of marine-oil supplementation on visual acuity at the age of 2 and 4 months. Specifically, infants fed with marine oil-supplemented formula (DHA: 0.2 and EPA: 0.3 g/100 g) had a better visual acuity than those fed with standard formula (ALA: 3 g/100 g) group.

The study by Koletzko et al. did not demonstrate any statistically significant effect of LCPUFA supplementation on visual acuity. ^251^

The results obtained by Carlson et al. ^191^ demonstrated that healthy infants (i.e., those without bronchopulmonary dysplasia) who were fed LCPUFA supplemented formula had a better visual acuity at 2 months of age than those infants who were fed formula with no supplementation (2.90 vs. 2.15 cycles/degree, p< 0.05). In contrast, there was no difference in visual acuity between the formula groups at 4 months. The study authors detected an interaction between bronchopulmonary dysplasia and diet at 0 and 2 months (p<0.03 and p<0.005, respectively). Namely, in infants without bronchopulmonary dysplasia the LCPUFA supplementation was related to an improved visual acuity. In contrast, this supplementation in infants with bronchopulmonary dysplasia was related to poorer visual acuity.

Faldella et al. found that the mean latencies of flash VEP (N4 and P4 waves) at 52 weeks PCA were significantly shorter in infants from LCPUFA supplemented formula (DHA: 0.23% and EPA: 0.08%) and breast milk groups compared with infants from standard/control formula groups. ^198^ No significant differences were observed across the study groups (control formula vs. LCPUFA-supplemented formula vs. human milk) in ERG and BAEP parameters (latencies a and b) measured at 52 weeks postconception. ^198^

Bougle et al. did not find any difference amongst the breastfed and the formula (with and without LCPUFA supplement) fed groups in VEP responses (latency of wave N1) after 30 days of diet. ^254^

Results in the trial by O'Connor et al. suggested that study diet did not have any significant effect on FPL and VEP acuity at 4 months CA. ^207^ However, at 6 months CA, infants randomized to either fish/fungal oil-supplemented or egg-TG/fish oil-supplemented formula had higher mean VEP acuity than infants in the control formula group. Infants in the fish/fungal oil- and egg-TG/fish oil-supplemented formula groups had similar VEP acuity at 4 and 6 months CA. There was no difference with respect to FPL acuity between the study groups at 6 months CA. ^207^

van Wezel-Meijler et al. did not reveal any statistically significant differences in flash VEP latencies (P200 and N300) and FLP acuity responses at any stage of follow up (at 3 and 12 months of age) between the supplemented and non-supplemented formula groups. ^272^ The authors reported that VEP responses could not be obtained from three infants at 3 months of age for technical reasons, and because of lack of parents' permission.

According to Innis et al., three randomized groups of infants had similar mean FLP values of visual acuity at 48 and 57 weeks PCA (differences were not statistically significant). ^201^ At 57 weeks PCA, breastfed term infants had a significantly higher visual acuity than preterm infants randomized to receive either control (without LCPUFA supplement) or LCPUFA supplemented formulas. ^201^

In Birch et al, the LCPUFA content of RBC-DHA/DPA ratio correlated with both FPL and VEP at 57 weeks PCA. ^212^ Based on ANOVA, there was a statistically significant correlation between RBC-PE-DHA at 2 months and visual acuity at 2 and 4 months in Carlson et al. ^185^

Faldella et al. found a negative correlation between the RBC DHA and the N4 and P4 wave latency of the VEP at 52 wks PCA. ^198^

The study by Birch et al. ^212^ reported the number (n=2) and reasons (medical complications) of dropouts/withdrawals. Carlson et al. ^185^ reported that of the 79 infants, there were ten non-completers (reasons for not completing the study not given) who eventually were replaced. At the end of the study, the authors also excluded four infants who had received enteral nutrition. Carlson et al. ^191^ reported that of the 94 enrolled infants, 35 were lost at 2-month follow up. Of those, 19 infants were lost for their intolerance to enteral feeding leading to sepsis and necrotizing enterocolitis, and an additional 14 infants dropped out of the study because their parents moved or refused any further participation in the study.

The study authors stated that the reasons for non-participation were not related to the type of study diet. Although Faldella et al. reported that eight infants could not complete the follow up, they failed to provide information on the reasons for the loss/withdrawal of infants. ^198^ In their study, Bougle et al. presented the data and reasons for dropouts: necrotizing enterocolitis (n=1), hydrocephalus (n=1), and transfer to referring hospital (n=5). ^254^

According to O'Connor et al., the percentage of study completers at 12 months of observation was about 80%. ^207^ van Wezel-Meijler et al. reported that of the 55 enrolled infants, 13 were excluded due to different reasons such as necrotizing enterocoloitis (n=2), chronic lung disease (n=3), grade 4 retinopathy of prematurity (n=1), cystic periventricular leucomalacia (1), practical reasons (n=4), and change from formula feeding to mother's expressed milk (n=2). ^272^ According to Innis et al., 21 infants did not complete the pre-term diet protocol due to necrotizing enterocolitis or other gastrointestinal disease, complications unrelated to the study, formula intolerance, receiving oxygen at discharge, and protocol violation. ^201^

#### Quantitative synthesis

Visual acuity was measured both through behavioral and electrophysiologic tests. For the behaviorally-based tests, we extracted data from the studies using the Teller Acuity Card Procedure (ACP) or the Forced Choice Preferential Looking Procedure (FPL). For all of the behaviorally-based tests, stimuli were high-contrast square-ware grating of two discrete luminance presented in equal duty cycles. Grating acuity can be expressed in units of cycles per degree (cy/degree) of visual angle. Higher values of cy/degree indicate better visual acuity. For electrophysiologic tests, we extracted data from studies using steady-state or transient VEP tests. Visual acuity was expressed as the minimal angle of resolution (MAR). Opposite to cy/degree, the lower the MAR value, the better the visual acuity. In this systematic review, visual acuity was measured at age 0, 2, 3, 4, 6, 7, 8, 9, 12, 24, and 39 months. In visual acuity research, measures of dispersion, such as the standard error of the mean are commonly represented in units of octaves. A one octaves change represents a doubling or a halving of the stimulus spatial frequency (or a thinning of the width of the individual stimulus lines by one half). In the studies included in this systematic review, visual acuity data were reported in cy/degree, MAR, log cy/degree, and log MAR. Most of the standard deviations of the visual acuity are in these units as well, although some are in octaves. For standardization, all the data has been converted into octaves.

Almost all of the studies included in this review only reported the mean of the visual acuity for each dietary group, not the difference of visual acuity between the groups. Thus, the visual acuity difference between groups consuming a source of DHA and groups not consuming a source of DHA needed to be calculated from individual values. Due to the different meanings of the magnitude of cy/degree and MAR, when the unit of the visual acuity is cy/degree, the visual acuity difference was calculated by subtracting the mean of visual acuity of the no-DHA intake group from the mean of visual acuity of the DHA intake group; however, if the unit was MAR, the reverse was done. Finally, these results (mean visual acuity difference with the standard error) were recorded into the database as the outcome data for each trial. Some studies did not report the actual data, but a graph. In these cases, data were extracted from the graph. The visual acuity development is very sensitive to the age of the infants. One of the complexities of this systematic review was that each included study started at different ages, for example, some visual acuity data were tested at the very beginning of the study. Since this data is actually baseline information, it was excluded from the final analyses since the data would confound observed treatment effects. For example, in the Hoffman 2003 study, there were two measurements, one obtained from 4 to 6 months, and the other at 12 months. However, the treatment was introduced from 4 to 6 months. This means that visual acuity data obtained at 4 to 6 months was actually baseline information. If we combine this data with data obtained from the other studies at the same age, the treatment effectiveness would be confounded by this baseline information.

Since the durations of the supplementation differed across trials, some studies tested visual acuity after the supplement was stopped. In order to separate “during”, and “post”supplement effectiveness, the data were split into two sets according to the duration of the supplementation reported in each trial. The effectiveness of the supplement was evaluated by using the database for “during” supplement.

## Statistical analysis

It was not reasonable to combine the results of visual acuity difference obtained from fullterm infants and preterm infants, or from different test ages, or from different visual acuity tests (behaviorally-based or electrophysiological-based), or from different study components (randomized and non-randomized components). One meta-analysis is required for each subgroup in which all the factors are the same across the studies. Therefore, the number of different combinations of these factors determined the number of meta-analyses needed for this systematic review.

Although all the included studies have a common interest, i.e., the effectiveness of omega-3 on child visual acuity, most of the studies (73%) included more than two dietary groups.

The fixed effect model was used to obtain combined estimates of visual acuity differences and their standard errors within each category in some meta-analyses. The weights of each study were taken by using the reciprocal of the variance of the visual acuity difference of each study. When heterogeneity was present between studies, a Dersimonian and Laird random-effect method was used instead to get the pooled estimates of the visual acuity difference across the studies. However, it is notable that in some meta-analyses that only included a small number of studies, the test for heterogeneity should be interpreted carefully.

The median of the number of dietary groups in a single study was 3.5. The dietary groups could be classified into 4 major groups—no-DHA intake, DHA intake, DHA+AA intake and human milk (HM) groups. Thus, the comparisons conducted were: DHA vs no-DHA intake and DHA+AA vs no-DHA. These were two randomized comparisons, whereas, a non-randomized comparison of HM vs no-DHA intake was also conducted as a reference.

DHA vs no-DHA

Meta-analysis for behaviorally-based test at 0, 2, 4, 6, and 9 months (Table 4, Figure 12). There was no statistically significant difference in visual acuity between DHA intake and placebo groups for preterm infants based on the behavioral test at age 0, 2, 4, 6, and 9 months.

Table 4. Meta-analysis of visual acuity difference (DHA vs. no-DHA) for preterm infants based on behavioral test

Age | Studies | Heterotest | Point estimate | 95% C.I. | P-value
0 | ^1^ Carlson 1992 | - | 0.20 | (-0.11, 0.51) | 0.21
2 | ^1^ Carlson 1992, ^2^ Innis 2002 | 0.07 | 0.27 | (-0.18, 0.71) | 0.24
4 | ^1^ Carlson 1992, ^2^ Innis 2002 | 0.02 | 0.15 | (-0.23, 0.52) | 0.44
6 | ^1^ Carlson 1992 | - | 0.19 | (-0.03, 0.41) | 0.08
9 | ^1^ Carlson 1992 | - | 0.20 | (-0.02, 0.42) | 0.07

Age: in months;

Studies: superscripts correspond to the report number in the graphs;

Heterotest: P-value for the heterogeneity test;

Point estimate: (in octaves); positive value means the point estimate favors DHA intake over no-DHA intake;

P-value: P-value for the effectiveness-only one study in this meta-analysis.

Figure 12. Meta-analysis of visual acuity difference (DHA vs. no-DHA) in preterm infants based on the behavioral test

Shaded circles represent the pooled estimates of visual acuity difference from the meta-analysis of randomized comparisons (formula fed DHA vs formula fed no-DHA) tested at certain ages. The open symbols represent the pooled estimates of visual acuity difference from the meta-analysis of nonrandomized comparisons (human milk vs formula without DHA).

DHA+AA vs no-DHA

Meta-analysis for behaviorally-based test at 0, 2, 3, 4 and 6months (Table 5, Figure 13). There is no statistically significant difference on visual acuity between DHA+AA intake and placebo groups for preterm infants based on the behavioral test at age 0, 2, 4, 6, and 9 months.

Table 5. Meta-analysis of visual acuity difference (DHA+AA vs. no-DHA) for preterm infants based on behavioral test

Age | Studies | Heterotest | Point estimate | 95% CI | P-value
0 | ^6^ Carlson 1996 | - | 0.24 | (-0.37, 0.85) | 0.44
2 | ^2^ Innis 2002, ^4^ O'Connor 2001, ^6^ Carlson 1996 | 0.12 | 0.12 | (-0.08, 0.33) | 0.24
3 | ^3^ Wezel-Meijl 2002 | - | 0.30 | (-0.03, 0.63) | 0.08
4 | ^2^ Innis 2002, ^4^ O'Connor, ^5^ Birch 1992 | <0.01 | 0.10 | (-0.18, 0.38) | 0.50
6 | ^3^ Wezel-Meijl 2002, ^4^ O'Connor | 0.20 | 0.06 | (-0.11, 0.23) | 0.46

Age: in months;

Studies: superscripts correspond to the report number in the graphs;

Heterotest: P-value for the heterogeneity test;

Point estimate: (in octaves); positive value means the point estimate favors DHA intake over no-DHA intake;

P-value: P-value for the effectiveness-only one study in this meta-analysis.

Figure 13. Difference in visual acuity (DHA+AA vs no-DHA)in preterm infants based on the behavioral based test

Shaded circles represent the pooled estimates of visual acuity difference from the meta-analysis of randomized comparisons (formula fed DHA vs. formula fed no-DHA) tested at certain ages. The open symbols represent the pooled estimates of visual acuity difference from the meta-analysis of nonrandomized comparisons (human milk vs. formula without DHA).

Meta-analysis for Electrophysiologically based test at 0, 4 and 6 months (Table 6, Figure 14). Except for the results at 4 month, the results show that at 0 and 6 month, DHA+AA intake group show better visual acuity than the placebo group. Notably, there is only 1 study at each month support the results.

Table 6. Meta-analysis of visual acuity difference (DHA+AA vs. no-DHA) for preterm infants based on electrophysiological test

Age | Studies | Heterotest | Point estimate | 95% CI | P-value
0 | ^5^ Birch 1992 | - | 0.3 | (0.16, 0.44) | <0.01
4 | ^4^ O'Connor, ^5^ Birch 1992 | <0.01 | 0.44 | (-0.41, 1.28) | 0.31
6 | ^4^ O'Connor | - | 0.51 | (0.22, 0.8,) | <0.01

Age: in months;

Studies: superscripts correspond to the report number in the graphs;

Heterotest: P-value for the heterogeneity test;

Point estimate: (in octaves); positive value means the point estimate favors DHA intake over no-DHA intake;

P-value: P-value for the effectiveness-only one study in this meta-analysis.

Figure 14. Difference in visual acuity (DHA+AA vs. no-DHA) in fullterm infants based on Electrophysiological test

Shaded circles represent the pooled estimates of visual acuity difference from the meta-analysis of randomized comparisons (formula fed DHA vs. formula fed no-DHA) tested at certain ages. The open symbols represent the pooled estimates of visual acuity difference from the meta-analysis of nonrandomized comparisons (Human milk vs. formula without DHA).

Human Milk vs no-DHA

Meta-analysis for Behaviorally based and Electrophysiologically based test at 0, 2, 4 and 6 months (Table 7).

Table 7. Meta-analysis of visual acuity difference (HM vs no-DHA) in preterm infants based on the behavioral and electrophysiological tests

Test | Age | Heterotest | Point estimate | 95% CI | P-value
B | 2 | 0.71 | -0.01 | (-0.2, 0.17) | 0.9
B | 4 | 0.02 | 0.26 | (0.04, 0.49) | 0.02
B | 6 | - | 0 | (-0.31, 0.31) | 1
E | 0 | - | 0.6 | (0.46, 0.74) | <0.01
E | 4 | 0.03 | 0.3 | (-0.25, 0.84) | 0.29
E | 6 | - | 0.85 | (0.46, 1.24) | <0.01

B: Behavioral test.

E: Electrophysiological test;

Age: in months;

Heterotest: P-value for the heterogeneity test;

Point estimate: of meta-analysis fo certain age (in octaves); The positive value means the point estimate favors DHA intake over no-DHA intake;

P-value: P-value for the effectiveness; only one study in this meta-analysis.

### Impact of covariates and confounders

Carlson et al. controlled the results for potential independent variables related to visual function such as birth weight, gestational age, oxygen supplementation, enrollment weight, RBC DHA at 2 months, and sex. Oxygen supplementation was negatively related to visual acuity at term in the whole population, whereas, birth weight and gestational age were derectly associated with visual acuity. ^185^ In a second trial, Carlson et al. used a regression analysis and correlations among neonatal and perinatal characteristics and 4 months grating acuity. ^191^ Variables were mechanical ventilation, birth weight, age and RBC DHA in infants, among others. Total hours of mechanical ventilation, volume of packed RBCs and days required to reach enteral intake of 418 kj/kg/d were significantly negatively correlated with visual acuity at 4 months of CA. Birth weight was positively correlated with a higher visual acuity at 4 months. ^191^

The power calculation was reported in four trials, ^123,^ ^310,^ ^312,^ ^316^ while the intention-to-treat analysis approach was reported in only one study. ^310^

### Infant Formula Intake - Term Infants

Thirteen unique parallel design RCTs met eligibility criteria. These studies were published between 1995 and 2003. All but one trial ^126^ were summarized in the Growth Pattern Outcomes section (see key question: Growth Patterns-Term Infant Formula Intake). (Summary Tables 38–40)

#### Overview of relevant studies

Carlson et al evaluated the effect of feeding DHA + AA (0.1 wt% and 0.43 wt%, respectively) supplemented formula compared with unsupplemented formula from birth to 12 months of age on visual acuity using the Teller Acuity Card protocol at 2, 4, 6, 9 and 12 months of age. ^277^ (Summary Table 38)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. All studies were parallel RCTs with at least two groups. Countries where the studies were conducted included Australia, ^205,^ ^262,^ ^266^ United States, ^104,^ ^182,^ ^203,^ ^227,^ ^263,^ ^269,^ ^277,^ ^342^ Denmark, ^264^ and Canada. ^263^ Makrides et al.'s study was funded by grants-in-aid from Channel 7 Children's Medical Research Foundation, Nestle Australia, Scotia Pharmaceuticals UK and Flinders Medical Research Foundation. ^262^ Jorgensen et al's study was funded by Food Technology Research and Development Program (FOTEK), DanoChemo AS, BASF Health & Nutrition (Denmark), Swedish Medical Research Council, and Semper AB supplied infant formula. ^264^ Carlson et al.'s study was funded by the National Institute of Child Health and Human Development Grant and infant formula supplied by Ross Products Division, Abbott Lab. ^277^ Auestad et al.'s 1997 study and the secondary report by Austed et al. were funded by Ross Products Division, Abbott Laboratories and a US Maternal & Child Health Bureau grant. ^104^ Innis et al.'s study was funded by the Mead Johnson Research Center. ^263^ Jensen et al.'s study was funded by Federal funds from the US dept of Agriculture, Agriculture Research Services, Mead-Johnson Nutritional Group, the Foundation Fighting Blindness, Research to Prevent Blindness Inc., and the Retina Research Foundation. ^203^ Formulas for this study was provided by Mead-Johnson Nutrition Group and weaning foods were provided by Gerber Products Co. ^203^ Birch et al. was funded by an NIH grant and Mead Johnson Nutritional Research. ^182^ Both of Auestad et al.'s 2001 studies were funded by Ross Products Division, Abbott Laboratories. ^227^ Makrides et al.'s study was funded by Nestec Ltd, the MS McLeod Research Trust, and the Australian National Health & Medical Research Council. ^205^ Makrides et al.'s study was funded by Wyeth Nutritionals International, the Australian National Health and Medical Research Council, and the MS McLeod Research Trust. ^266^ Birch et al.'s study was funded by an NIH grant and Mead Johnson Nutritional Group. ^269^ Hoffman et al.'s study was funded by NIH. ^270^

Population characteristics. The range of sample sizes were from 33 to 274 infants across the included studies.

The inclusion criteria were described by all of the included term infant studies. The definition of a term infant (range: 37–43 weeks GA) was described in ten studies. ^104,^ ^182,^ ^205,^ ^227,^ ^262–264,^ ^269,^ ^277^

All but one study described the exclusion criteria. ^203^ Enough detail was provided for the selection of healthy infants in nine studies. ^104,^ ^182,^ ^205,^ ^227,^ ^264,^ ^266,^ ^269,^ ^270^

Opthalmologic examination criteria for the exclusion of infants from visual acuity assessments after enrolment were described in four studies. ^104,^ ^262,^ ^266,^ ^277^ These infants participated in all the other assessments of the studies.

Exclusion of infants at risk for lipid metabolic abnormalities based on maternal risk factors was described in six studies. ^104,^ ^182,^ ^262,^ ^266,^ ^269,^ ^270^

In the RCTs, the mean GA of randomized infants (range:39.0–40.3 weeks) was reported in nine studies. ^104,^ ^203,^ ^205,^ ^227,^ ^262,^ ^264,^ ^266,^ ^277^ The GA was not reported in four studies. ^182,^ ^263,^ ^269,^ ^270^ The percentage of males of randomized infants was reported in ten studies and ranged from 37.5% to 69.2%. ^182,^ ^203,^ ^205,^ ^227,^ ^262,^ ^264,^ ^266,^ ^270,^ ^277^ This information was not reported in three studies. ^263,^ ^269,^ ^270^ Ten of the RCTs reported the race and/or ethnicity data. ^104,^ ^182,^ ^203,^ ^205,^ ^227,^ ^266,^ ^269,^ ^270,^ ^277^ Randomized infants were matched for GA at birth in nine studies, ^104,^ ^203,^ ^205,^ ^227,^ ^262,^ ^264,^ ^266,^ ^277^ and not reported in four studies. ^182,^ ^263,^ ^269,^ ^270^ The proportion of male to female randomized study infants was evenly distributed in four trials, ^182,^ ^227,^ ^277^ not reported in two studies, ^263,^ ^266^ and reported for all study infants but not for each study group in one study. ^270^

There was a disproportionately higher percentage of males in the control formula group in two studies ^104,^ ^269^ and in one of the supplemented formula groups in three studies. ^205,^ ^262,^ ^264^ There was a disproportionately lower percentage of males in one of the supplemented formula groups in one study. ^203^ The race and/or ethnicity of the randomized infants was reported in ten studies, ^104,^ ^182,^ ^203,^ ^205,^ ^227,^ ^266,^ ^269,^ ^270,^ ^277^ The majority of randomized infants were White in eight studies, ^104,^ ^182,^ ^205,^ ^227,^ ^266,^ ^269,^ ^270^ and Black/Hispanic in two studies. ^203,^ ^277^ The distribution of race/ethnicity among the study groups of randomized infants for these studies was closely matched in three studies, ^205,^ ^266,^ ^269^ somewhat matched four in studies, ^104,^ ^182,^ ^227^ discrepant in two studies, ^203,^ ^277^ and not reported in one study. ^270^

Parental sociodemographic factors were reported in nine studies. ^182,^ ^205,^ ^227,^ ^262,^ ^266,^ ^269,^ ^270,^ ^277^ Different variables were used to demonstrate family sociodemographic status in the various studies (parental education, social score, income, adults in household, children in household, smoking, marital status, birth order, HOME screening questionnaire score). There were no differences in sociodemographic variables among the study groups of randomized infants in five trials, ^227,^ ^262,^ ^269,^ ^277^ significantly different parental post-secondary education (p < 0.005) in one study ^270^ and reported but not analysed in three trials. ^205,^ ^266,^ ^343^ Two of these studies took the sociodemographic factors into account in comparing VEP acuity between randomized formula groups with analysis by covariance ^205,^ ^266^ and multiple linear regression. ^266^

Intervention/exposure characteristics. Randomized infants in all studies were fed ad libitum with a standard cow's milk based infant formula with or without the addition of omega-3 and/or omega-6 LCPUFA, ^104,^ ^182,^ ^205,^ ^227,^ ^262,^ ^264,^ ^269,^ ^270,^ ^277^ ALA and/or LA, ^203,^ ^263,^ ^266^ and/or GLA. ^262,^ ^264^

The sources of DHA in the studies included fish oil, ^104,^ ^205,^ ^227,^ ^248,^ ^262,^ ^264^ or single cell oils (DHASCO®). ^182,^ ^269,^ ^270^ The sources of DHA and AA included egg PL, ^104,^ ^205,^ ^227,^ ^277^ and sources of AA in the studies included single cell oils (ARASCO®) ^182,^ ^269,^ ^270^ and fungal lipid. ^227^ Sources of ALA included canola oil, ^203,^ ^266^ and sources of GLA included evening oil, ^262^ and borage oil. ^264^

The source of ALA and AA were not reported in one study. ^263^ Only one study monitored the volume of formula intake of the groups of study patients and found no difference. ^203^ Study infants were placed on the study formulas within the first week of life in the majority of the studies. ^104,^ ^182,^ ^203,^ ^205,^ ^227,^ ^262,^ ^263,^ ^266,^ ^277^ The second Auestad et al. study randomized the infants at 11 days of life, but had them begin formula feeding after 3 months of being exclusively breastfed. ^227^ Study formulas were started within the first month of life in Jorgensen et al's study, ^264^ from the beginning of week 7 in Birch et al's study, ^269^ and after weaning from breast feeding at 4 to 6 months of age in Hoffman et al's study. ^344^

The introduction of solid foods, usually starting with cereals, will not contribute to the omega-3 and omega-6 FA intake, and thus would have very little impact on the study diets. However, if a significant proportion of the diet is from supplementary foods and beverages other than the study formula, this may contribute to decreased study formula intake. Dietary intake information was not well documented in all the studies. Five studies in which study formula was initiated within the first week of life, supplementary foods and beverages were discouraged for varying durations during the intervention phase. ^104,^ ^182,^ ^203,^ ^262,^ ^266^

Innis et al. ^263^ specified that an infant would be withdrawn if more than 10% of dietary energy came from sources other than assigned formula for 5 days or more. Jorgensen et al.'s study documented that no supplementary food was consumed. ^264^ Infants were started on the study formulas from the beginning of week 7 of life in Birch et al's study, and it was documented that none of the infants consumed solid food before 17 weeks and most had no solid food other than cereal until 26 weeks of age. ^269^ In Hoffman et al's study, study formula started at 4 to 6 months of age and the diet was not controlled. ^270^ Criteria for inclusion/exclusion of supplementary foods or beverages was not stated in two studies. ^205,^ ^277^

Cointervention characteristics. Only two studies reported the use of tocopherol (vitamin E) in their formulas. ^182,^ ^264^ Auestad et al. also allowed the use of breast millk as a cointervention. ^227^

Outcome characteristics. Assessment of visual acuity was evaluated using the following methods: FPL with Teller Acuity Cards ^104,^ ^182,^ ^227,^ ^263,^ ^277^ or infant random dot stereocards, ^269,^ ^270^ VEP, ^203,^ ^205,^ ^262,^ ^266^ and sweep VEP. ^104,^ ^182,^ ^264,^ ^269,^ ^270^ Some studies employed more than one method for the assessment of visual acuity. ^182,^ ^269,^ ^270^ Birch et al. also employed electroretinography (ERG) to assess maturity of retinal function. ^182^ FPL using Teller Acuity Cards is reported as 1) threshold—the finest gating at which the tester can locate the grating based on the infant's behaviour, and 2) Log10 acuity score—represents the log transformed acuity based on the conversion of the finest grating recognized (cycles/cm) and the distance of the subject from the visual stimulus. The SD of Log10 acuity score is expressed in octaves (SD log acuity scores/0.301). A difference between groups of 1.0 octave means that the smallest stripe detected by one group is twice as large as the smallest stripe detected by the other. Only tests with confidence ratings of 3 to 5 (1–5, low to high) and good inter-rater reliability were included in the analyses.

Random dot stereoacuity by FPL using the infant random dot stereocards is reported as log10 s—log of the minimum detectable binocular disparity. VEP responses to a pattern-reversal stimulus at 2 hertz are reported as 1) latency—time between stimulus and maximal electrical response of the occipital cortex (msec), 2) amplitude—maximal height of the electrical response of the occipital cortex (mvolts), amd 3) logMAR (log10 minimal angle of resolution)—peak to peak amplitude of the VEP response is plotted against log of the angle subtended by each check size and the linear portion of the plot is extrapolated to 0 to give the theoretical value that would just elicit a response (valid only if there were at least three points and r2 was > 0.8 and p < 0.05). Sweep VEP responses to sine-wave gratings are reported as logMAR—the log10 transformed data of the extrapolation of the VEP amplitude versus spatial frequency function to zero amplitude. Some studies specified that only the trials that met a 3:1 signal-to-noise and phase coherence criteria were used in the estimates of logMAR. Lower values of logMAR represent better visual acuity. ERG responses are reported as 1) maximum response amplitude (Vmax), rod thresholds (light required to generate a 2 mV response), and 2) semisaturation constant (log k). Maturation = higher Vmax, lower rod threshold & log k.

Study quality and applicability. The 13 RCTs received a mean Jadad total quality score of 3.61, with a good internal validity (Summary Matrix 21). Six trials received a score of 5, ^182,^ ^205,^ ^266,^ ^269,^ ^329^ three studies received a score of 3, ^104,^ ^270,^ ^277^ and four reports received a score of 2. ^203,^ ^262–264^

#### Qualitative synthesis of individual study results

The 13 relevant unique trials that were reviewed reported their results on the effect of LCPUFA on visual function in term infants. These trials employed different methods for measuring the development of visual acuity. Therefore, the qualitative synthesis of the results will be presented in a stratified manner with respect to the types of visual acuity (i.e., VEP, Teller's visual acuity, random dot stereo-acuity, FPL).

Of the 13 unique trials, five ^104,^ ^182,^ ^264,^ ^269,^ ^270^ reported their results on the effect of LCPUFA supplementation on the development of sweep VEP measured in cycles/degrees or log MAR. Of the five trials, similar mean sweep VEP values between the randomized groups of infants were found in four trials ^104,^ ^182,^ ^264,^ ^269^ at 1.5, ^269^ 2, ^104^ 4, ^104,^ ^264^ 6, ^104^ 6.5, ^182^ and 9 ^104^ months of age (differences were statistically non-significant).

In contrast, the findings of the same two trials ^182,^ ^269^ and another trial ^270^ suggested that infants in the LCPUFA-supplemented formula groups had a lower sweep VEP log MAR values, meaning a significantly better visual acuity than those in the control formula groups at 1.5, ^182^ 4, ^182,^ ^269^ 6.5, ^269^ 12, ^270^ and 13 ^182,^ ^269^ months of age.

Five trials, ^182,^ ^203,^ ^205,^ ^262,^ ^266^ reported the effect of LCPUFA supplementation on the VEP), measured in log MAR. Of these, three ^203,^ ^205,^ ^266^ did not find any between-arm differences in VEP values at 4 and 8 months of age, i.e., the mean VEP values of the infants in the LCPUFA supplemented and control groups were not statistically significantly different. However, findings from the remaining two trials indicated that infants at 4 ^182,^ ^262^ and 13 ^182^ months of age, who had been fed with breast milk and LCPUFA supplemented formula, had lower mean log MAR values, i.e., better visual acuity, compared with those fed with control formula without the LCPUFA supplementation. In both studies, ^182,^ ^262^ the breastfed and LCPUFA groups of infants had very similar VEP acuities.

Teller's visual acuity, as an outcome measured in cycles/degrees, was explored in five trials. ^104,^ ^227,^ ^263,^ ^277^ In all but one, ^277^ the observed values of Teller's visual acuity in the LCPUFA-supplemented and control groups of infants did not differ statistically between groups at 2 ^104,^ ^227^ 3, ^263^ 4, ^104^ 6, ^104^ 10, ^104^ and 12 ^227^ months of age. In the trial by Carlson et al., ^277^ breastfed infants and those randomized to receive the LCPUFA supplemented formula, had on average a significantly higher visual acuity score (i.e., better Teller's visual acuity) than those randomized to receive the control formula at 2 months of age. In the same trial, ^277^ the observed effect of LCPUFA supplementation at 2 months of age was transient and was no longer present at 4, 6, 9, and 12 months of age.

Two trials ^269,^ ^270^ investigated the effect of supplementary LCPUFA on the random dot stereoacuity in term infants, measured in log seconds. The results of both trials indicated that stereoacuity did not differ statistically significantly across the randomized groups of infants at 8, 9, 12, and 13 months of age. Note that Hoffman et al. ^270^ found a trend for better stereoacuity in the infants receiving LCPUFA-enriched formula at 9 and 12 months of age. However, none of the observed differences was statistically significant at 9 and 12 months. Results of these two trials were less consistent for the effect of LCPUFA in the infants at 4 months of age. Specifically, Birch et al. ^269^ found that the infants randomized to receive LCPUFA-enriched formula had a better stereoacuity at 4 months of age than those randomized to receive the control formula (numerical data was not given). Whereas in the other trial, Hoffman et al. ^270^ suggested that the measures of stereoacuity did not differ across the randomized groups of infants receiving either LCPUFA-enriched or control formula at 4 months of age.

Of the 13 trials, only one trial ^182^ assessed the effect of LCPUFA supplementation on FPL acuity. In this trial, the mean FPL acuity, measured in log MAR at 1.5, 4, 6.5, and 13 months of age, did not differ across the groups of infants fed breast milk, LCPUFA-supplemented formula or control formula.

The effect of LCPUFA (DHA and AA) supplementation on the maturity of retinal function as measured by Naka-Rushton parameters (log k, log Vmax, and rod threshold) in term infants was only investigated in one trial. ^182^ The evaluation of the retinal function maturity was based ERG responses determined by electroretinography.

The results of this trial indicated that at 1.5 months of age, the log k (semisaturation constant) was statistically significantly lower (i.e., more mature ERG response) in the infants receiving DHA + AA supplemented formula, compared with those receiving DHA supplemented formula or control formula. This effect was no longer present at 4 months of age. Other two Naka-Rushton parameters, log Vmax and rod threshold, were not statistically significantly different across the diet groups at either 1.5 or 4 months of age. ^182^

Of the 13 trials, six ^104,^ ^205,^ ^227,^ ^266,^ ^277^ did not report any information regarding the associations (i.e., correlation, linear regression) between maternal/infant blood biomarkers (i.e., plasma-, RBC-LCPUFA content) and the measures of visual acuity (i.e., VEP, FLP, Teller's acuity) or ERG responses in infants. Seven trials ^182,^ ^203,^ ^262–264,^ ^269,^ ^270^ reported some information concerning the above-mentioned associations.

Of the seven trials, four ^182,^ ^264,^ ^269,^ ^270^ reported associations between milk or blood biomarkers (plasma/RBC-DHA and/or -AA content) and the sweep VEP acuity measures. Of these trials, three ^182,^ ^269,^ ^270^ found statistically significant negative linear regression coefficients indicating that higher RBC-DHA content was associated with a better sweep VEP acuity in infants at 1.5, 4, ^182,^ ^269^ 6.5, ^182^ 12, ^270^ and 13 ^182,^ ^269^ months of age. Results of the remaining study ^264^ suggested that milk- or RBC-DHA content was not associated with the measured sweep VEP acuity at 4 months of age. The results of both trials ^182,^ ^264^ that looked at the RBC-EPA and RBC-AA content in relation to the measure of sweep VEP acuity, indicated that neither RBC-AA nor RBC-EPA content was associated with the sweep VEP acuity during the first year of the infants' life. One study, ^269^ that investigated the relationship between infant's plasma-DHA and -AA content, found that higher plasma contents of both DHA and AA were associated with better sweep VEP acuity at 4 and 13 months of age.

The relationship between human milk or the infants' blood biomarkers (plasma/RBC-DHA and/or -AA content) and the measures of infant VEP acuity were reported in two trials. ^203,^ ^262^ Both trials suggested that RBC-DHA correlated negatively with the amplitude of VEP acuity (in log MAR), measured at 4 ^203,^ ^262^ and 7.5 ^262^ months of age (i.e., infants at 4 and 7.5 months of age who on average had a higher RBC-DHA content, tended to have a lower log MAR or better VEP acuity). The squared correlation coefficients for the association between RBC-DHA and the amplitude of VEP acuity, measured at 4 and 7.5 months of age were 0.23 (p < 0.001) and 0.12 (p < 0.005), respectively. ^262^ The former trial ^203^ also showed that there was no correlation between either plasma- or RBC-DHA content at 4 months of age, and the latency measure of VEP acuity obtained at either 4 or 8 months of age. The same trial, ^203^ however, found a statistically significant negative correlation between plasma-DHA content and the amplitude of VEP acuity both measured at 4 months of age.

Of the reviewed trials, only one ^263^ reported the association(s) for human milk and/or the infants' blood lipid composition (plasma-DHA and/or RBC-DHA content) in relation to the measure of Teller's visual acuity. The plasma-DHA content did not correlate with the Teller's acuity, measured at 3 ^263^ months of age. Similarly, the associations relating the infants' RBC-DHA ^263^ content to Teller's visual acuity did not reach the traditional level of statistical significance.

Only two trials reported the associations between the infants' RBC-DHA content and their stereoacuity (in log seconds) measured at 4 ^269^ and 12 ^270^ months of age. Both trials found that there was no association/correlation between the two factors. For example, in one trial, ^269^ the reported linear regression coefficient estimate was β = -0.31 (p > 0.05). In the same trial, the infants' plasma-DHA content was negatively correlated with their stereoacuity at 4 months of age, meaning that, on average, infants with higher plasma-DHA content tended to have a better stereoacuity.

The relationship (correlation) between blood lipid content (plasma- and RBC-DHA) and ERG parameters (measured by Naka-Rushton indicators) in infants was reported in one trial. ^182^ None of the Naka-Rushton parameters except for log k (in scotopic troland seconds) was statistically significantly correlated with plasma- or RBC-DHA content at either 1.5 or 4 months of age. There was a statistically significant negative correlation between the RBC-DHA content and log k in the infants at 1.5 months of age.

All the trials reported some information on the losses to follow up/non-completers/withdrawn. The trial that failed to report this information was presented in a form of an abstract. The most common reported reasons for the non-completion/withdrawal of study protocol were: intolerance to lactose or cow's milk/dietary hypersensitivity, poor compliance to the study regimen, early cessation of breast feeding, illness (cataract, meningitis, pyloric stenosis, allergic asthma, and phenylketonuria), declined to participate in the trial, and relocation. The number of non-completers/drop-outs varied across the trials ranging from two ^264^ to 116. ^104^ Across majority of the trials, ^182,^ ^203,^ ^205,^ ^262–264,^ ^266,^ ^269,^ ^270,^ ^277^ the number of non-completers ranged from two ^264^ to 47 ^263^ , with a mean of 20 per trial.

Carlson et al. ^277^ reported one infant was withdrawn for an abnormal ophthalmologic examination. It should be noted that in all studies, that not all infants who completed the study feeding protocol were successfully assessed for visual acuity. It was not always reported as to which study group the unsuccessful visual acuity assessments were in.

In the Makrides et al. study, there were 66 of 79 of all infants who completed the feeding study who had successful VEP assessments at 16 weeks, and 60 who has successful feeding assessments at 30 weeks; ^262^ the sample size calculation was not reported. In the Jorgensen et al. study, ^264^ there were 26 of 37 formula study infants with successful sweep VEP (DHAGF:18, STF:8). Auestad et al. ^104^ withdrew two from the control group, nine from the DHA + AA group, and four from the DHA group, due to abnormal ophthalmologic examination; one from the DHA group was excluded from the acuity card procedure. Some studies reported the exclusion of values from visual acuity assessments due to low tester confidence. ^104^

In Makrides et al., ^205^ one infant in the formula group was withdrawn due to cataracts. This resulted in smaller sample sizes that were determined a priori. Hoffman et al. ^270^ reported that 16 were lost to follow up or had unsuccessful stereoacuity testing, however, information regarding which group these participants belonged to was not specified, so it is unknown if the sample sizes were too small based on a priori sample size calculations. ^182^

#### Quantitative synthesis

Quantitative analysis of visual acuity was as described previously for pre-term infants (see above).

DHA vs. no-DHA.

Meta-analysis for behaviorally based test (Teller's Card test) at age 2, 4, 6, 9 and 12 months (Table 8, Figure 15). There is no statistically significant difference on visual acuity between DHA intake and placebo groups for term infants based on the behavioral test at age 2, 4, 6, 9 and 12 months.

Table 8. Meta-analysis of visual acuity difference (DHA vs. no-DHA) for term infants based on behavioral test

Age | Studies | Heterotest | Point estimate | 95% CI | P-value
2 | ^1^ Auestad 1997, ^2^ Birch 1998 | 0.72 | 0.20 | (-0.1, 0.51) | 0.19
4 | ^1^ Auestad 1997, ^2^ Birch 1998 | 0.38 | -0.14 | (-0.37, 0.10) | 0.25
6 | ^1^ Auestad 1997, ^2^ Birch 1998 | 0.96 | -0.07 | (-0.27, 0.12) | 0.45
9 | ^1^ Auestad 1997 | - | -0.18 | (-0.42, 0.06) | 0.13
12 | ^1^ Auestad 1997, ^2^ Birch 1998 | 0.97 | -0.19 | (-0.38, 0) | 0.05

Age: in months;

Studies: superscripts correspond to the report number in the graphs;

Heterotest: P-value for the heterogeneity test;

Point estimate: (in octaves); positive value means the point estimate favors DHA intake over no-DHA intake;

P-value: P-value for the effectiveness-only one study in this meta-analysis.

Figure 15. Meta-analysis of visual acuity difference (DHA vs no-DHA) in term infants based on behavior test

Shaded circles represent the pooled estimates of visual acuity difference from the meta-analysis of randomized comparisons (formula fed DHA vs. formula fed no-DHA) tested at certain ages. The open symbols represent the pooled estimates of visual acuity difference from the meta-analysis of nonrandomized comparisons (Human milk vs. formula without DHA).

Meta-analysis for electrophysiologically-based test (VEP) at 2, 4, 6, 9 and 12 months (Table 9, Figure 16). There is no statistically significant difference on visual acuity between DHA intake and placebo groups for term infants based on the Electrophysiologically based test at age 2, 4, 6, 8, 9 and 12 months.

Table 9. Meta-analysis of visual acuity difference (DHA vs. no-DHA) for term infants based on electrophysiological test

Age | Studies | Heterotest | Point estimate | 95% CI | P-value
2 | ^1^ Auestad 1997, ^2^ Birch 1998 | 0.01 | 0.25 | (-0.36, 0.86) | 0.42
4 | ^1^ Auestad 1997, ^2^ Birch 1998, ^3^ Makrides 1999 | 0.04 | -0.01 | (-0.25, 0.24) | 0.96
6 | ^1^ Auestad 1997, ^2^ Birch 1998 | 0.07 | -0.02 | (-0.36, 0.32) | 0.91
8 | ^3^ Makrides 1999 | - | -0.27 | (-0.64, 0.1) | 0.16
9 | ^1^ Auestad 1997 | - | -0.11 | (-0.33, 0.11) | 0.32
12 | ^1^ Auestad 1997, ^2^ Birch 1998 | <0.01 | 0.12 | (-0.45, 0.69) | 0.68

Age: in months;

Studies: superscripts correspond to the report number in the graphs;

Heterotest: P-value for the heterogeneity test;

Point estimate: (in octaves); positive value means the point estimate favors DHA intake over no-DHA intake;

P-value: P-value for the effectiveness-only one study in this meta-analysis.

Figure 16. Meta-analysis of visual acuity difference (DHA vs. no-DHA) in term infants based on electrophysiological test

Shaded circles represent the pooled estimates of visual acuity difference from the meta-analysis of randomized comparisons (formula fed DHA vs. formula fed no-DHA) tested at certain ages. The open symbols represent the pooled estimates of visual acuity difference from the meta-analysis of nonrandomized comparisons (Human milk vs. formula without DHA).

DHA+AA vs no-DHA

Meta-analysis for Behaviorally based test (Teller's Card test) at 2, 4, 6, 9 and 12 month (Table 10, Figure 17). Except for results at 2 months, there is no statistically significant difference in visual acuity between DHA + AA intake and placebo groups for term infants based on the behavioral test at age 4, 6, and 9 and 12 months.

Table 10. Meta-analysis of visual acuity difference (DHA+AA vs. no-DHA) for term infants based on behavioral test

Age | Studies | Heterotest | Point estimate | 95% C.I. | P-value
2 | ^1^ Auestad 1997, ^4^ Carlson 1996, ^2^ Birch 1998 | 0.32 | 0.37 | (0.15, 0.6) | <0.01
4 | ^1^ Auestad 1997, ^4^ Carlson 1996, ^2^ Birch 1998 | 0.55 | -0.14 | (-0.33, 0.05) | 0.16
6 | ^1^ Auestad 1997, ^2^ Birch 1998 | 0.29 | 0.07 | (-0.16, 0.3) | 0.57
9 | ^1^ Auestad 1997 | - | -0.04 | (-0.31, 0.23) | 0.78
12 | ^1^ Auestad 1997, ^2^ Birch 1998 | 0.63 | -0.04 | (-0.26, 0.17) | 0.7

Age: in months;

Studies: superscripts correspond to the report number in the graphs;

Heterotest: P-value for the heterogeneity test;

Point estimate: (in octaves); positive value means the point estimate favors DHA intake over no-DHA intake;

P-value: P-value for the effectiveness-only one study in this meta-analysis.

Figure 17. Meta-analysis of in visual acuity difference (DHA+AA vs no-DHA) in term infants based on behavior test

Shaded circles represent the pooled estimates of visual acuity difference from the meta-analysis of randomized comparisons (formula fed DHA+AA vs. formula fed no-DHA) tested at certain ages. The open symbols represent the pooled estimates of visual acuity difference from the meta-analysis of nonrandomized comparisons (human milk vs. formula without DHA).

Meta-analysis for Electrophysiologically based test (VEP) at 2, 4, 6, 7, 9 and 12 months (Table 11, Figure 18).Except results at 12 month, there is no statistically significant difference on visual acuity between DHA +AA intake and placebo groups for term infants based on the Electrophysiologically based test at age 2, 4, 6, 8, and 9 months.

Table 12. Meta-analysis of visual acuity difference (HM vs. no-DHA) in term infant based on behavioral and electrophysiological test

Test | Age | Heterotest | Point estimate | 95% CI | P-value
B | 2 | 0.38 | 0.5 | (0.29, 0.7) | 0
B | 3 | - | 0.12 | (-0.13, 0.37) | 0.36
B | 4 | 0.94 | 0.02 | (-0.17, 0.2) | 0.87
B | 6 | 0.48 | 0.07 | (-0.12, 0.26) | 0.47
B | 9 | - | 0.03 | (-0.17, 0.23) | 0.76
B | 12 | 0.93 | -0.05 | (-0.21, 0.11) | 0.57
E | 2 | <0.01 | 0.17 | (-0.6, 0.93) | 0.67
E | 4 | 0<0.01 | 0.24 | (0.02, 0.47) | 0.03
E | 6 | 0.01 | -0.03 | (-0.49, 0.43) | 0.89
E | 8 | 0.06 | 0.13 | (-0.3, 0.56) | 0.56
E | 9 | - | -0.12 | (-0.34, 0.1) | 0.28
E | 12 | <0.01 | 0.23 | (-0.33, 0.79) | 0.42

B: Behavioral test.

E: Electrophysiological test;

Age: in months;

Heterotest: P-value for the heterogeneity test;

Point estimate: of meta-analysis of certain age (in octaves); The positive value means the point estimate favors DHA intake over no-DHA intake;

Standard error: of pooled estimates from meta-analysis (in octaves);

P-value: P-value for the effectiveness; only one study in this meta-analysis.

Table 11. Meta-analysis of visual acuity difference (DHA+AA vs. no-DHA) for term infants based on electrophysiological test

Age | Studies | Heterotest | Point estimate | 95% CI | P-value
2 | ^1^ Auestad 1997, ^2^ Birch 1998 | <0.01 | 0.29 | (-0.32, 0.91) | 0.35
4 | ^5^ Birch 2002, ^3^ Makrides 1999, ^1^ Auestad 1997, ^7^ Makrides 1995, ^8^ Jorgensen 1997, ^2^ Birch 1997 | <0.01 | 0.17 | (-0.01, 0.36) | 0.07
6 | ^5^ Birch 2002, ^1^ Auestad 1997, ^2^ Birch 1998 | <0.01 | 0.16 | (-0.13, 0.45) | 0.28
8 | ^3^ Makrides 1999 | - | 0 | (-0.35, 0.35) | 1
9 | ^1^ Auestad 1997 | - | -0.12 | (-0.32, 0.08) | 0.23
12 | ^5^ Birch 2002, ^1^ Auestad 1997, ^2^ Birch 1998, ^6^ Hoffman 2003 | <0.01 | 0.32 | (0.09, 0.56) | 0.01

Age: in months;

Studies: superscripts correspond to the report number in the graphs;

Heterotest: P-value for the heterogeneity test;

Point estimate: (in octaves); positive value means the point estimate favors DHA intake over no-DHA intake;

P-value: P-value for the effectiveness-only one study in this meta-analysis.

Figure 18. Difference in visual acuity (DHA+AA vs. no-DHA) in term infants based on electrophysiological test

Shaded circles represent the pooled estimates of visual acuity difference from the meta-analysis of randomized comparisons (formula fed DHA vs. formula fed no-DHA) tested at certain ages. The open symbols represent the pooled estimates of visual acuity difference from the meta-analysis of nonrandomized comparisons (human milk vs. formula without DHA).

Human milk vs no-DHA

Here are listed the combined results of visual acuity difference between HM and no-DHA groups based on behavioral- and electrophysiological-based tests at different ages as references.

#### Impact of covariates and confounders

Of the 13 reviewed trials, 12 reported some information on statistical techniques/methods used to estimate the effect of LCPUFA formula supplementation on visual acuity development in term infants. In 11 trials, the effect of interest was estimated using analysis of variance with repeated measures (ANOVA) alone, ^262,^ ^263^ ANOVA and analysis of co-variance (ANCOVA), ^104,^ ^203,^ ^227^ ANCOVA and multiple linear regression (MLR), ^205,^ ^266^ or ANOVA and MLR. ^182,^ ^264,^ ^269,^ ^270^ In one trial, ^277^ ANOVA together with generalized linear model was used. Five trials reported that the analyses (ANOVA/ANCOVA/MLR) were adjusted for age only. ^182,^ ^262,^ ^263,^ ^269,^ ^277^ The analyses in other trials were reported to be adjusted for some additional covariates such as birth weight, ^203,^ ^205,^ ^264,^ ^266^ length at birth, ^203,^ ^205,^ ^264^ HC at birth, ^266^ sex, ^203,^ ^205,^ ^270^ ethnicity, ^203^ maternal smoking, ^205,^ ^266^ blood lipid (DHA) composition, ^203,^ ^266,^ ^270^ duration of breast feeding, ^264^ GA, ^205,^ ^264^ maternal education, ^205,^ ^266^ birth order, ^205^ and social score. ^205,^ ^266^ Three trials ^104,^ ^227^ reported that the adjustment in the analysis was done for the study site.

Several trials reported that the randomized formula study groups at baseline were not well-balanced (statistically significant differences) for the following factors: sex, ^205^ parental education, ^270^ ethnicity, ^182^ maternal smoking, ^104,^ ^266^ and birth weight. ^263,^ ^264^ For example, in one trial, ^104^ the percentage of infants whose mothers had been smokers were 26, 17, and 11 in the DHA + AA, DHA, and control formula groups, respectively (chi-square test based p < 0.05). The authors of this trial reported that the association between the diet and visual acuity was only adjusted for the study site. In the other trial, ^266^ a baseline distribution of the randomized infants whose mothers were smokers across the two ALA-enriched and LA-enriched formula groups was 51% and 39%, respectively. Furthermore, there was a higher proportion of smoker non-completers in the ALA-enriched than LA-enriched formula group (8% vs. 2%). These factors had been controlled for, as reported, in three trials. ^205,^ ^264,^ ^266^ It is not clear whether the trials reporting to have controlled only for age, ^182,^ ^262,^ ^263,^ ^269,^ ^277^ or site, ^104,^ ^227^ adjusted for additional factors such as maternal smoking, the infants' ethnicity, sex, and size, or other potentially important covariates.

Across the trials, mothers whose infants had been breastfed, tended to be more educated, ^104,^ ^205,^ ^262,^ ^277^ to have a higher social class, ^205^ to be non-smokers, ^104,^ ^205,^ ^266^ and of White race, ^104,^ ^182,^ ^277^ than those in the formula arms. ^104,^ ^277^

Most trials reported that infant sex, ^182,^ ^264,^ ^269,^ ^270^ maternal education, ^104,^ ^182,^ ^227,^ ^266,^ ^269^ maternal social score, ^262,^ ^266,^ ^270^ maternal age, ^182,^ ^227,^ ^264,^ ^269,^ ^270^ infant length and HC at birth, ^104,^ ^227,^ ^248,^ ^3262–264,^ ^270^ GA, ^104,^ ^262,^ ^264,^ ^277^ and duration of breast feeding ^264^ amongst the randomized formula groups were evenly distributed (statistically non-significant differences).

Four trials reported those covariates that influenced the outcome (visual function). These covariates were as follows: sex, ^205^ birth weight, ^205,^ ^264^ duration of breast feeding, ^264^ maternal smoking, ^205,^ ^266^ anthropometrical measures at birth, ^266^ partner's social score, ^266^ and RBC-DHA content. ^270^ In these trials, female gender, ^205^ lower rates of maternal/partner smoking, ^205,^ ^266^ higher birth weight, ^205,^ ^264^ greater HC, ^264,^ ^266^ and longer duration of breast feeding ^264^ were independently related with better visual acuity (p < 0.05).

In most trials, the analyzed main effect of age was statistically significant. It correlated with better visual functioning. The statistically significant interaction between age and diet was detected in two trials, ^269,^ ^270^ meaning that the effect of diet was not uniform with respect to the infants' age.

The power calculation was reported in ten trials, ^120,^ ^124,^ ^126,^ ^151,^ ^325,^ ^329,^ ^331,^ ^334,^ ^335^ while the intention-to-treat analysis approach was reported in only one study. ^120^

## Visual Function Outcomes in Light of Biomarker Data

### What is the Evidence That Term or Preterm Human Infants' Visual Function is Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Maternal Biomarkers During Pregnancy?

One cross-sectional study was identified to respond this question. Krasevec et al.'s ^275^ study was described in the Visual Function Outcomes questions (see key question: Maternal Intake/Visual Function).

### What is the Evidence That Term or Preterm Human Infants' Visual Function is Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Child Biomarkers?

There were a total of 21 studies that addressed this question. Eight cross-sectional studies, included in seven reports, published between 1993 and 2002, met the eligibility criteria. Since these were observational studies, and in order to respond to this particular question, the cross-sectional data was abstracted from three prospective cohort studies. ^271,^ ^281,^ ^282^ Krasevec et al. ^275^ was described above (see key question: Maternal Intake/Visual Function.). There were also nine RCT's described in the term population ^138,^ ^182,^ ^203,^ ^248,^ ^262–264,^ ^269,^ ^270^ and three RCTs in the preterm population (see above). ^185,^ ^198,^ ^212^ . (Summary Tables 38–40 and 41–43)

#### Overview of relevant studies

The studies that included preterm infants will be described separately from the term infant studies. Birch et al. assessed the association between LCPUFA RBC content of omega-3 FAs and the visual function development after dietary supply of LCPUFA (breast milk) in American infants. This report included two different study populations, one of healthy preterm infants and another of full-term infants. The outcomes were measured at 4 months CA and, for the term infants, also at 36 months CA. ^278^ (Summary Table 41)

Makrides et al. studied the FA profiles of Australian term infants (5 months of age) fed breast milk and infant formula, and its association with VEP acuity. ^280^ (Summary Table 41)

Innis et al. studied the development of preferential looking acuity in exlusively breastfed or formula-fed Canadian term infants. The goal was to measure the possible association between this outcome and the omega-3 and/or omega-6 FA content of RBC and plasma of the infants at 14 days and 3 months of age. ^281^ (Summary Table 42)

Leaf et al. evaluated the correlation between the FA composition of RBC and plasma in Australian preterm infants of 40 weeks of PCA and the development of visual function, using ERG and the Teller Acuity Card Procedure. The exposure was low breast-milk diet or high breast-milk diet, besides the use of total parenteral nutrition (TPN) until reaching 2,000 g of weight. ^279^ (Summary Table 42)

The aim of Jorgensen et al.'s study was to establish an association between the FA composition of RBC and plasma of term infants and their visual acuity, using the Teller Acuity Card Procedure at 4 months of life. ^282^ A small sample of Danish term infants were receiving either breast milk or formula without LCPUFA supplementation. ^282^ (Summary Table 42)

Innis et al. included a sample of Canadian term infants exclusively breastfed for at least 3 months since birth. The aim of the study was to determine the association between the RBC DHA content at 2 months of age and visual and neural development. The visual acuity was measured using the Teller Acuity Card Procedure at 2, 4, 6 and 12 months. ^271^ (Summary Table 43)

Krasevec et al. measured the LCPUFA content in maternal and infant's blood at 2 months of age and its correlation with the visual acuity using the Teller Acuity Card Procedure. The Cuban term infants were either breastfed or formula fed. ^275^ (Summary Table 43)

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. Eight unique cross-sectional studies were deemed relevant for the review. ^271,^ ^275,^ ^278–282^ One report included two unique studies, with preterm and full-term infants. Birch et al. and Leaf et al. included preterm infants, ^278,^ ^279^ whereas the remaining six studies selected full-term infants. ^271,^ ^275,^ ^278,^ ^280–282^ Two studies were conducted in the US, ^278^ two in Australia, ^279,^ ^280^ two in Canada, ^271,^ ^281^ one in Denmark, ^282^ and one in Cuba. ^275^

Leaf et al. ^279^ did not provide the funding source. Both Birch et al. studies were supported by the National institutes of Health, Delta Gamma Foundation of Dallas, Pediatric Subunit, and the United Cerebral Palsy Foundation. ^278^ Makrides et al. was funded by Scotia Pharmaceuticals and Nestle Australia, ^280^ whereas Jorgensen et al. received funds from Food Technology Research and Development Program, DanoChemo A/S, and the Swedish Medical Research Council. ^282^ The first Innis et al. study was supported by the British Columbia Children's Hospital Investigatorship, ^281^ and the second ^271^ by the Medical Research Council of Canada and Ross Laboratories. Finally, Krasevec et al. ^275^ was funded by a CIDA Award for Canadians.

Population characteristics. All the studies included healthy preterm ^278,^ ^279^ or term infants. The elegibility criteria was adequately described in six of eight studies. The preterm infant's studies included 48 patients (sample size range: 18–30), while the term infants' studies selected 296 subjects (sample size range: 16–83).

The preterm infants were included if they were healthy, and born before 32 and 33 weeks of GA; Birch et al. also included infants with birth weights of 1,000 g to 1,500 g and an appropriate weight for GA. ^278,^ ^279^ Birch et al. included two samples of healthy full-term infants, one was composed of 30 infants born at 39 to 41 weeks of GA and tested at 4 months of PCA, and the other was composed of 43 term infants tested at 36 months of age. ^278^ Makrides et al.' infants were selected at approximately 5 months of age, with an appropriate weight for GA at birth recorded from immunizations and/or postnatal clinics. ^280^ The first sample of infants from Innis et al.'s study had an appropriate weight for GA and their mothers had to choose to breast feed or formula feed for at least 3 months. ^281^ Yet, the second sample of term infants from Innis et al.'s study ^271^ had a birth weight 2,500 g to 4,500 g and were enrolled within 2 weeks of birth. Their mothers were required to intend to breast feed them without providing infant formula or cow's milk for at least 3 months, and without introducing solid foods for at least the first 4 months after birth. Jorgensen et al.s elected healthy children with birth weights between 2,700g and 4,500g and an Apgar score > 7 after 5 min. Finally, Krasevec et al. ^275^ was the only study that included healthy Cuban women who experienced a normal pregnancy and their infants at 2 months postpartum.

The preterm infants were excluded if they experienced a major congenital anomaly, severe intra/peri ventricular hemorrhage, 5-min Apgar score below 5, ^279^ were unable to tolerate enteral feeds by day 10 of life, with respirator treatment for more than 7 days, congenital infection or malformation, retinopathy of prematurity, or grade 3 or 4 intraventricular hemorrhage. ^278^ Term infants were excluded if they had a known eye disorder, family history of eye disorder, a neurological disorder, or neonatal morbidity. ^278,^ ^280^ Innis et al. ^271^ also excluded mothers with substance abuse, communicable diseases, metabolic or physiologic problems, infections likely to influence fetal growth, or multiple births and infants with evidence of metabolic or physical abnormality. Three studies did not provide the exclusion criteria. ^275,^ ^281,^ ^282^

None of the studies reported the use of medication and/or supplements before study entry. For both studies that included a preterm population, the weight and length at the time of the evaluation, ^278,^ ^279^ as well as the GA at birth, ^279^ were comparable between feeding groups.

The studies that evaluated term infants had a between-group nonstatistically difference in terms of birth weight, ^271,^ ^281,^ ^282^ GA, ^281,^ ^282^ current weight, length, ^278^ age, parity, social status, ^280^ pregnancy weight gain, maternal age, percentage of cesarians and percentage of males. ^282^

Only Leaf et al. ^279^ reported the comorbid condition of their preterm infants during the study period. The conditions were: subependymal intraventricular hemorrhage (n=4), mild ventricular dilatation (n=1), stage 1 retinopathy of prematurity (n=1) and stage 2 (n=1).

Intervention/exposure characteristics. The exposure desciption will be made separately for preterm and term infants. The preterm infants were fed according to nursery protocol and their parent's wishes in Leaf et al.'s study. ^279^ TPN was commenced in those with birth weight < 1,500 g (Vitamin-N, Pharmacia Ltd.) along with Intralipid 20% (Pharmacia Ltd.), which provided a source of lipids (receiving in 15 mL/kg/day approx. 6.4 mg/kg/day of AA and 5.8 mg/kg/day of DHA from egg-phospholipid). Enteral feed were started as soon as possible by intermittent gavage. Breast milk was given if available. If not, infants were commenced on Premature Enfalac formula until 2,000 g, and then standard on Enfalac, which contains vegetable oils as a source of lipids. No LCPUFAs were found in the formula milks. For breast milk, 150 mL/kg/day provided 32 mg/kg/day of AA and 17 mg/kg/day of DHA. The low breast-milk (LBM) and high breast-milk (HBM) groups did not differ in the amount of TPN and intralipid intake (less AA and DHA than breast milk). In Birch et al.'s study, preterm infants were fed with breast milk or a corn oil-based formula. ^278^

The term infant groups in Birch et al.'s study were either breastfed or fed corn oil-based formula. The diets were regulated until 12 months of age to maintain cholesterol and FA profiles consistent with the two dietary regimes. The breastfed group was provided with a monosaturated FA formula, with high oleic acid supplement and by feeding egg yolk as a solid food (LC PUFA). For the formula-fed group, a high LA supplement was provided and solid foods were selected to maintain a low cholesterol and omega-3 LCPUFA supply. ^278^

Makrides et al.'s formula-fed infants (n=8) received one of three infant formulas, each of which had a similar FA composition. LA ranged from 12% to 15% and ALA ranged from 1% to 1.6% of total FAs. The LA:ALA ratios were similar and ranged from 9.4 to 11.3. Both groups were receiving solid foods, like rice cereal and stewed fruit. None of the infants were receiving detectable quantities of DHA or AA from solids. ^280^ The first term formula group in Innis et al.'s study (no LCPUFA) (n=18) were fed with ready-to-feed Enfalac (by Mead Johnson Nutritionals) from 14 (SD=2) days of age. Enfalac is a whey protein based term formula with 17.9% LA (omega-6) and 2.1% ALA (omega-3). The breast milk was composed of 13.4 % LA, 1.5 % ALA, 0.1% EPA and 0.2 % DHA. This group was also provided with a daily supplement of vitamin D, A and C, while the formula-fed group did not receive supplements (vitamins or minerals). The duration of the intervention was 3 months. ^281^

In the second Innis et al. study, the infants were exclusively breastfed for 3 months, and the majority were exclusively breastfed for more than 3 months. ^271^ The mother's breast milk had 0.26 g DHA, 0.4 g AA, 12.5 g LA (per 100 g of milk FAs). ^271^

Jorgensen et al.'s breast feeding infants (n=17) received between 0.44% to 0.56%wt of AA, 0.13% to 0.23%wt of EPA and 0.43% to0.53%wt of DHA, while the formula-fed infants (n=16) received 14.4%wt LA and 1.7% wt of ALA (omega-3). The omega6/omega-3 ratio was comparable between groups. Small amounts of supplementary food (vegetable mashes and cereal-based gruel, one meal per day) were introduced to one breastfed and nine formula-fed infants from the age of 3 months. ^282^

Krasevec et al. ^275^ included data regarding the infant's feeding practices collected at 2 months of age. They were exclusively breastfed (n=31), fed with a combination of breast milk and bottle-feeding (n=22), or not fed any breast milk (n=3). The most common supplemental milk fed to these infants was a cow milk formulation made with skim milk powder and vegetable oil, as well as evaporated milk and yogurt. Supplemental milks had been fed for an average of 2 to 4 weeks before the 2-month study visit. Their mothers were receiving 454 g/week of a high fat fish (Trachurus mediterraneous) while breast feeding (source of LCPUFA). ^275^

Outcome characteristics. All but one of the studies ^280^ evaluated the visual function with the same test. The FPL was measured with the Teller Acuity Card Procedure. The retinal maturity was measured with an ERG in one study. ^279^ Visual acuity was also assessed using VEP acuity in three studies. ^278,^ ^280^ Finally, both Birch et al.'s term and preterm studies evaluated the visual function using the operant FPL acuity, stereo acuity, recognition acuity, color vision, letter matching, picture naming, orthopic exam at 36 months of age. All acuities were expressed in a common unit of measurement, which is independent of the technique, log MAR (log minutes of arc resolution). ^278^

All of the studies drew blood samples from the infants, and in one case from the mothers. ^275^ The description of the lipid extraction was adequate. The correlation between the RBC or plasma FA composition and the visual function outcomes was calculated.

Study quality and applicability. Although the studies employed different reseach designs, the mean quality score was 5.3 and the applicability assigned was level III.

#### Qualitative synthesis of individual study results

The results will be analyzed separately for preterm and term infants.

Both preterm studies reported different clinical outcomes related to visual function, thus they will be depicted independently. Birch et al. found that the breastfed infants had a significantly better VEP acuity than the formula-fed infants at 4 months of age. LogMAR acuity was significantly correlated with the end-product ratio [DHA n-3/DPA n-6] in total RBC lipids. For FPL acuity, the results were the same for both the breastfed and formula-fed groups. For the mean RBC end-product ratio, DHA/DPA was significantly higher in the human milk-fed infants compared with the formula-fed infants, and the LogMAR was significantly correlated with this ratio. ^278^

Leaf et al. analyzed the ERG (retinal function measure) at 40 weeks PCA in relation to dietary intake and to plasma and RBC LCPUFA content, and also to infant variables such as GA and age at recording, as possible effect modifiers. ^279^ The infant group was separated by the predominance of breast milk intake (nine infants had a high breast milk intake [mean 74% of total diet] and nine had a low breast milk intake [mean 17.5% of total diet]) in order to make comparisons. Scotopic and photopic ERG results were analyzed in relation to plasma and RBC FAs: AA and DHA, total omega-6 LCPUFA and total omega-3 LCPUFA as continuous variables. There was a positive correlation between scotopic b wave implicit time and percentage composition of DHA in both plasma and RBC PL. A similar relationship was seen with total n-3 LCPUFA in both plasma and RBC PL. There was a positive correlation between both RBC AA and total n-6 LCPUFA and scotopic a-b amplitude. No significant relationships were seen between photopic ERGs and either plasma or RBC LCPUFAs. The correlation between the Teller Card visual acuity test and blood biomarkers was not measured.

For the term population, since the exposure characteristics as well as the population characteristics were so different across the studies, the outcome measures will be described separately for each study.

Birch et al.'s mean VEP and FPL acuities were better in human milk-fed infants than in the formula-fed infants at 4 months of age. No correlation with RBC FA content was measured. ^278^ However, the 36-month evaluation of the full-term infant group showed that there was no statistical differences between groups (human milk vs. formula fed) in terms of mean OPL grating acuities, near recognition acuity and distance recognition. Human milk-fed infants had significantly better OPL stereoacuity than the formula-fed group at 36 months. The mean RBC end-product ratio, DHA/DPA in total RBC lipids, was significantly higher in the human milk group compared with the formula group, and stereo acuity was significantly correlated with the end-product ratio. The human milk group was significantly better in letter matching than the formula group. Performance on this outcome at 36 months was significantly correlated with the end-product ratio, DHA/DPA in total RBC lipids at 4 months. No significant differences were found between the two diet groups in picture naming or color vision. ^278^

Makrides et al.'s breastfed infants had a significantly smalled logMAR (i.e., better VEP acuity) than those who had been formula-fed at 5 months of age. There was no correlation between postnatal age and VEP acuity. Infants fed with breast milk had a greater proportion of RBC DHA and less RBC LA relative to those who had received infant formula. There was a significant correlation between logMAR (VEP acuity) and the proportion of DHA and LA (p < 0.01) in RBC PL. ^280^

The Innis et al.'s first study, the covariates used in the analysis were age (14 days of age vs. 3 months) and diet (human milk vs. formula). There was a nonsignificant difference between groups in visual acuity test at 14 days and at 3 months. Regression analysis indicated that visual acuity was not related to dietary intake or to plasma PL, RBC PC or PE concentrations of DHA, when tested for the entire group of infants, or just within the breastfed or formula-fed group of infants. ^281^

In the second Innis et al. study, the RBC PE DHA at 2 months was significantly and positively correlated to visual acuity at 2 and 12 months, but not at 4 and 6 months of age. Infants with an RBC PE DHA concentration < 8.53 g/100 g had significantly lower visual acuity at 2 and 12 months than infants with an RBC PE DHA > 10.78 g/100 g FAs. ^271^

Jorgensen et al.infant's visual acuity increased over time in both feeding groups, with a significantly higher increase in the breastfed group. There was no significant correlation between RBC DHA and visual acuity within the two feeding groups at 4 months. However, when the two groups were combined, the correlation became significant. There was no significant correlation between AA levels and visual acuity. ^282^ Finally, Krasevec et al.'s study did not find significant correlations between visual acuity scores and any individual EFA concentration, ratio of EFA concentrations, or group of EFA in infant tissues. The same results were obtained when the correlation was measured in the entire sample, and when assessing each feeding group (i.e., exclusively breast milk vs. not exclusively breastfed) separately. There were no relations between EFA profiles of maternal tissues for exclusively breastfed infants and visual acuity. ^275^ The mean visual acuity scores did not differ between feeding groups.

## Cognitive Development Outcomes

### What is the Evidence That Maternal Intake of Omega-3 Fatty Acids During Pregnancy Influences Cognitive Development in Term or Preterm Human Infants?

One RCT published in 2001 was identified which answered this question. ^141^ This study also answered the question regarding cognitive outcomes in breastfed infants whose mothers received the LCPUFA intervention. (Summary Table 44)

#### Overview of relevant study characteristics and results

Helland et al. assessed the gestational length, birth weight, and neurologic and cognitive outcomes in a sample of healthy pregnant women. They were randomized to receive cod liver oil (1183 mg/10 mL DHA, 803 mg EPA) or corn oil (LA and ALA) from week 18 of pregnancy to 3 months post delivery. ^141^

Helland et al. was conducted in Norway and funded by Peter Moller, Avd. Orkla ASA, and “Aktieselskabet Freia Chocoladefrabriks Medicinske Fond.”

The participants (n=590 enrolled) were included if they were healthy women with single pregnancies between 19 and 35 years of age, and intended to breastfeed their infant. They should not have taken any supplements of omega-3 FAs earlier during the pregnancy. The exclusion criteria were premature births, birth asphyxia, infections, and anomalies in the infants that required special attention. ^141^ Helland et al. had a high rate of dropouts, leaving 341 women in the final analysis (57%). ^288^

There was no difference between groups in body mass index before pregnancy and at birth, parity, smoking, or maternal and paternal education at baseline. ^141^ The mean age of mothers receiving cod liver oil was significantly higher than the age of mothers receiving corn oil.

The subjects were randomly assigned to either 10 mL/day of cod liver oil (Peter Moller, Avd Orkla ASA, Oslo, Norway), or identical 10 mL/day of corn oil from 18 week of pregnancy to 3 months after delivery. ^141^ The cod liver oil contaned 1,183 mg/10 mL DHA, 803 mg/10 mL of EPA. The corn oil contained 4,747 mg/10 mL LA (omega-6) and 92 mg/10 mL ALA (omega-3). The amount of fat-soluble vitamins was identical in both oils. There was no significant difference between groups in the maternal dietary intake of nutrients at baseline. ^141^ There was no significant difference in maternal plasma PL concentration of DHA before entering the study.

The cognitive outcomes were assessed using the Fagan test of Infant Intelligence at 27 and 39 weeks of age (6–9 months). A subpopulation analysis (n=90) was performed at 4 years of age, assessing the children's intelligence using the Kaufman Assessement Battery for Children (K-ABC). ^141^

Helland et al. did not observe a significant difference between groups in the novelty preference at 6 or 9 months of age. When the score from 6 and 9 months of age were combined, there still was no difference between the two groups. ^141^ When infants with high DHA concentration in umbilical plasma PL were compared with infants with low DHA concentration, there were no differences in novelty preference. Neither did they find differences in DHA concentrations between infants with high and low novelty preference. ^141^

Children in the cod liver oil group had significantly higher scores than the corn oil group on Mental Processing Composite of the K-ABC test at 4 years of age. There was nonsignificant difference between groups in the rest of the test composites (simultaneous processing scale and nonverbal scale). The Mental Processing Composite correlated significantly with HC at birth, but not with birth weight or gestational length. ^141^ No correlation was found between LCPUFA content in umbilical plasma PL and intelligence scores. Yet intelligence scores at 4 years correlated with plasma PL concentrations of DPA (omega-3) and DHA at 4 weeks of age. Mental processing skills of the children correlated significantly with maternal intake of EPA and DHA during pregnancy. ^141^

There were 153 withdrawals from randomization to the second Fagan test assessment. The reasons were congenital anomalies, infections in the mothers or infants, miscarriages, premature births, and before giving birth (lack of compliance, discomfort taking the oil). ^141^

Study quality and applicability. Helland's Jadad total quality score was 4, indicating good internal validity, yet with an unclear allocation concealment.

### What is the Evidence That the Omega-3 Fatty Acid Content of Maternal Breast Milk, With or Without Known Maternal Intake of Omega-3 Fatty Acids, Influences Cognitive Development in Term or Preterm Human Infants?

One RCT and a single prospective cohort study published between 1997 and 2001 were identified to answer this question. ^138,^ ^284^ Helland et al. also addressed this question, which was described above (see key question: Maternal Intake/Cognitive Development). (Summary Table 44 and 45)

#### Overview of relevant study characteristics and results

Gibson et al. was a double-blind RCT that investigated the maternal intake effect on breastfed infant's neurological and visual function outcomes in Australia. ^138^ This study included mothers of term infants (> 37 weeks of GA) who intended to breast feed for at least 12 weeks (n=52, means age: 30 [SD=4] years). These mothers were randomized to receive one of five doses (0, 0.2, 0.4, 0.9, or 1.3 g DHA/day) of a DHA-rich algal oil (DHASCO, Market Biosciences, MD, US) between day 5 and week 12 postpartum. The oil contained 43% DHA, 1% omega-6 FA, 38% saturates and 18% monosaturates. Infants who were exclusively breastfed for 12 weeks were assessed. Infants (n=20) were healthy, with appropriate weight for GA and Apgar scores greater than 7 at 5 minutes. ^138^ (Summary Table 45)

Infant's visual function using VEP (logMAR) was assessed at 12 and 16 weeks of life, and for global development (Bayley's Scales of Infant development) at 1 and 2 years of age. Blood was drawn for biomarker analysis in infants at 12 weeks of age. Mothers were from middle class families and completed year 12 education. The five groups were compared in terms of maternal age, maternal BMI, GA, infant's gender, birth weight, birth length, birth HC, Apgar score, siblings, maternal social score, smoking, education, home stimulation, and length of breast feeding, at baseline. There was a predominance of boys in the group that received the highest dose of DHA. ^138^

Agostoni et al. evaluated the neurodevelopmental indices at 1 year of age in a single prospective cohort of term infants (n=44; 54.5% males) who were exclusively breastfed for at least 3 months in Italy. ^284^ (Summary Table 45)

The children received breast milk for at least 3 months, after which weaning foods were introduced in all subjects. They underwent clinical examination at 0, 1, 3, 6, 9 and 12 months.

The mother's milk lipid composition was determined at each time-point. The day before, the control pooled milk was collected from all feedings over 24 hours. There was a progressive reduction of the number of breastfed infants to n=29 (at 6 months), n=17 (n=9 months) and n=10 (at 1 year).

Gibson et al.'s mean Bayley's Mental Developmental Index (MDI) score did not differ between groups at 1 or 2 years of age. ^138^ Bayley's MDI score at 1 year of age (n=51) was found to correlate with DHA indices in the infant's diet and status, although no association was found at 2 years (n=49). Length of breast feeding was also significantly correlated with MDI at 1 year, but not at 2 years. Length of breast feeding was collinear with indices of social status, education and home stimulation. ^138^ All these factors were consistent predictors of Bayleys MDI at both ages. Whether the partner smoked was also related to Bayley's MDI at 1 year, but not at 2 years. In a post hoc analysis, it was observed that at 1 year, home stimulation and RBC DHA were the only significant predictors of Bayley's MDI score. By 2 years of age, the model only included gender plus the social score of the oartner as predictors of Bayley's MDI. ^138^

The Bayley's MDI at 1 year old was 93.39 (SD=8.1). After correcting for potential confounders such us parity and mother's characteristics (i.e., age, education, smoking habits), breast-feeding for 6 months or longer was not significantly correlated to the mean MDI result compared with subjects who were breastfed for 3 to 6 months (n=15). ^284^ Associations between MDI and the milk fat content and composition were measured with a multiple regression analysis. There was a positive correlation between MDI and the milk total fat content at 6 months, but not at 12 months. There was no correlation between the AA and DHA FA content of breast milk and the MDI result at 12 months. ^284^

Study quality and applicability. Gibson et al.'s Jadad total quality score was 3, indicating a sound internal validity. However, the allocation concealment was unclear. ^138^ Agostoni et al. had a quality score of 8. ^284^

### What is the Evidence That the Omega-3 Fatty Acid Content of Infant Formula Influences Cognitive Development in Term or Preterm Human Infants?

### What is the Evidence That the Omega-3 Fatty Acid Content of Maternal Breast Milk, With or Without Known Maternal Intake of Omega-3 Fatty Acids, and Together With the Omega-3 Fatty Acid Content of Infant Formula, Influences Cognitive Development in Term or Preterm Human Infants?

### Infant Formula Intake - Preterm infants

Six RCTs met the eligibility criteria. They were published between 1992 and 2004. All the studies were summarized in the Growth Pattern Outcomes and Neurological Development Outcomes sections (see key questions: Growth Patterns & Neurological Development-Preterm Infants). (Summary table 46)

#### Overview of relevant studies

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. Six parallel RCTs involving preterm infants were identified to address these questions. ^193,^ ^207,^ ^258,^ ^272,^ ^273^ Five of them were published in English scientific journals, while one was published as an abstract. ^193^ Carlson et al. was conducted in the United States. ^185^ Both Fewtrell et al.'s studies were conducted in the UK, ^258,^ ^273^ van Wezel-Meijler et al.was located in the Netherlands, ^225,^ ^272^ Clandinin et al. was conducted in Canada, ^193^ and O'Connor et al. was sited in the US, UK and Chile. ^207^

Two studies involved three arms comparing the use of supplemented and unsupplemented infant formula with the addition of a fourth reference standard group (i.e., human milk). ^193,^ ^207^ Three RCTs compared only two study groups of formula with or without LCPUFA, ^185,^ ^258,^ ^272^ while another study also used a group using human milk as a reference standard. ^273^ Carlson et al. was supported by the National Eye Institute and Ross Laboratories. ^185^ van Wezel-Meijler et al. and Fewtrell et al.'s 2002 studies were supported by a private source, Numico Research. ^272,^ ^273^ Clandinin et al. was funded by Mead Johnson & Company (pharmaceutical-nutritional company), ^193^ while Fewtrell et al.'s 2004 study was supported by H.J. Heinz Company (food company). ^258^ O'Connor et al. did not report the funding source. ^207^

Population characteristics. There were 1,486 preterm infants enrolled across the included studies that were randomized to receive the supplemented or control formulas. The sample sizes ranged from 55 to 470 participants. The mean age of the infants at randomization was nonsignificantly different between study groups across the four RCTs. One study did not report the age of their infants. ^193^ The GA of the preterm infants was below 37 weeks across four studies, except for one study that also included VLBW term infants. ^193^ The between-group difference on the GA was not significant across the studies.

In five studies, the proportion of male participants did not differ significantly between randomized groups, although two studies did not mention this information or the between-group difference. ^185,^ ^193^ The range of percentage of males was from 35% to 56%.

Carlson et al. and O'Connor et al. described the racial composition of their participants. ^185,^ ^207^ Carlson et al. included 86.5% of Black infants, ^185^ while O'Connor included predominatly White subjects. ^207^ The rest of the studies failed to provide the race and/or ethnicity of their subjects.

Variables like birth weight, proportion of SGA patients, percentage from multiple pregnancies, Apgar score at birth were nonstatistically different between groups in two studies. ^185,^ ^207^ van Wezel-Meijler et al. matched their population by birth weight and proportion of SGA at baseline. ^272^ Both Fewtrell et al.'s infants were well matched by birth weight and length, proportion of SGA, proportion from multiple pregnancies, and delivered by C-section, at baseline. ^258,^ ^273^

Four of six studies analyzed the between-group difference of maternal covariates. Carlson et al.'s sample did not differ in maternal age and parental education. ^185^ O'Connor et al. matched their study groups by maternal age, education, smoking status during pregnancy and in the home, prenatal care, the HOME inventory score and the maternal intelligence measured with WAIS-R Raw vocabulary score. ^207^ Statistically siginificant differences in the HOME Inventory Score were observed between the following birth weight groups: 1) Infants with < 1,250 g, the control group had a higher score than infants in the AA + DHA (fish/fungal) group; 2) Infants > 1,250 g, the control group had a higher score than those in the AA + DHA (egg-TG/fish) group; and 3) Infants with a birth weight higher than 1,250 g in the AA + DHA (fish/fungal) group had a higher score than those in the AA + DHA (egg-TG/fish) group. ^207^

The inclusion criteria were described in every included study, however the exclusion criteria were not reported in two studies. ^193,^ ^273^

The studies included mostly healthy preterm infants with a defined weight range, drawn from neonatal intensive care units (NICU). Carlson et al. included VLBW (between 748 g and 1,390 g) preterm infants. ^185^ O'Connor et al. selected preterm infants (< 33 weeks of GA) with a birth weight range of 750 g to 1,805 g in NICU that could initiate enteral feeding by 28th day of life, including singleton and twin births, as well as SGA subjects. ^207^ van Wezel-Meijler et al. included premature infants (< 34 weeks of GA), with birth weight of < 1,750 g, normal neurological examination throughout the neonatal period, normal repeated brain ultrasound or showing minor abnormalities such as isolated subependymal haemorrhage and subventricle, with no ventricular dilation, transient periventricular echodensities, without evolution into cysts or any combination of previous findings. ^272^ Infants in Fewtrell et al.'s 2002 study had a GA below 37 weeks and a birth weight of < 1,750 g, free of congenital malformations known to affect neurodevelopment, whose mothers decided not to breastfeed at 10 days of age. ^273^ Preterm infants (GA < 35 weeks) in Fewtrell et al.'s study had a birth weight ≤ 2,000 g, and had received at least one of their enteral feeds as formula milk during their hospital stay. ^258^ Clandinin et al. included VLBW term and preterm infants after their feeding reached 30 mL/kg/day. ^193^

Four studies excluded infants with serious congenial abnormalities affecting growth and development, major surgery before randomization, periventricular or intraventricular hemorrhage, maternal incapacity, liquid ventilation asphyxia resulting in severe and permanent neurologic damage, or uncontrolled systemic infection at the time of enrollment. ^185,^ ^207,^ ^258,^ ^272^

Three RCT measured the blood content of FAs at baseline. ^185,^ ^207,^ ^272^ O'Connor et al. and van Wezel-Meijler et al. found a nonsignificant difference between groups in the plasma or PE or PC fractions of RBC levels of AA and DHA. ^207,^ ^272^ None of the studies measured the FA content of human milk.

Only two studies reported the presence of concurrent conditions in the study population and/or the use of medications. ^185,^ ^272^ Carlson et al.'s preterm infants had VLBW, and some were in mechanical ventilation and IV nutrition at randomization. ^185^ van Wezel-Meijler et al.'s study reported that 13 patients were excluded from the analyses for the following reasons: necrotizing enterocolitis (n=2, 1 each group), chronic lung disease (n=3, n=2 DHA-AA vs. n=1 control), grade 4 retinopathy of prematurity (n=1, AA + DHA), cystic periventricular leucomalacia (n=1, control), and the duration of artificial ventilation of their patients at baseline. No differences were found between groups. ^272^ None of the studies included information related to maternal concurrent conditions or medications, which could be relevant to patients taking human milk.

No other prestudy medications or treatments were mentioned in the included studies.

O'Connor et al.'s infants were formula and/or human milk fed before study entry, ^207^ whereas van Wezel-Meijler et al.'s study used parenteral nutrition with glucose/Vaminolact 6.75%/Intralipid 20% (Kabi-Fresenius, Stockohlm, Sweden) being administered for an average of 12 to 17 days, starting 24 hours after birth. This parenteral nutrition contained negligible amounts of LCPUFA. Three to 7 days after birth, enteral feeding was introduced using preterm formula (without LCPUFA). Total enteral nutrition was usually achieved within 2 to 3 weeks after birth. ^272^

Intervention/exposure characteristics. The intervention groups in each trial received different types of supplemented infant formula, thus each study will be discussed separately.

Carlson et al.'s patients received either a marine oil-supplemented formula with 0.3 g EPA and 0.2 g DHA as preterm formula until discharge (1,800 g), then term formula until 79 weeks of age. ^185^ The manufactured was Ross Laboratories.

O'Connor et al.'s study randomized its participants to receive one of three study formulas, with or without the addition of LCPUFA and/or human milk: intrahospital preterm formula (modified version of Similac Special Care [SSC]; ready-to-feed by Ross Products Division, Columbus, OH, US) with AA or DHA enriched oils until term CA; and at term CA, postdischarge nutrient-enriched formula (modified version of NeoSure powder) AA and DHA and/or human milk until 12 months of CA. ^207^ The first group received a supplemented formula with fungal and low-EPA fish oil (DHA/EPA ratio: 3.5/1) providing 0.27 g DHA, 0.08 g EPA and 0.43 g AA (per 100 mL) in the SSC formula and 0.16 g DHA and 0.43 g AA in the NeoSure formula. In the other group, egg- TG and low-EPA fish oil provided 0.24 g DHA and 0.41 g AA in SSC, but 0.15 g DHA in NeoSure. The purveyors of the fish, fungal and egg-TG oils were Mochida International (Japan), Suntory Ltd. (Japan) and Eastman Chemicals Co (US), respectively. The duration of the treatment was until 12 months of CA. ^207^

In van Wezel-Meijler et al., the neonates were randomized to receive preterm liquid formula supplemented with (4.4 g/100mL fat) a 2/1 ratio of DHA (0.015 g/100 mL [0.34% fat]) as DHASCO® oil produced by microalgae (Martek Inc., Columbia, US) and AA (0.031 g/100 mL [0.68% fat] as ARASCO® oil produced by fungi (Martek Inc.). The formula was continued from enrollment until a weight of 3,000 g was reached. Subsequently, this group continued with a supplemented term formula (3.5 g/100 mL fat) with a reduced absolute amount of DHA (0.012 g/100 mL; 0.34% fat) and AA (0.025 g/100 mL; 0.70 % fat) until 6 months of CA. ^272^

Fewtrell et al. used a LCPUFA-supplemented preterm formula (n=95) (Prematil, Milupan) fat blended with vegetable oils (palm coconut, soya, sunflower) and milk fat, with derivates of LA, and ALA sourced from evening primrose oil (GLA) and egg-lipids (AA 0.31 g; DHA: 017 g; EPA: 0.04 g [per 100mL]). Formula was provided as ready-to-feed form for a mean of 31 days until neonatal unit care discharge. ^273^

Clandinin et al. included two interventional groups. The intervention for the first group (DAS) was 17 mg DHA plus 34 mg AA/100 Kcal from single cell oils (SCO) (n=72) as preterm formula (24 Kcal oz), discharge formula (22 Kcal oz) and term formula (20 Kcal oz). The intervention for the second group (DAF) was the same as for DAS but with 17 mg DHA/100 Kcal from fish oil and 34 mg AA/100 Kcal from SCO (n=90). ^193^

Fewtrell et al.'s study used a preterm infant formula supplemented with LCPUFA (OsterPrem with LCPUFA) until the infants were discharged from NICU. Afterwards, a nutrient-enriched postdischarge formula was used (Farley's PremCare with LCPUFA). The fat was a blend of vegetable oils (high oleic sunflower oil, palmolein, palm kernel oil, and canola oil). LCPUFA were sourced from borage (starflower) oil (GLA: n-6 0.9g/100 mL) and tuna fish oil (high DHA/EPA ratio: DHA 0.5 g/100 mL, EPA: 0.1 g/100 mL, AA: 0.04 g/100 mL). Formula was provided in ready-to-feed form during the hospital stay and in powdered form after discharge up to 9 months after term. ^258^

The studies compared interventional formulas with identical appearance and smell, ^185,^ ^258,^ ^273^ and unsupplemented infant formulas containing the same proportion of monosaturated and saturated FAs, over the same time period as the intervention group.

The studies did not provide information regarding the background diet, when introduced, and the purity data for the omega-3 supplements. No study report included details as to whether, or how, the presence of methylmercury was tested or eliminated from the omega-3 FA exposure.

Cointervention characteristics. Human milk was the reference standard group, either as a separate arm, ^193,^ ^258,^ ^273^ or as part of the formula groups that did not comply with the intervention. ^207^ O'Connor et al.'s infant preterm and term formulas contained beta-carotene and natural vitamin E. ^207^ Both Fewtrell et al.'s subjects received and identical proportion of minerals and vitamins (A, D, E, and K) in their formulas. ^258,^ ^273^

Outcome characteristics. The instruments used to measure the cognitive development in the preterm infants were the Bayley's Scale of Infant Development (MDI), ^193,^ ^207,^ ^258,^ ^272,^ ^273^ the Fagan Test of Infant Intelligence (Infantest), novelty preference (a measure of visual recognition memory) by determining the percentage of total looking time spent looking at a novel versus familiar face stimuli during the test phase, mean duration of individual looks (measure of efficiency of information processing), ^185^ and the vocabulary checklist from the infant version of the MacArthur Communicative Development Inventories (a standardized parent-report instrument. ^207^ O'Connor et al.'s average percent of agreement on scoring between site testers and central testers was 91% (range: 71%-100%) for the Bayley's MDI. ^207^

Study quality and applicability. The six RCTs received a mean Jadad total quality score of 4.4, indicating a good internal validity (Summary Matrix 25). Three trials received a score of 5, ^258,^ ^272,^ ^273^ Carlson et al. received a score of 4, ^185^ and O'Connor received a score of 3. ^207^ O'Connor et al. was unblinded, ^310^ and Carlson et al. failed to report the method of double-blinding. ^150^

#### Qualitative synthesis of individual study results

O'Connor et al. did not find a statistical difference in the Bayley's MDI score between groups at 12 months CA. ^207^ van Wezel-Meijler et al. and both Fewtrell et al.'s studies failed to observe a statistically different MDI score between groups at any follow up. ^258,^ ^272,^ ^273^ Clandinin et al. ^193^ showed that term infants had higher MDI scores than preterm infants (data not shown). Infants in the DAA and DAF formula groups had significantly higher scores than infants in the control formula group, whereas infants in the human milk group had significantly higher scores than infants from the other groups at 118 weeks of postmenstrual age.

Carlson et al. and O'Connor et al. measured the Fagan Test of Infant Intelligence (Infantest) at 6, 9 and 12 months of CA. ^185,^ ^207^ Carlson et al. observed that, during novelty tests, both diet groups had a significant preference for novelty (i.e., longer looking time viewing the novel stimuli). ^185^ However, at 12 months DHA-supplemented group had a significantly lower novelty preference compared to control group. Diet influenced the number of discrete looks during the novelty test: the DHA group had more total (novel and familiar) discrete looks compared with the control group, as well as a shorter average look duration. ^185^ O'Connor et al. found that the mean novelty preference look was significantly greater in AA + DHA (egg-TG/fish) formula group than in the control and AA + DHA (fish/fungal) groups at 6 months. ^207^ Novelty preference has been interpreted as an early measure of information processing capability and it has validity for performance on standardized intelligent tests in childhood. ^345^ Shorter visual fixation look duration in infancy has also been shown to be related to superior performance in infancy and childhood. Shorter look duration has been interpreted as evidence of more efficient information processing or enhanced ability to disengage from attended stimuli. ^345^ However, there was a nonstatistically different result between groups in the Infant version of the MacArthur Communicative Development Inventories (a standardized parent-report instrument) at 9 months CA and 14 months CA. ^207^

Although the correlation between the FA content in blood and clinical outcomes was not measured, the level of AA and DHA was significantly higher at hospital discharge (mean time: 41 days) in the supplemented groups compared with the control group in the O'Connor et al. study. ^207^ With the exception of AA levels in RBC PE at 4 and 12 months CA, infants fed the AA + DHA supplemented formulas had higher levels of AA and DHA in plasma and RBC PL than those infants fed the control formulas. Infants fed AA + DHA (fish/fungal) but not AA + DHA (egg-TG/fish), had higher levels of AA in RBC PE than infants fed the control formulas (p < 0.02).

van Wezel-Meijler et al. did not find a statistically difference in AA levels in RBC between groups at 2 to 3 weeks. ^272^ DHA levels were significantly lower in the control group compared with the group receiving supplemented formula. ^272^

O'Connor et al.'s had 94 withdrawals (80%) at 12 months of CA. There were nonstatistically significant differences between groups. The main reason of the withdrawals was symptoms related to feeding intolerance. During the study, the following infant deaths were reported: six infants from the control group, three infants from the AA + DHA (fish/fungal) group, and six infants from the AA + DHA (egg-TG/fish) group; none of the infants from the human milk groups died. No infants deaths were related to study feedings. ^207^

There were 13 dropouts in van Wezel-Meijler et al.'s study. ^272^ The reasons were: necrotizing enterocolitis (NEC), chronic lung disease, grade 4 retinopathy of prematurity, cystic periventricular leucomalacia, change from formula feeding to mother's expressed milk and home to hospital distance. There were no losses to follow up. ^272^

In the first Fewtrell et al.'s study, ^273^ six patients randomized to the control formula withdrew from the trial before 3 weeks for the following reasons: early discharge (< 3 weeks of age) (n=3); NEC (n=1); intolerance of feeds (n=1); and breastfed (n=1). Fourteen infants withdrew from the supplemented formula group for the following reasons: early discharge (n=2); NEC (n=5); maternal concern (n=2); and death (n=2). There were 14 infants lost to follow up at 9 months in the control group, one was lost to follow up in the supplemented formula group, and three were lost to follow up in the human milk groups. There were two deaths in the supplemented formula group and three were lost to follow up in the human milk groups. ^273^ Clandinin et al. failed to report the dropouts. ^193^ In Fewtrell et al.'s study, reasons for dropout in the control group included: abdominal distention (n=1), death due to bronchopulmonary dysplasia at 25 days of age (n=1), and lost to follow up(n=21). In the supplemented formula group, reasons for dropout included: NEC (n=1), and lost to follow up at 18 months (n=15). ^258^

#### Quantitative synthesis

Only five studies measured the Bayley's MDI. This outcome was chosen to evaluate the possibility of meta-analysis. Yet, outcome results were only available for more than one study at two follow-up times: CA 12 months and 18 months. At CA 12 months, outcomes were available for two studies. ^207,^ ^272^ In van Wezel-Meijler et al., ^272^ the experimental group received supplemented formula from the first enteral feeding time until 6 months CA. In O'Connor et al., ^207^ however, supplemented formula was used until 12 months CA. We would have combined data at 6 months follow-up, but it was not available in O'Connor et al. ^207^ Thus, meta-analysis was not possible for this outcome.

#### Impact of covariates and confounders

Carlson et al. adjusted (ANOVA) the novelty test results in both groups for diet and study age and failed to find an change in the results; however, at 12 months, the DHA-supplemented group had a significantly lower novelty prederence compared with the control group. ^185^

In an intention-to-treat analysis using ANCOVA and taking into consideration covariates like site, gender, birth-weight stratum, feeding per gender, feeding per birth-weight stratum, HOME, maternal WAIS-R raw vocabulary score, GA, human milk intake, birth order, and the first language of the biological mother, O'Connor et al. did not find a statistical difference between groups at 12 months CA in the Bayley's MDI score. ^207^

The second Fewtrell et al. study, in a subgroup analysis, observed that the boys in the supplemented formula group had a significantly higher score than those in the control group at 18 months, and there was a significant interaction between diet and sex on the MDI score. These differences were maintained after adjusting for effect modifiers, such as maternal education and social class. ^258^

The power calculation and the intention-to-treat analysis approach was reported in three trials. ^310,^ ^321,^ ^322^

### Infant Formula Intake - Term Infants

Eight unique studies published between 1997 and 2002 were identified that addressed this set of questions. All the trials were summarized in the Growth Pattern Outcomes section (see key question: Growth Patterns-Term Infant Formula Intake). (Summary Table 47)

#### Overview of relevant studies

#### Qualitative synthesis of relevant studies' key characteristics

Study characteristics. Eight parallel RCTs involving term infants were identified. All of them were published in English scientific journals. Four studies were conducted in the United States, ^104,^ ^203,^ ^227^ whereas, two studies were located in the United Kingdom ^223,^ ^265^ and one in Australia. ^205^

Four studies involved two arms which compared formulas with or without LCPUFA, ^223,^ ^227,^ ^265^ however, Lucas et al. also had a reference standard group (i.e., human milk). ^265^ Three studies randomized their patients to three study groups, comparing the use of two different LCPUFA supplemented formulas with a standard formula, ^104,^ ^205,^ ^227^ yet two of them also included a breastfed group as a reference standard. ^104,^ ^205^ Finally, patients in Jensen et al.'s study received four different formulas with increasing amounts of ALA (omega-3), and decreasing amounts of LA (omega-6) and omega-6/omega-3 ratios. ^203^

Jensen et al. was supported by the U.S. Department of Agriculture, Agricultural Research Service, Mead-Johnson Nutritional Group, the Foundation Fighting Blindness, Research to Prevent Blindness, Inc. and the Retina Research Foundation. ^203^ Auestad et al. (1997 and 2001ab) were funded by Ross Products Division, Abbot Laboratories, ^104,^ ^227^ whereas, Lucas et al. ^265^ and Makrides et al. ^205^ were financially supported by Nestec Ltd., Switzerland. Willatts et al. was supported by Milupa Ltd., UK. ^223^

Population characteristics. There were 1,470 term infants enrolled across the included studies of infants randomized to receive LCPUFA supplemented formula or control formula. The sample sizes ranged from 40 to 447 participants. Most studies performed the randomization since birth or from the time when the infant could tolerate enteral feeding (mean time= 7 days of life). The mean age at randomization was only reported in two studies. ^104,^ ^203^ Three studies reported that the mean age of their participants was nonsignificantly different between groups, either at baseline or at the time of the assessment. ^104,^ ^203,^ ^223^ Four studies did not provide this information. ^205,^ ^227,^ ^265^ Six studies reported that the between-group difference in terms of gender or percentage of males was nonsignificant. ^104,^ ^205,^ ^223,^ ^227,^ ^265^ Jensen et al. did not provide the difference between study arms. ^203^

Makrides et al. only selected White participants. ^205^ Jensen et al.'s racial composition was: Black (62%), Hispanic (28.5%), and White (9.5%) at 120 days, yet statistical differences among groups was not reported. ^203^ Auestad et al. 1997's subjects were predominantly White among the groups, but this group was significantly larger in the nonrandomized breastfed group compared with the formula groups. ^104^ Auestad et al. 2001ab's studies included about 80% of European American infants, but the study groups did not differ significantly. ^227^ Two studies failed to provide the racial and/or ethnical composition of their participants. ^223,^ ^265^

Birth weight, GA, length and HC at birth, birth order, triceps skinfold thickness at birth, and Apgar score at 5 minutes were measured in most studies. The GA did not differ between groups in the four studies, ^104,^ ^227,^ ^265^ however, in Willatts et al.'s study, infants in the LCPUFA formula group had a significantly longer GA than infants in the control group. ^223^ Seven studies did not find a statistical difference between groups for birth weight. ^104,^ ^203,^ ^205,^ ^223,^ ^227,^ ^265^ None of the studies provided information regarding the maternal clinical history and/or medications that could have some influence on the FA composition of the breast milk.

The inclusion and exclusion criteria were reported in five studies. ^104,^ ^205,^ ^227,^ ^265^ The exclusion criteria were not reported in two studies. ^203,^ ^223^

The studies included healthy term infants (at least 37 weeks of GA) with appropriate weight for the GA (2,500 g–4,000 g). Two studies also included babies whose Apgar score was > 7 (at 5 minutes). ^227^ To receive formula, their mothers had to decide to not breastfeed and viceversa. The patients were excluded if they had congenital abnormalities, ^104,^ ^205,^ ^227,^ ^265^ Apgar score < 7 ^104^ , significant illness, ^104,^ ^227^ IV lipid infusion, blood transfusion, ^104^ and maternal medical history known to have proven adverse events on the fetus. ^227^

The maternal socioeconomic status was not reported in one trial. ^203^ Seven studies did not observe a statistically different status between group, in terms of maternal education, marital status, housing, and family size. Only Makrides et al.'s breastfed infants (reference standard group) had parents who were less likely to smoke, had attained a higher level of education, and had more prestigious social scores compared with formula-fed infants. ^205^

None of the studies reported the use of medications and/or treatments as well as concurrent conditions, at baseline, in the eligible infants or their mothers. The smoking status during pregnancy and at birth (in household) was significantly higher in mothers in the AA + DHA formula group compared with the other groups in Auestad et al. 1997's study. ^104^ In Makrides et al.'s study, the proportion of smokers in the DHA formula group was higher than in the other groups. ^205^ Both of Auestad et al. 2001's studies ^227^ did not reveal a significant difference between groups for maternal smoking status. ^227^

The prestudy diet characteristics in the mothers were not reported. Two studies mentioned that their infants received standard formula since birth until enrollment, yet not description was made. ^227,^ ^265^ One study mentioned that their infants were breastfed since birth and during the whole study. ^227^

None of the studies measured the biomarkers status in either plasma or RBC PL at baseline, in infants or their mothers.

Intervention/exposure characteristics. The intervention with formula was heterogeneous across the included studies, thus the description will be done separately for each trial.

Auestad et al. 1997 randomized their patients to receive two different liquid ready-to-feed formulas supplemented with LCPUFA. One of them contained AA (0.43 wt% total FAs) and DHA (0.12 wt%) from egg yolk PL (AA + DHA formula). T he second (DHA formula) provided DHA (0.2 wt%) from high DHA, low EPA fish (tuna) oil with a ration of DHA/EPA of ~4:1. The formulas contained the same amount of protein, carbohydrate, fat and energy (670–694 kcal) per liter. The oil blend consisted of high oleic safflower, coconut, and soy oils with or without PL or TG sources of LPUFA. The control formula contained the same amount of nutrients, but without the addition of DHA, EPA or AA. These formulas were provided as the sole source of nutrition for a minimum of 4 months. ^104^ In the reference standard group, the human milk contained similar amounts of AA and DHA than the supplemented formulas.

The infants were exclusively breastfed for at least 3 months, after which supplementation with commercial formula SW1 was permitted. ^104^

Birch et al. compared the use of three different infant formulas: Enfamil with iron; Enfamil with iron supplemented with 0.35% DHA (of total FA); or Enfamil with iron supplemented with 0.36% DHA and 0.72% AA. ^182^ All formulas provided LA and ALA. The source of the PUFA was single cell oils (DHASCO® and ARASCO®, Martek Biosciences, Columbia, US). All formulas were provided in ready-to-feed cans. The duration of intervention was from a mean of 2.1 days of life until 17 weeks (4 months). ^182^

Willatts et al. compared the use of LCPUFA supplemented formula with an unsupplemented formula. The standard formula was the Aptamil brand without DHA and AA. The supplemented formula was ready-to-feed Aptamil/Milupan manufactured by Milupa Ltd., Trowbridge, UK). The fat blend was derived from milk fat, vegetable oils, and egg lipids. While the omega-3 content was 0.15 g to 0.25 g/100 mL of DHA and 0.60 g to 0.65 g/100 mL of ALA, the omega-6 content was 11.5 g to 12.8 g/100 mL of LA and 0.30 g to 0.40g of AA. The intervention length was until 4 months of age. The total amount of formula intake during the trial did not differ between groups. ^223^

Lucas et al. compared the use of a supplemented formula (Nestec Ltd, Vevey, Switzerland) that contained 0.30% AA and 0.32% DHA from purified egg PL and TG fractions (Lipid Teknic, Norway), with an identical unsupplemented formula. ^265^ The duration of the intervention was until the age of 6 months. ^265^ The reference standard group (n=138) received only breast milk for at least 6 weeks. ^265^

In the Makrides et al. study, the LCPUFA supplemented formula (provided by Nestec Ltd., Konolfingen, Switzerland) contained 0.35% DHA as total FAs from tuna oil in one formula, and 0.34% DHA and 0.34% AA from an egg PL fraction in the second formula. ^205^ The control formula did not contain LCPUFA, yet the protein, fat and carbohydrate composition of all the formulas was identical, as well as the packaging. ^205^ The reference standard group's breast milk contained (n=33) 0.9 % EPA, 0.20 % DHA and 0.39% AA. ^205^

Auestad et al. 2001's reported trials had different intervention characteristics. The Auestad et al. 2001a compared the use of three formulas, two of them were supplemented with DHA+AA, one derived from fish oil and fungal oil, and the other derived from egg- TG. ^227^ All were liquid ready-to-use formulas with similar amount of protein, carbohydrate, fat and calories. The fat blend consisted of high-oleic safflower, coconut, and soy oils. They were indistinguishable in appearance and odor. All contained ALA and LA. The DHA+AA (fish/fungal) formula contained (per 100 mL) 0.46g AA, <0.04g EPA and 0.13g DHA, while the DHA+AA (egg-TG) contained (per 100 mL) 0.45g AA and 0.14g DHA. The duration of the intervention was from less than 9 days of life to 12 months of age. The formulas were exclusively administered during the first 4 months, then as sole milk beverage up to 12 months. ^227^ In Auestad et al. 2001b, ^227^ breast feeding was supplemented with a DHA+AA (human milk/egg-TG) formula, containing the same amount of DHA and AA described above in one group and a control formula and human milk as the comparator (human milk/control). The breast milk contained (per 100 mL) 0.51g AA, 0.05g EPA and 0.12g DHA. The duration of the breast feeding was exclusively until 3 months, after which only the formula was administered as the milk source. ^227^

Jensen et al. compared the use of four formulas with different content of LA (omega-6) and ALA (omega-3). The content of ALA and LA in each formula (from lowest to highest content of omega-3) was 0.4%, 0.95%, 1.7% and 3.2% of total FAs, for ALA, and 17.6%, 17.3%, 16.5% and 15.6% of total FAs, for LA, respectively. The PUFA's were abstracted from canola, safflower, high oleic sunflower and coconut oil. The amount of protein, total fat, energy, carbohydrate, vitamin and minerals were similar to those of Enfamil brand. The formulas were manufactured by Mead Johnson Nutritionals (Evansville, Ind.). The duration of the intervention was from day 1 of life to 120 days of life. ^203^

Cointervention characteristics. The background diet during the study period was not reported in two studies. ^205,^ ^223^ In Jensen et al.'s study, infants were exclusively formula-fed for 120 days, after which the diet intake was neither controlled nor monitored. ^203^ In Auestad et al.1997's study, supplementation with solid foods was permitted for all infants since 4 months of age. ^104^ The mean age of the first introduction of any solid food did not differ between groups in Lucas et al's study. ^265^ In both of Auestad et al. 2001's studies, infants were allowed to drink water and solid foods after 4 months of age. ^227^

Regarding the cointervention characteristics, three studies failed to provide this information. ^205,^ ^223,^ ^227^ Jensen et al. did not allow any medication during the study. ^203^ Auestad et al. 1997 only stated that there was a nonstatistically significant difference between groups in terms of cointerventions, yet did not provide details. ^104^ Lucas et al.'s LCPUFA group was prescribed more antibiotics (OR 1.3) and had more visits from a medical practitioner (OR 1.8) during the study period, but the differences were not significant compared with the control group. ^265^ Finally, since the infants in Auestad et al. 2001b ^227^ received breast milk besides the interventional formula, the former would be considered the cointervention. ^227^

Outcome characteristics. Seven studies used the Bayley's MDI scale. ^104,^ ^182,^ ^203,^ ^205,^ ^227,^ ^265^ Three studies utilized the MacArthur Communicative Development Inventories (a standardized parent-report instrument that evaluates the early word production, language comprehension, and gesture communication). ^104,^ ^227^

Jensen et al. also used the DQ for language development (CLAMS DQ), visual problem solving ability (CAT DQ) and overall cognition (mean of CLAMS and CAT DQ). ^203^ To assess the cognitive and language development at 39 months, the Stanford-Binet Intelligence Scale Form L-M, the Peabody Picture Vocabulary Test Revised (PPVT-R), and the Beery Visual-Motor Index test were used after standardization procedures in the Auestad et al. 1997. ^104^ Willatts et al. ^223^ used a problem-solving assessment in two steps, at 3 and 9 months of age. Lucas et al. also utilized the Knobloch, Passamanik, and Sherrards Developmental Screening Inventory at 9 months (as DQ). ^265^ Both of Auestad et al.2001's studies also assessed the cognitive development with the Fagan test of Infant Intelligence (Infantest) at 6 and 9 months. ^227^

Study quality and applicability. The eight RCTs received a mean Jadad total quality score of 4.1, indicating a good internal validity (Summary Matrix 26). Five trials received a score of 5, ^124,^ ^205,^ ^227,^ ^265^ Auestad et al. 1997 and Willatts et al. received a score of 3, ^104,^ ^223^ and one report received a score of 2. ^203^ Jensen et al. failed to report the method of randomization, ^325^ and three trials were unblinded. ^325,^ ^327,^ ^333^

#### Qualitative synthesis of individual study results

The Bayley's MDI scale was assessed in seven of eight studies. None of these studies but one observed a between-group significant difference at any follow up point. ^104,^ ^203,^ ^205,^ ^227,^ ^265^ Birch et al. found that the group supplemented with omega-3 FA for 4 months had a significantly higher score compared with the control group at 18 months of age. ^182^ Jensen et al. recognized that the groups were too small to detect an among-group difference in the neurodevelopmental indices. ^203^ The purpose of this study was to determine the correlation between the plasma and/or the RBC PL content of any omega-3 FAs, total omega-3 and/omega-6 FAs at 120 days, and neurodevelopmental indices at 1 year of age. ^203^

In Makrides et al.'s study, there was no difference when the scores were compared between the human milk with the formula groups at 1 year. There was a significant decrease in MDI scores of formula-fed infants between 1 and 2 years of age that was independent of the diet. ^205^

In relation to the Knobloch, Passamanik, and Sherrards Developmental Screening Inventory, Lucas et al. did not reveal a significant difference between study groups at 9 months, including the comparison with the reference standard group. ^265^

Only Auestad et al. 2001 evaluated the Fagan Test of Infant Intelligence (Infantest) in both study populations, failing to detect a significant difference between groups at 6 and 9 months. ^227^ The Infant version of the MacArthur Communicative Development Inventories (a standardized parent-report instrument) was measured in three studies. ^104,^ ^227^ At 14 months, two statistically significant differences were found in the components of this test in Auestad et al. 1997. ^104^ Vocabulary comprehension was significantly lower in the DHA group than in the human milk group. ^104^ Vocabulary production in the DHA group was marginally lower than that in the control formula group (p=0.052). The DHA + AA group did not differ from the human milk group. When the comparison is made only among the three formula groups, there was a significantly lower Vocabulary Production Score in the DHA group compared with the control group. ^104^ Both of Auestad et al. 2001's studies had a nonsignificantly different result between groups at 9 months. However, at 14 months, infants fed the DHA + AA (fish/fungal) formula had a slightly significantly higher vocabulary expression score than those fed the DHA + AA (egg-TG) formula. ^227^

Auestad et al. 1997 did not find a significant difference between groups for the IQ (Stanford-Binet), Receptive Vocabulary (PPVT-R), Expressive Vocabulary and Visual-Motor Index Score. ^104^

Regarding the problem-solving scores, Willatts et al. observed a nonsignificant difference between groups in the intention score and number of solutions at 3 months. ^223^

Jensen et al. did not find a correlation between the blood content of omega-3 and/or omega-6 FAs and the Bayley's MDI score at 1 year. ^203^ There were no statistical correlations, in a multiple regression analysis, between CAT/CLAMS DQ and the plasma or RBC PL content of any omega-3 or omega-6 LCPUFA at 120 days of age. CLAMS DQ (and index of the language development) correlated positively with the RBC PL content of EPA, but not with the plasma or RBC PL content of DHA. The CAT DQ (an index of visual problem solving ability) correlated positively with the plasma PL content of LA (omega-6) at 120 days. Finally, Makrides et al.'s regression analysis found that no FA variables significantly predicted MDI scores at either 1 or 2 years. ^205^

Birch et al. found that the MDI score at 18 months was positively correlated with plasma and RBC DHA at 4 months of age. None of the other plasma biomarkers (LA, AA, ALA, EPA) were correlated with the MDI at 18 months, although the RBC-LA and RBC ALA were negatively correlated with the MDI at 18 months of age. ^182^ None of the biomarkers measured at 12 months of age were correlated with the MDI at 18 months of age. ^182^

#### Quantitative synthesis

The outcome assessed was Bayley's MDI at age 4 and 12 months given that at these ages, the diet was exclusively formula (4 months) or a 12-month followup. At 4 months of age, the outcomes were not available in any of the studies. At age 12 months, outcomes were noted in three studies that were using the same comparators, i.e., DHA+AA versus unsupplemented formula. ^104,^ ^205,^ ^227^

Meta-analysis was performed using the random effects weighted mean difference (WMD)

The WMD for the Bayley's MDI score at 12 months of age in three studies (DHA+AA vs. control) was nonstatistically significant (WMD: -0.80, CI 95%: -3.24; 1.63). ^104,^ ^205,^ ^227^

#### Impact of covariates and confounders

The effect modifiers that could be influencing the results were controlled in all the studies. Variables like GA, gender, birth weight, length at birth, maternal age, and socioeconomic status were detected in most of the studies. Jensen et al.'s groups were comparable in terms of the study formula's intake. ^203^ The CAT DQ (an index of visual problem solving ability) correlated positively with weight at 120 days of age. ^203^

Auestad et al. 1997 observed that female sex was positively associated with IQ, receptive vocabulary, and visual-motor ability at 39 months. ^104^ Maternal education was positively associated with IQ and receptive vocabulary, when either all four feeding groups or only the formula groups were included in the regression model. The variable selection model identified which of 22 potentially influential variables contributed significantly to the variance for IQ and expressive language. Approximately one third of the variance for IQ was explained by four factors: sex, years of maternal education, number of siblings, and exposure to cigarette smoke. Positive associations were found for female sex and maternal education, and negative associations were found for the other two variables previously described. Expressive language was positively associated with maternal education, but negatively associated with average hours in childcare per week and hospitalizations since birth, but only when the breastfed group was included in the analysis. ^104^ At 14 months, there was a significant association between vocabulary production and comprehension. At 39 months, there was a significant association between receptive (PPVT-R) and expressive (MLU) language and between expressive language (MLU) and IQ. However, no significant associations between vocabulary production at 14 months and expressive language (MLU) at 39 months were found. ^104^

In the early peak-fixation infants, none of the covariables was significantly related to number of intentional solutions in Willatts et al. ^223^ In the late peak-fixation infants, only diet and birth weight were significantly related to the number of intentional solutions. ANCOVA on the intention scores for the effects of diet and peak fixation showed no significant main effects, and diet per peak interaction was not significant. ^223^ Regarding the problem-solving scores, Willatts et al. observed a nonsignificant difference between groups in the intention score and number of solutions at 3 months. ^223^ When adjusted by GA, the differences were still nonsignificant. ANCOVA on number of intentional solutions for the effects of diet and peak fixation, covariated with GA and birth weight, showed a significant diet per peak fixation interaction. Simple-effects analysis showed that the number of intentional solutions did not differ significantly between the early-peak fixation infants receiving LCPUFA. In contrast, the number of intentional solutions was significantly reduced in the late peak-fixation infants receiving the standard formula. ^223^

In Lucas et al.'s study, the results did not change after adjusting by center or observer (see above). ^265^ A multiple linear regression with adjustement for possible confounding factors and imbalance at baseline was made between the formula groups and the human milk reference standard group. ^265^ It did not observe a significant difference between formula groups and breastfed infants, even after adjusting by effect modifiers (sex, center, maternal age, maternal education, maternal marital status, and social class). ^265^ In relation to the Knobloch, Passamanik, and Sherrards Developmental Screening Inventory, Lucas et al. did not reveal a significant difference between study groups at 9 months, including the comparison with the reference standard group, which was maintained after adjusting by effect modifiers. ^265^

Makrides et al. found that the feeding mode was the only nutritional variable to predict MDI with formula feeding resulting in lower MDI scores. ^205^ Although environmental variables such as parental education, occupational prestige, and Home Screening Questionnaire scores were associated with Bayley's MDI at 1 and 2 years of age, only weight (at 1 year) and birth order, feeding mode, and gender (at 2 years) significantly predicted MDI. ^205^ At 2 years the MDI scores of breastfed infants were higher than those of the formula-fed group, even after adjusting for the significant covariates of gender and number of siblings (95% CI: 4.4–21.7). ^205^

The power calculation was reported in seven trials, ^124,^ ^132,^ ^151,^ ^325,^ ^329,^ ^333^ while the intention-to-treat analysis approach was reported in only one study. ^132^

## Cognitive Development Outcomes in Light of Biomarker Data

### What is the Evidence that Term or Preterm Human Infants' Cognitive Development is Associated With the Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Child Biomarkers?

Six studies were identified to answer this question. Two were RCTs and were described above (see key questions: Growth Patterns-Term Infant Formula Intake, and Maternal Intake/Visual Function). ^138,^ ^182,^ ^203,^ ^205^ Innis et al. and Ghys et al. were prospective single cohort studies published between 2001 and 2002. ^271,^ ^285^ (Summary Tables 45, 47 and 48)

#### Overview of relevant study characteristics and results

Innis et al. selected a cohort of 83 Canadian term infants who were exclusively breastfed, with birth weights in the range of 2,500 g to 4,500 g. ^271^ The objective of the study was to measure the infant RBC DHA content and its association with the visual, neuro or cognitive development. ^271^

Ghys et al. evaluated the association between the AA and DHA status at birth and the cognitive development at 4 years of age in a full-term infant cohort. ^285^

Innis et al. was funded by the Medical Research Council (MRC) of Canada and Ross Laboratories, OH. ^271^ Ghys et al. failed to report the funding source. ^285^

Innis et al. enrolled infant (n=83) with less than 2 weeks of age and to be eligible, their mothers were required to intend to breastfeed their infant without providing infant formula or cow's milk for at least 3 months, and without introducing solid foods for at least the first 4 months after birth. The infants were excluded if their mothers had substance abuse, metabolic or physiologic problems, communicable diseases, and infants with evidence of metabolic or physical abnormality. ^271^

Ghys et al. included full-term newborns (n=246) from healthy Caucasian women born between 1994 and 1995. A total of 128 (mean age 47 [SD=1.3] months, 55% males) infants were assessed for cognitive development outcomes at 4 years of age. ^285^

Only one mother was taking FA supplements with LA and DHA in Innis et al. The maternal diet was not reported or controlled. Only five mothers were smokers during the study. ^271^

In Ghys et al.'s study, 84% of infants were first born and none had suffered any neurologically damaging disorder or event, and 5% of the families lived on social security. ^285^

Innis et al. used the Bayley's MDI at 6 and 12 months to assess the cognitive development and its correlation with the RBC DHA and AA content in infants. ^271^ Another test used for this outcome, was Novelty preference with the Fagan Test of Infant Intelligence (Infantest) at 6 and 9 month of age. ^271^ Ghys et al. used the Dutch version of the Kaufman Assessement Battery for Children (K-ABC), and the Groningen Developmental Scale (GOS) for children between 2.5 and 4.5 years of age. ^285^

Multiple linear regression analysis was used to determine the impact of the FA variables on the outcomes in both studies. ^271,^ ^285^ In Innis et al.'s study, the analysis controlled statistically for the duration of breast feeding, maternal education, family income, gender, maternal smoking, birth order and birth weight, length and HC. ^271^

The covariables used in Ghys et al. were birth weight, breast feeding, maternal intelligence (IQ) and parental educational attainment, which are associated with cognitive development in infants. ^285^

Innis et al. did not find a statistically significant relation between the infant DHA or AA status (RBC) at 2 months of age and the Bayley's MDI score at 6 and 12 months of age, as well as the Novelty Preference at 6 and 9 months. ^271^

In a bivariate analysis, Ghys et al. did not observe a correlation between the DHA and AA concentration in infant's plasma or RBC and the cognitive development at 4 years of age. Small but significant associations occurred with maternal IQ, birth weight, duration of breast feeding, maternal smoking during pregnancy, and paternal educational attainment.

Study quality and applicability. Both studies had a mean total quality score of 8 and a level of applicability of III.

## Safety Issues

### What is the Evidence for the Risk, in Pregnant Women, of Short and Long-Term Adverse Events Related to Their Intake of Omega-3 Fatty Acids?

### What is the Evidence for the Risk, in Breast Feeding Women, of Short and Long-Term Adverse Events Related to Their Intake of Omega-3 Fatty Acids?

All nine unique relevant trials, ^196,^ ^230,^ ^232,^ ^233^ that were reviewed, reported some information on safety and/or adverse events (e.g., complications, intolerance) (See Summary Tables in Appendix E *). In one report, Olsen et al. ^230^ presented pregnancy-related adverse events/outcomes aggregated across six unique trials, four of which were preventive and two of which were therapeutic. ^230^ In seven of the nine trials, the experimental intervention consisted of LCPUFA enriched (fish oil) capsules. ^230,^ ^233^ The remaining two trials studied LCPUFA-enriched eggs ^232^ or margarine. ^196^ Control intervention in the nine trials consisted of the capsules, eggs, and margarine without the LCPUFA-supplementation, respectively.

In seven trials, ^230,^ ^233^ women in the experimental arms reported belching and unpleasant taste more often than those in the control arms. Two of eight studies reported the occurrence of nausea, ^196,^ ^230^ finding similar between-arm rates of nausea as opposed to another trial, ^233^ which showed that women in the LCPUFA supplementation arm experienced nausea more frequently than those allocated to the regimen of standard intervention (9.7% vs 2.9%). Note that the daily dose of EPA/DHA intake in this trial ^233^ was greater than that in other trials. ^196,^ ^230^

In the trial by Onwude et al., ^233^ the proportion of women who had had stomach pain was higher in the experimental arm compared with the control arm (4.8% vs. 0%). The aggregated results of six trials ^230^ showed the rates of stillbirths, stay at hospital after delivery, vaginal bleeding, macrosomia, anaemia, vomiting, constipation, diarrhoea, and nose bleeding were similar between the experimental and control arms. In their trial, Smuts et al. ^232^ observed fewer adverse events for the omega-3 supplemented than for the control arm (birth of infant with LBW: 0% vs. 26%, preterm delivery: 5.6% vs. 26%, C-section: 11% vs 32%, gestational diabetes: 0% vs. 16% ). De Groot et al. ^196^ observed similar rates of long-term hospitalization, diabetes mellitus, still birth, and postpartum depression in the two randomized groups. In this trial, six women were withdrawn/lost to follow up for the following reasons: morning sickness (n=2), long-term hospitalization (n=2), diabetes mellitus (n=1), and stillbirth (n=1). Of the nine trials, only Smuts et al.'s ^232^ explicitly reported their opinion on the underlying reasons (breech, preterm delivery, maternal gestational diabetes and chorioamnionitis) for the observed adverse events (admission to intensive care unit).

### What is the Evidence for the Risk, in Term or Preterm Human Infants, of Short and Long-Term Adverse Events Related to Maternal Intake of Omega-3 Fatty Acids During Pregnancy?

### What is the Evidence for the Risk, in Term or Preterm Human Infants, of Short and Long-Term Adverse Events Related to Their Intake of Omega-3 Fatty Acids After Birth (e.g., Maternal Breast Milk, Infant Formula Supplemented With Omega-3 Fatty Acids)?

### What is the Evidence That These Adverse Events, or any Contraindications, are Associated With the Intake of Specific Sources (e.g., Marine, Plant), Types (e.g., EPA, DHA, ALA) or Doses of Omega-3 Fatty Acids, Including in Specific Populations Such as Diabetics?

### Preterm infants

All the eleven relevant trials ^193,^ ^201,^ ^207,^ ^212,^ ^218,^ ^251,^ ^257,^ ^258,^ ^273,^ ^286,^ ^287^ that were reviewed, reported some information on safety/adverse events (e.g., complications, intolerance) (See Summary Tables in Appendix E *). The trials reported explicitly that the study infants had experienced similar arm-specific rates of the following adverse events (ascribed or not ascribed to the study participation): neonatal morbidity, ^193,^ ^212^ bleeding time, ^212^ gastric residuals, ^251,^ ^257,^ ^286^ spitting/abdominal distention, ^251,^ ^258,^ ^273^ respiratory effects (pharyngitis, rhinitis, bronchiolitis, pneumonia, and increased cough), ^218,^ ^273^ cardiovascular (bradycardia, cardiovascular event), gastrointestinal (increased abdomen, vomiting, diarrhoea, infection), haemic (anemia, hypoxia), lymphatic, urogenital, flatulence, otitis media, apnea,billirubinemia, ^218^ eczema, ^258,^ ^273^ death, ^201,^ ^207,^ ^218,^ ^258,^ ^273^ chronic lung disease, ^207^ systemic infection, ^207,^ ^258,^ ^273^ hospital readmission, ^207,^ ^273^ feeding intolerance, ^207,^ ^258,^ ^273^ retinopathy of prematurity, ^201,^ ^273^ intra-ventricular haemorrhage (IVH), ^201,^ ^273^ pulmonary haemorrhage, ^273^ necrotizing enterocolitis (NEC), ^201,^ ^258,^ ^273^ sepsis, ^201,^ ^273^ vomiting, ^257^ bradycardia, ^286^ and stool frequency. ^257,^ ^258^

The difference in the frequency of adverse events between the study arms was found only in three trials. ^218,^ ^258,^ ^273^ Specifically, in one trial ^218^ at 48 weeks of post-conception age (after 17 weeks of feeding), infants in the omega-3 supplemented arm had a higher rate of diarrhoea (vs. human milk arm) and flatulence (vs. control formula and human milk arms), but lower rates of milk intolerance and anaemia (vs. control formula).

Note that in the same trial, ^218^ but at 92 weeks post-conception age (after 60 weeks of feeding), the omega-3 FA-supplemented and control dietary arms had similar rates of flatulence, anaemia, and diarrhoea. In another trial, infants in the omega-3 FA-supplemented arm were found to have a lower mean number of stools per day, compared with those in the control arm (1.96 vs. 2.12). ^273^ In the trial by Fewtrell et al., ^258^ infants in the supplemented arm required the use of ventilation and umbilical catheters for a longer period of time than those in the control formula arm (median days ventilated: 4 [3–8] vs. 2 [2–5] and median days with umbilical catheters: 4 [3–6] vs. 3 [2–5]).

Information on the consequences (i.e., withdrawals, death) of adverse effects/intolerance was reported in six trials. ^201,^ ^207,^ ^218,^ ^258,^ ^273,^ ^287^ McClead et al., ^287^ reported that two infants who had developed tachycardia and tachypnea subsequently recovered. In the trial conducted by Vanderhoof et al., ^218^ the majority of those who were withdrawn, had cow's milk intolerance (n=8), vomiting (n=5), diarrhoea (n=3), ileus (n=3), enlarged abdomen (n=2), and NEC (n=2). Other more rare events leading to the infant's withdrawal were oesophageal reflux (n=1), constipation (n=1), rash (n=1), and cerebral necrosis (n=1). In another trial, ^207^ the formula feeding intolerance resulted in 51 (12% of the total number of randomized infants) withdrawals. Innis et al. ^201^ reported that amongst the 21 infants who were withdrawn from the feeding protocol, three infants had had NEC (n=2) and formula feeding intolerance (n=1). In the trial by Fewtrell et al., ^273^ ten infants were withdrawn for the following reasons: death (n=3; had chronic pulmonary disease requiring ventilation), NEC (n=6), and formula feeding intolerance (n=1). In another trial, ^258^ three infants, each of whom had developed bronchopulmonary dysplasia resulting in death, NEC, and abdominal distension, were withdrawn from the feeding protocol.

Most commonly reported reasons for death were SIDS (n=4; totalled across studies), ^201,^ ^218^ NEC (n=2; totalled across studies), ^218,^ ^273^ and pulmonary disease requiring ventilation (n=4; totalled across studies). ^258,^ ^273^ Only six trials reported explicitly that the adverse events and/or death occurring in these trials could not have been ascribed to the feeding diets. ^207,^ ^212,^ ^218,^ ^251,^ ^273,^ ^287^

### Term infants

Of the twelve unique relevant trials that were reviewed, eleven reported some information on safety and/or adverse events (e.g., complications, intolerance). ^104,^ ^182,^ ^203,^ ^205,^ ^227,^ ^261,^ ^265,^ ^266,^ ^268,^ ^287^ (See Summary Tables in Appendix E) The authors of one trial ^263^ failed to report any relevant data on the above-mentioned outcome of interest. Given the information provided by the study authors, in general, the experimental regimens had been well tolerated and the trial authors observed either no or very few serious adverse events occurring to the infants. In addition, even if certain adverse events were observed, none of the between-group differences with respect to their occurrence reached the traditional level of statistical significance, regardless of the timing of observation.

For example, six trials ^104,^ ^205,^ ^227,^ ^265,^ ^266,^ ^268^ reported that the infants had experienced similar arm-specific rates of the following adverse events (ascribed or not ascribed to the experimental diet): cataracts, ^104^ viral meningitis, ^104^ pyloric stenosis, ^104,^ ^265^ phenylketonuria, ^104^ , ≥1 hospitalization, ^104,^ ^268^ prescribed antibiotics, ^104,^ ^265^ otitis media, ^104^ respiratory infections, ^265,^ ^268^ gastroenteritis, ^265,^ ^268^ eczema, ^265^ asthma, ^265^ visit to medical practitioner, ^265,^ ^268^ vomiting, ^205,^ ^227,^ ^265,^ ^266^ constipation, ^205,^ ^265,^ ^266^ diarrhoea, ^205,^ ^266^ stool consistency, ^227,^ ^268^ and allergy. ^268^

The inability to find the between-group statistically significant differences in the proportions of infants with adverse events, could have been partially due to the small numbers of these events across these trials and/or insufficient sample size. For example, in one study, ^104^ the between-arm differences in the number of used prescriptions for antibiotics could not reach the statistically significant result (formula with [DHA]: 57% vs. formula with [DHA+AA]: 46% vs. breastfed group: 66%). Another study, ^265^ found that the formula with [DHA+EPA] supplementation group was prescribed more antibiotics (OR = 1.3, 95% CI: 0.8, 2.2) and had more visits to medical practitioner (OR = 1.8, 95% CI: 0.8, 4.2) than the control formula group, but neither of these differences was statistically significant. Of the remaining four trials, ^182,^ ^203,^ ^261,^ ^287^ three trials ^182,^ ^261,^ ^287^ reported explicitly that the experimental regimens had been well tolerated (i.e., trial authors observed either no or very few adverse events in the infants). These adverse events were: tachycardia and tachypnea, ^287^ diaper dermatitis, ^261^ unspecified illness unrelated to the diet and lactose intolerance, ^182^ and dietary protein hypersensitivity. ^203^ In the trial by Jensen et al., ^203^ it was not clear if the study infants had or had not experienced any adverse events (the authors did not state this explicitly). Note that these four trials, ^182,^ ^203,^ ^261,^ ^287^ on average, had a shorter length of intervention (range: 1–17 weeks) and smaller total sample size (range: 20–108 infants) than the six trials ^104,^ ^205,^ ^227,^ ^265,^ ^266,^ ^268^ (range: 12–48 weeks and 109–447 infants, respectively) that observed the greater number of adverse events (though with similar arm-specific rates of adverse events).

In seven trials, ^104,^ ^203,^ ^205,^ ^227,^ ^265,^ ^266,^ ^268^ it was explicitly reported that the infants who had had adverse events were withdrawn/non-completers. Three trials, ^104,^ ^182,^ ^266^ explicitly stated that some of the observed adverse events (viral meningitis, pyloric stenosis, cataracts, phenylketonuria, sudden infant death syndrome, and unspecified illness) were not related to the experimental formula feeding.