# Methods

## Overview

The UO-EPC's evidence report on omega-3 fatty acids in child and maternal health is based on a systematic review of the scientific-medical literature to identify, and synthesize the results from, studies addressing key questions. Together with content experts, UO-EPC staff identified specific issues integral to the review. A Technical Expert Panel (TEP) helped refine the research questions as well as highlighted key variables requiring consideration in the evidence synthesis. Evidence tables presenting key study-related characteristics were developed and are found in the Appendices. In-text summary tables were derived from the evidence tables. The methodological quality and generalizability of the included studies was appraised, and individual study results were summarized.

## Key Questions Addressed In This Report

The purpose of this evidence report was to synthesize information from relevant studies to address various questions. The questions are organized by the type of population (i.e., maternal/pregnancy versus child [e.g., term versus preterm delivery]) and the type of outcome data (i.e., clinical/pregnancy versus clinical/child-developmental capacity versus biological/biomarker status versus adverse effects):

- Maternal population, clinical/pregnancy outcomes:
  - What is the evidence that intake of omega-3 fatty acids influences the duration of gestation in women with or without a history of a previous preterm birth (gestational duration less than 37 weeks)?
  - What is the evidence that maternal intake of omega-3 fatty acids influences the incidence of preeclampsia, eclampsia or gestational hypertension?
  - What is the evidence that maternal intake of omega-3 fatty acids influences the incidence of births of human infants small for gestational age?
- Maternal population, biomarker data relating to clinical/pregnancy outcomes:
  - What is the evidence that the duration of gestation in women with or without a history of a previous preterm birth is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?
  - What is the evidence that the incidence of preeclampsia, eclampsia or gestational hypertension is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?
  - What is the evidence that the incidence of births of human infants small for gestational age is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?
- Child population, growth pattern outcomes:
  - What is the evidence that maternal intake of omega-3 fatty acids during pregnancy influences growth patterns in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences growth patterns in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of infant formula influences growth patterns in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, and together with the omega-3 fatty acid content of infant formula, influences growth patterns in term or preterm human infants?
  - What is the evidence that intake of omega-3 fatty acids from sources other than maternal breast milk or infant formula supplemented with omega-3 fatty acids, by term or preterm human infants, influences growth patterns?
- Child population, biomarker data relating to growth pattern outcomes:
  - What is the evidence that term or preterm human infants' growth patterns are associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?
  - What is the evidence that term or preterm human infants' growth patterns are associated with the omega-3 or omega-6/omega-3 fatty acid content of fetal biomarkers during pregnancy?
  - What is the evidence that term or preterm human infants' growth patterns are associated with the omega-3 or omega-6/omega-3 fatty acid content of child biomarkers?
- Child population, neurological development outcomes:
  - What is the evidence that maternal intake of omega-3 fatty acids during pregnancy influences neurological development in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences neurological development in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of infant formula influences neurological development in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, and together with the omega-3 fatty acid content of infant formula, influences neurological development in term or preterm human infants?
  - What is the evidence that intake of omega-3 fatty acids from sources other than maternal breast milk or infant formula supplemented with omega-3 fatty acids, by term or preterm human infants, influences neurological development?
- Child population, biomarker data relating to neurological development outcomes:
  - What is the evidence that term or preterm human infants' neurological development is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?
  - What is the evidence that term or preterm human infants' neurological development is associated with the omega-3 or omega-6/omega-3 fatty acid content of fetal biomarkers?
  - What is the evidence that term or preterm human infants' neurological development is associated with the omega-3 or omega-6/omega-3 fatty acid content of child biomarkers?
- Child population, visual function outcomes:
  - What is the evidence that maternal intake of omega-3 fatty acids during pregnancy influences visual function in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences visual function in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of infant formula influences visual function in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, and together with the omega-3 fatty acid content of infant formula, influences visual function in term or preterm human infants?
  - What is the evidence that intake of omega-3 fatty acids from sources other than maternal breast milk or infant formula supplemented with omega-3 fatty acids, by term or preterm human infants, influences visual function?
- Child population, biomarker data relating to visual function outcomes:
  - What is the evidence that term or preterm human infants' visual function is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?
  - What is the evidence that term or preterm human infants' visual function is associated with the omega-3 or omega-6/omega-3 fatty acid content of fetal biomarkers?
  - What is the evidence that term or preterm human infants' visual function is associated with the omega-3 or omega-6/omega-3 fatty acid content of child biomarkers?
- Child population, cognitive development outcomes:
  - What is the evidence that maternal intake of omega-3 fatty acids during pregnancy influences cognitive development in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences cognitive development in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of infant formula influences cognitive development in term or preterm human infants?
  - What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, and together with the omega-3 fatty acid content of infant formula, influences cognitive development in term or preterm human infants?
  - What is the evidence that intake of omega-3 fatty acids from sources other than maternal breast milk or infant formula supplemented with omega-3 fatty acids, by term or preterm human infants, influences cognitive development?
- Child population, biomarker data relating to cognitive development outcomes:
  - What is the evidence that term or preterm human infants' cognitive development is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?
  - What is the evidence that term or preterm human infants' cognitive development is associated with the omega-3 or omega-6/omega-3 fatty acid content of fetal biomarkers?
  - What is the evidence that term or preterm human infants' cognitive development is associated with the omega-3 or omega-6/omega-3 fatty acid content of child biomarkers?
- Maternal or child population, adverse effects:
  - What is the evidence for the risk, in pregnant women, of short and long-term adverse events related to their intake of omega-3 fatty acids?
  - What is the evidence for the risk, in breastfeeding women, of short and long-term adverse events related to their intake of omega-3 fatty acids?
  - What is the evidence for the risk, in term or preterm human infants, of short and long-term adverse events related to maternal intake of omega-3 fatty acids during pregnancy?
  - What is the evidence for the risk, in term or preterm human infants, of short and long-term adverse events related to their intake of omega-3 fatty acids after birth (e.g., maternal breast milk, infant formula supplemented with omega-3 fatty acids)?
  - What is the evidence that these adverse events, or any contraindications, are associated with the intake of specific sources (e.g., marine, plant), types (e.g., EPA, DHA, ALA) or doses of omega-3 fatty acids, including in specific populations such as diabetics?

The overarching goal was to identify and systematically review whatever evidence exists within the eligibility boundaries established for this review in consultation with our TEP and in light of the topics being addressed by SC-RAND and Tufts-NEMC EPCs. These boundaries are delineated in the Eligibility Criteria section (below). At all times, data obtained from children delivered at term and preterm (i.e., gestational duration less than 37 weeks) were evaluated separately. More details concerning the questions are provided in conjunction with the description of the Analytic Frameworks (below).

We were also guided collectively by ODS, our TEP and our UO-EPC review team content experts to examine, where data permitted, the possible influence on efficacy, association or safety evidence of the following potential effect modifiers:

- intervention/exposure length;
- timing of intervention/exposure period (e.g., beginning the 3^rd^day of life, for 4 months);
- type(s) of omega-3 fatty acid (e.g., ALA, EPA, DHA);
- source of the omega-3 fatty acids (e.g., marine, plant, nut), including the specific source (e.g., mackerel as an oily fish);
- total caloric/energy intake;
- delivery format (e.g., whole food servings, capsules, pourable or spreadable oils);
- dose/serving size, including the precision/control of its delivery (e.g., per-day specific, minimum, maximum or range of numbers of capsules, whole food servings or bottle-pourable litres);
- type of processing used to purify the intervention/exposure and/or to maintain the experimental blind (e.g., ethyl esterification; adding an anti-oxidant to stabilize/preserve oils; adding flavor to oils; [vacuum] deodorization);
- amount/dose of omega-6 fatty acid intake either added as a cointervention or identified as being present in the background diet, thereby establishing a specific, minimum, maximum or range of allowable or mandated on-study omega-6/omega-3 fatty acid intake;
- the identity of the manufacturer and/or certain characteristics of their product(s) (i.e., purity; presence of other potentially active agents that have not been added intentionally: e.g., methylmercury content);
- for questions relating to efficacy or association, the prestudy/baseline or on-study omega-3 or omega-6/omega-3 fatty acid content of blood lipid biomarkers;
- absolute or relative omega-3 fatty acid content of the prestudy/baseline diet;
- omega-6/omega-3 fatty acid content in the prestudy/baseline diet, with the study population's country of origin as a possible surrogate measure of the omega-6/omega-3 fatty acid content of the background diet; and,
- any study subpopulations (e.g., minority; ethnic; genetic, including diabetics).

Furthermore, where data permitted, the following factors with the potential to influence child and maternal health outcomes were also investigated:

- obstetric history (e.g., maternal age at conception and delivery; history of a previous and/or current preterm birth [length in weeks; etiology; spontaneous versus induced; history of preeclampsia, eclampsia or gestational hypertension; history of a previous birth of an infant small for gestational age);
- gynecologic history (e.g., uterine abnormalities);
- maternal general health history (e.g., medical and psychiatric), including maternal medication/treatment history (e.g., prescription and non-prescription drugs);
- breastfeeding history;
- setting (e.g., tertiary care hospital; community facility);
- other sociodemographic/economic factors (e.g., marital status, education, income, employment status);
- other maternal cointerventions (e.g., other supplement use [e.g., vitamins, minerals], psychological interventions, use of complementary/alternative [CAM] medicine/products);
- maternal illicit drug use history;
- history of domestic violence;
- maternal smoker history;
- history of maternal alcohol consumption;
- prenatal history (e.g., delivery anomalies);
- neonatal history (e.g., asphyxia; intracranial hemorrhage);
- pediatric history (e.g., medications/treatments; supplement use [e.g., vitamins, minerals]; immunizations); and,
- with respect to each child outcome in turn (e.g., cognitive development), the developmental capacity/status regarding the other child outcomes (i.e., growth patterns [e.g., weight, height and head circumference at birth]; neurological development; visual development).

Parental smoking and alcohol consumption especially during pregnancy yet also post-delivery are particularly important effect modifiers in that they have been observed to influence both child or maternal health and essential fatty acid status, with levels of the latter potentially affecting the former. ^152^

## Analytic Framework

Two analytic frameworks were developed to make explicit the review's specific links relating the populations and settings of interest (i.e., term versus preterm infants), the focal exposure or intervention (i.e., omega-3 fatty acids ingested as supplementation and/or from food sources), potential effect-modifying factors, key child and maternal health outcomes, and the possible role played by the omega-3 or omega-6/omega-3 fatty acid content of biomarkers in mediating the intake-outcome relationship. A first analytic framework (Figure 2) highlights maternal outcomes, whereas a second one focuses on child/developmental capacity outcomes (Figure 3). The possibility of adverse events (e.g., side effects) and contraindications is recognized in each framework. In short, the analytic frameworks outline the various lines of logic defining the review's research questions. But, not all linkages in each analytic framework were investigated.

Figure 2. Analytic Framework for omega-3 fatty acids in maternal health

Populations of interest in rectangles. Exposure in oval. Outcomes in rounded rectangles. Effect modifiers in hexagons. Solid connecting arrows indicate associations and effects reviewed in this report.

Figure 3. Analytic Framework for omega-3 fatty acids in child health

Populations of interest in rectangles. Exposure in oval. Outcomes in rounded rectangles. Effect modifiers in hexagons. Solid connecting arrows indicate associations and effects reviewed in this report.

One criterion established in this review is that each researchable question had to be clinically relevant. That is, irrespective of the population of interest, a question had to involve the investigation of at least one relevant clinical/pregnancy (i.e., maternal population: Figure 2) or developmental (i.e., child population: Figure 3) outcome. Likewise, to be eligible for inclusion in the review each study had to entail an investigation of at least one such outcome. Considering the purpose of the two-year task order is to afford a clinically-relevant research agenda, this decision was judged to be appropriate by both our TEP and our review team. Thus, excluded were studies whose sole focus was to examine the impact of omega-3 fatty acid interventions or exposures on the omega-3 or omega-6/omega-3 fatty acid content of biomarkers, even if the study populations met other eligibility criteria for the present review.

The questions investigating maternal/pregnancy outcomes refer to clinical events whose likelihood might be influenced by the maternal intake of omega-3 fatty acids (i.e., from supplementation and/or the diet) and/or which might be associated with specific levels of omega-3 fatty acid content (i.e., composition or concentrations) derived from any biomarker type obtained from pregnant women (e.g., red blood cells [RBCs]; plasma phospholipids) (Figure 2).

The clinical events constitute the outcomes of interest, and include the shorter-than-term duration of gestation, the birth of an infant small for gestational age, or the maternal development of preeclampsia, eclampsia, or gestational hypertension. Otherwise “healthy” pregnant women, with or without a history of the following, constitute the study populations of interest:

- a previous preterm birth (i.e., gestational duration less than 37 weeks);
- preeclampsia, eclampsia or gestational hypertension; or,
- a previous birth of an infant small for gestational age.

The questions investigating child outcomes refer to progress along four developmental arcs, which might be influenced by the term or preterm child's intake of omega-3 fatty acids from various sources (i.e., mother via the placenta, breast milk, post-delivery formula supplementation, and/or from other food sources or supplementation) and/or which might be associated with specific levels of omega-3 fatty acid content (i.e., composition or concentrations) derived from any biomarker type (e.g., RBCs; plasma phospholipids) or source (i.e., mother; child) (Figure 3).

At the time they and their breast milk serve as the child's source of omega-3 fatty acids, mothers may or may not have been receiving a supply of omega-3 fatty acids in their diet and/or from supplementation. The developmental arcs constitute the clinical-developmental outcomes of interest: growth patterns, neurological development, visual development, and cognitive development. The child populations of interest include otherwise “healthy” children delivered at term or preterm, with data from these populations investigated separately.

Overall, questions pertaining to maternal populations center on the possible preventive, or protective, value of omega-3 fatty acid content (i.e., intake and/or in biomarkers) with respect to specific pregnancy outcomes. On the other hand, questions regarding child populations concern the possible value of omega-3 fatty acid content (i.e., intake and/or in biomarkers) in facilitating (e.g., “catching up to,” maintaining, or accelerating) expected or possible types or rates of development. Questions relating to adverse effects in both populations are investigated with data obtained from interventional/exposure studies meeting eligibility criteria.

The possible influence of predefined effect modifiers is evaluated in relation to each of the questions. Where data permit, question-specific sections titled “Impact of Covariates and Confounders” elucidate a) those variables (e.g., intervention/exposure; population) that were consistently observed, across reviewed studies, to influence study outcomes as well as b) those variables (e.g., caloric/energy intake; smoker status; alcohol consumption), which having been controlled for either experimentally or analytically in reviewed studies, were observed to consistently influence, or consistently fail to influence, study outcomes.

## Study Identification

### Search Strategy

The search strategy for this project was designed to be comprehensive and achieve the highest possible recall of relevant clinical studies. The electronic search strategy was developed by an information specialist in consultation with clinical content experts in child and maternal health. The child and maternal health search concept was combined with the core omega-3 fatty acids search strategy established in collaboration with the project librarians, biochemists, nutritionists, and clinicians from the three EPCs involved in the 2-year, Health Benefits of Omega-3 Fatty Acids task order. Consultation among these sources provided the biochemical names and abbreviations of omega-3 fatty acids, names of commercial omega-3 fatty acids products, and food sources of omega-3 fatty acids.

The following electronic databases were searched: Medline (1966 - November Week 2 2003 and updated to February Week 3 2004), Premedline (Dec 13 2003), Embase (1980 to 2003 Week 50 and updated to 2004 Week 09), the Cochrane Library including the Cochrane Central Register of Controlled Trials (3rd Quarter 2003) and CAB Health (1973-Sept 2003). All databases were searched via the Ovid interface using Search Strategy 1 (Appendix A *), except CAB Health, which was searched through SilverPlatter using Search Strategy 2 (Appendix A). Searches were not restricted by language of publication, publication type, or study design, except with respect to the MeSH term “dietary fats,” which was limited by study design to increase its specificity. A total of 2,932 bibliographic records were downloaded, with duplicate records identified and removed using citation management software (Reference Manager®).

* Appendices and Evidence tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/o3mchtp.htmhttp://www.ahrq.gov/clinic/tp/o3mchtp.htm

Reference lists of included studies, book chapters, and narrative or systematic reviews retrieved after having passed the first level of relevance screening, were manually searched to identify additional unique references. Through contact with content experts, attempts were made to identify both published and unpublished studies. On behalf of the three EPCs investigating the evidence concerning the health benefits of omega-3 fatty acids, a letter was written to industry representatives to obtain additional evidence (Appendix B *). Investigators who frequently published study reports that were included in the review were contacted to clarify which of their reports were companion documents (i.e., multiple reports referring to the same study yet where each contains some unique outcome data or unique descriptions of the methods: e.g., additional follow-up data) or duplicate documents (i.e., a report which exclusively presents data published elsewhere). These informants were also asked to provide citations or copies of reports that our searches failed to detect and to identify the study each described. Investigators who responded with clarifying information included: Drs. Eileen Birch, Susan Carlson, Maria Makrides, Sjurdur Frodi Olsen, and Mary Fewtrell. All of these supplementary efforts to identify more evidence identified an additional 18 records that were entered into the collection for review. A final set of 2,049 unique references was identified.

### Eligibility Criteria

Published and unpublished studies, written in any language, were eligible for inclusion. Excluding grey literature from systematic reviews of interventions can lead to the overestimation of effect sizes. ^153^ Substantial bias in the results of a systematic review pertaining to a complementary/alternative medical (CAM) intervention can ensue from the exclusion of data from reports written in languages other than English. ^154^ AHRQ and ODS consider omega-3 fatty acids to be a CAM exposure.

To maximize their generalizability, clinical, developmental and biomarker data were required from live, otherwise “healthy” human study populations or subpopulations (e.g., genetic, minority, ethnic: e.g., diabetic) of any age. For sake of simplicity, we decided to use the generic term “child” when referring to infants (less than 12 months of age), toddlers and children up to 18 years old. Excluded were studies whose biomarker data were solely obtained from aborted fetuses because the circumstances associated with or leading to spontaneous or elective abortions (e.g., chromosomal abnormalities; non-chromosomal congenital abnormalities) could influence the fatty acid status of biomarkers in ways that would preclude an interpretation of these observations that is meaningful for the purposes of the present review. Moreover, different types of abnormal fetus may exhibit different rates of omega-3 fatty acid accumulation in tissue and/or different patterns of tissue-specific omega-3 fatty acid accumulation during gestation, resulting in the limited generalizability of the respective data.

Explicit affirmation of the health status of both the maternal and child populations, as well as the preterm/term status of the child populations, had to be provided in study reports. The concept of “child” was not predefined, and the impact on outcomes of any idiosyncratic definitions could not be evaluated post hoc. To allow the meaningful comparison of results from term and preterm infants, age was defined as postconceptional age. Also, if a study did not distinguish data obtained from term and preterm births, it was excluded from the review. Additional details concerning eligibility criteria (e.g., specific types of population required to address the research questions) have already been described with reference to the Analytic Frameworks, and are not repeated here. Excluded populations were those with peroxisomal (e.g., Zellweger's) disorders since this topic was addressed in SC-RAND's year-2 review of the evidence concerning omega-3 fatty acids in neurology.

Ideal interventional/exposure studies of newborns might be expected to enroll and expose them to sources of omega-3 fatty acids immediately post-delivery so as to have, at least in theory, the greatest possible impact on development, and to minimize confounding from earlier exposure to other sources of nutrition,. However, neither the exact or requisite timing of the onset of the intervention/exposure nor the absence of an intervention/exposure to other sources of nutrition (e.g., parenteral feeding in preterm infants) prior to study entry constituted eligibility criteria. Plans were nevertheless made to explore, where data would permit, the possible impact of these factors on outcomes.

No restrictions on the length or number of followups with respect to either study population were pre-established. Yet, given the dynamic nature of development, ideal studies of children might be thought to include multiple followups conducted at least according to expected developmental milestones specific to the four types of developmental arc of interest to the present review.

Interventional/exposure studies had to specifically investigate foods or supplements known to contain omega-3 fatty acids of any type (e.g., EPA, ALA), from any source (e.g., mother's milk, fish, walnuts, seed oil), any serving size or dose, delivered in any fashion (e.g., breastfeeding, capsules, liquid, LCPUFA-rich diet), and for any length of time. In all studies, some method had to have been employed to suggest the presence of omega-3 fatty acid content in the exposure, if not its actual amount (e.g., g/d). Studies investigating “PUFAs” or “ LC PUFAs,” or even types of diet one might presume would contain marine or land sources of omega-3 fatty acids (e.g., “Mediterranean diet”) at minimum had to highlight at least one source of the omega-3 fatty acid content (e.g., oily fish servings). No restrictions were placed on the types or doses of pre- or on-study cointerventions (e.g., omega-6 fatty acid intake, other dietary supplements). While omega-6 fatty acids appear to play a key role in health and development, and their possible co-influence on outcomes is thus assessed in our review, studies exclusively investigating their impact on health outcomes are excluded. A table placed at the end of this report summarizes the content of the fatty acids (and other constituents) in the various types of infant formula provided as supplementation in the included studies.

Randomized controlled trials (RCTs) are the gold standard method to investigate questions of intervention efficacy or effectiveness. ^155^ and were sought to address the research questions. If at least two RCTs were identified, no other types of design were required. Yet, if insufficient numbers of RCT were retrieved, non-RCT (i.e., controlled clinical trials, without random allocation) and observational studies were included. Excluded from this review were descriptive study designs, however (i.e., noncomparative case series; case studies).

RCTs exhibit a greater inherent potential to deal with potentially serious biasing influences (e.g., selection bias) although a poorly designed or conducted RCT can produce results whose interpretability is no less complicated by the presence of confounding influences, for example, than observations derived from a well-constructed and conducted study employing a design with a lesser intrinsic capacity to control for these biases (e.g., non-RCT; prospective cohort study). For example, not all intervention RCTs succeed, either through an explicit experimental plan or the process of randomization per se, to equally distribute known confounding influences (e.g., background diet; energy/caloric intake from the intervention) across their respective study groups.

That said, questions concerning the impact on child developmental outcomes of omega-3 fatty acid intake via formula supplementational alone, or formula supplementation given in addition to breast milk, could be investigated exclusively by RCT evidence. Other questions required the inclusion of observational study evidence (e.g., maternal intake of omega-3 fatty acids, and child developmental outcomes; the role of biomarkers). The observational studies included cross-sectional designs, which by virtue of the lack of temporal separation in their assessments of exposure and outcome, constitute the weakest evidence when it comes to suggesting causal relationships.

Any definition of control or comparator was permitted in the controlled studies (e.g., DHA versus olive oil placebo). However, not every control or comparator group constituted the most appropriate one. For example, with women in a study permitted to choose either to breast- or formula-feed their child, selection bias makes the analyzed comparison of the outcomes from these two groups difficult to interpret unequivocally. The breatfeeding group cannot be construed as the most appropriate control, even though some manufacturers of formula supplementation have attempted to match their fatty acid contents and other constituents to what is contained in human breast milk.

Designs potentially affording less equivocal interpretations include women, having chosen not to breastfeed their children, being randomized to receive formula supplementation either with or without omega-3 fatty acid content. These data would be eligible for inclusion in one type of meta-analysis in our review. Often, as stated earlier, these designs can also include women who exclusively chose to breastfeed their children. However, data from the breastfed children in such studies are exclusively used here as a possible reference standard, or comparison group, yet whose data are not entered into possible meta-analysis as control observations. Another type of design potentially affording less equivocal interpretations involve women, having chosen to exclusively breastfeed their children, who are then randomized to receive formula supplementation either with or without omega-3 fatty acid content. These data would be eligible for an independent meta-analysis.

The specific pregnancy outcomes were identified with reference to the Analytic Frameworks. Any and all child developmental outcomes reflecting the four categories of developmental arc were considered relevant. As markers of omega-3 fatty acid metabolism, the following fatty acid compositions or concentrations, from any source (e.g., red blood cell [RBC] membranes, plasma phospholipids), were considered relevant: EPA, DHA, AA/EPA, AA/DHA, AA/EPA+DHA. Studies exclusively evaluating the role of other biomarkers (e.g., cytokine production, eicosanoid levels), including preconditions (e.g., specific PG levels) often thought to be associated with our review-relevant clinical outcomes (i.e., the development of preeclampsia), were not included. These decisions were made with the assistance of our TEP.

### Study Selection Process

The present review employed specific electronic functionality in the form of an internet-based software system, housed on a secure web site. It brings appreciable efficiencies to the systematic review process and the management of a systematic review team. Electronic yields of literature searches are posted to the system for review. Reviewers then submit all of their results of relevance screening, data appraisal or data abstraction directly to the system. The software system automatically conducts an internal comparison of multiple reviewers' responses to screening questions, to determine the eligibility/relevance of a bibliographic record or a full report. As well, the software captures responses to specific requests to abstract pre-specified data (e.g., mean age of study participants; the assessment of a study's internal validity) from pertinent reports. One large advantage associated with using this software is that review team members are able to complete their work from wherever they have internet access.

Following a calibration exercise, which involved screening five sample records using an electronic form developed and tested especially for this review (Appendix C *), two reviewers independently screened the title, abstract, and key words from each bibliographic record for relevance by liberally applying the eligibility criteria. A record was retained if it appeared to contain pertinent study information. If the reviewers did not agree in finding at least one unequivocal reason for excluding it, it was entered into the next phase of the review. The reasons for exclusion were noted using a modified QUOROM format (Appendix D). ^156^ The screening process also aimed to identify the exact child and maternal health question a record addressed, in addition to determining whether it might also or instead pertain to any of the other topics being systematically reviewed by the three EPCs in year 2 of the omega-3 fatty acids project.

Print or electronic copies of the full reports for those citations having passed level one screening were then retrieved. After completing a calibration exercise which involved evaluating five sample reports using the same eligibility criteria (Appendix C), the rest of the reports were independently assessed by two reviewers. Reports were not masked given the equivocal evidence regarding the benefits of this practice. ^157^ To be considered relevant at this second level of screening, all eligibility criteria had to be met. A third level of dual-review screening aimed to exclude studies whose designs were not required to investigate the research questions (see Eligibility Criteria). All the levels of evidence were reviewed and when there were at least one study to address a given question, it was included regardless of the level of evidence. However, if there were at least two RCTs addressing the question, lower level of evidence reports were excluded (see list of excluded observational trials in Appendix F).

Disagreements arising either at screening levels 2 or 3 were resolved by consensus and, if necessary, third party intervention. Excluded studies at each of these levels are noted as to the reason for their ineligibility in listings found at the end of this report.

## Data Abstraction

Following a calibration exercise involving two studies, 11 reviewers independently abstracted the contents of included studies using an electronic Data Abstraction form developed especially for this review (Appendix C *). A second reviewer then verified these data. Data abstracted included the characteristics of the:

- report (e.g., publication status, language of publication, year of publication);
- study (e.g., sample size; research design; number of study arms/groups, cohorts, or phases; funding source);
- population (e.g., preterm versus term status);
- intervention/exposure (e.g., omega-3 fatty acid types, sources, doses, and intervention/exposure length), and comparator(s);
- cointerventions (e.g., omega-6 fatty acid use);
- withdrawals and dropouts, including reasons;
- clinical outcomes;
- fatty acid content of biomarkers; and,
- adverse events (e.g., side effects).

## Summarizing the Evidence

### Overview

The evidence is presented in three ways. Evidence tables in the Appendices offer a detailed description of the included studies (e.g., study design, population characteristics, intervention/exposure characteristics [e.g., omega-3 fatty acid types and doses], cointervention [e.g., background diet]), with a study represented only once. These tables are organized by research design (Evidence Table 1: RCTs; Evidence Table 2: observational studies), with studies arranged alphabetically within each of the two table/design categories.

Question-specific summary tables embedded in the text describe each study addressing a given question in abbreviated fashion, highlighting some key characteristics, including sample size (as measure of the “weight” of the evidence and possible precision of the results), dose and type of omega-3 fatty acids, and comparators' (i.e., comparison groups') specifications. This affords a comparison of all studies addressing a given question. A study can appear in more than one summary table since it can address more than one research question. Also question-specific is each summary matrix, situating each study in terms of its study quality and its applicability.

### Study Quality

Study quality refers to the internal validity, or methodological soundness, of a study. A systematic review can be faced with great variability in the quality of its included studies. Our approach is not to use a minimal level of quality as an inclusion criterion since this precludes assessing the possible impact of study quality on study results.

A study with low quality can make it difficult to clearly and meaningfully interpret its results, that is, to unequivocally attribute a significant observed benefit exclusively to an intervention/exposure (as opposed to other factors). Since definitions, or standards, of study quality can depend on the type of research design, different constructs were selected to evaluate, from study reports, the quality of RCTs and studies employing other types of research design. After a calibration exercise involving two studies with an RCT design, two assessors independently evaluated study quality. Disagreements were resolved via forced consensus. In the case of designs other than RCTs, a single quality assessor performed the evaluations. Time did not permit their dual assessment.

Four fundamental quality constructs from two instruments were used to rate the internal validity of RCTs. These tools were chosen collectively by the three EPCs involved in the 2-year task order because they have been validated. The Jadad items ^158^ assess the reporting of randomization, double blinding, and, withdrawals and dropouts (Appendix C *). Total scores range from 0 to 5, with a score less than 3 indicating low quality. The reporting of the concealment of a trial's allocation to treatment ^159^ yields three grades (A = adequate; B = unclear; C = inadequate) (Appendix C).

The assessment of the quality of studies using designs other than RCTs is complicated by the dearth of validated instruments and the variety of such designs (e.g., non-randomized controlled trials; uncontrolled studies). Nevertheless, a recent systematic review by Deeks et al. identified a number of “best tools” for use with these designs. ^160^ Among them was a published instrument developed by Downs and Black ^161^ and an unpublished albeit validated instrument derived by experts in Newcastle and Ottawa (NOS). ^162^ The former validated both design-specific and design-neutral items.

Where case-control studies were included in the review, the validated NOS was employed. Items applicable to cross-sectional designs were taken from the Downs and Black instrument; or, if the required constructs were not operationalized in this instrument, they were developed as modifications of existing NOS items (e.g., single prospective cohort studies).(Appendix C).

It should be noted that the items defining the case-control assessment tool from the NOS were used as a whole, although specific guidelines as to which total score indicates either low or sound quality are unavailable. Likewise, no guidelines exist to mark low or sound study quality based on any subset of Downs and Black's 27-item instrument. As already asserted, an Jadad total quality score of less than 3 indicates low quality. To permit the entry of these quality data into a summary matrix, cutpoints for each type of design were set somewhat arbitrarily to establish three levels of internal validity (see Summary Matrix).

It was decided by our review team that, given the limitations of space, especially in print-based study reports, and the amount of detail that would likely be required to provide all of the details we needed to fully establish that only appropriate methods had been used to extract, prepare, store and analyze lipid content, it was reasonable to appraise these methods by focusing instead on identifying extant descriptions of inappropriate methods. On occasion, the inappropriateness of methods had to be determined by reference to standard protocols.

Pilot-tested exclusively for their ease of use within the data abstraction form were questions designed to informally assess the successful control of study confounding from variables identified by content experts as potential threats to the internal validity of studies pertinent to the review. In their view, these variables required experimental or statistical control to permit an uncomplicated interpretation of study results (Appendix C *). The two major categories of threat in controlled designs came from having study groups vary in terms of key prestudy or baseline characteristics (e.g., background diet), or from having certain on-study changes (e.g., unexpected illness) unrelated to the exposure or intervention, occur unequally across study groups to produce confounding. Even RCTs are not immune to being influenced by these threats to internal validity.

For example, if in a placebo-controlled RCT test of the supplemental treatment efficacy of omega-3 fatty acids, only certain treatment group members' background diets changed appreciably from what was observed at baseline (e.g., decreased fish intake and thus an increased omega-6/omega-3 ratio in the background diet), at which point the two study groups' baseline diets had been deemed comparable, then this on-study inequality could influence study outcomes. Because of this change in background diet, one study group might all of a sudden be receiving a different ratio of omega-6/omega-3 fatty acid intake than what had been set in the study protocol. This would amount to a change in the planned, on-study between-group difference in omega-6/omega-3 fatty acid intake; and, it is this intake ratio which could have the greatest influence on clinical outcomes. In general, contraventions of planned on-study between-group equivalences (e.g., caloric/energy intake; background diet; current smoker status; alcohol consumption) or of planned, on-study between-group differences (e.g., amount of omega-3 fatty acid intake) related to events other than the intervention/exposure (e.g., stressors, which can alter participants' patterns of eating, smoking, and alcohol consumption), that is, in variables with the potential to affect child and maternal health outcomes (and biomarker levels), could either “mask” or incorrectly “reveal” clinical benefits of the intervention depending on the groups in which these unexpected changes occurred. Then, unless statistical adjustments are made, such a scenario will complicate the meaningful interpretation of outcomes.

These informal assessment items were modified to assess single group studies since on-study changes involving the same key variables can also complicate the interpretation of their study results. However, no quality scores were derived from the data abstractors' responses to these questions pertaining to controlled or uncontrolled studies.

### Study Applicability

As specified in the scope of work for this series of evidence reports on the health benefits of omega-3 fatty acids, the primary focus is on the US population. Given the geographical location of the UO-EPC, however, the definition of study applicability was expanded slightly to include Canada as part of a larger North American context. This study's reference point became the “typical” North American.

Also known as external validity, or generalizability, the construct of applicability refers to the degree to which a given study's sample population is sufficiently representative of the population to which one wishes to generalize its results. In the present review, two schemes operationally defined applicability (Appendix C *). One assessed studies involving at least one otherwise “healthy” maternal population, with the other evaluating studies involving at least one otherwise “healthy” maternal population with a known elevated risk for a particular pregnancy and/or infant outcome.

With regards to the highest level of applicability (Level I) in the first scheme, the broadest definition of the population of interest is the otherwise “healthy” North American (or similar individual), drawn from a somewhat broad socio-demographic spectrum (i.e., age, race), and who eats a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15: see below for references). For Level I applicability in the second scheme, the broadest definition of the population of interest is the otherwise “healthy” North American (or similar individual), at known risk for a particular pregnancy and/or infant outcome perhaps because of a similar past occurrence, representing a somewhat broad socio-demographic spectrum (i.e., age, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15). Together, these level I definitions represent the respective reference points, with applicability decreasing as the definition of the sample study population narrows in terms of the factors represented in the two schemes.

Operationalized ideally in this review as the omega-6/omega-3 fatty acid ratio, background diet may be an important factor in assessing both types of study population (i.e., no known risk versus known risk). Given the competitive relationship between omega-3 and omega-6 fatty acids, both for enzymes to yield key metabolites with specific effects in the human biosystem (see Chapter 1) and for positions in cell membranes from which to have these and other possible influences (e.g., clinical prevention), the absolute and relative intake of omega-3 and omega-6 fatty acids from all sources, and not just from the identified exposure, likely need to be taken into account when deciding whether populations assessed in different studies are comparable. The likelihood of biological and/or clinical effects in studies may turn out to vary depending on these absolute or relative intake values. A high background dietary omega-6/omega-3 fatty acid intake ratio—potentially reflected in a corresponding differential in these contents in cell membranes—may make it harder for omega-3 fatty acid supplementation to make a clinically meaningful difference, ^163^ although already having considerable omega-3 fatty acid content in the background diet and in cell membranes because of a low omega-6/omega-3 fatty acid intake ratio may make it difficult for typically small amounts of omega-3 fatty acid supplementation to make a clinically meaningful difference (see Discussion).

Irrespective of which of these hypotheses may be eventually confirmed elsewhere, the fact that national, and sometimes regional, populations can vary in terms of their diet's omega-6/omega-3 fatty acid intake ratio strongly suggests that this potential confounding influence on study outcomes needs to be represented in the applicability schemes whereby the North American value is the reference point. The typical North American diet contains an omega-6/omega-3 fatty acid intake ratio of at least 15, whereas urban India and Japan's corresponding values are 38–50 and 4, respectively. ^152,^ ^164–175^

UK populations represent somewhat of a special case in that, while they can exhibit socio-demographic pictures similarly broad to the ones seen in North American study populations, their somewhat different lifestyle and background diet recommended an applicability value of “II.” However, if participants were drawn from a narrower UK population, then a “III” was assigned. One assessor evaluated study applicability.

### Summary Matrix

For a given research question, and where possible (e.g., more than one study addressing the question), a summary matrix situates the pertinent studies in terms of their respective study quality (internal validity) and applicability (external validity) values. The Jadad total quality score defined RCTs' internal validity in summary matrices. A three-level format was derived from the range of possible RCT quality scores (A = Jadad total score of 4 or 5; B = Jadad total score of 3; C = Jadad total score of 0, 1 or 2). Given that allocation concealment scores have in the past tended to vary less widely than Jadad total scores, allocation concealment values were entered as superscripts in the summary matrices. ^163^ A similar approach was taken for the studies employing other research designs. The following cutpoints were established, albeit without benefit of a validational exercise:

- case-control study (NOS): A = 9–12; B = 5–8; C = 1–4;
- (multiple-group) cross-sectional study: A = 8–11; B = 5–7; C = 1–4; and,
- single prospective cohort study (Modified NOS): A = 8–10; B = 4–7; C = 1–3.

The three-level applicability format was established by the 3 EPCs involved in the 2-year project for practical reasons, to permit the incorporation of quality scores within a summary matrix. Studies assigned an “X” (i.e., insufficient information to establish applicability) were excluded from summary matrices.

### Qualitative Data Synthesis

An overarching qualitative synthesis describes the progress of each citation, then report, through the stages of the systematic review. It also highlights certain report and study design characteristics of included studies (e.g., distributions of research design by research question). Then, for each question, a separate qualitative synthesis is derived for included evidence, organized by broad categories of research design (i.e., RCTs vs observational studies). A brief study-by-study overview typically introduces the synthesis, followed by a narrative summary of the key defining features of relevant studies (e.g., inclusion/exclusion criteria), including their populations (e.g., diagnosis-related), intervention/exposures (e.g., types of omega-3 fatty acid), cointerventions (e.g., psychotropic medication), outcomes, study quality, applicability, and results. Whether or not data can be organized according to these subheadings depends on the number of studies addressing a given question and the amount or variety of detail available in the study reports. For example, having identified too few studies per research question that exhibit significant effects for a given clinical outcome can preclude determining the impact of covariables with the potential to modify or confound study results (e.g., type or dose of omega-3 fatty acids).

Juxtaposing, in turn, all pertinent studies' parameters for a given research question has two key consequences. It allows us to identify the “gaps” in knowledge deemed crucial by content experts to understanding the clinical phenomenon (e.g., efficacy of omega-3 fatty acids). That is, data regarding possible confounders may be lacking, making it difficult to interpret study results with unfettered confidence. These gaps point to those variables requiring measurement and experimental or statistical control in future research. Second, it affords an understanding of the definition and extent of the included studies' clinical homogeneity (i.e., population, intervention, cointervention, outcome), which can then inform decisions regarding the appropriateness of meta-analysis. Where strong clinical heterogeneity is observed, it may be important to forego meta-analysis because the “population” to which any point estimate, and its measure of precision, might be extrapolated may not exist per se; it, too, is synthetic (e.g., the “average” preterm infant). Subject to scrutiny in the evaluation of cross-study clinical homogeneity is the ability of each study to control for confounding influences and yield results that can be interpreted without serious question marks. The existence of statistical heterogeneity also plays a role in the decision to do without a quantitative synthesis. Whether or not meta-analysis is considered appropriate, an attempt is made to make sense of the possible influence of covariates and confounders within the context of the qualitative synthesis.

Where eligibility criteria permit, evidence from research designs with a lesser inherent potential to control for biasing influences are used to see whether, collectively, they confirm the picture of efficacy, or association, derived from designs with a greater inherent potential to achieve this goal (e.g., RCTs: see Eligibility Criteria). For the purposes of interpreting results, greater emphasis is placed on the latter, with “greater emphasis” meaning that we assign greater interpretative, not numerical or statistical, weight to these intrinsically stronger designs. Factors other than study design also taken into account in interpreting results include study quality, the number of studies, and whether studies were sufficiently powered.

### Quantitative Data Synthesis

Meta-analysis was conducted providing there was a clearly defined population to which to generalize the synthetic result (and its precision). Given its greater potential to control for possible confounding factors, only RCT evidence regarding the question of efficacy/effectiveness was considered for inclusion in meta-analysis. Details concerning certain study design requirements for entry into meta-analysis are presented in the Eligibility Criteria section (see above), and are not repeated here. All things being equal, it was also assumed that priority in meta-analysis should be given to clinical outcomes evaluated using validated measures pertinent to the present day practice of medicine (e.g., respective Bayley's scales for neurological and cognitive development).

The inclusion criteria to conduct meta-analysis were:

1. at least two RCTs;
2. same population characteristics (mean age, health status, gender);
3. same co-interventions;
4. same intervention based on the type of omega-3 FA supplemented (DHA+AA vs. DHA vs. DHA+EPA, etc.) regardless of the daily dose in the child population;
5. same comparator based on source of placebo (e.g., olive oil, unsupplemented formula);
6. outcomes relevant to respond the key-questions: percentage (n) of premature deliveries, incidence of GHT, pre-eclampsia or eclampsia, incidence of IUGR or SGA infants, weight, length and head circumference of infants (means), neurological and cognitive development measured by validated scales (e.g., Bayley's Develomental Scale score), and visual acuity or visual function of infants measured by appropriate tests (Teller's Card test, etc.).

Insufficient numbers of study with comparable populations, interventions, intervention-comparator contrasts or outcomes precluded the conduct of a) many planned meta-analyses; b) planned subgroup analyses involving virtually all of the predefined covariables with the presumed potential to influence pertinent clinical-developmental outcomes (e.g., source, type or dose of omega-3 fatty acids); and c) planned sensitivity analyses investigating the possible impact of study quality and publication bias on clinical-developmental outcomes.

Decisions regarding statistical models and related issues such as statistical heterogeneity are provided where results of meta-analysis are reported.