# Introduction

This evidence report by the University of Ottawa's Evidence-Based Practice Center (EPC) concerning the effects of omega-3 fatty acids on child and maternal health is one among several that address topics related to omega-3 fatty acids that were requested and funded by the Office of Dietary Supplements, National Institutes of Health (NIH), through the EPC program at the Agency for Healthcare Research and Quality (AHRQ). Three EPCs—the Tufts-New England Medical Center (Tufts-NEMC) EPC, the Southern California-RAND (SC-RAND) EPC, and the University of Ottawa EPC (UO-EPC)—each produced evidence reports. To ensure consistency of approach, the three EPCs collaborated on selected methodological elements, including literature search strategies, rating of evidence, and data table design.

The aim of these reports is to summarize the current evidence concerning the health effects of omega-3 fatty acids on the following: cardiovascular diseases, cancer, child and maternal health, eye health, gastrointestinal/renal diseases, asthma, autoimmune diseases, immune-mediated diseases, transplantation, mental health, and, neurological diseases and conditions. In addition to informing the research community and the public on the effects of omega-3 fatty acids on various health conditions, it is anticipated that the findings of the reports will also be used to help define the agenda for future research.

The focus of this report is on child and maternal health outcomes in humans. In this chapter, the metabolism, physiological functions, and sources of omega-3 fatty acids are briefly discussed. This constitutes background material, putting in context the data presented in the evidence report. As well, the description of the U.S. population intake of omega-3 fatty acids is provided in response to a general question posed within the task order. This introductory material is then complemented by a brief review of the epidemiology and descriptions of the child and maternal health issues related to this intervention. The brief review is intended as an overview, rather than a comprehensive description.

Chapter 2 describes the methods used to identify, review and synthesize the results from studies concerning omega-3 fatty acids and child and maternal health. Chapter 3 presents the findings of studies meeting eligibility criteria, with discussion points, including recommendations for future research completing the report in Chapter 4.

## Metabolism and Biological Effects of Essential Fatty Acids

Dietary fat is an important source of energy for biological activities in human beings. It encompasses saturated fatty acids, which are usually solid at room temperature, and unsaturated fatty acids, which are liquid at room temperature. Unsaturated fatty acids can be further divided into monounsaturated and polyunsaturated fatty acids. Polyunsaturated fatty acids (or PUFAs) can be classified, on the basis of their chemical structure, into two groups: omega-3 (n-3) fatty acids and omega-6 (n-6) fatty acids. The omega-3 or n-3 notation means that the first double bond in this family of PUFAs is 3 carbons from the methyl end of the molecule. The same principle applies to the omega-6 or n-6 notation. Despite their differences in structure, all fats contain the same amount of energy (i.e., 9 kcal/g or 37 kJ/g).

Of all fats found in food, two—alpha-linolenic acid (chemical abbreviation: ALA; 18:3 n-3) and linoleic acid (LA; 18:2 n-6)—cannot be synthesized in the human body, yet these are necessary for proper physiological functioning. These two fats are thus called “essential fatty acids.” The essential fatty acids can be converted in the liver to long-chain polyunsaturated fatty acids (LC PUFAs), which have a higher number of carbon atoms and double bonds. These LC PUFAs retain the omega type (n-3 or n-6) of the parent essential fatty acids.

ALA and LA comprise the bulk of the total PUFAs consumed in a typical North American diet. Typically, LA comprises 89% of the total PUFAs consumed, while ALA comprises 9%. Smaller amounts of other PUFAs make up the remainder. ^1^ Both ALA and LA are present in a variety of foods. For example, LA is present in high concentrations in many commonly used oils, including safflower, sunflower, soy, and corn oil. ALA, which is consumed in smaller quantities, is present in leafy green vegetables and in some commonly used oils, including canola and soybean oil. Some novelty oils, such as flaxseed oil, contain relatively high concentrations of ALA, but these oils are not commonly found in the food supply.

The Institute of Medicine (IOM) suggests that, for adults 19 and older, an adequate intake (AI) of ALA is 1.1–1.6 grams/day, and 11–17 grams/day for LA. ^2^ Recommendations regarding AI differ by age and gender groups, and for special conditions such as pregnancy and lactation.

As shown in Figure 1, eicosapentaenoic acid (EPA; 20:5 n-3) and docosahexaenoic acid (DHA; 22:6 n-3) can act as competitors for the same metabolic pathways as arachidonic acid (AA; 20:4 n-6). In human studies, the analyses of fatty-acid compositions in both blood phospholipids and adipose tissue have shown a similar competitive relationship between omega-3 LC PUFAs and AA. General scientific agreement supports an increased consumption of omega-3 fatty acids and reduced intake of omega-6 fatty acids to promote good health. However, for omega-3 fatty acid intake, the specific quantitative recommendations vary widely among countries not only in terms of different units — ratio, grams, total energy intake — but also in quantity. ^3^

Figure 1. Classical omega-3 and omega-6 fatty acid synthesis pathways and the role of omega-3 fatty acids in regulating health/disease markers

Furthermore, there remain numerous questions relating to the inherent complexities concerning omega-3 and omega-6 fatty acid metabolism, in particular the relationships between the two fatty acids. For example, it remains unclear to what extent ALA is converted to EPA and DHA in humans, and to what extent the high intake of omega-6 fatty acids compromises any benefits of omega-3 fatty acid consumption. Without the resolution of these two fundamental questions, it remains difficult to study the importance of the omega-6/omega-3 fatty acid ratio.

## Metabolic Pathways of Omega-3 and Omega-6 Fatty Acids

Omega-3 and omega-6 fatty acids share the same pools of enzymes and go through the same oxidation pathways while being metabolized (Figure 1). Once ingested, the parent of the omega-3 fatty acids, ALA, and the parent of the omega-6 fatty acids, LA, can be elongated and desaturated into LC PUFAs. LA is converted into gamma-linolenic acid (GLA; 18:3 n-6), an omega-6 fatty acid that is a positional isomer of ALA. GLA, in turn, can be converted to the long-chain omega-6 fatty acid, AA, while ALA can be converted, to a lesser extent, to the long-chain omega-3 fatty acids, EPA and DHA. However, the conversion from parent fatty acids into LC PUFAs occurs slowly in humans, and conversion rates are not well understood. Because of the slow rate of conversion, and the importance of LC PUFAs to many physiological processes, humans must augment their level of LC PUFAs by consuming foods rich in these important compounds. Meat is the primary food source of AA, and fish is the primary food source of EPA.

The specific biological functions of fatty acids depend on the number and position of double bonds and the length of the acyl chain. Both EPA and AA are 20-carbon fatty acids and are precursors for the formation of prostaglandins (PGs), thromboxane (Tx), and leukotrienes (LTs)—hormone-like agents that are members of a larger family of substances called eicosanoids. Eicosanoids are localized tissue hormones that seem to be one of the fundamental regulatory classes of molecule in most higher forms of life. They do not travel in the blood, but are created in the cells to regulate a large number of processes, including the movement of calcium and other substances into and out of cells, dilation and contraction of muscles, inhibition and promotion of clotting, regulation of secretions including digestive juices and hormones, and, the control of fertility, cell division, and growth. ^4^

As shown in Figure 1, the long-chain omega-6 fatty acid, AA, is the precursor of a group of eicosanoids including series-2 prostaglandins (PG_2_) and series-4 leukotrienes (LT_4_). The omega-3 fatty acid, EPA, is the precursor to a group of eicosanoids including series-3 prostaglandins (PG_3_) and series-5 leukotrienes (LT_5_). The series-2 prostaglandins and series-4 leukotrienes derived from AA are involved in intense actions (such as accelerating platelet aggregation, and enhancing vasoconstriction and the synthesis of mediators of inflammation) in response to physiological stressors. The series-3 prostaglandins and series-5 leukotrienes derived from EPA are less physiologically potent than those derived from AA. More specifically, the series-3 prostaglandins are formed at a slower rate and work to attenuate excessive series-2 prostaglandins. Thus, adequate production of the series-3 prostaglandins, which are derived from the omega-3 fatty acid, EPA, may protect against heart attack and stroke as well as certain inflammatory diseases like arthritis, lupus, and asthma. ^4^ In addition, animal studies have demonstrated that omega-3 LC PUFAs, such as EPA and DHA, engage in multiple cytoprotective activities that may contribute to antiarrhythmic mechanisms. ^5^ Arrhythmias are thought to contribute to “sudden death” in heart disease.

In addition to affecting eicosanoid production as described above, EPA also affects lipoprotein metabolism and decreases the production of other compounds—including cytokines, interleukin 1β (IL-1β), and tumor necrosis factor α (TNF-α)—which have pro-inflammatory effects. These compounds exert pro-inflammatory cellular actions that include stimulating the production of collagenase and increasing the expression of adhesion molecules necessary for leukocyte extravasation ^6^ The mechanism responsible for the suppression of cytokine production by omega-3 LC PUFAs remains unknown, although suppression of eicosanoid production by omega-3 fatty acids may be involved. EPA can also be converted into the longer chain omega-3 form of docosapentaenoic acid (DPA, 22:5 n-3), and then further elongated and oxygenated into DHA. EPA and DHA are frequently referred to as VLN-3FA—very long chain n-3 fatty acids. DHA, which is thought to be important for brain development and functioning, is present in significant amounts in a variety of food products, including fish, fish liver oils, fish eggs, and organ meats. Similarly, AA can convert into an omega-6 form of DPA.

Studies have reported that omega-3 fatty acids decrease triglycerides (Tg) and very low density lipoprotein (VLDL) in hypertriglyceridemic subjects, concomitant with an increase in high density lipoprotein (HDL). However, they appear to increase or have no effect on low density lipoprotein (LDL). Omega-3 fatty acids apparently lower Tg by inhibiting VLDL and apolipoprotein B-100 synthesis, and decreasing post-prandial lipemia. ^7^ Omega-3 fatty acids, in conjunction with transcription factors (small proteins that bind to the regulatory domains of genes), target the genes governing cellular Tg production and those activating oxidation of excess fatty acids in the liver. Inhibition of fatty acid synthesis and increased fatty acid catabolism reduce the amount of substrate available for Tg production. ^8^

As noted earlier, omega-6 fatty acids are consumed in larger quantities (> 10 times) than omega-3 fatty acids. Maintaining a sufficient intake of omega-3 fatty acids is particularly important since many of the body's physiologic properties depend upon their availability and metabolism.

## U.S. Population Intake of Omega-3 Fatty Acids

The major source of omega-3 fatty acids is dietary intake of fish, fish oil, vegetable oils (principally canola and soybean), some nuts such as walnuts, and, dietary supplements. Two population-based surveys, the third National Health and Nutrition Examination (NHANES III) 1988-94, and the Continuing Survey of Food Intakes by Individuals 1994-98 (CSFII), are the main sources of dietary intake data for the U.S. population. NHANES III collected information on the U.S. population aged ≥2 months. Mexican Americans and non-Hispanic African-Americans, children ≤5 years old, and adults ≥ 60 years old were over-sampled to produce more precise estimates for these population groups. There were no imputations for missing 24-hour dietary recall data. A total of 29,105 participants had complete and reliable dietary recall.

The CSFII 1994-96, popularly known as the “What We Eat in America” survey, addressed the requirements of the National Nutrition Monitoring and Related Research Act of 1990 (Public Law 101–445) for continuous monitoring of the dietary status of the American population. The CSFII 1994-96 utilized an improved data-collection method for 24-hour recall known as the multiple-pass approach. Given the large variation in intake from day-to-day, multiple 24-hour recalls are considered to be best suited for most nutrition monitoring and will produce stable estimates of mean nutrient intake from groups of individuals. ^9^ In 1998, the Supplemental Children's Survey, a survey of food and nutrient intake by children under the age of 10 years, was conducted as a supplement to the CSFII 1994-96. The CSFII 1994-96, 1998 surveyed 20,607 people of all ages with over-sampling of low-income population (<130% of the poverty threshold). Dietary intake data from individuals of all ages were collected over 2 nonconsecutive days via two 1-day dietary recalls.

Table 1 reports the NHANES III survey mean intake ± the standard error of the mean (SEM), in addition to the median and range for each omega-3 fatty acid. Distributions of EPA, DPA, and DHA were very skewed; therefore, the means and standard errors of the means should be used and interpreted with caution. Table 2 reports the CSFII survey mean and median intakes for each omega-3 fatty acid, along with SEMs, as reported in the Dietary Reference Intakes from the Institute of Medicine. ^2^

Table 1. Estimates of the mean±standard error of the mean (SEM) intake of linoleic acid (LA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), and docosahexaenoic acid (DHA) in the US population, based on analyses of a single 24-hour dietary recall of NHANES III data

| Grams/day | | % Kcal/day
| Mean±SEM | Median (range)^1^ | Mean±SEM | Median (range)^1^
LA (18:2 n-6) | 14.1±0.2 | 9.9 (0 – 168) | 5.79±0.05 | 5.30 (0 – 39.4)
ALA (18:3 n-3) | 1.33±0.02 | 0.90 (0 – 17) | 0.55±0.004 | 0.48 (0 – 4.98)
EPA (20:5 n-3) | 0.04±0.003 | 0.00 (0 – 4.1) | 0.02±0.001 | 0.00 (0 – 0.61)
DHA (22:6 n-3) | 0.07±0.004 | 0.00 (0 – 7.8) | 0.03±0.002 | 0.00 (0 – 2.86)

1 The distributions are not adjusted for the over-sampling of Mexican-Americans, non-Hispanic African-Americans, children ≤5 years old, and adults ≥ 60 years old in the NHANES III dataset.

Table 2. Mean, range, median, and standard error of the mean (SEM) of usual daily intakes of linoleic acid (LA), total omega-3 fatty acids (n-3 FA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA) and docosahexaenoic acid (DHA) in the US population, based on CSFII data (1994-1996, 1998)

| Grams/day
| Mean±SEM | Median±SEM
LA (18:2 n-6) | 13.0±0.1 | 12.0±0.1
Total n-3 FA | 1.40±0.01 | 1.30±0.01
ALA (18:3 n-3) | 1.30±0.01 | 1.21±0.01
EPA (20:5 n-3) | 0.028 | 0.004
DPA (22:5 n-3) | 0.013 | 0.005
DHA (22:6 n-3) | 0.057±0.018 | 0.046±0.013

## Dietary Sources of Omega-3 Fatty Acids

Omega-3 fatty acids can be found in many different sources of food, including fish, shellfish, some nuts, and various plant oils. Selected from the USDA website, Table 3 lists the amount of omega-3 fatty acids in some commonly consumed fish, shellfish, nuts, and edible oils, selected from the USDA website. ^10^

Table 3. The omega-3 fatty acid content, in grams per 100 g food serving, of a representative sample of commonly consumed fish, shellfish, fish oils, nuts and seeds, and plant oils that contain at least 5 g omega-3 fatty acids per 100 g

Food item | EPA | DHA | ALA
[underlined: Fish (Raw^a^)]
Anchovy, European | 0.6 | 0.9 | -
Bass, Freshwater, Mixed Sp. | 0.2 | 0.4 | 0.1
Bass, Striped | 0.2 | 0.6 | trace
Bluefish | 0.2 | 0.5 | -
Carp | 0.2 | 0.1 | 0.3
Catfish, Channel | trace | 0.2 | 0.1
Cod, Atlantic | trace | 0.1 | trace
Cod, Pacific | trace | 0.1 | trace
Eel, Mixed Sp. | trace | trace | 0.4
Flounder & Sole Sp. | trace | 0.1 | trace
Grouper, Mixed Sp. | trace | 0.2 | trace
Haddock | trace | 0.1 | trace
Halibut, Atlantic and Pacific | trace | 0.3 | trace
Halibut, Greenland | 0.5 | 0.4 | trace
Herring, Atlantic | 0.7 | 0.9 | 0.1
Herring, Pacific | 1.0 | 0.7 | trace
Mackerel, Atlantic | 0.9 | 1.4 | 0.2
Mackerel, Pacific and Jack | 0.6 | 0.9 | trace
Mullet, Striped | 0.2 | 0.1 | trace
Ocean Perch, Atlantic | trace | 0.2 | trace
Pike, Northern | trace | trace | trace
Pike, Walleye | trace | 0.2 | trace
Pollock, Atlantic | trace | 0.4 | -
Pompano, Florida | 0.2 | 0.4 | -
Roughy, Orange | trace | - | trace
Salmon, Atlantic, Farmed | 0.6 | 1.3 | trace
Salmon, Atlantic, Wild | 0.3 | 1.1 | 0.3
Salmon, Chinook | 1.0 | 0.9 | trace
Salmon, Chinook, Smoked^b^ | 0.2 | 0.3 | -
Salmon, Chum | 0.2 | 0.4 | trace
Salmon, Coho, Farmed | 0.4 | 0.8 | trace
Salmon, Coho, Wild | 0.4 | 0.7 | 0.2
Salmon, Pink | 0.4 | 0.6 | trace
Salmon, Pink, Canned^c^ | 0.9 | 0.8 | trace
Salmon, Sockeye | 0.6 | 0.7 | trace
Sardine, Atlantic, Canned in Oil^d^ | 0.5 | 0.5 | 0.5
Seabass, Mixed Sp. | 0.2 | 0.4 | -
Seatrout, Mixed Sp. | 0.2 | 0.2 | trace
Shad, American | 1.1 | 1.3 | 0.2
Shark, Mixed Sp. | 0.3 | 0.5 | trace
Snapper, Mixed Sp. | trace | 0.3 | trace
Swordfish | 0.1 | 0.5 | 0.2
Trout, Mixed Sp. | 0.2 | 0.5 | 0.2
Trout, Rainbow, Farmed | 0.3 | 0.7 | trace
Trout, Rainbow, Wild | 0.2 | 0.4 | 0.1
Tuna, Fresh, Bluefin | 0.3 | 0.9 | -
Tuna, Fresh, Skipjack | trace | 0.2 | -
Tuna, Fresh, Yellowfin | trace | 0.2 | trace
Tuna, Light, Canned in Oil^e^ | trace | 0.1 | trace
Tuna, Light, Canned in Water^e^ | trace | 0.2 | trace
Tuna, White, Canned in Oil^e^ | trace | 0.2 | 0.2
Tuna, White, Canned in Water^e^ | 0.2 | 0.6 | trace
Whitefish, Mixed Sp. | 0.3 | 0.9 | 0.2
Whitefish, Mixed Sp., Smoked | trace | 0.2 | -
Wolffish, Atlantic | 0.4 | 0.3 | trace
Shellfish (Raw)
Abalone, Mixed Sp. | trace | - | -
Clam, Mixed Sp. | trace | trace | trace
Crab, Blue | 0.2 | 0.2 | -
Crayfish, Mixed Sp., Farmed | trace | 0.1 | trace
Lobster, Northern | - | - | -
Mussel, Blue | 0.2 | 0.3 | trace
Oyster, Eastern, Farmed | 0.2 | 0.2 | trace
Oyster, Eastern, Wild | 0.3 | 0.3 | trace
Oyster, Pacific | 0.4 | 0.3 | trace
Scallop, Mixed Sp. | trace | 0.1 | -
Shrimp, Mixed Sp. | 0.3 | 0.2 | trace
Squid, Mixed Sp. | 0.1 | 0.3 | trace
Fish Oils
Cod Liver Oil | 6.9 | 11.0 | 0.9
Herring Oil | 6.3 | 4.2 | 0.8
Menhaden Oil | 13.2 | 8.6 | 1.5
Salmon Oil | 13.0 | 18.2 | 1.1
Sardine Oil | 10.1 | 10.7 | 1.3
Nuts and Seeds
Butternuts, Dried | - | - | 8.7
Flaxseed | | | 18.1
Walnuts, English | - | - | 9.1
Plant Oils
Canola (Rapeseed) | - | - | 9.3
Flaxseed Oil | - | - | 53.3
Soybean Lecithin Oil | - | - | 5.1
Soybean Oil | - | - | 6.8
Walnut Oil | - | - | 10.4
Wheatgerm Oil | - | - | 6.9

Trace = <0.1;

- = 0 or no data;

Sp. = species;

a Except as indicated;

b Lox.;

c Solids with bone and liquid;

d Drained solids with bone;

e Drained solids.

## Omega-3 Fatty Acids in Child and Maternal Health

The following description is intended only as an overview of the domain of inquiry in which it has been hypothesized that omega-3 fatty acid content, which includes both their intake and their levels in specific biomarkers, plays an important role in maternal pregnancy and child health outcomes in human subjects. This account serves exclusively to introduce the pertinence of this systematic review of the empirical evidence.

Over the past 60 years, the influence of maternal nutrition on fetal growth and development has been extensively studied as part of attempts to understand the causes and consequences of protein-calorie malnutrition. ^11^ This field of investigation has since expanded to encompass experimental, observational and descriptive studies designed to identify the specific roles of a broad range of sources and constituents of maternal nutrition. In addition, studies have also been conducted to evaluate the impact of maternal nutrition on maternal health during pregnancy and pregnancy outcomes. The following overview will focus on the the role played by omega-3 fatty acids in modulating the duration of pregnancy, incidence of pregnancy-induced hypertension, fetal growth and development, and infant (preterm and term) neurocognitive and visual development. The mechanisms by which omega-3 fatty acids or their eicosanoid derivatives impact the observed biological outcomes may include one or more of their identified functions in modulating the cell membrane microenviroment, signaling pathways, and gene expression. ^12,^ ^13^

It has been posited that the accretion of omega-3 fatty acids within, and use by, the maternal biological system has the potential to influence both maternal health during pregnancy, and fetal health. Likewise, it has been hypothesized that their accumulation within, and use by, the post-delivery child's biological system can affect their development and health. However, notwithstanding problems affecting their metabolism or availability, since EFAs must be “obtained” from “external sources” in order for their contents to accumulate and, in turn, potentially influence health, mothers and their fetuses/children require that omega-3 fatty acid content be “delivered” (i.e., via the placenta, breast milk, formula supplementation, food sources such as oily fish, or supplementation).

Birth weight is the single most important factor affecting neonatal morbidity and mortality. ^14^ Infants born with low birth weights (less than 2,500 grams by WHO criterion) may be the result of: 1. being constitutionally small; 2. intrauterine growth retardation (IUGR); or 3. preterm birth. In the United States, approximately 350,000 infants are born weighing less than 2,500 grams. ^15^

Preterm birth is a multifactorial condition that results in significant morbidity and mortality. Premature infants are at risk of injury to every organ system in the newborn period: intraventricular hemorrhage, retinopathy of prematurity, respiratory distress syndrome, chronic lung disease, necrotizing enterocolitis, growth failure, and infections. Of greatest concern for the infants who survive are the risks of developing permanent neurocognitive deficits (i.e., cerebral palsy, hearing and vision loss, cognitive deficits) that impact on their lifelong health and functional capacity. ^16–19^ In addition, studies now suggest that premature infants are at higher risk for developing adult-onset chronic diseases including hypertension, cardiovascular disease, and diabetes, as a result of permanent physiologic changes induced by abnormal conditions during sensitive periods of human growth and development. ^20–22^ There is an hypothesis that suboptimal n-3 and n-6 nutrititure during sensitive periods of fetal growth and development may result in permanent changes in neurocognitive and visual function and the development of adult-onset diseases such as hypertension. In the United States, preterm birth of low birth weight infants is 6%–10% of all births, which is approximately 300,000 annually. ^23^ In the United States, the cost of preterm births is estimated at several billion dollars annually, not including the costs of care for the associated-adult onset diseases. ^24^

Without exploring too deeply what was not, in fact, eligible for synthesis in our review—because it failed to satisfy our eligibility criterion relating to research design—some evidence is introduced here merely to demonstrate that there can coexist more than one interpretation of how maternal intake of omega-3 fatty acids could influence a child outcome. Results of epidemiological studies conducted with residents of the Faroe Islands ^25,^ ^26^ have been taken to suggest that marine diets, which contain omega-3 fatty acids, increase birth weight either by prolonging pregnancy. ^27^ or increasing the fetal growth rate. ^28,^ ^29^ Proposed mechanisms have included: a) the delayed timing of spontaneous delivery, which results from the altered balance among the PGs involved in the initiation of labor; ^27^ or, b) an increased fetal growth rate, which results from enhanced placental blood flow associated with a decreased Tx/prostacyclin ratio ^28^ and decreased blood viscosity. ^30^ These observations might not be replicated in populations that regularly consume lesser amounts of omega-3 fatty acids from marine sources, however. With respect to maternal health during human pregnancy, it has been hypothesized that marine oils may lower risks of certain complications of pregnancy, in particular preterm delivery, intrauterine growth retardation, preeclampsia, and gestational hypertension. ^31^ Given that some of their presumed mechanisms of action overlap with those of aspirin, it was thought that omega-3 fatty acids might protect pregnant women against preeclampsia and gestational hypertension, for example. ^32–34^

Essential fatty acid derived eicosanoids play important roles as biochemical mediators in normal term labor that initiate uterine contractions, cervical maturation, and rupture of membranes. ^35,^ ^36^ There is an elevation of omega-6 fatty acid eicosansoid series (PGE2 and PGF2alpha, LTC4, LTB4) in the maternal circulation prior to the onset of labor ^37^ and inhibition of their synthesis with cyclooxygenase inhibitors stops the onset of labor. ^38^ Women who deliver prematurely have higher erythrocyte total plasma lipid omega-6 fatty acids and lower omega-3 fatty acids compared with women who delivered at term, suggesting that an imbalance in favor of omega-6 fatty acids and their eicosanoid derivatives contribute to the premature onset of labor. ^39,^ ^40^ By altering the balance of omega-6 to omega-3 eicosanoids by diet supplementation with omega-3 fatty acids in human, rodent, and sheep, studies have been successful in increasing the duration of gestation. ^31,^ ^41–46^

In Western societies, placental insufficiency is the major cause of IUGR, with maternal hypertension having the most profound effect. ^47^ Fetal adaptations that are required to compensate for poor placental function result in increased perinatal morbidity and mortality. Of greatest concern is the increased risk for permanent adverse effects on growth and development. ^47–51^ Epidemiologic data suggests that the fetal adaptations may be associated with an increased risk for the development of adult-onset chronic diseases including hypertension, cardiovascular disease, obesity and diabetes. ^20–22^ In keeping with these observations, animals studies on fetal growth restriction demonstrate metabolic, hormonal and end organ changes that predispose the animals to the development of hypertension, cardiovascular disease and diabetes. ^52–54^

Hypertension in pregnancy of varying degrees of severity (chronic hypertension, preeclampsia, eclampsia) occurs in approximately 6%8% of pregnancies and is the second leading cause of maternal death in the United States. ^55^ The pathophysiologic mechanisms of preeclampsia remain unclear but a consistent finding is endothelial dysfunction resulting in intense vasospasm due to increased endothelial sensitivity to pressors. ^56,^ ^57^ It is thought, in part, that the enhanced vasoconstriction may be caused by increased synthesis of the potent omega-6 fatty acid derived vasoconstrictor, thromboxane A_2_, that is found in maternal plasma and placental tissue of preeclamptic women. ^58–60^ Non-pregnant hypertensive adults have been shown to have significantly lower plasma phospholipids levels of omega-3 fatty acids which results in decreased nitric oxide synthesis and increased aceylcholinesterase activity resulting in increased vascular tone. ^61,^ ^62^ In contrast, populations with high marine oil intake or hypertensive patients supplemented with omega-3 fatty acids had higher plasma omega-3 fatty acid levels had lower blood pressures. ^62–66^ Inuit women who ate a diet rich in marine foods were 2.6 times less likely to develop hypertension during pregnancy than Inuit women whose diets contained less marine foods. ^67^ Supplementation with omega-3 fatty acids would correct an imbalance between prostacylin and thromboxane, reduce blood viscosity, reduce endogenous pressors, or alter baroreceptor function which may help to reduce the occurrence of hypertension in pregnancy. ^68–73^

Normal placental blood flow is critical for adequate delivery of nutrients to the fetus to support normal growth and development. It has been proposed that the balance of omega-3 and omega-6 derived eicosanoids may play a key role in maintaining adequate placental blood flow and delivery of nutrient substrates to support normal fetal growth and development. ^74,^ ^75^ Based on biochemical indices (decreased PGI_2_ synthesis and increased 20:5n-6 DPA content of umbilical artery endothelium), it appears that low birth weight infants are deficient in omega-3 fatty acids. ^74^ In addition, observational and interventional studies have demonstrated a direct association between fetal growth and maternal intake of omega-3 fatty acids. ^24,^ ^74–77^

In keeping with other nutrients, the bulk of fatty acid delivery and storage in the fetus occurs in the last trimester. Infants born prematurely have lower total body content of omega-3 LCPUFA. ^78–80^ Omega-3 fatty acids accumulate in fetal fat stores, liver and neural tissues. The highest quantities are found in fat stores, but the relative proportion of omega-3 LCPUFA is highest in the retina and brain. ^79^ It appears that the fetus is dependent on the maternal supply of omega-3 LCPUFA with levels in the umbilical plasma phosphoplipids that strongly correlate with maternal plasma phospholipids. ^81–84^

The fetus is capable of converting ALA (18:3n-3) to DHA, but it remains controversial as to whether the rate of conversion is adequate to meet their needs. ^85–87^ Preformed DHA is preferentially transferred from the maternal circulation to the fetus, although the mechanism is unclear. ^74,^ ^88,^ ^89^ Maternal stores of DHA are mobilized during pregnancy for transfer to the fetus since plasma DHA (g/ml or FA%) has been shown to be decreased in multiparous versus primiparous women. This finding correlated with the lower DHA FA% in cord tissue of higher birth order newborns. Taken together, these findings suggest that the current omega-3 fatty acid intake during pregnancy in Western countries is inadequate. ^90^

Parallel to the high rates of fatty acid delivery and accretion in the fetus in the third trimester, is the rapid growth and development of neural tissues which continues for the first 18 months after birth. ^81,^ ^91^ During this period, the accretion of DHA in the brain is about 3 times greater than the relative increase in brain weight. ^92^ DHA accretion in the human retinal begins in the third trimester and peaks at 36–40 weeks gestation. ^93^ DHA and AA have been identified as important structural components of the highly specialized membrane lipids of the human central nervous system, with phospholipids of brain gray matter containing high proportions of DHA. ^94–96^ DHA has also been observed to be the major LCPUFA in the outer segments of the retina's rods and cones. ^94^ The functional roles of DHA were first shown in animals (fetus or newborn) deprived of DHA. Investigators have reported that the depletion of DHA from the developing retina and brain leads to abnormal electroretinograms (ERGs) and decreased VEP responses, in addition to altered learning behavior (e.g., performance in maze tasks, habituation, exploratory activity in novel environments, brightness discrimination, and olfactory-based learning tasks). ^97–104^ There is concern with findings that suggest that these changes in function may be irreversible despite correction of DHA status after deprivation of omega-3 fatty acids during critical periods of retinal development. ^105^ As well, the dietary deficiency of ALA in developing animals has resulted in decreased DHA levels, with a reciprocal increase in omega-6 fatty acids, and especially DPA, observed in the retina, whole brain, isolated brain membranes, and specific brain regions. ^106–108^

Animal studies have suggested the value of providing omega-3 fatty acid supplementation as well. Recent studies have shown that omega-3 fatty acids alter the metabolism of dopamine and serotonin in the brain of rodents and piglets. ^109–114^ Particular interest has been given to the dopaminergic system because of its role in the cognitive advances of early childhood, for example, as a modulator of attention and motivation, and in the visual pathways. ^115^ Other recent studies have suggested that omega-3 fatty acids regulate the expression of genes involved in cytoskeleton and membrane association, signal transduction, ion channel formation, energy metabolism, synaptic plasticity, and the retinoid X receptor in the brain. ^116–119^

Supplementation with DHA in human infants have shown variable results, with improved visual acuity demonstrated in premature infants ^120–123^ and variable results in term infants. ^124–127^ In part, the variability was thought to be due to differences in study design, age and duration of intervention, method(s) of assessment. The different measures of visual function may reflect different neural processes, making the comparison of findings between studies problematic. For example, the Teller acuity card or forced choice preferential looking method evaluates an infant's tendency to gaze at a pattern and assesses not only visual acuity but also an infant's ability to respond which requires integration of motor and behavioral responses to the visual stimuli. Visual evoked potentials (VEP) directly measures the amplitude of electrical responses to visual stimuli that signal transduction from the eye to visual cortex and is not dependent on the infant's behavioral state or motor abilities.

Based on observational studies, it has been shown that human milk fed infants have improved neurocognitive development compared to formula fed infants, it was hypothesized that one of the contributing factors may be the availability of long chain derivatives of LA and ALA that is present only human milk ^82,^ ^128^ This difference in fatty acid intake is reflected in lower erythrocyte membrane phospholipid DHA in infants fed formula. ^82^ Until the recent availability infant formula with added omega-3 LCPUFA, standard infant formula was devoid of these fatty acids. Human milk contains DHA ranging from 0.2 to 0.4 FA% and varies considerably among different populations with differences in DHA intake. ^120,^ ^124^ It is thought that the rate of conversion of ALA (18:3n-3) present in standard infant formula to DHA does not meet rates of accretion in the CNS that is seen in human milk fed infants. ^129–131^ As with the DHA intervention trials in term infants on visual acuity, the effect of DHA supplementation on neurocognitive development is also inconsistent. ^127,^ ^132–134^ Thevariability may, in part, be due to the use of different assessment tools.

While it could be hypothesized that the intake of omega-3 fatty acids might have a greater impact on preterm, than term, infants because the former have been exposed for a shorter period of time to what the latter likely received as significant contributors to their development, the present review was not planned to test this hypothesis. Even so, there may be considerable justification for giving omega-3 fatty acids to mothers who eventually deliver term babies as well as to these term infants post-delivery. Mothers of term infants may not exhibit uniform levels of omega-3 fatty acid content in their biomarkers, which are passed on to their children.

For example, it has recently been observed that the human milk of North American women has significantly less DHA and AA content, when compared with milk obtained from women in China, Japan, or India. ^135,^ ^136^ Furthermore, higher amounts of DHA in human milk have been associated with higher plasma and erythrocyte levels of DHA in breastfed infants; ^137–139^ and, a significant association between DHA levels in human milk and visual evoked potential (VEP) acuity was recently reported in a cross-sectional study of breastfed infants in Denmark. ^140^ Related observations, which are reviewed in depth here, suggest the possible importance of the intake of omega-3 fatty acids by pregnant and lactating women for the health of their offspring.

Moreover, when compared with women with lower plasma levels of AA and DHA during gestation, women with higher plasma levels gave birth to infants with higher levels of AA and DHA; ^137,^ ^141,^ ^142^ and, higher levels of omega-6 and omega-3 fatty acid content in biomarkers at birth were found to be associated with higher blood levels of AA and DHA in the infant for several weeks after birth. ^138,^ ^140,^ ^143^ Thus, individual differences in the levels of fatty acid content observed in mothers' biomarkers, which appear to be paralleled by individual differences in the levels of fatty acid content in the biomarkers obtained from their children, might ultimately be found to account for differences in child development. DHA deficiency related to low maternal intake of omega-3 fatty acids during pregnancy, for example, might adversely impact child development.

Direct measurement of tissue levels is not feasible for most tissues such as brain and retina. As such, fatty acid biomarkers are used as surrogate measures of tissue levels. How closely these biomarkers reflect tissue levels are not certain. ^131,^ ^144–147^ Different measurements of the fatty acid content of different lipid pools reflect either the effects of short term (hours) or long term (days to months) dietary intake of fatty acids.

The likely significance of omega-3 fatty acids for child health is therefore suggested by the observations that: a) the human brain and retina each contain considerable omega-3 fatty acid content; b) the child delivered at term receives an important supply of omega-3 fatty acids especially in the third trimester of pregnancy; and, c) due to a shortened gestational period, the child delivered prematurely receives less exposure to omega-3 fatty acid content than does the term child. Not surprisingly, the observation concerning preterm infants has afforded considerable empirical study of the impact of omega-3 fatty acids on their health. This evidence is systematically reviewed here.

Given this overview, and the expected availability of empirical evidence, we aimed to evaluate the impact of omega-3 fatty acid content (i.e., intake; in biomarkers), from any and all sources (e.g., breast milk; formula), on the growth patterns, neurological development, visual development, and cognitive development of preterm and term children. We also planned to investigate the influence of omega-3 fatty acid content (i.e., intake; in biomarkers), from any and all sources (e.g., food; supplements), on specific pregnancy outcomes relating to offspring (i.e., preterm births; children born small for gestational age) and maternal health (i.e., preeclampsia; eclampsia; gestational hypertension). However, as pointed out in Chapter 2, not all of the relationships between the intake of omega-3 fatty acids, the fatty acid content of biomarkers, and clinical-developmental outcomes are investigated in either population (i.e., maternal; child).

It should also be pointed out that, given the likely important role played by the omega-6 fatty acids—and AA in particular—in health and development, their co-influence on clinical and developmental outcomes are investigated, where possible. Finally, safety data (i.e., adverse effects) are evaluated. For example, concerns have been raised about the safety of fish oil supplementation in infants and pregnant women include, decreased platelet aggregation, immunosuppression, growth ^148,^ ^149^ and environmental contaminants. ^26,^ ^132,^ ^148–151^ However, the clinical significance of these potential risks need to be determined.