# Appendix I. Additional Acknowledgements

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgement does not reflect endorsement of this report.

- Bruce Holub PhD
- Professor, Department of Human Biology and Nutritional Sciences
- University of Guelph
- Guelph, ON
- (Industry representative)

- Bill Harris PhD
- Co-director, Lipid and Diabetes Research Center
- Saint Luke's
- Kansas City, MO

- James Friel PhD
- Professor, Dept. of Human Nutritional Sciences
- Faculty of Human Ecology
- University of Manitoba
- Winnipeg, MB

- Catherine Spong, MD
- Chief of NICHD's Pregnancy and Perinatology Branch
- National Institutes of Health
- Arlington, VA

- Ralph Hale, M.D.
- Executive Vice President
- The American College of Obstetricians and Gynecologists
- Washington, D.C

- Eileen Birch, PhD
- Retina Foundation of the Southwest
- Dallas, TX

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

- Bill Harris PhD
- Co-director, Lipid and Diabetes Research Center
- Saint Luke's
- Kansas City, MO

- James Friel PhD
- Professor, Dept. of Human Nutritional Sciences
- Faculty of Human Ecology
- University of Manitoba
- Winnipeg, MB

- Ralph Hale, M.D.
- Executive Vice President
- The American College of Obstetricians and Gynecologists
- Washington, D.C

- Dr. Guttorm Haugen
- Head
- Division of Fetal Medicine
- Department of Obstetrics and Gynaecology
- Rikshospitalet University Hospital
- Oslo, Norway

- K.S. Joseph MD, PhD
- Associate Professor
- Depts. of Obstetrics & Gynaecology and Pediatrics
- Dalhousie University and the IWK Health
- Halifax

- David Atkins, MD
- Chief Medical Officer,
- Agency for Healthcare Researcy and Quality (AHRQ)
- Rockville, MD

- Linda Dodds, PhD
- Associate Professor
- Departments of Obstetrics & Gynecology &
- Pediatrics at Dalhousie University;
- IWK Health Centre, Perinatal Epidemiology
- Research Unit, 5980 University Ave, Halifax
- Halifax, NS

- Karen Simmer, MD
- Professor, Neonatal Medicine
- Director, Neonatal Clinical Care Unit
- King Edward Memorial Hospital
- Subiaco, Western Australia

- Mary Frances Picciano, Ph.D.
- Senior Nutrition Research Scientist
- Office of Dietary Supplements National Institutes of Health Bethesda, MD

- Dr. Sheila M. Innis, PhD
- Professor, Dept. of Pediatrics,
- University of British Columbia;
- BC Research Institute for Children's & Women's Health
- Vancouver, BC