# Appendix H. Listing of Excluded Studies at Level 2 and 3 Screening

### Level 2

Adair C D, Sanchez-Ramos L, Briones D L, et al. The effect of high dietary n-3 fatty acid supplementation on angiotensin II pressor response in human pregnancy. American Journal of Obstetrics & Gynecology. 1996;175(3 Pt 1):688-691. Not related to predefined child or maternal health outcomes. [pmid: 8828435].
Agostoni C. Breast-feeding, human milk, long-chain polyunsaturated fatty acids and development. Developmental Medicine & Child Neurology 2001;43(SUPPL. 86). Not a first publication of empirical evidence (e.g., review)
Agostoni C. Effects of diet on the lipid and fatty acid status of full-term infants at 4 months.[comment]. J Am Coll Nutr. 1994;13(6):658-664. Not related to predefined child or maternal health outcomes. [pmid: 7706601].
Agostoni C, Giovannini M. Cognitive and visual development: influence of differences in breast and formula fed infants. Nutr Health. 2001;15(34):183-188. Not a first publication of empirical evidence (e.g., review). [pmid: 12003083].
Agradi E, Galli C. Requirement and role of essential fatty acids during brain development. [Review][28 refs]. Beitr Infusionther Klin Ernahr 1988;19128–139. Not a first publication of empirical evidence (e.g., review)
Alexander S. On the prevention of preeclampsia: nutritional factors back in the spotlight?[comment]. Am J Epidemiol. 2002;13(4):382-383. Not a first publication of empirical evidence (e.g., review).
Amadi B. Role of food antigen elimination in treating children with persistent diarrhea and malnutrition in Zambia. Journal of Pediatric Gastroenterology & Nutrition. 2002;34(Suppl 1):S54-S56. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12082390].
Arnold R W, Kesler K, Avila E. Susceptibility to retinopathy of prematurity in Alaskan natives. Journal of Pediatric Ophthalmology & Strabismus 1994;31(3). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Asch M J, Sperling M, Fiser R, et al. Metabolic and hormonal studies comparing three parenteral nutrition regimens in infants. Ann Surg. 1975;182(1):62-65. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 807170]. [pmcid: 1343880].
Ashwell M. Infant brain lipids and diet.[comment]. Lancet. 31–10. 1992;340(8827):1093. Not related to predefined child or maternal health outcomes. [pmid: 1357472].
Baker P, Broughton Pipkin F. Fish-oil and pre-eclampsia.[comment]. British Journal of Obstetrics & Gynaecology. 1991;98(5):499-500. Not a first publication of empirical evidence (e.g., review). [pmid: 2059604].
Bang H O, Dyerberg J. Urinary thromboxane metabolites in pre-eclampsia (II). Lancet 1990;335(8698). Not involving human participants
Baryshkov Iu A. [The level of higher unsaturated fatty acids in the blood serum of infants during the 1st months of life]. [Russian]. Vopr Okhr Materin Det. 1967;12(1):25-27. Not related to predefined child or maternal health outcomes.
Bell J D, Margen S, Calloway D H. Ketosis, weight loss, uric acid, and nitrogen balance in obese women fed single nutrients at low caloric levels. Metabolism: Clinical & Experimental. 1969;18(3):193-208. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 4887615].
Berry C, Montgomery C, Sattar N, et al. Fatty acid status of women of reproductive age. Eur J Clin Nutr. 2001;55(7):518-524. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 11464224].
Bistrian B R. Clinical aspects of essential fatty acid metabolism: Jonathan Rhoads Lecture. [Review] [68 refs]. Jpen: Journal of Parenteral & Enteral Nutrition. 2003;27(3):168-175. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12757109].
Bjerve K S, Thoresen L, Borsting S. Linseed and cod liver oil induce rapid growth in a 7-year-old girl with N-3 fatty acid deficiency. JPEN J Parenter Enteral Nutr. 1988;12(5):521-525. Not related to predefined child or maternal health outcomes. [pmid: 3184425].
Black D D. Intestinal lipoprotein metabolism. Journal of Pediatric Gastroenterology & Nutrition 1995;20(2). Not involving human participants
Bottai F, Franchini F, Cocchi C et al. EFA's effects on child's health: Recent advances about a therapeutic, prophylactic and dietetic tool. Pediatr Med Chir 1994;16(2). Not a first publication of empirical evidence (e.g., review)
Boue C, Combe N, Billeaud C, et al. Nutritional implications of trans fatty acids during perinatal period, in French pregnant women. Lipids, fats and oils: opportunities and responsibilities in the New Century 2001; Wurzburg, Germany, 8–10 October, 2000. OCL -Oleagineux,-Corps-Gras,-Lipides. 2001;8(1):68-72. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Bougle D. Red blood cell vitamin E in the premature effect of an alpha-linolenic acid supplementation [abstract]. Am J Clin Nutr. 1995;14(Suppl 2):26. Not related to predefined child or maternal health outcomes.
Brenna J T. Efficiency of conversion of alpha-linolenic acid to long chain n-3 fatty acids in man. Curr Opin Clin Nutr Metab Care. 2002;5(2):127-132. Not a first publication of empirical evidence (e.g., review). [pmid: 11844977].
Broughton Pipkin F, McCormack M J, Constantine G et al. Fish-oil and pre-eclampsia [1]. British Journal of Obstetrics & Gynaecology 1991;98(7). Not a first publication of empirical evidence (e.g., review)
Bruce A. Skeletal muscle lipids. 3. Changes in fatty acid composition of individual phosphoglycerides in man from fetal to middle age. J Lipid Res. 1974;15(2):109-113. Not involving human participants. [pmid: 4832753].
Bruce A, Svennerholm L. Skeletal muscle lipids. I Changes in fatty acid composition of lecithin in man during growth. Biochimica et Biophysica Acta. 1971;239(3):393-400. Not involving human participants. [pmid: 5113502].
Carlson S E. Functional effects of increasing omega-3 fatty acid intake.[comment]. Eur J Pediatr. 1997;131(2):173-175. . Not a first publication of empirical evidence (e.g., review).
Carlson S E. Docosahexaenoic acid and arachidonic acid in infant development. Semin Neonatol. 2001;6(5):437-449. . Not a first publication of empirical evidence (e.g., review). [pmid: 11988033].
Carlson S E, Montalto M B, Ponder D L, et al. Lower incidence of necrotizing enterocolitis in infants fed a preterm formula with egg phospholipids. Pediatr Res. 1998;44(4):491-498. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 9773836].
Carroll. Essential fatty acids: what level in the diet is most desirable?. Advances in Experimental Medicine & Biology 1977;83535–546. Not related to predefined child or maternal health outcomes
Carruth B R, Nevling W, Skinner J D. Developmental and food profiles of infants born to adolescent and adult mothers. J Adolesc Health. 1997;20(6):434-441. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 9178080].
Cicmanec J L. Comparison of four human studies of perinatal exposure to methylmercury for use in risk assessment. Toxicology 1996;111(1–3). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Clandinin M T, VanAerde J. Formula supplementation and growth.[comment]. Pediatrics. 2003;112(6 Pt 1):1456-1458. . Not a first publication of empirical evidence (e.g., review). [pmid: 14654632].
Clandinin M T, Chappell J E, Heim T. Do low weight infants require nutrition with chain elongation-desaturation products of essential fatty acids?. Prog Lipid Res 1981;20901–904. Not involving human participants
Crawford M A. Is there a common denominator between fetal growth retardation and cardiovascular disease?. Acta Cardiol. 1989;44(6):449-453. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 2626902].
Crawford M A. Essential fatty acids and neurodevelopmental disorder. Advances in Experimental Medicine & Biology. 1992;318:pp 307-314. Not a first publication of empirical evidence (e.g., review). [pmid: 1636499].
Crawford M A. Aspirin in pregnancy.[comment]. Lancet. 20–3. 1993;341(8847):753-754. Not a first publication of empirical evidence (e.g., review). [pmid: 8095644].
Crawford M A, Ghebremeskel K, Phylactos A. The biochemistry of unsaturated fatty acids and development of preterm infants. Br J Clin Pract 1995;49(SUPPL. 80). Not a first publication of empirical evidence (e.g., review)
Crawford M A, Hassam A G, Hall B M. Metabolism of essential fatty acids in the human fetus and neonate. Ann Nutr Metab. 1977;21(Suppl):1187-188. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Cunnane S C, Crawford M A. Survival of the fattest: fat babies were the key to evolution of the large human brain. [Review][39 refs]. Comparative Biochemistry & Physiology 2003;Part A, Molecular & Integrative Physiology. 136(1):17–26. No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Cunnane S C, Francescutti V. Fatty acid profiles of maternal adipose tissue in relation to infant development. Br J Nutr. 1999;82(4):253-254. . Not a first publication of empirical evidence (e.g., review). [pmid: 10655972].
Cunnane S C, Francescutti V, Brenna J T. Docosahexaenoate requirement and infant development.[comment]. Adv Nutr Res. 1999;15(10):801-802. . Not a first publication of empirical evidence (e.g., review).
Davidson M, Levine S Z, Bauer C H, et al. Feeding studies in low-birth-weight infants. I. Relationships of dietary protein, fat, and electrolyte to rates of weight gain, clinical courses, and serum chemical concentrations. Eur J Pediatr. 1967;70(5):695-713. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Davis K C. Vitamin E: adequacy of infant diets. Am J Clin Nutr. 1972;25(9):933-938. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 5054219].
De Lucchi C, Pita M L, Faus M J, et al. Influences of diet and postnatal age on the lipid composition of red blood cell membrane in newborn infants. Ann Nutr Metab. 1988;32(4):231-239. Not related to predefined child or maternal health outcomes. [pmid: 3195991].
Deckelbaum R J, Williams C L. Fat intake in children: is there a need for revised recommendations?[comment]. Eur J Pediatr. 2000;136(1):7-9. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Decsi T. Plasma lipid and apolipoprotein concentrations in full term infants fed formula supplemented with long-chain polyunsaturated fatty acids and cholesterol. Eur J Pediatr. 1997;156(5):397-400. Not related to predefined child or maternal health outcomes. [pmid: 9177986].
Decsi T, Boehm G, Tjoonk H M R, et al. Trans isomeric octadecenoic acids are related inversely to arachidonic acid and DHA and positively related to mead acid in umbilical vessel wall lipids. Lipids. 1–10. 2002;37(10):01. Not related to predefined child or maternal health outcomes.
de Swiet M. Pre-eclampsia. III: The role of aspirin in prevention. Modern Midwife. 1994;4(12):20-22. Not a first publication of empirical evidence (e.g., review). [pmid: 7697403].
Diener U C, Fink M M, Demmelmair H. Docosahexaenoic acid intake affects alpha-linolenic acid metabolism in preterm infants [abstract]. Am J Clin Nutr. 1999;18(Suppl 1):55. Not related to predefined child or maternal health outcomes.
Diener U. Effect of docosahexaenoic acid supplementation on conversion of linoleic and a-linolenic acid in preterm infants. J 1999;Pediatr.Gastroenterol.Nutr 28(05):589. Not related to predefined child or maternal health outcomes.
Drane D L, Logemann J. An explanation for the association between specific language impairment and toxemia. Med Hypotheses. 1–8. 2003;61(2):01. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Drongelen M M H P, Zeijdner E E, Houwelingen A C V, et al. Essential fatty acid status measured in umbilical vessel walls of infants born after a multiple pregnancy. Early Hum Dev. 1996;46(3):205-215. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 8922565].
Duchen K, Yu G, Bjorksten B. Polyunsaturated fatty acids in breast milk in relation to atopy in the mother and her child. International Archives of Allergy & Immunology 1999;118(2–4). Not related to predefined child or maternal health outcomes
Duhamel J F, Travert G, Briere S, et al. [Nutritional management of neonates and infants with cystic fibrosis of the pancreas detected at birth]. [French]. Arch Fr Pediatr. 1986;43(4):229-233. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 3767582].
Dunstan J A, Mori T A, Barden A. Fish oil supplementation in pregnancy modifies neonatal allergen-specific immune responses and clinical outcomes in infants at high risk of atopy: A randomized, controlled trial. Journal of Allergy & Clinical Immunology. 2003;112(6):1178-1184. Not related to predefined child or maternal health outcomes. [pmid: 14657879].
Dyerberg J, Bang H O. Pre-eclampsia and prostaglandins. Lancet 1985;1(8440). Not a first publication of empirical evidence (e.g., review)
Elswyk ME, van Hatch S D, Stella G G et al. Eggs as a functional food alternative to fish and supplements for the consumption of DHA. Egg nutrition and biotechnology 1999;121–133; 25 ref. Not related to predefined child or maternal health outcomes
Fairey A K, Butte N F, Mehta N, et al. Nutrient accretion in preterm infants fed formula with different protein:energy ratios. Journal of Pediatric Gastroenterology & Nutrition. 1997;25(1):37-45. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 9226525].
Fasching P. [Fish oil as lipostatic factor]. [German]. Vasa - Supplementum 1990;3062–63. Not related to predefined child or maternal health outcomes
Figueira F, Mendonca S, Rocha J, et al. Absorption of vitamin A by infants receiving fat-free or fat-containing dried skim milk formulas. Am J Clin Nutr. 1969;22(5):588-593. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 5819115].
Fokkema M R, Smit E N, Martini I A, et al. Assessment of essential fatty acid and [omega]3-fatty acid status by measurement of erythrocyte 20:3[omega]9 (Mead acid), 22:5[omega]6/20:4[omega]6 and 22:5[omega]6/22:6[omega]3. Prostaglandins, Leukotrienes and Essential Fatty Acids. 2002;67(5):345-356. Not related to predefined child or maternal health outcomes.
Fomon S J, Thomas L N, Filer L J, et al. Requirements for protein and essential amino acids in early infancy. Studies with a soy-isolate formula. Acta Paediatr Scand. 1973;62(1):33-45. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 4734855].
Foreman-van Drongelen M M, Westdorp J M, van Houwelingen A C et al. The essential fatty acid status of premature infants and the fatty acid composition of their diet. Am J Clin Nutr 1993;57(5 SUPPL.). Not related to predefined child or maternal health outcomes
Forsyth J S, Willatts P, Agostoni C, et al. Long chain polyunsaturated fatty acid supplementation in infant formula and blood pressure in later childhood: Follow up of a randomised controlled trial. Br Med J. 3–5. 2003;326(7396):03. Not related to predefined child or maternal health outcomes.
Friedman G, Goldberg S J. An evaluation of the safety of a low-saturated-fat, low-cholesterol diet beginning in infancy. Pediatrics. 1976;58(5):655-657. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 980598].
Friedman Z, Shochat S J, Maisels M J, et al. Correction of essential fatty acid deficiency in newborn infants by cutaneous application of sunflower-seed oil. Pediatrics. 1976;58(5):650-654. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 824609].
Fronczak C M. In utero dietary exposures and risk of islet autoimmunity in children. Diabetes Care. 2003;26(12):3237-3242. Not related to predefined child or maternal health outcomes. [pmid: 14633808].
Gallo A, Kohan A, Schele C, et al. [Use of soybean flour in infant nutrition]. [Spanish]. Rev Chil Pediatr. 1971;42(6):433-442. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 5167609].
German J B, Dillard C J, Whelan J. Biological effects of dietary arachidonic acid. Introduction. Br J Nutr. 1996;126(4 Suppl):1076S-1080S. Not a first publication of empirical evidence (e.g., review).
Ghebremeskel K, Leighfield M. Infant brain lipids and diet.[comment]. Lancet. 31–10. 1992;340(8827):1093. Not a first publication of empirical evidence (e.g., review). [pmid: 1357473].
Ghisolfi J. Long-chain polyunsaturated fatty acids and brain development. Arch Pediatr 1996;3(SUPPL. 1). Not a first publication of empirical evidence (e.g., review)
Ghraf R, Jelinek J, Lehwalder D. Innovations in infant formulas: Clinical development of formulas containing the fat blend LCP Milupan. Br J Clin Pract 1995;49(SUPPL. 80). Not a first publication of empirical evidence (e.g., review)
Gibson R A. Long-chain polyunsaturated fatty acids and infant development.[comment]. Lancet. 4–12. 1999;354(9194):1919-1920. Not a first publication of empirical evidence (e.g., review). [pmid: 10622289].
Gross S, Vanderhoof J, Hegvi T et al. A new arachidonic acid (ARA) and docosahexanoic acid (DHA) supplemented preterm formula: effect on plasma and erythrocyte phospholipid fatty acids. Pediatr Res 1997;232A1376. Not related to predefined child or maternal health outcomes
Guesnet P, Alessandri J M. Milk essential fatty acids and central nervous system development in the newborn. Cahiers de Nutrition et de Dietetique. 1995;30(2):109-116. Not a first publication of empirical evidence (e.g., review).
Haggarty P. Placental regulation of fatty acid delivery and its effect on fetal growth--a review. [Review] [101 refs]. Placenta. 2002;23(Suppl A):S28-S38. Not a first publication of empirical evidence (e.g., review). [pmid: 11978057].
Hamosh M. The milky way: From mammary gland to milk to newborn. Macy-Gyorgy award presentation (1999). Advances in Experimental Medicine & Biology. 2002;503:pp 17-25. . Not a first publication of empirical evidence (e.g., review). [pmid: 12026017].
Hamosh M. Long chain polyunsaturated fatty acids in neonatal nutrition.[comment]. J Am Coll Nutr. 1994;13(6):546-548. Not a first publication of empirical evidence (e.g., review). [pmid: 7706584].
Hansen H S, Olsen S F. Sleep patterns, docosahexaenoic acid, and gestational length.[comment]. Am J Clin Nutr. 2004;79(2):334-335. Not a first publication of empirical evidence (e.g., review). [pmid: 14749243].
Harvie A. Randomised controlled trial of a long chain polyunsaturated fatty acid (LC PUFA) supplemented low phe infant formula. J Inherit Metab Dis. 1998;21(Suppl. 2):13. Not related to predefined child or maternal health outcomes.
Hawkes J S, Bryan D L, Neumann M A, et al. Transforming growth factor beta in human milk does not change in response to modest intakes of docosahexaenoic acid. Lipids. 2001;36(10):1179-1181. Not related to predefined child or maternal health outcomes. [pmid: 11768164].
Heird W C, Jensen C L, Gomez M R. Practical aspects of achieving positive energy balance in low birth weight infants. Eur J Pediatr 1992;120(4 II SUPPL.). Not a first publication of empirical evidence (e.g., review)
Hernell O. The requirements and utilization of dietary fatty acids in the newborn infant. Acta Paediatrica Scandinavica - Supplement 1990;36520–27. Not related to predefined child or maternal health outcomes
Herrera E. Implications of dietary fatty acids during pregnancy on placental, fetal and postnatal development--a review. [Review] [166 refs]. Placenta. 2002;23(Suppl A):S9-19. Not related to predefined child or maternal health outcomes. [pmid: 11978055].
Heymans H S, van den, Heuvel C G, et al. Catch-up growth following long-term administration of essential fatty acids in a girl with growth failure and essential fatty acid deficiency. Acta Paediatr Scand. 1982;71(6):1037-1039. Not related to predefined child or maternal health outcomes. [pmid: 7158328].
Houwelingen A C, Drongelen M M H P, Nicolini U, et al. Essential fatty acid status of fetal plasma phospholipids: Similar to postnatal values obtained at comparable gestational ages. Early Hum Dev. 1996;46(12):141-152. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 8899362].
Houwelingen A C, Puls J, Hornstra G. Essential fatty acid status during early human development. Early Hum Dev. 1992;31(2):97-111. Not involving human participants. [pmid: 1292926].
Houwelingen A C, van Sorensen J D, Hornstra G, et al. Essential fatty acid status in neonates after fish-oil supplementation during late pregnancy. Br J Nutr. 1995;74(5):723-731. Not related to predefined child or maternal health outcomes. [pmid: 8541278].
Huang Y, Shao X M, Neu J. Immunonutrients and neonates. [Review] [39 refs]. Eur J Pediatr. 2003;162(3):122-128. Not related to predefined child or maternal health outcomes. [pmid: 12655412].
Hull D, Elphick M C. Evidence for fatty acid transfer across the human placenta. Ciba Found Symp 30-3-1978;(63):75–91. No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Hurgoiu V, Mark S. [The fat ration for the premature infant]. [Romanian]. Pediatrie. 1992;41(2):71-75. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 1327223].
Hurgoiu V, Ciupe R, Adam M, et al. [Optimization of nutrition for premature infants using essential fatty acids]. [Romanian]. Revista de Pediatrie, Obstetrica Si Ginecologie - Pediatria. 1986;35(4):367-370. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Infante J P, Huszagh V A. Impaired arachidonic (20:4n-6) and docosahexaenoic (22:6n-3) acid synthesis by phenylalanine metabolites as etiological factors in the neuropathology of phenylketonuria. [Review] [170 refs]. Molecular Genetics & Metabolism. 2001;72(3):185-198. Not related to predefined child or maternal health outcomes. [pmid: 11243724].
Innis S M. Maternal diet, length of gestation, and long-chain polyunsaturated fatty acid status of infants at birth.[comment]. Am J Clin Nutr. 1999;70(2):181-182. Not a first publication of empirical evidence (e.g., review). [pmid: 10426693].
Innis S M. Essential fatty acid requirements in human nutrition. Canadian Journal of Physiology & Pharmacology 1993;71(9). Not a first publication of empirical evidence (e.g., review)
Innis S, Uauy R, Heird W et al. Mechanisms of action of LCPUFA effects on infant growth and neurodevelopment: Perinatal biochemistry and physiology of LCPUFA discussion. Eur J Pediatr 2003;143(4 SUPPL.). Not a first publication of empirical evidence (e.g., review)
Jacobson SWretlind. The role of fat in total parenteral nutrition. [Monograph Citation] 1976;(161):170. Not involving human participants
James W P T, Vadillo-Ortega F, Valencia J et al. Long-term fetal programming of body composition and longevity. Nutr Rev 1997;55(1 II). Not a first publication of empirical evidence (e.g., review)
Johns T, Sibeko L. Pregnancy Outcomes in Women Using Herbal Therapies. Birth Defects Research. Part B. Developmental and Reproductive Toxicology. 2003;68(6):501-504. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 14745987].
Jong N, de Dusseldorp M, van Bergsma J S, et al. Growth and nutritional status of macrobiotically fed children until 10 years of age. Aktuel Ernahrungsmed. 1996;21(1):14-15. Not a first publication of empirical evidence (e.g., review).
Jorgensen M H, Lauritzen L, Fleischer-Michaelsen K. The role of long-chain polyunsaturated fatty acids in neonatal nutrition.[comment] (multiple letters). Acta Paediatr. 1999;88(8):916-918. Not related to predefined child or maternal health outcomes. [pmid: 10503696].
Kaapa P, Uhari M, Nikkari T, et al. Dietary fatty acids and platelet thromboxane production in puerperal women and their offspring. American Journal of Obstetrics & Gynecology. 1986;155(1):146-149. Not related to predefined child or maternal health outcomes. [pmid: 3089014].
Kaempf-Rotzoll D E H. Influence of long-chain polyunsaturated fatty acid formula feeds on vitamin E status in preterm infants. International Journal for Vitamin & Nutrition Research. 2003;73(5):377-387. Not related to predefined child or maternal health outcomes. [pmid: 14639802].
Kagan B M, Stanincova V, Felix N S, et al. Body composition of premature infants: relation to nutrition. Am J Clin Nutr. 1972;25(11):1153-1164. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 5086038].
Kashyap S, Ohira-Kist K, Abildskov K, et al. Effects of quality of energy intake on growth and metabolic response of enterally fed low-birth-weight infants. Pediatr Res. 2001;50(3):390-397. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 11518827].
Kashyap S, Schulze K F, Forsyth M, et al. Growth, nutrient retention, and metabolic response in low birth weight infants fed varying intakes of protein and energy. Eur J Pediatr. 1988;113(4):713-721. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Keil T U. Advantages of a lipid adapted infant nutrition. Fortschr Med 1993;111(13). Not a first publication of empirical evidence (e.g., review)
Kekomaki M P. Food requirements in normal children. Acta Anaesthesiol Scand 1969;Supplementum. 3718–23. No omega-3 fatty acid focus (intervention/exposure or biomarkers)
King K C, Adam P A, Laskowski D E, et al. Sources of fatty acids in the newborn. Pediatrics. 1971;47(1):Suppl-8. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Klenoff-Brumberg H L, Genen L H. High versus low medium chain triglyceride content of formula for promoting short term growth of preterm infants. [Review][34 refs]. Cochrane Database Syst Rev 2003;(1):CD002777. No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Knapp H R. Fatty acids and hypertension. [Review][29 refs]. World Review of Nutrition & Dietetics 1994;769–14. Not a first publication of empirical evidence (e.g., review)
Kohn G. Long-chain polyunsaturated fatty acids in infant nutrition. Eur J Clin Nutr. 1994;48(Suppl 2):S1-S7. Not related to predefined child or maternal health outcomes. [pmid: 7995259].
Koletzko B. Parenteral feeding of preterm infants with fat emulsions based on soybean and olive oils: effects on plasma phospholipid fatty acids [abstract]. Am J Clin Nutr. 1998;17(Suppl 1):25. Not related to predefined child or maternal health outcomes.
Koletzko B. HDL subclass distribution in preterm infants given parenteral lipids based on olive or soybean oil [abstract]. Am J Clin Nutr. 1999;18(Suppl 1):54. Not related to predefined child or maternal health outcomes.
Koletzko B. Long chain polyenoic fatty acids in the nutrition of premature infants. Ernahrungs Umschau. 1990;37(11):426. Not related to predefined child or maternal health outcomes.
Koletzko B. Fats for brains. [Review] [47 refs]. Eur J Clin Nutr. 1992;46(Suppl 1):S51-S62. Not a first publication of empirical evidence (e.g., review). [pmid: 1612052].
Koletzko B. Response to and range of acceptable fat intakes in infants and children. Eur J Clin Nutr 1999;53(SUPPL. 1). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Koletzko B. Arachidonic acid supply and metabolism in human infants born at full term. Lipids. 1996;31(1):79-83. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 8649238].
Koletzko B, Decsi T, Bendich A et al. Role of long-chain polyunsaturated fatty acids in infant growth and development. Primary and secondary preventive nutrition 2001;237–252; 68 ref. Not a first publication of empirical evidence (e.g., review)
Koletzko B, Schmidt E, Bremer H J, et al. Dietary long chain polyunsaturates for premature infants. Journal of Pediatric Gastroenterology & Nutrition. 1987;6(6):997-998. Not related to predefined child or maternal health outcomes. [pmid: 3681589].
Koo W W. Efficacy and safety of docosahexaenoic acid and arachidonic acid addition to infant formulas: can one buy better vision and intelligence?. [Review] [54 refs]. J Am Coll Nutr. 2003;22(2):101-107. Not a first publication of empirical evidence (e.g., review). [pmid: 12672705].
Koo W W K, Hammami M, Margeson D P, et al. Reduced bone mineralization in infants fed palm olein-containing formula: A randomized, double-blinded, prospective trial. Pediatrics. 1–5. 2003;111(5 I):01. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Krugman S, Law P. Breastfeeding and IQ. Pediatrics. 1999;103(1):193-194. Not a first publication of empirical evidence (e.g., review). [pmid: 9988628].
Ksiazyk J. Influence of feeding long-chain polyunsaturated fatty acids on children's health. [Polish]. Medycyna Wieku Rozwojowego. 2000;4(3 Suppl 1):35-39. Not a first publication of empirical evidence (e.g., review). [pmid: 11381150].
Lagstrom H, Seppanen R, Jokinen E, et al. Influence of dietary fat on the nutrient intake and growth of children from 1 to 5 y of age: the Special Turku Coronary Risk Factor Intervention Project. Am J Clin Nutr. 1999;69(3):516-523. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 10075339].
Langer J W. [Drug information. Fish oils can make big babies]. [Danish]. Sygeplejersken. 16–9. 1992;92(38):28. Not a first publication of empirical evidence (e.g., review). [pmid: 1292104].
Lapinleimu H, Jokinen E, Myyrinmaa A, et al. Individualized dietary counselling of families: serum cholesterol concentration and growth of children aged 7–13 months. Acta Paediatr. 1994;83(4):383-388. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 8025393].
Lapinleimu H, Viikari J, Jokinen E et al. Prospective randomised trial in 1062 infants of diet low in saturated fat and cholesterol. Lancet 1995;345(8948). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Laube H. [Effect of nutritional factors on the development of obesity and hyperinsulinism]. [German]. Dtsch Med Wochenschr. 22–6. 1973;98(25):1256-1259. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 4714513].
Leung S S F, Lee W T K, Lui S S H, et al. Fat intake in Hong Kong Chinese children. Fat intake during childhood 2000;Houston, Texas, USA, 8–9 June, 1998. American-Journal-of-Clinical-Nutrition. 2000;72(5 suppl.):1373S-1378S. Not related to predefined child or maternal health outcomes. [pmid: 11063480].
Liu Y M, Williams S, Basualdo-Hammond C, et al. A prospective study: growth and nutritional status of children treated with the ketogenic diet. J Am Diet Assoc. 2003;103(6):707-712. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12778041].
Luepker R V, Perry C L, McKinlay S M et al. Outcomes of a field trial to improve children's dietary patterns and physical activity: The Child and Adolescent Trial for Cardiovascular Health (CATCH). J Am Med Assoc 1996;275(10). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Luukkainen P, Salo M K, Janas M, et al. Fatty acid composition of plasma and red blood cell phospholipids in preterm infants from 2 weeks to 6 months postpartum. J Pediatr Gastroenterol Nutr. 1995;20(3):310-315. Not related to predefined child or maternal health outcomes. [pmid: 7608826].
Lynch R D. Utilization of polyunsaturated fatty acids by human diploid cells aging in vitro. Lipids. 1980;15(6):412-420. Not involving human participants. [pmid: 7401939].
Makrides M. Erythrocyte fatty acids of term infants fed either breast milk, standard formula, or formula supplemented with long-chain polyunsaturates. Lipids. 1995;30(10):941-948. Not related to predefined child or maternal health outcomes. [pmid: 8538382].
Makrides M, Neumann M A, Bvard R W et al. Fatty acid composition of brain, retina, and erythrocytes in breast- and formula-fed infants. Am J Clin Nutr 1994;60(2). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Marini A V. Influence of different types of post-discharge feeding on somatic growth, cognitive development and their correlation in very low birthweight preterm infants. Acta Paediatrica Supplement. 2003;91(441):18-33. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 14599038].
Marsh D O, Turner M D, Crispin Smith J et al. Fetal methylmercury study in a Peruvian fish-eating population. Neurotoxicology 1995;16(4). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Martinez M, Ballabriga A, Gil-Gibernau J J. Lipids of the developing human retina: I. Total fatty acids, plasmalogens, and fatty acid composition of ethanolamine and choline phosphoglycerides. Journal of Neuroscience Research. 1988;20(4):484-490. Not involving human participants. [pmid: 3184211].
Martinez M, Conde C, Ballabriga A. Some chemical aspects of human brain development. II. Phosphoglyceride fatty acids. Pediatric Research. 1974;8(2):93-102. Not involving human participants. [pmid: 4810513].
McCarty M F. Nutritional prevention of pre-eclampsia--a special role for 1 series prostaglandin precursors?. Med Hypotheses. 1982;9(3):283-291. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 6890622].
McFadyen, M., Farquharson, J., and Cockburn, F. Maternal and umbilical cord erythrocyte omega-3 and omega-6 fatty acids and haemorheology in singleton and twin pregnancies. Archives of Disease in Childhood Fetal & Neonatal Edition 2003;88(2). Not related to predefined child or maternal health outcomes
Medesan F. [Current aspects of feeding of the full-term newborn and premature infant]. [Romanian]. Pediatria (Bucur). 1971;20(6):553-560. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 5147010].
Mendy F, Hirtz J, Berret R, et al. [Variation of the ratio of oleic triene--arachidonic acid or C20: 3 omega 9--C20: 4 omega 6--in serum of infants according to age and diet]. [French]. Arch Sci Physiol (Paris). 1970;24(3):279-296. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 5536442].
Merzouk H, Khan N A. Implication of lipids in macrosomia of diabetic pregnancy: Can n-3 polyunsaturated fatty acids exert beneficial effects?. Clin Sci 2003;105(5). Not related to predefined child or maternal health outcomes
Michaelsen K F, Lauritzen L, Jorgensen M H et al. Breast-feeding and brain development. Scandinavian Journal of Nutrition/Naringsforskning 2003;47(3). Not a first publication of empirical evidence (e.g., review)
Mihrshahi S, Peat J K, Marks G B, et al. Eighteen-month outcomes of house dust mite avoidance and dietary fatty acid modification in the Childhood Asthma Prevention Study (CAPS). Journal of Allergy & Clinical Immunology. 1–1. 2003;111(1):01. Not related to predefined child or maternal health outcomes.
Mihrshahi S, Peat J K, Webb K, et al. The childhood asthma prevention study (CAPS): design and research protocol of a randomized trial for the primary prevention of asthma. Control Clin Trials. 2001;22(3):333-354. Not related to predefined child or maternal health outcomes. [pmid: 11384793].
Mitsuhashi Y. Does the salmon patch reappear?. Lancet. 4–4. 1998;351(9108):04. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Monteil H, Klein F, Ruff R, et al. [Variations of essential fatty acids in relation to nutrition in the newborn]. [French]. Ann Pediatr (Paris). 2–1. 1967;14(1):23-27. Not related to predefined child or maternal health outcomes. [pmid: 5597344].
Moodley J, Norman R J. Attempts at dietary alteration of prostaglandin pathways in the management of pre-eclampsia. Prostaglandins Leukotrienes & Essential Fatty Acids. 1989;37(3):145-147. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Morley, R. Breast feeding and cognitive outcome in children born prematurely. Advances in Experimental Medicine & Biology. 2002;503:77-82. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12026030].
Moser A B, Jones D S, Raymond G V, et al. Plasma and red blood cell fatty acids in peroxisomal disorders. Neurochem Res. 1999;24(2):187-197. Not related to predefined child or maternal health outcomes. [pmid: 9972864].
Moya M, Juste M, Cortes E et al. Fatty acid composition of mature breast milk according to the mothers diet during pregnancy. Short and long term effects of breast feeding on child health 2000;405–406; 3 ref. Not related to predefined child or maternal health outcomes
Moya M, Serrano Rios M, Sastre A et al. Dairy products during perinatal stage: relevance of their calcium and long chain polyunsaturated fatty acids content. Dairy products in human health and nutrition 1994;Madrid, Spain, 7–10 June 1993. 1994, 199–205; 45 ref.Spain, 7-Spain,10. Not related to predefined child or maternal health outcomes
Mueller I, Vounatsou P, Allen B J, et al. Spatial patterns of child growth in Papua New Guinea and their relation to environment, diet, socio-economic status and subsistence activities. Ann Hum Biol. 2001;28(3):263-280. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 11393334].
Muskiet F A J, van Beusekom C M, Boersma E R et al. Long chain polyunsaturated fatty acids in the perinatal period. Nederlands Tijschrift voor de Klinische Chemie 1995;20(1). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Myers G J, Davidson P W, Cox C, et al. The Seychelles child development study: Results and new directions through twenty-nine months. Water, Air, & Soil Pollution. 1997;97(12):53-61. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Newby P K, Peterson K E, Berkey C S, et al. Dietary composition and weight change among low-income preschool children. Arch Pediatr Adolesc Med. 8–1. 2003;157(8):01. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Ney D, Hollingsworth D R, Cousins L. Decreased insulin requirement and improved control of diabetes in pregnant women given a high-carbohydrate, high-fiber, low-fat diet. Diabetes Care. 1982;5(5):529-533. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 6329613].
Niinikoski H, Viikari J, Ronnemaa T, et al. Regulation of growth of 7- to 36-month-old children by energy and fat intake in the prospective, randomized STRIP baby trial. Pediatrics. 1997;100(5):810-816. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 9346980].
not found, in reference. The 1988 report of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure.[comment]. Arch Intern Med 1988;148(5):1023–1038. Not related to predefined child or maternal health outcomes
not found, in reference. The 1988 report of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure.[comment]. Arch Intern Med 1988;148(5):1023–1038. Not related to predefined child or maternal health outcomes
not found, in reference. Macronutrient and energy intakes in young children fed milk products containing different quantities and qualities of fat and protein. Journal of Pediatric Gastroenterology & Nutrition 1999;29(3). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
not found, in reference. ISSFAL Board Statement: recommendations for the essential fatty acid requirement for infant formulas. International Society for the Study of Fatty Acids and Lipids. J Am Coll Nutr 1995;14(2):213–214. Not a first publication of empirical evidence (e.g., review)
not found, in reference. Fish oils in pregnancy. Lancet 30-5-1992;339(8805):1327–1328. Not a first publication of empirical evidence (e.g., review)
not found, in reference. Fish-oil and pre-eclampsia.[comment]. British Journal of Obstetrics & Gynaecology 1991;98(7):737–740. Not a first publication of empirical evidence (e.g., review).
not found, in reference. Infants born of mothers with higher DHA levels have better sleep patterns. NutraCos 2002;1(5):34–35. Not a first publication of empirical evidence (e.g., review)
not found, in reference. Essential fatty acid deficiency in premature infants. Nutr Rev 1989;47(2):39–41. No omega-3 fatty acid focus (intervention/exposure or biomarkers)
O'Brien P M S, Pipkin F B. The effect of essential fatty acid and specific vitamin supplements on vascular sensitivity in the mid-trimester of human pregnancy. Clinical & Experimental Hypertension - Part B, Hypertension in Pregnancy 1983;2(2). No omega-3 fatty acid focus (intervention/exposure or biomarkers)
O'Brien P M, Morrison R, Broughton Pipkin F. The effect of dietary supplementation with linoleic and gammalinolenic acids on the pressor response to angiotensin II--a possible role in pregnancy-induced hypertension?. Br J Clin Pharmacol. 1985;19(3):335-342. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 2985102]. [pmcid: 1463724].
O'Neill J A. The contribution of parenteral nutrition to pediatric care. Acta Chirurgica Scandinavica - Supplementum 1983;5171–6. No omega-3 fatty acid focus (intervention/exposure or biomarkers)
Odent M. Land food … sea food … brain food. Midwifery Today Childbirth Educ 1996;(40):18–20. Not a first publication of empirical evidence (e.g., review)
Ogburn P L, Turner S I, Williams P P, et al. Essential fatty acid patterns in preeclampsia. Zentralbl Gynakol. 1986;108(16):983-989. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 3096014].
Olsen SFSecher, NJBjA rnsson, SWeber. The potential benefits of using fish oil in relation to preterm labor: the case for a randomized controlled trial?. Acta Obstet Gynecol Scand. 2003;82(11):978-982. Not a first publication of empirical evidence (e.g., review). [pmid: 14616269].
Olsen S F. Commentary: Mercury, PCB, and now eicosapentaenoic acid: Still another reason why pregnant women should be concerned about eating seafood?. Int J Epidemiol 2001;30(6). Not a first publication of empirical evidence (e.g., review).
Olsen S F. Further on the association between retarded foetal growth and adult cardiovascular disease. Could low intake or marine diets be a common cause?. [Review] [46 refs]. J Clin Epidemiol. 1994;47(5):565-569. Not a first publication of empirical evidence (e.g., review). [pmid: 7730882].
Olsen S F. Pregnancy and food: The significance of food for the health during pregnancy seen from an epidemiological point of view. Ugeskr Laeger. 11-17. 2003;165(47):4533-4537. Not a first publication of empirical evidence (e.g., review). [pmid: 14677232].
Olsen S F, Hansen H S, Sorensen T et al. Hypothesis: dietary (N-3)-fatty acids prolong gestation in human beings. Progress in Clinical & Biological Research 1987;24251–56. Not a first publication of empirical evidence (e.g., review).
Olson R E, Zlotkin S H, Newman T B et al. Reducing dietary intake of fat and cholesterol in children [1]. J Am Med Assoc 1995;274(18). No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Papoz L, Eschwege E, Pequignot G, et al. Maternal smoking and birth weight in relation to dietary habits. American Journal of Obstetrics & Gynecology. 1-4. 1982;142(7):870-876. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 7065066].
Paulsrud J R, Pensler L, Whitten C F, et al. Essential fatty acid deficiency in infants induced by fat-free intravenous feeding. Am J Clin Nutr. 1972;25(9):897-904. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 4626563].
Peat J K. Can asthma be prevented? Evidence from epidemiological studies of children in Australia and New Zealand in the last decade. Clinical & Experimental Allergy 1998;28(3). Not related to predefined child or maternal health outcomes.
Pereira G R, Baumgart S, Bennett M J, et al. Use of high-fat formula for premature infants with bronchopulmonary dysplasia: metabolic, pulmonary, and nutritional studies.[comment]. Eur J Pediatr. 1994;124(4):605-611. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Perteagudo L, Matorras R, Sanjurjo P et al. Lipidic intake by pregnant women, with especial reference to polyunsaturated fatty acids. Progresos de Obstetricia y Ginecologia 1995;38(7). Not related to predefined child or maternal health outcomes.
Picaud J-C. Formula-fed preterm neonates. Minerva Pediatr 2003;55(3). No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Pichard C. A randomized double-blind controlled study of 6 months of oral nutritional supplementation with arginine and omega-3 fatty acids in HIV-infected patients. Swiss HIV Cohort Study. Int J STD AIDS. 1-1. 1998;12(1):53-63. Not related to predefined child or maternal health outcomes.
Pipkin F B, Crowther C, de Swiet M, et al. Where next for prophylaxis against pre-eclampsia?[comment]. British Journal of Obstetrics & Gynaecology. 1996;103(7):603-607. Not a first publication of empirical evidence (e.g., review). [pmid: 8688382].
Potter J M. The effects of dietary fatty acids and cholesterol on the milk lipids of lactating women and the plasma cholesterol of breast-fed infants. Am J Clin Nutr. 1976;29(1):54-60. Not related to predefined child or maternal health outcomes. [pmid: 1246976].
Pulsifer M B, Gordon J M, Brandt J et al. Effects of ketogenic diet on development and behavior: Preliminary report of a prospective study. Developmental Medicine & Child Neurology 2001;43(5). No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Puri P. 13th international symposium on pediatric surgical research, Ann Arbor, Michigan, USA, 2–4 November, 2000. Pediatr Surg Int. 2001;17(4):253-333. Not involving human participants.
Rao S, Yajnik C S, Kanade A, et al. Intake of micronutrient-rich foods in rural Indian mothers is associated with the size of their babies at birth: Pune Maternal Nutrition Study. Br J Nutr. 2001;131(4):1217-1224. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Rask Nissila L, Jokinen E, Terho P, et al. Neurological development of 5-year-old children receiving a low-saturated fat, low-cholesterol diet since infancy. A randomized controlled trial. JAMA. 2000;284(8):993-1000. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 10944645].
Reichelderfer T E, Levin S, McPherson T C. Feeding of prematures. Evaluation by use of the Latin Square. Am J Dis Child. 1967;114(4):385-388. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 6072196].
Reynolds J W. Enteral and parenteral nutrition of low birth weight infants. Boletin - Asociacion Medica de Puerto Rico. 1985;77(7):302-304. Not a first publication of empirical evidence (e.g., review). [pmid: 2933046].
Rice R D. Breastfeeding and intelligence.[comment]. Lancet. 7-3. 1992;339(8793):613-614. Not a first publication of empirical evidence (e.g., review). [pmid: 1347109].
Roberts S B, Lucas A. Energetic efficiency and nutrient accretion in preterm infants fed extremes of dietary intake. Human Nutrition - Clinical Nutrition. 1987;41(2):105-113. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 3570867].
Robertson A F, Karp W B. Placental transport of nutrients. South Med J. 1976;69(10):1358-1362. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 982117].
Rodriguez M K A, Calero O R. Preeclampsia - Eclampsia syndrome. Rev Colomb Obstet Ginecol 1993;44(4). No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Roem K. Nutritional management of multiple pregnancies. [Review] [60 refs]. Twin Res. 2003;6(6):514-519. Not a first publication of empirical evidence (e.g., review). [pmid: 14965462].
Rogers I S, Emmett P M. ALSPAC Study, et al. Fat content of the diet among preschool children in southwest Britain: II. relationship with growth, blood lipids, and iron status. Pediatrics. 2001;108(3):E49. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 11533367].
Rojas C V, Martinez J I, Flores I, et al. Gene expression analysis in human fetal retinal explants treated with docosahexaenoic acid. Invest Ophthalmol Vis Sci. 2003;44(7):3170-3177. Not involving human participants. [pmid: 12824268].
Roy C C, Ste-Marie M, Chartrand L, et al. Correction of the malabsorption of the preterm infant with a medium-chain triglyceride formula. Eur J Pediatr. 1975;86(3):446-450. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Rump P, Hornstra G. Relation between arachidonic acid and docosahexaenoic acid in maternal and neonatal blood.[comment]. Eur J Clin Nutr. 2001;55(10):916-917. Not related to predefined child or maternal health outcomes. [pmid: 11593355].
Sanchez-Bayle M, Soriano-Guillen L. Influence of dietary intervention on growth in children with hypercholesterolaemia. Acta Paediatr. 9-1. 2003;92(9):01. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Sanders T A, Reddy S. Infant brain lipids and diet.[comment]. Lancet. 1992;340(8827):1093-1094. Not a first publication of empirical evidence (e.g., review). [pmid: 1357474].
Sanders T A, Reddy S. Vegetarian diets and children. [Review] [54 refs]. Am J Clin Nutr. 1994;59(5 Suppl):1176S-1181S. Not a first publication of empirical evidence (e.g., review). [pmid: 8172120].
Sauerwald T U. Effect of alpha-linolenic acid intake and postmenstrual age on arachidonic and docosahexaenoic acid biosynthesis in preterm infants. Journal of Pediatric Gastroenterology & Nutrition. 1995;21(3):358. Not related to predefined child or maternal health outcomes.
Sauerwald T U, Hachey D L, Jensen C L, et al. Effect of dietary alpha-linolenic acid intake on incorporation of docosahexaenoic and arachidonic acids into plasma phospholipids of term infants. Lipids. 1996;31(Suppl):S131-S135. Not related to predefined child or maternal health outcomes. [pmid: 8729107].
Saugstad L F. Manic depressive psychosis and schizophrenia are neurological disorders at the extremes of CNS maturation and nutritional disorders associated with a deficit in marine fat. [Review] [136 refs]. Med Hypotheses. 2001;57(6):679-692. Not a first publication of empirical evidence (e.g., review). [pmid: 11918426].
Schiff E, Ben Baruch G, Barkai G, et al. Reduction of thromboxane A2 synthesis in pregnancy by polyunsaturated fatty acid supplements. American Journal of Obstetrics & Gynecology. 1993;168(1 Pt 1):122-124. Not related to predefined child or maternal health outcomes. [pmid: 8420313].
Schwarz K B, Cox J, Savitri Sharma, et al. Progressive decrease in plasma omega3 and omega6 fatty acids during pregnancy: time course and effects of dietary fats and antioxidant nutrients. Journal of Nutritional and Environmental Medicine. 1998;8(4):335-344. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Shea S, Basch C E, Stein A D, et al. Is there a relationship between dietary fat and stature or growth in children three to five years of age?. Pediatrics. 1993;92(4):579-586. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 8414831].
Shenai J P, Jhaveri B M, Reynolds J W, Huston R K, Babson S G. Nutritional balance studies in very low-birth-weight infants: role of soy formula. Pediatrics. 1981;67(5):631-637. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 7196014].
Shennan A H, Chappell L. Pre-eclampsia. Contemporary Clinical Gynecology & Obstetrics 2002;1(4). Not a first publication of empirical evidence (e.g., review).
Shilina N M, Konovalova L S, Koterov A N, et al. [Dynamics of malonic aldehyde, transferrin levels and blood antioxidant activity in women with normal pregnancy and pregnancy complicated by toxicosis: effect of eiconol]. [Russian]. Vopr Med Khim. 1999;45(5):398-406. Not related to predefined child or maternal health outcomes. [pmid: 10635534].
Simell O, Niinikoski H, Ronnemaa T, et al. Special Turku Coronary Risk Factor Intervention Project for Babies (STRIP). Am J Clin Nutr. 2000;72(5 Suppl):1316S-1331S. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 11063474].
Simopoulos A P. Summary of the NATO Advanced Research Workshop on Dietary omega3 and omega6 Fatty Acids: Biological Effects and Nutritional Essentiality. Br J Nutr. 1989;119(4):521-528. Not a first publication of empirical evidence (e.g., review).
Skinner E R, Postle A D. Brain lipids and mental disorders. A colloquium from the 664th Meeting of the Biochemical Society, University of Reading, Reading, UK, 15–17 December, 1997. Biochem Soc Trans. 1998;26(2):243-277. Not a first publication of empirical evidence (e.g., review). [pmid: 9649755].
Smuts C M, Tichelaar H Y, Kirsten G F. The vital role of essential fatty acid metabolites in normal growth and development of preterm infants--new perspectives. S Afr Med J. 1996;86(8):933-934. Not a first publication of empirical evidence (e.g., review). [pmid: 8823411].
Sorensen J D, Olsen S F, Pedersen A K, et al. Effects of fish oil supplementation in the third trimester of pregnancy on prostacyclin and thromboxane production. American Journal of Obstetrics & Gynecology. 1993;168(3 Pt 1):915-922. Not related to predefined child or maternal health outcomes. [pmid: 8456902].
Soriano C R, Martinez F E, Jorge S M. Cutaneous application of vegetable oil as a coadjutant in the nutritional management of preterm infants. Journal of Pediatric Gastroenterology & Nutrition. 2000;31(4):387-390. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 11045835].
Sovik O, Mansson J-E, Bjorke Monsen A L et al. Generalized peroxisomal disorder in male twins: Fatty acid composition of serum lipids and response to n - 3 fatty acids. J Inherit Metab Dis 1998;21(6). Not related to predefined child or maternal health outcomes.
Starling M B, McCowan L, Stewart F, Gunn T. Fish-oil and pre-eclampsia.[comment]. British Journal of Obstetrics & Gynaecology. 1992;99(4):351-352. Not a first publication of empirical evidence (e.g., review). [pmid: 1581287].
Steuerwald U, Weihe P, Jorgensen P J et al. Maternal seafood diet, methylmercury exposure, and neonatal neurologic function. Eur J Pediatr 2000;136(5). No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Stier C, Hess M, Watzer B, et al. Prostanoid formation during feeding of a preterm formula with long-chain polyunsaturated fatty acids in healthy preterm infants during the first weeks of life. Pediatr Res. 1997;42(4):509-513. Not related to predefined child or maternal health outcomes. [pmid: 9380445].
Svennerholm L, Vanier M T. The distribution of lipids in the human nervous system. 3. Fatty acid composition of phosphoglycerides of human foetal and infant brain. Brain Research. 1973;50(2):341-351. Not involving human participants. [pmid: 4705503].
Szostak-Wegierek D. Importance of proper nutrition before and during pregnancy. [Polish]. Medycyna Wieku Rozwojowego. 2003;4(3 Suppl 1):77-88. Not a first publication of empirical evidence (e.g., review).
Thomas E L, Hanrahan J D, Ala Korpela M, et al. Noninvasive characterization of neonatal adipose tissue by 13C magnetic resonance spectroscopy. Lipids. 1997;32(6):645-651. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 9208394].
Thorpe M. Infant formula supplemented with DHA: are there benefits?. J Am Diet Assoc. 2003;103(5):551-552. Not a first publication of empirical evidence (e.g., review). [pmid: 12733531].
Thorsdottir I, Gunnarsdottir I, Palsson G I. Birth weight, growth and feeding in infancy: Relation to serum lipid concentration in 12-month-old infants. Eur J Clin Nutr 2003;57(11). Not related to predefined child or maternal health outcomes.
Thorsdottir I, Gunnarsson B S, Atladottir H, et al. Iron status at 12 months of age -- effects of body size, growth and diet in a population with high birth weight. Eur J Clin Nutr. 2003;57(4):505-513. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12700611].
Tichelaar H Y. Possible relevance of abnormal fatty acid metabolism in undernutrition: the relationship between oleic acid and growth. Med Hypotheses. 2000;54(5):708-711. Not a first publication of empirical evidence (e.g., review). [pmid: 10859672].
Tolley E A, Carlson S E. Considerations of statistical power in infant studies of visual acuity development and docosahexaenoic acid status. Am J Clin Nutr 2000;71(1). Not a first publication of empirical evidence (e.g., review).
Tonstad S. A rational approach to treating hypercholesterolaemia in children. Weighing the risks and benefits. Drug Saf 1997;16(5). Not related to predefined child or maternal health outcomes.
Totlandsdal J K, Tvedt N, Breilid R, et al. [Does supplementation of essential fatty acids influence the visual acuity and cognitive function of term infants?]. [Review] [40 refs] [Norwegian]. Tidsskr Nor Laegeforen. 10-9. 2001;121(21):2504-2509. Not a first publication of empirical evidence (e.g., review). [pmid: 11875928].
Uauy, R. Are essential fatty acids required for normal eye and brain development? International Pediatrics 1991; 6(1). Not a first publication of empirical evidence (e.g., review).
Uauy R, Castillo C. Lipid requirements of infants: implications for nutrient composition of fortified complementary foods. [Review] [83 refs]. Br J Nutr. 2003;133(9):2962S-2972S. Not related to predefined child or maternal health outcomes.
Uauy R, Birch E, Birch D, et al. Visual and brain function measurements in studies of n-3 fatty acid requirements of infants.[erratum appears in J Pediatr 1992 Aug;121(2):329]. [Review] [107 refs]. Eur J Pediatr. 1992;120(4 Pt 2):S168-S180. Not a first publication of empirical evidence (e.g., review).
Uauy R, Mena P, Salem N J et al. Long-chain polyunsaturated fatty acid requirements of preterm infants. Essential fatty acids and eicosanoids: invited papers from the Fourth International Congress, Edinburgh, Scotland, UK, July 20 24, 1997 1998;141–146; 25 ref. Not a first publication of empirical evidence (e.g., review).
Valenzuela A, Nieto M S. Docosahexaenoic acid (DHA) in fetal development and in infant nutrition. [Review] [39 refs] [Spanish]. Revista Medica de Chile. 2001;129(10):1203-1211. Not a first publication of empirical evidence (e.g., review). [pmid: 11775350].
van Buul B J, Steegers E A, Jongsma H W, et al. Dietary sodium restriction in the prophylaxis of hypertensive disorders of pregnancy: effects on the intake of other nutrients. Am J Clin Nutr. 1995;62(1):49-57. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 7598066].
van Egmond A W, Kosorok M R, Koscik R, et al. Effect of linoleic acid intake on growth of infants with cystic fibrosis. Am J Clin Nutr. 1996;63(5):746-752. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 8615359].
Van Herreweghe I. New perspectives in lipid emulsions for preterm infants: a mixture of medium chain (MCT) soybean oil (LCT) and fish oil (FO): MLF. Pediatr Res. 2002;51(4):318A. Not related to predefined child or maternal health outcomes.
van Houwelingen A C, Foreman-van Drongelen M M, Al M D M et al. Fetal essential fatty acids during gestation. Am J Clin Nutr 1993;57(5 SUPPL.). No omega-3 fatty acid focus (intervention/exposure or biomarkers).
van Houwelingen A C, Puls J, Hornstra G. Fetal essential fatty acid (EFA) status during early human development: Relationship with maternal EFA status. Am J Clin Nutr 1993;57(5 SUPPL.). Not involving human participants.
Vancassel S, Durand G, Barthelemy C, et al. Plasma fatty acid levels in autistic children. Prostaglandins Leukotrienes & Essential Fatty Acids. 2001;65(1):1-7. Not related to predefined child or maternal health outcomes.
Verkade H J, van Asselt W A, Vonk R J, et al. Fat absorption in premature infants: the effect of lard and antibiotics. Eur J Pediatr. 1989;149(2):126-129. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 2512163].
Villar J, Merialdi M, Gulmezoglu A M, et al. Nutritional interventions during pregnancy for the prevention or treatment of maternal morbidity and preterm delivery: an overview of randomized controlled trials. [Review] [170 refs]. Br J Nutr. 2003;133(5 Suppl 2):1606S-1625S. Not a first publication of empirical evidence (e.g., review).
von Houwelingen A C, Hornstra G. Trans fatty acids in early human development. World Review of Nutrition & Dietetics 1994;75175–178. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
von Muralt A. The developing brain and the damage inflicted by malnutrition: an introduction. In: lipids, malnutrition & the developing brain. Ciba Found Symp 1971;1–7. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Walker T, Singh P K, Wyatt K M, et al. The effect of prostanoid precursors and inhibitors on platelet angiotensin II binding. J Obstet Gynaecol. 1999;19(1):56-58. Not related to predefined child or maternal health outcomes. [pmid: 15512224].
Walker W A. Role of nutrients and bacterial colonization in the development of intestinal host defense. Journal of Pediatric Gastroenterology & Nutrition 2000;30(SUPPL. 2). No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Warshaw J B. Fatty acid metabolism during development. Semin Perinatol. 1979;3(2):131-139. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 115094].
Welsch H, Heinz F, Lagally G, et al. [Fat resorption from human milk in the newborn]. [German]. Klin Wochenschr. 15-8. 1965;43(16):902-904. Not related to predefined child or maternal health outcomes. [pmid: 5862694].
Wemmer U, Erhard U. [Balanced parenteral and oral feeding of underweight newborn infants]. [German]. Infusionsther Klin Ernahr. 1979;6(5):268-272. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 118117].
White H B, Galli C, Paoletti R. Ethanolamine phosphoglyceride fatty acids in aging human brain. J Neurochem. 1971;18(7):1337-1339. Not involving human participants. [pmid: 5118886].
Whyte R K, Campbell D, Stanhope R, et al. Energy balance in low birth weight infants fed formula of high or low medium-chain triglyceride content. Eur J Pediatr. 1986;108(6):964-971. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Willatts P. Long chain polyunsaturated fatty acids improve cognitive development. J Fam Health Care. 2002;12(6 Suppl):5. Not a first publication of empirical evidence (e.g., review). [pmid: 12630150].
Williams M L, Shoot R J, O'Neal P L, et al. Role of dietary iron and fat on vitamin E deficiency anemia of infancy. N Engl J Med. 24-4. 1975;292(17):887-890. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 1117912].
Woodbury M M, Woodbury M A. Neuropsychiatric development: Two case reports about the use of dietary fish oils and/or choline supplementation in children. J Am Coll Nutr 1993;12(3). Not related to predefined child or maternal health outcomes.
Yurdakok M, Yurdakok K. Topical vegetable oil therapy for premature infants.[comment]. Eur J Pediatr. 1997;130(2):330-332. No omega-3 fatty acid focus (intervention/exposure or biomarkers).

### Level 3 Exlusions

Agostoni C, Verduci E, Massetto N, Radaelli G, Riva E, Giovannini M. Plasma long-chain polyunsaturated fatty acids and neurodevelopment through the first 12 months of life in phenylketonuria. Dev Med Child Neurol. 2003;45(4):257-261. Not level of evidence. [pmid: 12647927].
Andersen H J, Andersen L F, Fuchs A R. Diet, pre-eclampsia, and intrauterine growth retardation. Lancet. 1989;1(8647):1146. Not level of evidence. [pmid: 2566093].
Araya A J, Rojas G M, Fernandez F P, Mateluna A A. [Differences in percent composition of long chain polyunsaturated fatty acids in maternal-fetal erythrocytes in term and preterm infants]. [Spanish]. Arch Latinoam Nutr. 1998;48(3):210-215. Not level of evidence. [pmid: 9951532].
Araya J, Rojas M, Fernandez P, Mateluna A. [Essential fatty acid content of maternal erythrocyte phospholipids. A study in preterm and full-term human newborns]. [Spanish]. Rev Med Chil. 1998;126(4):391-396. Not level of evidence. [pmid: 9699369].
Badart-Smook A, van Houwelingen A C, Al M D, Kester A D, Hornstra G. Fetal growth is associated positively with maternal intake of riboflavin and negatively with maternal intake of linoleic acid. J Am Diet Assoc. 1997;97(8):867-870. Not level of evidence. [pmid: 9259708].
Bakker E C, Ghys A J, Kester A D, Vles J S, Dubas J S, Blanco C E, et al. Long-chain polyunsaturated fatty acids at birth and cognitive function at 7 y of age. Eur J Clin Nutr. 2003;57(1):89-95. Not level of evidence. [pmid: 12548302].
Bellati U, Pompa P, Liberati M. [Evaluation of the effect of a “Mediterranean diet” and pre-pregnancy body mass on fetal growth]. [Italian]. Minerva Ginecol. 1995;47(6):259-262. Not level of evidence. [pmid: 7478095].
Bjerve K S, Thoresen L, Bonaa K, Vik T, Johnsen H, Brubakk A M. Clinical studies with alpha-linolenic acid and long-chain n-3 fatty acids. Nutrition. 1992;8(2):130-132. Not level of evidence. [pmid: 1350473].
Bjerve K S, Brubakk A M, Fougner K J, Johnsen H, Midthjell K, Vik T. Omega-3 fatty acids: essential fatty acids with important biological effects, and serum phospholipid fatty acids as markers of dietary omega 3-fatty acid intake. Am J Clin Nutr. 1993;57(5 Suppl):801S-805S. Not level of evidence. [pmid: 8475898].
Buchanan G R, Uauy R, Holtkamp C, Nickell M. Bleeding time (BT) measurements in healthy very low birth weight neonates (VLBWN) between 10 and 120 days of age. Pediatr Res. 1990;27:262a. Not level of evidence.
Carlson S E, Cooke R J, Peeples J M, Werkman S H, Tolley E A. Docosahexaenoate (DHA) and eicosapentaenoate (EPA) status of preterm infants: relationship to visual acuity in n-3 supplemented and unsupplemented infants. Pediatr Res. 1989;25:285a. Not level of evidence. [pmid: 2704597].
Carlson S E. Arachidonic acid status of human infants: influence of gestational age at birth and diets with very long chain n-3 and n-6 fatty acids. J Nutr. 1996;126(4 Suppl):1092S-1098S. Not level of evidence. [pmid: 8642439].
Chao P, Wang B, Lin H, Tsai H. The red blood cell fatty acid composition of preterm and term infants in Taichung, Taiwan. Nutr Sci J. 1997;22(3):267-276. Not level of evidence.
Clandinin M T, Aerde Jv, Parrott A, Field C J, Euler A R, Lien E L, et al. Assessment of the efficacious dose of arachidonic and docosahexaenoic acids in preterm infant formulas: fatty acid composition of erythrocyte membrane lipids. Pediatr Res. 1997;42(6):819-825. Not level of evidence. [pmid: 9396564].
Clandinin M T, Aerde Jv, Parrott A, Field C J, Euler A R, Lien E, et al. Assessment of feeding different amounts of arachidonic and docosahexaenoic acids in preterm infant formulas on the fatty acid content of lipoprotein lipids. Acta Paediatr. 1999;88(8):890-896. Not level of evidence. [pmid: 10503691].
Clausen T, Slott M, Solvoll K, Drevon C A, Vollset S E, Henriksen T. High intake of energy, sucrose, and polyunsaturated fatty acids is associated with increased risk of preeclampsia. Am J Obstet Gynecol. 2001;185(2):451-458. Not level of evidence. [pmid: 11518908].
Courage M L, McCloy U R, Herzberg G R, Andrews W L, Simmons B S, McDonald A C, et al. Visual acuity development and fatty acid composition of erythrocytes in full-term infants fed breast milk, commercial formula, or evaporated milk. J Dev Behav Pediatr. 1998;19(1):9-17. Not level of evidence. [pmid: 9524300].
Crawford M A, Doyle W, Drury P, Lennon A, Costeloe K, Leighfield M. n-6 and n-3 fatty acids during early human development. J Intern Med Suppl. 1989;225(731 Suppl):159-169. Not level of evidence. [pmid: 2706039].
Crawford M A, Costeloe K, Doyle W, Leighfield M J, Lennon E A, Meadows N. Potential diagnostic value of the umbilical artery as a definition of neural fatty acid status of the fetus during its growth: the umbilical artery as a diagnostic tool. Biochem Soc Trans. 1990;18(5):761-766. Not level of evidence. [pmid: 2083670].
Cuellar A, Frenk S. [Omega-6 and omega-3 polyunsaturated fatty acids in healthy and sick children under 5 years of age. Part II. Pathologic metabolism]. [Review] [82 refs] [Spanish]. Bol Med Hosp Infant Mex. 1992;49(10):631-640. Not level of evidence. [pmid: 1449621].
Decsi T, Molnar D, Koletzko B. The effect of under- and overnutrition on essential fatty acid metabolism in childhood. [Review] [54 refs]. Eur J Clin Nutr. 1998;52(8):541-548. Not level of evidence. [pmid: 9725653].
Decsi T, Kelemen B, Minda H, Burus I, Kohn G. Effect of type of early infant feeding on fatty acid composition of plasma lipid classes in full-term infants during the second 6 months of life. J Pediatr Gastroenterol Nutr 2000; 30(5). Not level of evidence.
Deheeger M, Rolland-Cachera M-F, Labadie M-D, Rossignol C. Longitudinal study of nutrition and growth in children followed from 10 months to 8 years of age. Cah Nutr Diet 1994; 29(1). Not level of evidence.
Di Cintio E, Parazzini F, Chatenoud L, Surace M, Benzi G, Zanconato G, et al. Dietary factors and risk of spontaneous abortion. Eur J Obstet Gynecol Reprod Biol. 2001;95(1):132-136. Not level of evidence. [pmid: 11267735].
Felton C V, Chang T C, Crook D, Marsh M, Robson S C, Spencer J A. Umbilical vessel wall fatty acids after normal and retarded fetal growth. Arch Dis Child Fetal Neonatal Ed. 1994;70(1):F36-F39. Not level of evidence. [pmid: 8117125].
Fomon S J, Thomas L N, Filer L J Jr, Ziegler E E, Leonard M T. Food consumption and growth of normal infants fed milk-based formulas. Acta Paediatr Scand. 1971;223(Suppl):1-36. Not level of evidence.
Foreman-van Drongelen M M, van Houwelingen A C, Kester A D, Hasaart T H, Blanco C E, Hornstra G. Long-chain polyunsaturated fatty acids in preterm infants: status at birth and its influence on postnatal levels. J Pediatr. 1995;126(4):611-618. Not level of evidence. [pmid: 7699544].
Foreman-van Drongelen M M, Al M D, van Houwelingen A C, Blanco C E, Hornstra G. Comparison between the essential fatty acid status of preterm and full-term infants, measured in umbilical vessel walls. Early Hum Dev. 1995;42(3):241-251. Not level of evidence. [pmid: 7493590].
Gerrard J, Popeski D, Ebbeling L, Brown P, Hornstra G. Dietary omega 3 fatty acids and gestational hypertension in the Inuit. Arctic Med Res. 1991;(Suppl):763-767. Not level of evidence.
Ghebremeskel K, Crawford M A, Lowy C, Min Y, Thomas B, Golfetto I, et al. Arachidonic and docosahexaenoic acids are strongly associated in maternal and neonatal blood.[comment]. Eur J Clin Nutr. 2000;54(1):50-56. Not level of evidence. [pmid: 10694772].
Grandjean P, Bjerve K S, Weihe P, Steuerwald U. Birthweight in a fishing community: significance of essential fatty acids and marine food contaminants.[comment]. Int J Epidemiol. 2001;30(6):1272-1278. Not level of evidence. [pmid: 11821327].
Guldan G S, Zhang M Y, Zhang Y P, Hong J R, Zhang H X, Fu S Y, et al. Weaning practices and growth in rural Sichuan infants: a positive deviance study. J Trop Pediatr. 1993;39(3):168-175. Not level of evidence. [pmid: 8326537].
Hansen I B, Friis-Hansen B, Clausen J. The fatty acid composition of umbilical cord serum, infant serum and maternal serum and its relation to the diet. Z Ernahrungswiss. 1969;9(4):352-363. Not level of evidence. [pmid: 5395483].
Harper V, MacInnes R, Campbell D, Hall M. Increased birth weight in northerly islands: is fish consumption a red herring?. BMJ. 1991;303(6795):166. Not level of evidence. [pmid: 1878642]. [pmcid: 1670406].
Hayes K C, Pronczuk A, Wood R A, Guy D G. Modulation of infant formula fat profile alters the low-density lipoprotein/high-density lipoprotein ratio and plasma fatty acid distribution relative to those with breast-feeding. J Pediatr. 1992;120(4 Pt 2):S109-S116. Not level of evidence. [pmid: 1560323].
Helland I B, Smith L, Saarem K, Saugstad O D, Drevon C A. Maternal supplementation with very-long-chain n-3 fatty acids during pregnancy and lactation augments children's IQ at 4 years of age. Pediatrics. 2003;111(1):e39-e44. Not level of evidence. [pmid: 12509593].
Hurgoiu V, Caseanu E, David-Mark S. Supplementation of energy supply in premature infants by parenteral lipid administration. Pediatrie (Bucur) 1993; 48(7–8). Not level of evidence.
Innis S M, Nelson C M, Lwanga D, Rioux F M, Waslen P. Feeding formula without arachidonic acid and docosahexaenoic acid has no effect on preferential looking acuity or recognition memory in healthy full-term infants at 9 mo of age. Am J Clin Nutr. 1996;64(1):40-46. Not level of evidence. [pmid: 8669412].
Jurgenssen O. [Clinical report on the experiences with a new modified infant formulay “Adapta”]. [German]. Wien Med Wochenschr. 1967;117(29):715-718. Not level of evidence. [pmid: 4877390].
Kesmodel U, Olsen S F, Salvig J D. Marine n-3 fatty acid and calcium intake in relation to pregnancy induced hypertension, intrauterine growth retardation, and preterm delivery. A case-control study. Acta Obstet Gynecol Scand. 1997;76(1):38-44. Not level of evidence. [pmid: 9033242].
Koletzko B, Braun M. Arachidonic acid and early human growth: is there a relation?. Ann Nutr Metab. 1991;35(3):128-131. Not level of evidence. [pmid: 1952812].
Ladodo K S, Barashneva S M, Sadyrbaeva Z S, Sirota A V, Gribakin S G. [Effectiveness of feeding premature infants in the 2d month of life with milk formulas having a varying fat content]. [Russian]. Pediatriia. 1985;(4):10-13. Not level of evidence.
Leaf A A, Leighfield M J, Costeloe K L, Crawford M A. Factors affecting long-chain polyunsaturated fatty acid composition of plasma choline phosphoglycerides in preterm infants. J Pediatr Gastroenterol Nutr. 1992;14(3):300-308. Not level of evidence. [pmid: 1535657].
Leaf A A, Leighfield M J, Costeloe K L, Crawford M A. Long chain polyunsaturated fatty acids and fetal growth. Early Hum Dev. 1992;30(3):183-191. Not level of evidence. [pmid: 1468382].
Matorras R, De Larrucea AL, Sanjurjo P, Ruiz JI, Echevarria Y, Nieto A et al. Increased tissue concentrations of arachidonic acid in umbilical artery and placenta in fetal growth retardation. Acta Obstet Gynecol Scand 2001; 80(9). Not level of evidence.
Mourek J, Dohnalova A. Relationship between birth weight of newborns and unsaturated fatty acid(n-3) proportions in their blood serum. Physiol Res. 1996;45(2):165-168. Not level of evidence. [pmid: 9496767].
Mydlilova A, Mourek J, Base J, Smidova L, Tomasova H, Dvorak M. [The fatty acid spectrum in the serum of mothers and infants after premature delivery]. [Czech]. Cesk Gynekol. 1991;56(9-10):477-483. Not level of evidence. [pmid: 1824342].
Olsen S F, Hansen H S, Sorensen T I, Jensen B, Secher N J, Sommer S, et al. Intake of marine fat, rich in (n-3)-polyunsaturated fatty acids, may increase birthweight by prolonging gestation. Lancet. 1986;2(8503):367-369. Not level of evidence. [pmid: 2874370].
Olsen S F, Hansen H S, Jensen B, Sorensen T I. Pregnancy duration and the ratio of long-chain n-3 fatty acids to arachidonic acid in erythrocytes from Faroese women. J Intern Med Suppl. 1989;225(731 Suppl):185-189. Not level of evidence.
Olsen S F, Secher N J. A possible preventive effect of low-dose fish oil on early delivery and pre-eclampsia: indications from a 50-year-old controlled trial. Br J Nutr. 1990;64(3):599-609. Not level of evidence. [pmid: 2265175].
Olsen S F, Olsen J, Frische G. Does fish consumption during pregnancy increase fetal growth? A study of the size of the newborn, placental weight and gestational age in relation to fish consumption during pregnancy. Int J Epidemiol. 1990;19(4):971-977. Not level of evidence. [pmid: 2084030].
Olsen S F, Hansen H S, Sommer S, Jensen B, Sorensen T I, Secher N J, et al. Gestational age in relation to marine n-3 fatty acids in maternal erythrocytes: a study of women in the Faroe Islands and Denmark. Am J Obstet Gynecol. 1991;164(5 Pt 1):1203-1209. Not level of evidence. [pmid: 1827949].
Olsen S F, Grandjean P, Weihe P, Videro T. Frequency of seafood intake in pregnancy as a determinant of birth weight: evidence for a dose dependent relationship. J Epidemiol Community Health. 1993;47(6):436-440. Not level of evidence. [pmid: 8120495].
Olsen S F, Hansen H S, Secher N J, Jensen B, Sandstrom B. Gestation length and birth weight in relation to intake of marine n-3 fatty acids. Br J Nutr. 1995;73(3):397-404. Not level of evidence. [pmid: 7766563].
Olsen S F, Secher N J. Low consumption of seafood in early pregnancy as a risk factor for preterm delivery: Prospective cohort study. BMJ. 2002;324(7335):23. Not level of evidence. [pmid: 11777800]. [pmcid: 61654].
Petridou E, Koussouri M, Toupadaki N, Youroukos S, Papavassiliou A, Pantelakis S, et al. Diet during pregnancy and the risk of cerebral palsy. Br J Nutr. 1998;79(5):407-412. Not level of evidence. [pmid: 9682658].
Pita M, Sanchez-Pozo A, Gil A, Robles R, Faus M J, Sanchez-Medina F. [Lipid profile in low birth weight neonates, small for gestational age]. [Spanish]. An Esp Pediatr. 1984;21(3):215-221. Not level of evidence. [pmid: 6508028].
Popeski D, Ebbeling L R, Brown P B, Hornstra G, Gerrard J M. Blood pressure during pregnancy in Canadian Inuit: community differences related to diet. CMAJ. 1991;145(5):445-454. Not level of evidence. [pmid: 1878826]. [pmcid: 1335827].
Ramirez M, Gallardo E M, Souto A S, Weissheimer C, Gil A. Plasma fatty-acid composition and antioxidant capacity in low birth-weight infants fed formula enriched with n-6 and n-3 long-chain polyunsaturated fatty acids from purified phospholipids. Clin Nutr. 2001;20(1):69-76. Not level of evidence. [pmid: 11161546].
Reddy S, Sanders T A, Obeid O. The influence of maternal vegetarian diet on essential fatty acid status of the newborn. Eur J Clin Nutr. 1994;48(5):358-368. Not level of evidence. [pmid: 8055852].
Rodriguez A, Raederstorff D, Sarda P, Lauret C, Mendy F, Descomps B. Preterm infant formula supplementation with alpha linolenic acid and docosahexaenoic acid. Eur J Clin Nutr. 2003;57(6):727-734. Not level of evidence. [pmid: 12792656].
Rossi E, Costa M. Fish oil derivatives as a prophylaxis of recurrent miscarriage associated with antiphospholipid antibodies (APL): a pilot study. Lupus. 1993;2(5):319-323. Not level of evidence. [pmid: 8305926].
Santiago Burruchaga M, Ruiz-Sanz J I, Pijoan-Zubizarreta J I, Benito Fernandez J, Sanjurjo Crespo P. Intellectual development in the second year of life in healthy breast-fed children vs. formula-fed children. An Esp Pediatr. 2000;52(6):530-536. Not level of evidence. [pmid: 11003961].
Tichelaar H Y, Steyn N P, Nel J H, Smuts C M, Jaarsveld P Jv, Prinsloo J F, et al. Effect of catfish supplementation on the fatty acid status and growth of undernourished rural preschool children under 6 years of age: an intervention trial in Lebowa, South Africa. Asia Pac J Clin Nutr. 1999;8(2):96-105. Not level of evidence.
van der Schouw Y T, Al M D, Hornstra G, Bulstra-Ramakers M T, Huisjes H J. Fatty acid composition of serum lipids of mothers and their babies after normal and hypertensive pregnancies. Prostaglandins Leukot Essent Fatty Acids. 1991;44(4):247-252. Not level of evidence. [pmid: 1815240].
Velzing-Aarts F V, van der Klis F R, van der Dijs F P, Muskiet F A. Umbilical vessels of preeclamptic women have low contents of both n-3 and n-6 long-chain polyunsaturated fatty acids. Am J Clin Nutr. 1999;69(2):293-298. Not level of evidence. [pmid: 9989695].
Vik T, Bjerve K, Andersson H, Skanes J, Brubakk A M. Psychomotor development at one year of age in very low birth weight infants and omega-3 fatty acid status. Pediatr Res. 1991;29:305a. Not level of evidence.
Vizek K, Mourek J, Base J, Smidova L, Mikova M, Cechova I. [Serum fatty acids in premature neonates]. [Czech]. Sb Lek. 1993;94(1):19-24. Not level of evidence. [pmid: 7991993].
Wang J, Zhang Y. Effect of the long chain polyunsaturated fatty acids levels in mothers on fetuses. [Chinese]. Chung Hua Fu Chan Ko Tsa Chih. 1998;33(12):722-723. Not level of evidence. [pmid: 10806659].
Williams M A, Zingheim R W, King I B, Zebelman A M. Omega-3 fatty acids in maternal erythrocytes and risk of preeclampsia. Epidemiology. 1995;6(3):232-237. Not level of evidence. [pmid: 7619928].
Xiang M, Lei S, Li T, Zetterstrom R. Composition of long chain polyunsaturated fatty acids in human milk and growth of young infants in rural areas of northern China. Acta Paediatr. 1999;88(2):126-131. Not level of evidence. [pmid: 10102142].
Zhang L. The effects of essential fatty acids preparation in the treatment of intrauterine growth retardation. Am J Perinatol. 1997;14(9):535-537. Not level of evidence. [pmid: 9394162].