# Appendix G. Interventional Formula's Content

## Interventional Study Formula Content

Formula | DHA | EPA | ALA | LA | AA | GLA | DPA | DGLA | Mono | n-6/ n-3 | References
Algal + DHA (%) | 0.37 | | | | | | | | | | {240}
Algal oil (%) | 48. | | | | | | | | 18.0 | | {2959}
Aptamil + Milupan | 0.15–0.25 | | 0.60–0.65 | 11.5–12.8 | 0.30–0.40 | | | | | | {2293}{2307} {359}{2940} {467}
Borage oil (%) | 0.32 | 0.37 | 1.17 | 12.67 | 0.06 | 0.54 | 0.10 | 0.16 | | 10.8 | {1159}
Borage oil (g/100g) | 0.5 | 0.1 | 1.5 | 12.3 | | 0.9 | | | 43 | | {2938}
Cod liver oil (mg/10ml) | 1183 | 803 | 75 | 160 | 27.5 | | 112 | | | | {111}
Corn oil (g/100g) | | | 0.8 | 31.4 | | | | | 17.1 | 39:1 | {1354}
Corn oil (mg/10ml) | 8.3 | | 92 | 4747 | | | | | | | {111}
Egg phospholipids (%) | .34 | | 1.0 | 16.6 | .34 | | | | 31.0 | | {213}
Egg phospholipids (%) | 0.34 | | 1.02 | 16.56 | 0.34 | 0.13 | | | 31.03 | | {229}
Egg yolk (g/100g) | 0.12 | | 1.9 | 21.7 | 0.43 | | | | 42.1 | 11.1 | {380}
Egg yolk Lecithin (g/100g) | 0.1 | | 2.0 | 21.8 | 0.43 | | | | | | {415}
Egg-derived triglyceride/fish oil (%) | 0.26 | | | | 0.42 | | | | | | {1538}
Egg-DTG (g/100g) | 0.14 | | | 22.4 | 0.45 | 2.5 | | | 41.0 | | {125}
Egg-TG/Fish* (g/100g) | 0.24 | | 2.5 | 17.5 | 0.41 | | | | 9.8 | | {126}
Egg-TG/Fish** (g/100g) | 0.15 | | 2.4 | 20.3 | 0.41 | | | | 29.8 | | {126}
Enfamil + LCPUFA(%) | 0.36 | | 1.53 | 14.9 | 0.72 | | | 0.05 | 29.2 | 8.3 | {2958}
Enfamil - 0.4% ALA | | | 0.4 | 17.6 | | | | | | 44.0 | {350}
Enfamil - 1% ALA | | | 0.95 | 17.3 | | | | | | 18.2 | {350}
Enfamil (%) | | | 1.9 | 18 | | | | | | | {374}
Enfamil (%) | | | 4.7 | 34.2 | | | | | | | {374}
Enfamil + DHA (%) | 0.34 | | 3.1 | 22.0 | | | | | | | {80}
Enfamil + DHA +ARA (%) | 0.33 | | 3.0 | 21.0 | 0.60 | | | | | | {80}
Enfamil + LCPUFA (g/L) | 0.21 | | 0.86 | 8.37 | 0.42 | | | 0.01 | 16.42 | 8.3 | {87}
Enfamil -1.7% ALA | | | 1.7 | 16.5 | | | | | | 9.7 | {350}
Enfamil -3.2% ALA | | | 3.2 | 15.6 | | | | | | 4.8 | {350}
Enfamil iron DHA+AA (%) | 0.36 | | 1.53 | 14.9 | 0.72 | | | | 29.2 | 8.3 | {2301}
Enfamil iron+ DHA (%) | 0.35 | | 1.54 | 15.1 | 0.02 | | | | 30.3 | 7.9 | {2301}
EPA (g) | | 3.0 | | | | | | | | | {481}
Fish oil | 0.31 | 0.08 | 1.07 | 17.62 | 0.03 | | | | | | {1621}
Fish oil - DD (mol/100ml) | 0.43 | 0.34 | 1.05 | 11.40 | 0.03 | 0.32 | 0.01 | 0.01 | | | {275}
Fish oil - high EPA (%) | 0.45 | 0.35 | 0.85 | 17.8 | 0.05 | | | | 33.8 | | {1650}
Fish oil - low EPA (%) | 0.45 | 0.10 | 1.10 | 17.7 | 0.05 | | | | 34.0 | | {1650}
Fish oil - PT (%) | 0.37 | 0.05 | | | | | | | | | {1760}
Fish oil - SD (mol/100ml) | 0.20 | 0.17 | 1.06 | 11.22 | 0.02 | 0.31 | 0.02 | | | | {275}
Fish oil - term (%) | 0.45 | 0.09 | | | | | | | | | {1760}
Fish oil (%) | 0.36 | 0.58 | 1.52 | 17.44 | 0.01 | 0.27 | 0.07 | | 30.75 | | {477}
Fish oil (%) | 40.4 | 7.2 | 0.8 | 1.2 | | | 4.1 | | | | {12}
Fish oil (%) | 56.0 | 27.7 | | 0.3 | 1.8 | | 7.1 | | | | {2917}
Fish oil (%) | 0.32 | 0.39 | 1.20 | 11.95 | 0.06 | | 0.07 | 0.16 | | 10.0 | {1159}
Fish oil (%) | 0.39 | | | | | | | | | | {240}
Fish oil (%) | 23.0 | 32.0 | | | | | | | | | {614}
Fish oil (%) | 23.0 | 32.0 | | | | | | | | | {66}
Fish oil (g) | 1.08 | 1.62 | | | | | | | | | {480}
Fish oil (mg/100kcal) | 17 | | | | 34 | | | | | | {1553}
Fish/Fungal (g/100g) | 0.13 | <0.04 | | 21.0 | 0.46 | 2.4 | | | 40.0 | | {125}
Fish/fungal ** (g/100g) | 0.16 | | 2.4 | 19.5 | 0.43 | | | | 27.9 | | {126}
Fish/fungal oil (%) | 0.26 | | | | 0.42 | | | | | | {1538}
Fish/fungal* (g/100g) | 0.27 | 0.08 | 2.6 | 16.8 | 0.43 | | | | 8.4 | | {126}
Fish oil + GLA (mg) | 10 | 18 | | | | 37 | | | | | {580}
Formula + LCPUFA (%) | 0.32 | 0.01 | 1.4 | 15.9 | 0.30 | | | | | 9.47 | {270}
Formula A (%) | | | 1.3 | 14.1 | | | | | | | {233}
Formula B (%) | 0.6 | 0.1 | 1.2 | 17.7 | 0.1 | 0.4 | | | | | {233}
Formula LCPUFA-F (%) | 0.57 | 0.13 | 1.2 | 17.7 | 0.1 | 0.4 | | | 26.9 | | {940}
Formula+LCPUFA (%) | 0.2 | | 2.3 | 11.6 | 0.4 | 0.2 | | | | | {2231}
High-DHA eggs (g/100g) | 5.45 | | | | | | | | | | {31}
LA:ALA 10:1 (%) | | | 1.7 | 16.9 | | | | | 35.8 | | {220}
LA:ALA 5:1 (%) | | | 3.3 | 16.6 | | | | | 36.7 | | {220}
Margarine + ALA | | | 14.18 | 45.36 | | | | | 17.41 | | {2907}
Marine oil - PT (g/100g) | 0.2 | 0.3 | 3.1 | 18.7 | | | | | | 6.0 | {581}
Marine oil - term (g/100g) | 0.2 | 0.3 | 4.9 | 32.6 | | | | | | 6.6 | {581}
Marine oil (%) | 0.20 | 0.06 | 2.4 | 21.2 | | | | | | | {434}
MaxEPA (mg) | 120 | 180 | | | | | | | | | {547}
Microalgae & fungi | 0.34 | | | | 0.70 | | | | | | {40}
Pre-Aptamil Milupan LCPUFA-F (%) | 0.3 | 0.03 | 1.0 | 13.8 | 0.5 | 0.2 | | | 34.4 | | {460}
Preemie SMA + LCPUFA (%) | 0.35 | | 1.5 | 12.1 | 0.50 | | | | | | {2143}
Preemie SMA+LCPUFA (%) | 0.35 | | 1.5 | 12.1 | 0.49 | | | | | | {2191}
Preglandin (mg) | | | | 375. | | 45. | | | | | {547}
Prematil + LCPUFA (%) | 0.3 | 0.03 | 0.8 | 13.8 | 0.5 | 0.2 | | 0.1 | | | {455}
Prematil Milupan (g/100g) | 0.17 | 0.04 | 0.6 | 12.0 | 0.31 | 0.4 | | | | | {2129}
Prematil Milupan + LCPUFA (%) | 0.30 | 0.05 | 0.73 | 10.85 | 0.44 | 0.30 | 0.07 | 0.12 | | | {2262}
Single cell oils (mg/100kcal) | 17 | | | | 34 | | | | | | {1553}
Soy oil (g/100g) | | | 4.8 | 34.2 | | | | | 17.3 | 7:1 | {1354}
Soy/Marine oil (g/100g) | 0.35 | 0.65 | 1.4 | 20.4 | 0.1 | | | | 10.7 | 8.5 | {603}
Tuna fish oil (g/100g) | 0.5 | 0.1 | 1.5 | 12.3 | | 0.9 | | | 43 | | {2938}
Tuna oil (%) | .35 | .10 | 1.2 | 16.8 | | | | | 31.9 | | {213}
Tuna oil (%) | 0.35 | 0.10 | 1.22 | 16.76 | | 0.12 | | | 31.85 | | {229}
Tuna oil (g/100g) | 0.23 | 0.07 | 1.9 | 20.7 | | | | | 40.2 | 9.4 | {380}

* = in-hospital;

** = post discharge;

PT = preterm;

SD = single dose;

DD = double dose;

DHA = docosahexaenoic acid;

EPA = eicosapentanoic acid;

ALA = α-linolenic acid;

LA = linoleic acid;

AA = arachidonic acid;

GLA = gammalinolenic acid;

DGLA = dihomo-gama-linolenic acid