# Appendix F. List of excluded studies (no RCTs)

### 1. Pregnancy outcomes

### 1a. Duration of gestation

1 Olsen S F, Hansen H S, Sommer S, Jensen B, Sorensen T I, Secher N J, Zachariassen P. Gestational age in relation to marine n-3 fatty acids in maternal erythrocytes: a study of women in the Faroe Islands and Denmark. Am J Obstet Gynecol. 1991;164(5 Pt 1):p.1203-1209. [pmid: 1827949].
2 Grandjean P, Bjerve K S, Weihe P, Steuerwald U. Birthweight in a fishing community: significance of essential fatty acids and marine food contaminants.[comment]. Int J Epidemiol. 2001;30(6):p.1272-1278. [pmid: 11821327].
3 Velzing-Aarts F V, van der Klis F R, van der Dijs F P, Muskiet F A. Umbilical vessels of preeclamptic women have low contents of both n-3 and n-6 long-chain polyunsaturated fatty acids. Am J Clin Nutr. 1999;69(2):p.293-298. [pmid: 9989695].
4 Araya, Araya J, Rojas, Garcia M, Fernandez, Fraile P, Mateluna, Acevedo A. [Differences in percent composition of long chain polyunsaturated fatty acids in maternal-fetal erythrocytes in term and preterm infants]. [Spanish]. Arch Latinoam Nutr. 1998;48(3):p.210-215. [pmid: 9951532].
5 Araya J, Rojas M, Fernandez P, Mateluna A. [Essential fatty acid content of maternal erythrocyte phospholipids. A study in preterm and full-term human newborns]. [Spanish]. Rev Med Chil. 1998;126(4):p.391-396. [pmid: 9699369].
6 Wang J, Zhang Y. Effect of the long chain polyunsaturated fatty acids levels in mothers on fetuses. [Chinese]. Chung-Hua Fu Chan Ko Tsa Chih [Chinese Journal of Obstetrics & Gynecology]. 1998;33(12):p.722-723.
7 Kesmodel U, Olsen S F, Salvig J D. Marine n-3 fatty acid and calcium intake in relation to pregnancy induced hypertension, intrauterine growth retardation, and preterm delivery. A case-control study. Acta Obstet Gynecol Scand. 1997;76(1):p.38-44. [pmid: 9033242].
8 Foreman-van Drongelen M M, Al M D, van Houwelingen A C, Blanco C E, Hornstra G. Comparison between the essential fatty acid status of preterm and full-term infants, measured in umbilical vessel walls. Early Hum Dev. 18-8. 1995;42(3):p.241-251. [pmid: 7493590].
9 Olsen S F, Hansen H S, Secher N J, Jensen B, Sandstrom B. Gestation length and birth weight in relation to intake of marine n-3 fatty acids. Br J Nutr. 1995;73(3):p.397-404. [pmid: 7766563].
10 Vizek K, Mourek J, Base J, Smidova L, Mikova M, Cechova I. [Serum fatty acids in premature neonates]. [Czech]. Sb Lek. 1993;94(1):p.19-24. [pmid: 7991993].
11 Olsen S F, Grandjean P, Weihe P, Videro T. Frequency of seafood intake in pregnancy as a determinant of birth weight: evidence for a dose dependent relationship. J Epidemiol Community Health. 1993;47(6):p.436-440. [pmid: 8120495].
12 Leaf A A, Leighfield M J, Costeloe K L, Crawford M A. Long chain polyunsaturated fatty acids and fetal growth. Early Hum Dev. 1992;30(3):p.183-191. [pmid: 1468382].
13 Leaf A A, Leighfield M J, Costeloe K L, Crawford M A. Factors affecting long-chain polyunsaturated fatty acid composition of plasma choline phosphoglycerides in preterm infants. J Pediatr Gastroenterol Nutr. 1992;14(3):p.300-308. [pmid: 1535657].
14 Olsen S F, Olsen J, Frische G. Does fish consumption during pregnancy increase fetal growth? A study of the size of the newborn. lacental weight and gestational age in relation to fish consumption during pregnancy. Int J Epidemiol. 1990;19(4):p.971-977. [pmid: 2084030].
15 Olsen S F, Secher N J. A possible preventive effect of low-dose fish oil on early delivery and pre-eclampsia: indications from a 50-year-old controlled trial. Br J Nutr. 1990;64(3):p.599-609. [pmid: 2265175].
16 Olsen S F, Hansen H S, Jensen B, Sorensen T I. Pregnancy duration and the ratio of long-chain n-3 fatty acids to arachidonic acid in erythrocytes from Faroese women. J Intern Med Suppl. 1989;225(731):p.185-189.
17 Olsen S F, Hansen H S, Sorensen T I, Jensen B, Secher N J, Sommer S, Knudsen L B. Intake of marine fat, rich in (n-3)-polyunsaturated fatty acids, may increase birthweight by prolonging gestation. Lancet. 16-8. 1986;2(8503):p.367-369. [pmid: 2874370].
18 Olsen S F, Secher N J. Low consumption of seafood in early pregnancy as a risk factor for preterm delivery: Prospective cohort study. Br Med J. 23-2. 2002;324(7335):p.23. [pmid: 11777800]. [pmcid: 61654].

### 1b. Gestational hypertension, pre-eclampsia and eclampsia

1 Clausen T, Slott M, Solvoll K, Drevon C A, Vollset S E, Henriksen T. High intake of energy, sucrose, and polyunsaturated fatty acids is associated with increased risk of preeclampsia. Am J Obstet Gynecol. 2001;185(2):p.451-458. [pmid: 11518908].
2 Velzing-Aarts F V, van der Klis F R, van der Dijs F P, Muskiet F A. Umbilical vessels of preeclamptic women have low contents of both n-3 and n-6 long-chain polyunsaturated fatty acids. Am J Clin Nutr. 1999;69(2):p.293-298. [pmid: 9989695].
3 Kesmodel U, Olsen S F, Salvig J D. Marine n-3 fatty acid and calcium intake in relation to pregnancy induced hypertension, intrauterine growth retardation, and preterm delivery. A case-control study. Acta Obstet Gynecol Scand. 1997;76(1):p.38-44. [pmid: 9033242].
4 Williams M A, Zingheim R W, King I B, Zebelman A M. Omega-3 fatty acids in maternal erythrocytes and risk of preeclampsia. Epidemiology. 1995;6(3):p.232-237. [pmid: 7619928].
5 Gerrard, J., Popeski, D., Ebbeling, L., Brown, P., and Hornstra, G., Dietary omega 3 fatty acids and gestational hypertension in the Inuit, Arctic Med Res, Suppl, 1991, p.763–767
6 Popeski D, Ebbeling L R, Brown P B, Hornstra G, Gerrard J M. Blood pressure during pregnancy in Canadian Inuit: community differences related to diet. CMAJ. 1-9. 1991;145(5):p.445-454. [pmid: 1878826]. [pmcid: 1335827].
7 van der Schouw Y T, Al M D, Hornstra G, Bulstra-Ramakers M T, Huisjes H J. Fatty acid composition of serum lipids of mothers and their babies after normal and hypertensive pregnancies. Prostaglandins Leukot Essent Fatty Acids. 1991;44(4):p.247-252. [pmid: 1815240].
8 Olsen S F, Secher N J. A possible preventive effect of low-dose fish oil on early delivery and pre-eclampsia: indications from a 50-year-old controlled trial. Br J Nutr. 1990;64(3):p.599-609. [pmid: 2265175].

### 1c. Small for Gestational Age

1 Grandjean P, Bjerve K S, Weihe P, Steuerwald U. Birthweight in a fishing community: significance of essential fatty acids and marine food contaminants.[comment]. Int J Epidemiol. 2001;30(6):p.1272-1278. [pmid: 11821327].
2 Velzing-Aarts F V, van der Klis F R, van der Dijs F P, Muskiet F A. Umbilical vessels of preeclamptic women have low contents of both n-3 and n-6 long-chain polyunsaturated fatty acids. Am J Clin Nutr. 1999;69(2):p.293-298. [pmid: 9989695].
3 Wang J, Zhang Y. Effect of the long chain polyunsaturated fatty acids levels in mothers on fetuses. [Chinese]. Chung-Hua Fu Chan Ko Tsa Chih [Chinese Journal of Obstetrics & Gynecology]. 1998;33(12):p.722-723.
4 Zhang L. The effects of essential fatty acids preparation in the treatment of intrauterine growth retardation. Am J Perinatol. 1997;14(9):p.535-537. [pmid: 9394162].
5 Badart-Smook A, van Houwelingen A C, Al M D, Kester A D, Hornstra G. Fetal growth is associated positively with maternal intake of riboflavin and negatively with maternal intake of linoleic acid. J Am Diet Assoc. 1997;97(8):p.867-870. [pmid: 9259708].
6 Kesmodel U, Olsen S F, Salvig J D. Marine n-3 fatty acid and calcium intake in relation to pregnancy induced hypertension, intrauterine growth retardation, and preterm delivery. A case-control study. Acta Obstet Gynecol Scand. 1997;76(1):p.38-44. [pmid: 9033242].
7 Mourek J, Dohnalova A. Relationship between birth weight of newborns and unsaturated fatty acid(n-3) proportions in their blood serum. Physiol Res. 1996;45(2):p.165-168. [pmid: 9496767].
8 Foreman-van Drongelen M M, Al M D, van Houwelingen A C, Blanco C E, Hornstra G. Comparison between the essential fatty acid status of preterm and full-term infants, measured in umbilical vessel walls. Early Hum Dev. 18-8. 1995;42(3):p.241-251. [pmid: 7493590].
9 Olsen S F, Hansen H S, Secher N J, Jensen B, Sandstrom B. Gestation length and birth weight in relation to intake of marine n-3 fatty acids. Br J Nutr. 1995;73(3):p.397-404. [pmid: 7766563].
10 Foreman-van Drongelen M M, van Houwelingen A C, Kester A D, Hasaart T H, Blanco C E, Hornstra G. Long-chain polyunsaturated fatty acids in preterm infants: status at birth and its influence on postnatal levels. J Pediatr. 1995;126(4):p.611-618. [pmid: 7699544].
11 Felton C V, Chang T C, Crook D, Marsh M, Robson S C, Spencer J A. Umbilical vessel wall fatty acids after normal and retarded fetal growth. Arch Dis Child Fetal Neonatal Ed. 1994;70(1):p.F36-F39.
12 Olsen S F, Grandjean P, Weihe P, Videro T. Frequency of seafood intake in pregnancy as a determinant of birth weight: evidence for a dose dependent relationship. J Epidemiol Community Health. 1993;47(6):p.436-440. [pmid: 8120495].
13 Leaf A A, Leighfield M J, Costeloe K L, Crawford M A. Long chain polyunsaturated fatty acids and fetal growth. Early Hum Dev. 1992;30(3):p.183-191. [pmid: 1468382].
14 Leaf A A, Leighfield M J, Costeloe K L, Crawford M A. Factors affecting long-chain polyunsaturated fatty acid composition of plasma choline phosphoglycerides in preterm infants. J Pediatr Gastroenterol Nutr. 1992;14(3):p.300-308. [pmid: 1535657].
15 Koletzko B, Braun M. Arachidonic acid and early human growth: is there a relation?. Ann Nutr Metab. 1991;35(3):p.128-131. [pmid: 1952812].
16 Harper V, MacInnes R, Campbell D, Hall M. Increased birth weight in northerly islands: is fish consumption a red herring?. BMJ. 20-7. 1991;303(6795):p.166. [pmid: 1878642]. [pmcid: 1670406].
17 Olsen S F, Olsen J, Frische G. Does fish consumption during pregnancy increase fetal growth? A study of the size of the newborn, placental weight and gestational age in relation to fish consumption during pregnancy. Int J Epidemiol. 1990;19(4):p.971-977. [pmid: 2084030].
18 Crawford M A, Costeloe K, Doyle W, Leighfield M J, Lennon E A, Meadows N. Potential diagnostic value of the umbilical artery as a definition of neural fatty acid status of the fetus during its growth: the umbilical artery as a diagnostic tool. Biochem Soc Trans. 1990;18(5):p.761-766. [pmid: 2083670].
19 Crawford M A, Doyle W, Drury P, Lennon A, Costeloe K, Leighfield M. n-6 and n-3 fatty acids during early human development. J Intern Med Suppl. 1989;225(731):p.159-169.
20 Olsen S F, Secher N J. A possible preventive effect of low-dose fish oil on early delivery and pre-eclampsia: indications from a 50-year-old controlled trial. Br J Nutr. 1990;64(3):p.599-609. [pmid: 2265175].
21 Hansen I B, Friis-Hansen B, Clausen J. The fatty acid composition of umbilical cord serum, infant serum and maternal serum and its relation to the diet. Z Ernahrungswiss. 1969;9(4):p.352-363. [pmid: 5395483].
22 Olsen S F, Secher N J. Low consumption of seafood in early pregnancy as a risk factor for preterm delivery: Prospective cohort study. Br Med J. 23-2. 2002;324(7335):p.23. [pmid: 11777800]. [pmcid: 61654].
23 Matorras R, De Larrucea A L, Sanjurjo P, Ruiz J I, Echevarria Y, Nieto A, Perteagudo L, Aldamiz-Echvarria J L. Increased tissue concentrations of arachidonic acid in umbilical artery and placenta in fetal growth retardation. Acta Obstet Gynecol Scand. 2001;80(9).

### 2. Growth Pattern Outcomes

1 Foreman-van Drongelen M M, van Houwelingen A C, Kester A D, Hasaart T H, Blanco C E, Hornstra G. Long-chain polyunsaturated fatty acids in preterm infants: status at birth and its influence on postnatal levels. J Pediatr. 1995;126(4):p.611-618. [pmid: 7699544].
2 Guldan G S, Zhang M Y, Zhang Y P, Hong J R, Zhang H X, Fu S Y, Fu N S. Weaning practices and growth in rural Sichuan infants: a positive deviance study. J Trop Pediatr. 1993;39(3):p.168-175. [pmid: 8326537].
3 Olsen S F, Olsen J, Frische G. Does fish consumption during pregnancy increase fetal growth? A study of the size of the newborn, placental weight and gestational age in relation to fish consumption during pregnancy. Int J Epidemiol. 1990;19(4):p.971-977. [pmid: 2084030].
4 Fomon S J, Thomas L N, Filer L J Jr, Ziegler E E, Leonard M T. Food consumption and growth of normal infants fed milk-based formulas. Acta Paediatr Scand Suppl. 1971;223:p.1-36. [pmid: 5291969].
5 Decsi, T., Kelemen, B., Minda, H., Burus, I., and Kohn, G., Effect of type of early infant feeding on fatty acid composition of plasma lipid classes in full-term infants during the second 6 months of life, J Pediatr Gastroenterol Nutr, 30(5), 2000
6 Clandinin M T, Aerde J E, van Parrott A, Field C J, Euler A R, Lien E, Van Aerde J E. Assessment of feeding different amounts of arachidonic and docosahexaenoic acids in preterm infant formulas on the fatty acid content of lipoprotein lipids. Acta Paediatr. 1999;88(8):p.890-896. [pmid: 10503691].
7 Clandinin M T, Aerde J E, van Parrott A, Field C J, Euler A R, Lien E L, Van Aerde J E. Assessment of the efficacious dose of arachidonic and docosahexaenoic acids in preterm infant formulas: fatty acid composition of erythrocyte membrane lipids. Pediatr Res. 1997;42(6):p.819-825. [pmid: 9396564].
8 Tichelaar H Y, Steyn N P, Nel J H, Smuts C M, Jaarsveld P J, van Prinsloo J F, Rooyen J, van Lombard C J, Dhansay M A, Benade A J S, van Jaarsveld P J, van Rooyen J. Effect of catfish supplementation on the fatty acid status and growth of undernourished rural preschool children under 6 years of age: an intervention trial in Lebowa, South Africa. Asia Pac J Clin Nutr. 1999;8(2):p.96-105.
9 Courage M L, McCloy U R, Herzberg G R, Andrews W L, Simmons B S, McDonald A C, Mercer C N, Friel J K. Visual acuity development and fatty acid composition of erythrocytes in full-term infants fed breast milk, commercial formula, or evaporated milk. J Dev Behav Pediatr. 1998;19(1):p.9-17. [pmid: 9524300].

### 3. Neurological outcomes

1 Vik T, Bjerve K, Andersson H. Psychomotor development at one year of age in very low birth weight infants and omega-3 fatty acid status. Pediatr Res. 1991;29:p.305a.
2 Bjerve K S, Brubakk A M, Fougner K J, Johnsen H, Midthjell K, Vik T. Omega-3 fatty acids: essential fatty acids with important biological effects, and serum phospholipid fatty acids as markers of dietary omega 3-fatty acid intake. Am J Clin Nutr. 1993;57(5 Suppl):p.801S-805S. [pmid: 8475898].
3 Bjerve K S, Thoresen L, Bonaa K, Vik T, Johnsen H, Brubakk A M. Clinical studies with alpha-linolenic acid and long-chain n-3 fatty acids. Nutrition. 1992;8(2):p.130-132. [pmid: 1350473].
4 Agostoni C, Marangoni F, Giovannini M, Galli C, Riva E. Prolonged breast-feeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol. 2001;501:p.137-141. [pmid: 11787675].
5 Agostoni C, Verduci E, Massetto N, Radaelli G, Riva E, Giovannini M. Plasma long-chain polyunsaturated fatty acids and neurodevelopment through the first 12 months of life in phenylketonuria. Dev Med Child Neurol. 2003;45(4):p.257-261. [pmid: 12647927].
6 Cheruku S R, Montgomery-Downs H E, Farkas S L, Thoman E B, Lammi-Keefe C J. Higher maternal plasma docosahexaenoic acid during pregnancy is associated with more mature neonatal sleep-state patterning. Am J Clin Nutr. 2002;76(3):p.608-613. [pmid: 12198007].

### 4. Cognitive Outcomes

1 Bakker E C, Ghys A J, Kester A D, Vles J S, Dubas J S, Blanco C E, Hornstra G. Long-chain polyunsaturated fatty acids at birth and cognitive function at 7 y of age. Eur J Clin Nutr. 2003;57(1):p.89-95. [pmid: 12548302].
2 Santiago, Burruchaga M, Ruiz-Sanz J I, Pijoan-Zubizarreta J I, Benito, Fernandez J, Sanjurjo, Crespo P. Intellectual development in the second year of life in healthy breast-fed children vs. formula-fed children. An Esp Pediatr. 2000;52(6):p.530-536. [pmid: 11003961].

### 5. Visual outcomes

1 Werkman S H, Carlson S E. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until nine months. Lipids. 1996;31(1):p.91-97. [pmid: 8649241].
2 Carlson S E, Werkman S H. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until two months. Lipids. 1996;31(1):p.85-90. [pmid: 8649239].
3 Carlson S E, Werkman S H, Rhodes P G, Tolley E A. Visual-acuity development in healthy preterm infants: effect of marine-oil supplementation. Am J Clin Nutr. 1993;58(1):p.35-42. [pmid: 8317386].
4 Birch E E, Birch D G, Hoffman D R, Uauy R. Dietary essential fatty acid supply and visual acuity development. Invest Ophthalmol Vis Sci. 1992;33(11):p.3242-3253. [pmid: 1399429].
5 Agostoni C, Verduci E, Massetto N, Radaelli G, Riva E, Giovannini M. Plasma long-chain polyunsaturated fatty acids and neurodevelopment through the first 12 months of life in phenylketonuria. Dev Med Child Neurol. 2003;45(4):p.257-261. [pmid: 12647927].
6 Innis S M, Nelson C M, Lwanga D, Rioux F M, Waslen P. Feeding formula without arachidonic acid and docosahexaenoic acid has no effect on preferential looking acuity or recognition memory in healthy full-term infants at 9 mo of age. Am J Clin Nutr. 1996;64(1):p.40-46. [pmid: 8669412].
7 Courage M L, McCloy U R, Herzberg G R, Andrews W L, Simmons B S, McDonald A C, Mercer C N, Friel J K. Visual acuity development and fatty acid composition of erythrocytes in full-term infants fed breast milk, commercial formula, or evaporated milk. J Dev Behav Pediatr. 1998;19(1):p.9-17. [pmid: 9524300].
8 Carlson S E, Peeples J M, Werkman S H. Docosahexaenoate (DHA) and eicosapentaenoate (EPA) status of preterm infants: relationship to the Fagantest of Infant intelligence and the Bayley scale of mental development. FASEB J. 1990;4:p.A1156.
9 Carlson S E, Cooke R J, Peeples J M. Docosahexaenoate (DHA) and eicosapentaenoate (EPA) status of preterm infants: relationship to visual acuity in n-3 supplemented and unsupplemented infants. Pediatr Res. 1989;25:p.285a. [pmid: 2704597].