# Appendix E. Evidence Tables

Evidence Table 1. Randomized controlled trial evidence for omega-3 fatty acids in child and maternal health

Author, Year, Location | Study Design | Population Characteristics | Intervention/ comparators | Timing & Dose of intervention (if appropriate) | Clinical Outcomes Results | Funding Source
Agostoni, 1995, Italy | • RCT Parallel Double-blind | Inclusion criteria: | LCPUFA formula (palm, coconut, soybean, sunflower, evening primrose oils, egg-lipids) (n=29) vs. crtl formula (n=31) vs. HM (RS) (n=30) | LCPUFA formula (0.44 wt% AA+ 0.05 wt% EPA + 0.30 wt% DHA) within d 3 of life to 4 mo of age | • Brunet-Lézine's psychomotor developmental test: S better score in DHA+EPA in Brunet-Lezine test (DQ) at 4; NS at 24 mo | NR
{2940,359,467} | • Jadad total: 4 [Grade: A] | Healthy term infants of both sexes born between Sept. 1992-Aug. 1993; GA end of 37 wk-42 wk, AGA; Apgar >7 @ 5min & absence of disease | | | • PUFA in RBC PC & PE (n=20): RBC DHA at 4 mo S (+) correlation with DQ at 4 mo; NS at 24 mo
| • Schulz: Unclear | Exclusion criteria: NR
| | Enrolled/Completed: n=90/86
| | Mean Age:
| | • Child: F1 39.0 (1.3) wks GA; F2: 39.4 (1.4); BF 39.0 (1.1)
Auestad, 1997, US | • RCT Parallel | Inclusion criteria: | DHA+AA formula (from egg yolk phospholipids) (n=68) vs. DHA+EPA formula (from high-DHA, low-EPA tuna oil) (n=65) vs. Crtl formula (n=65) vs. HM (RS) (n=76) | Dose NR; all formulas at least 4 mo | • Growth patterns: S↓wt in F4 than in F1 at 4 mo; NS in L, HC, TST, & SST at 4 & 8 mo | Ross Products Division, Abbott Laboratories; US Maternal & Child Health Bureau
{380,298,6} | • Jadad total: 3 [Grade: B] | Healthy term infants ≥ 37 wk AGA. | | | • Bayley's PDI & MDI: S better in crtl gp vs. DHA+AA in PDI at 12 mo; NS among 3 gps
| • Schulz: Unclear | Exclusion criteria: | | | • Sweep VEP: NS acuity thresholds at 2, 4, 6, 9 or 12 mo
| | Apgar <7 @ 5 min, physical or metabolic defects, receipt of lipid or blood transfusion, infants born to mothers with hx diabetes, hyperlipidemia, or perinatal infection | | | • Acuity card procedure: NS at 2,4,6,9, 12 or 39 mo of age
| | Enrolled/Completed: n=274/173
| | Mean Age:
| | • Child: (d) HM: 3.6 ± 2.3; F crtl: 3.2 ± 2.5; F DHA+AA: 2.8 ± 1.9; F DHA n= 2.6 ± 1.9
Auestad, 2001a US | • RCT Parallel | Inclusion criteria: | DHA+AA formula (derived from egg-TG) (n=80) vs. DHA+EPA+AA formula (LCPUFAs derived from fish and fungal oils) (n=82) vs. Crtl formula (n=77) vs. HM (n=165) | LCPUFA formulas (0.13–0.14 wt% DHA & 0.45 wt% AA & <0.04 wt% EPA) for 12 mo | • Teller Acuity Card Procedure: NS at 2, 4, 6 & 12 mo of age | Ross Products Division
{125} | • Double-blind | Healthy term infants fed formula (GA 37–42 wk) | | | • Growth patterns: NS in wt, L, HC at 1, 2, 4, 6, 9, & 12 mo; S↑ wt gain in males in DHA+AA (egg) at 4 mo
| • Jadad total: 5 [Grade: A] | Exclusion criteria: | | | • Fagan Test: NS at 6, 9 mo
| • Schulz: Adequate | Evidence of S cardiac, respiratory, ophthalmologic, gastrointestinal, hematologic, or metabolic disease; milk-protein allergy; or maternal medical hx with proven adverse effects on the fetus, tuberculosis, human immunodeficiency virus infection, prenatal infections or substance abuse | | | • Bayley Scale: NS in PDI & MDI at 6 & 12 mo
| | Enrolled/Completed:n=239/165 | | | • MacArthur Communicative Development Inventories: NS at 9 mo; S ↑ vocabulary expressions score in DHA+AA (fish/fungal) vs. DHA+AA (egg-TG) at 14 mo
| | Mean Age:
| | • Maternal: NR
| | • Child: FF crtl = 39.4 ± 1.2 wk; FF egg-DTG = 39.0 ±1.3 wk, FF fish/fungal = 39.3 ± 1.2 wk
Auestad, 2001b US | • RCT Parallel Double-blind | Inclusion criteria: | HM/DHA+AA formula (derived from egg-TG) (n=83) vs. HM/Crtl formula (n=82) | LCPUFA formulas (0.13–0.14 wt% DHA & 0.45 wt% AA) from 3 mo of age to 12 mo | • Teller Acuity Card Procedure: NS at 2, 4, 6 & 12 mo of age | Ross Products Division
{125} | • Jadad total: 5 [Grade: A] | Healthy term infants breast-fed (gestational age 37–42 wk) | | | • Growth patterns: NS in wt, L, HC at 1, 2, 4, 6, 9, & 12 mo or in wt, L, HC gain
| • Schulz: Adequate | Exclusion criteria: | | | • Fagan Test: NS at 6, 9 mo
| | Evidence of significant cardiac, respiratory, ophthalmologic, gastrointestinal, hematologic, or metabolic disease; milk-protein allergy; or maternal medical hx with proven adverse effects on the fetus, tuberculosis, human immunodeficiency virus infection, prenatal infections or substance abuse | | | • Bayley Scale: NS in PDI & MDI at 6 & 12 mo
| | Enrolled/Completed: NR | | | • MacArthur Communicative Development Inventories: NS at 9 mo; S ↑ vocabulary expressions score in DHA+AA (fish/fungal) vs. DHA+AA (egg-TG) at 14 mo
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Birch, 1992 US | • RCT Parallel | Inclusion criteria: | Soy/marine oil (DHA+EPA+AA) formula (n=26) vs. soy oil formula (n=22) vs. corn oil formula (low n-3) (n=18) vs. HM (RS) (n=10) | LCPUFA formula (1.4 g AA, 0.65 g EPA, 0.35 g DHA in 100 ml) for 6 mo | • VEP: S↓ in VEP for all grps at 57 wks; S ↓ VEP in DHA+EPA vs. grps 2–3 at 36–57 wks | National Eye Institute, National Institute of Child Health & Development, United Cerebral Palsy Research Foundation, Pediatric Subunit US Public Health Service
{603,672,598,235,534,561} | • Jadad: total: 2 [Grade: C] | VLBW infants with birth weight of 1000–1500 g appropriate for GA, able to receive enteral feedings (70–120 kcal/g) & free of major neonatal morbidity by d 10 | | | • Full-field ERG: NS b-Rod ERG at 36–57 wks
| • Schulz: Unclear | Exclusion criteria: | | | • FPL acuity: DHA+EPA gp had a better FPL acuity (of borderline statistical significance) vs. corn oil at 57 wks
| | S respirator tx > 7 d, congenital infection, gross congenital malformation, Grade III or IV intracranial hemorrhage, & > Grade 2 retinopathy of prematurity | | | • Growth parameters: NS in wt, L, HC, TST, SST at 3, 9, 17, 26 wks
| | Enrolled/Completed: n=81/52 | | | • BMK: S correlation (-) between RBC AA at 57 wks & length z score at 57 wks PCA; S correlation between RBC-DHA/DPA & VEP; RBC-DHA/DPA & FPL at 57 wks
| | Mean Age:
| | • Materanl: NR
| | • Child: Intrauterine = 35.0 wk (0); VLBW gp = 30.4 wk (1.5)
Birch, 1998, US | • RCT Parallel Double-blind | Inclusion criteria: | DHA+AA formula (derived from SCO) (n=27) vs. DHA formula (derived from SCO) (n=26) vs. Crtl formula (n=26) vs. HM (n=29) | DHA+AA formula (0.36 wt% DHA, 0.72wt% AA, 14.9wt% LA, 1.53 wt% ALA); DHA formula (0.35 wt% DHA, 0.02 wt% AA, 15.1 wt% LA, 1.54 wt% ALA); Crtl formula (14.6 wt% LA, 1.49 wt% ALA) for 17 wk | • Sweep VEP: S poorer sweep VEP acuity in crtl than DHA or DHA+AA at 6 wks; DHA or DHA+AA at 17 wks; DHA or DHA+AA at 52 wks | NIH
{2301,198,164} | • Jadad total: 5 [Grade: A] | Term infants (37–40 wk) singleton, appropriate weight for GA | | | • ERG: S better ERG & DHA or DHA+AA at 6 wks
| • Schulz: Adequate | Exlusion criteria: | | | • FPL acuity: NS diet on FPL acuity
| | Family hx of mild protein allergy, genetic or familial eye disease, vegetarian or vegan maternal dietary patterns, maternal metabolic disease, anemia, or infection, presence of congenital malformation or infection, jaundice, perinatal asphyxiameconium aspiraton, & any perinatal event leading to NICU admission | | | • Growth pattern: NS in wt, L, HC, TST, SST at 17 wks
| | Enrolled/Completed: n=108/80 | | | • Neurological development: NS in PDI at 18 mo; NS in BRS at 18 mo
| | Mean Age: | | | • Cognitive: MDI S better in n-3 formulas vs. crtl at 18 mo
| | • Maternal: 29.1 (4.8) y | | | • BMK: NS correlation of PDI & BRS at 18 mo and plasma & RBC LA, ALA, AA, EPA, or DHA at 4 mo & 12 mo; MDI score at 18 mo correlated (+) with plasma & RBC DHA at 4 mo; RBC-LA & ALA correlated (-) with MDI at 18 mo
| | • Child: NR
Birch, 2002, US | • RCT Parallel | Inclusion criteria: | DHA+AA formula (derived from SCO) (n=32) vs. Crtl formula (n=33) | DHA+AA formula (0.36 wt% DHA, 0.72wt% AA, 14.9wt% LA, 1.53 wt% ALA); Crtl formula (14.6 wt% LA, 1.49 wt% ALA) from 7 to 52 wk | • Cortical VEP: NS DHA+AA on sweep VEP at 6 wks; S DHA+AA & better sweep VEP 17, 26 & 52 wks | NIH
{87} | • Jadad total: 5 [Grade: A] | Healthy term infants 6 wks age born at 37–40 wk PMA, singleton births, BW appropriate for GA. | | | • FPL: S DHA+AA & better FPL at 17 wks
| • Schulz: Adequate | Exclusion criteria: | | | • Growth patterns: NS in wt, L, HC, TST & SST at 0,6,17,26 & 52 wks
| | Family hx of milk protein allergy; genetic or familial eye disease; vegetarian or vegan maternal dietary patterns; maternal metabolic disease, anemia or infection; presence of a congenital malformation or infection; jaundice; perinatal asphyxia; meconiumaspiration; & any perinatal event that resulted in NICU admission | | | • BMK: S better sweep VEP & plasma AA at 17, 52 wks & plasma DHA at 17, 52 wks; S better sweep VEP & RBC AA at 52 wks & RBC DHA at 17 & 52 wks; NS sweep VEP & plasma or RBC LA or ALA at 17 or 52 wks; S better FPL & plasma DHA at 17 wks or RBC LA at 17 wks; NS FPL & plasma or RBC ALA, AA, plasma LA, or RBC DHA
| | Enrolled/Completed: n=65/58
| | Mean Age
| | • Maternal: NR
| | • Child: 5.1± 1.2 wks
Bougle, 1999, France | • RCT Parallel Double-blind | Inclusion criteria: | LCPUFA-enriched formula (DHA, EPA, ALA) (n=14) vs. Crtl formula | Dose: NR during 30 d (from 1^st^ d of enteral feeding) | • Growth: NS in wt, L, HC,ΔL, & ΔHC at 1 mo | NR
{233} | • Jadad total: 3 [Grade: B] | Premature, healthy, appropriate for GA infants (<34 wk postmenstrual age); free of respiratory, metabilic or neurological disease, of malformation, & of infection; fed by digestive route within the first 7 d of life, no hx of intrauterine asphyxia | (n=11)/ HM: DHA 0.5%; EPA 0.5%; ALA 0.4% (n=15) | | • Electrophysiologic studies of peripheral nerves: NS LAEP between d 0 & 30d; S↑Δmotor NCT (m/s) in DHA/EPA/AA supplemented formula & HM from d0–30; NSΔsensory (m/s) test
| • Schulz: Unclear | Exclusion criteria: | | | • VEP: NS in VEP (N1 wave latency) at 30 d
| | Stop or change of study diet for > 2 d; any neurological event; haemorrhage of > 2 in cerebral ultrasound
| | Enrolled/Completed: 40/33
| | Mean Age:
| | • Maternal: NR
| | • Child: BF GA = 33.1 (1.5) wk; FF gp A GA = 32.2 (1.1) wk; FF gp B GA = 33.9 (1.0) wk
Bulstra-Ramakers, 1994, Netherlands | • RCT | Inclusion criteria: | EPA + DHA capsules (n=32) vs. placebo (coconut oil) (n=31) | 4 capsules, 025 mg EPA +DHA, 3 x d (3g/d); from 12–14 wks PMA unitl delivery | • Incidence of IUGR: NS in IUGR recurrence rate (grp 1 vs. grp 2) | NR
{481} | • Parallel Double-blind | BW < the 10^th^ PC corrected for gestational age, parity & sex in association with GHT; BW < the 10^th^ PC in association with chronic renal disease; BW < the 10^th^ PC & placental abnormalities suggestive of impaired uterplacental circulation | | | • Incidence GHT: NS rate of GHT (grp 1 vs. grp 2)
| • Jadad total: 5 [Grade: A]; | Exclusion criteria: | | | • Duration of gestation: NS in % premature deliveries
| • Schulz: Adequate | Women with diabetes, systemic lupus erythematosus or other connective tissue disease; women on low dose aspirin for tx with obstetric hx
| | Enrolled/Completed: n=68/63
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Carlson, 1987, US | • RCT parallel | Inclusion criteria: | MaxEPA preterm formula (fish oil) (n=30) vs. preterm formula (n=31) | MaxEPA 750 mg/kg/d 1/d by orogastric tube during 4 wks | • Weight gain: NS inΔwt at 4 wks | Ross Laboratories
{736} | • Double-blind | Healthy LBW infants < 1,500g
| • Jadad total: 2 | Exclusion criteria:
| • [Grade: C]; | Free of major congenital malformations & had no major disease process such as bronchopulmonary dysplasia
| • Schulz: Unclear | Enrolled/Completed: n=61/39
| | Mean Age:
| | • Maternal: NR
| | • Child: crtl = 28 ± 14 d, fish oil = 26 ± 10 d; age for subgroup of n=19 (completing 6 wk f/u) crtl = 29 ± 18 d, fish oil = 27 ± 11 d
Carlson, 1992, US | • RCT Parallel | Inclusion criteria: | Supplemented formula (marine oil) (n=31) vs. crtl formula (n=34) | Preterm formula (0.3 g EPA, 0.2 g DHA) until discharge (1,800g), then term formula until 79 wks | • Growth patterns: S↓wt, L, HC in marine oil at 40, 48, 57, 68, 79, 93 wks PCA | National Eye Institute
{581,555,423,634,573,2950} | • Jadad total: 4 [Grade: A] | VLBW premature infants, tolerating enteral intakes > 462 kJ.kg body wt -1 for 5–7 d if at that time they did not require 1) mechanical ventilation, 2) have intraventricular hemorrhage > grade 2, 3) have ROP > stage 2, 4) require surgical intervention for necrotizing enterocolitis, 5) have severe intrauterine growth retardation defined as BW < 5^th^ PC for GA, or 6) have a hx of maternal substance abuse | | | • Teller Acuity Card: S ↑ resolution acuity in DHA + EPA vs. crtl at 2 & 4 mo | Ross Laboratories
| • Schulz: Adequate | Exclusion criteria: | | | • Fagan Test of Infant Intelligence: DHA-supplemented infants had a S ↓novelty preference vs. crtl gp
| | Risk factors for poor growth other than prematuritly, severely growth retarded in utero (weight < the 5^th^ PC for their GA), long tx of mechanical ventilation or GI surgery; risk factors for cognitive & visual development: intraventricular/ periventricular hemorrhage > grade 2, ROP > stage 2, hx of maternal cocaine use | | | • BMK: wt & L z-scores correlated + with plasma & RBC AA at 2,4,5,6,9, 12 mo; HC correlated (+) plasma & RBC AA at 2, 4 mo; S correlation (+) RBC DHA at 2 mo with visual acuity at 2 & 4 mo
| | Enrolled/Completed: n=79/65
| | Mean Age:
| | • Maternal: NR
| | • Child: crtl = 25 (10) d; marine FF = 22 (8) d
Carlson, 1996, US | • RCT Parallel Double-blind | Inclusion criteria: | DHA+AA formula (LCPUFAs derived from egg-TG) (n=28) vs. Crtl formula (n=31) vs. HM (n=35) | LCPUFA formula (0.1 wt% DHA, 0.43 wt% AA) for at least 4 mo | • Binocular visual acuity: S better visual acuity with DHA+AA at 2 mo of age | National Institute of Child Health & Human Development
{415} | • Jadad total: 3 [Grade: B] | Full term healthy infants (37–43 wk PMA)
| • Schulz: unclear | Exclusion criteria:
| | IUGR; medical problems that may influence long-term growth & development
| | Enrolled/Completed: n=94/58
| | Mean Age:
| | • Maternal: NR
| | • Child: BF GA = 39.5 ± 1.3 wk; Crtl FF GA = 40.3 ± 0.9 wk; Experimental FF GA = 39.8 ± 1.2 wk
Carlson, 1996 US | • RCT Parallel Double-blind | Inclusion criteria: | LCPUFA formula (marine oil) (n=18) vs. crtl formula (n=18) | Similac Special Care 0.2%DHA, 0.06%EPA, vitamin E from 3–5 d age to 2 mo CA | • Teller Acuity Card: S↑ higher acuity in DHA+EPA vs. crtl at 2 mo; NS at 4–12 mo | National Eye Institute
{434,424} | • Jadad total: 3 [Grade: B] | Healthy preterm infants who acheived full enteral feeding of 418 kJ (200 kcal). kg-1 by 6 wk of age & tolerated enteral feeding thereafter were allowed to remain in the study | | | • Growth patterns: S↓wt, L, HC in LCPUFA at 6 & 9 mo | National Institute of Child Health & Human Development
| • Schulz: Unclear | Exclusion criteria: | | | • BMK: S (-) correlation between wt-for-L & RBC PE DHA at 5 mo; S (+) correlation between L & RBC PC AA at 5 mo | Ross Products Division
| | Intraventricular or perventricular hemorrhage > grade 2, hx of maternal cocaine or alcohol abuse, congenital anomalies affecting long-term growth & development, or intrauterine growth retardation (wt < the 5^th^ PC for GA) | | | | Abbott Laboratories
| | Enrolled/Completed: n=94/59
| | Mean Age:
| | • Maternal: NR
| | • Child: Ctrl no BPD = 28.6 (1.3) wk, BPD =27.5 (1.6) wk; FF (marine) no BPD = 28.5 (1.2) wk, BPD = 27.0 (1.1) wk
Clandinin, 2002, Canada | • RCT Parallel Double Blind | Inclusion criteria: | DAS (DHA+AA from SCO) (n=72) vs. DAF (DHA from fish oils+AA from SCO) (n=90) vs. | Preterm, discharge & term formulas until 57 wks PMA, then beikost until 92 wks PMA | • Bayley's MDI, PDI: MDI: DAS & DAF formulas had S > scores than crtl formula (118 wks PMA); S↑ PDI score formula; (DAS, DAF) vs. crtl gp | Mead Johnson & Co.
{1553,1552,1565} | • Abstract | VLBW term & preterm infants | Crtl formula (n=83) vs. HM (RS) (n=105) | | • Growth patterns: NS in GP at 40, 57 wks PMA; S↑ wt in DHA+AA (SCO) than in crtl at 66–118 wks PMA; S↑ L in DHA+AA (SCO) than in other 2 formulas at 79, 92 wks PMA
| | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=361/NR
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
D'Almeida, 1992, South Africa | • RCT parallel Partially double-blind | Inclusion criteria: | GLA+EPA+DHA (primrose + fish oil) (n=50) vs. magnesium oxide (n=50) vs. placebo (olive oil + vitamin E) (n=50) | GLA+EPA+DHA & placebo: 240 capsules (8 x d); Magnesium oxide: 60 tablets x mo (2 tablets x d; 500 mg) | • Incidence of GHT, preeclampsia & eclampsia during pregnancy: Rate of GHT ↑ in grps 1–3 vs. grp 2 (p = NR); rate of preeclampsia/eclampsia ↑ in grp 3 vs. grps 1–2 | Efamol Ltd.
{580} | • Jadad total: 2 [Grade: C] | Primiparous & multiparous women in the first 4 mo of pregnancy
| • Schulz: Inadequate | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=150/NR
| | Mean Age:
| | • Maternal: 14–40 y
de Groot, 2003, Netherlands | • RCT parallel Double-blind | Inclusion criteria: | ALA enriched, ↑ LA margarine (n=29) vs. crtl gp (n=29) | 25 g margarine/d: 45.4% LA + 14.2% ALA (n-3) of total FA from wk 14 GA until delivery | • Duration of gestation: NS in GA | Unilever Research & Development
{2907,2935} | • Jadad total: 3 [Grade: B] | Healthy white pregnant women GA < 14 wk; normal health; fish consumption of < 2 /wk | | | • Birth weight: S ↑ in ALA+LA vs. LA
| • Schulz: Unclear | Exclusion criteria: | | | • BMK: S (+) correlation maternal plasma & RBC DHA & birth wt; S (+) correlation DHA intake & BW
| | Diastolic BP >90mmHg, multiple pregnancy, use of medication, use of LCPUFA rich supplements
| | Enrolled/Completed: n=79/58
| | Mean Age:
| | • Maternal: Crtl = 29.2 ± 3.8 y; Experimental = 30.0 ± 3.3 y
| | • Child: Crtl GA = 276.5 ± 12.2 d; Experimental GA = 281.0 ± 7.4 d
Decsi, 1995, Hungary | • RCT Parallel | Inclusion criteria: | Pre-Aptamil with Milupan (egg lipids, primrose oil) (n=12) vs. Pre-Aptamil without LCPUFA (n=10) | 120–150 ml/kg/d 0.5% AA + 0.03% EPA + 0.3% DHA + vitamin E formula ad libitum for 4 mo | • Growth patterns: NS in wt, L, HC at 6, 16, 30 wks | Deutsche Forschungsgemeinschaft, Bonn Germany; scholarship Milupa Austria
{460} | • Jadad total: 1 [Grade: C] | FF full term infants appropriate for GA | | | • BMK: NS correlation of RBC LCPUFA & GP
| • Schulz: Unclear | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=22/NR
| | Mean Age:
| | • Maternal: NR
| | • Child: FF gp = 39.4 ± 1.3 wk; LCPUFA-F gp = 38.9 ± 1.1 wk
Dunstan, 2004, Australia | • RCT Parallel Double-blind | Inclusion criteria: | Capsules with LCPUFAs (derived from fish oil, treatment gp) (n=40*) vs. Capsules with olive oil (Crtl grp) (n=43*) | 2.2 g/day DHA, 1.1 g/day EPA in capsules for 19 wk | • Duration of gestation: NS in GA | NH & MRC and Raine Medical Research Foundation
{2917} | • Jadad total: 3 [Grade: B] | Pregnant women with hx of allergic rhinitis or asthma but otherwise healthy | | | • Growth patterns at birth: NS in L, wt, & HC at birth
| • Schulz: Unclear | Exclusion criteria:
| | Smokers; high risk pregnancy; ate fish more than once/week
| | Enrolled/Completed: n=98/83
| | Mean Age:
| | • Maternal: crtl: 32.4 ±0.5 y; fish Oil: 31.1 ± 0.6 y
| | • Child: NR
Faldella, 1996, Italy | • RCT Parallel | Inclusion criteria: | LCPUFA-enriched formula (Milupan) (n=23) vs. Crtl formula (n=26)/ HM (RS) (n=17) | LCPUFA formula (DHA 0.23%; EPA 0.08%;ALA 0.40%) until 52 wks PCA | • VEP: S shorter wave (N4 & P4) latencies VEP in DHA+EPA vs. crtl at 52 wks PCA | NR
{390,2375} | • Jadad total: 1 [Grade: C] | Healthy preterm infants < 33 wk GA, of appropriate weight, no malformation interfering with somatic & / or psychomotor development, no neurological, visual, acoustic or gastroenterological illnesses, no hx of perinatal asphyxia, normal fundus oculi, & by 10 d age all received at least 50% of calorie requirement through enteral feeding | | | • BAEP test: NS in BAEP across grps1–3
| • Schulz: Unclear | Exclusion criteria: | | | • ERG: NS in ERG (a & b) latencies across grps1–3
| | NR | | | • Growth patterns: NS inΔwt,ΔL, ΔHC at 52 wks PCA
| | Enrolled/Completed: n=66/58 | | | • BMK: at 52 wks PCA, inverse correlation between: RBC-DHA & N4 wave latency; RBC-DHA & P4 wave latency
| | Mean Age
| | • Maternal: NR
| | • Child: BF = 31.8 wk, FF LCPUFA = 31.1 wk, FF Crtl = 31.3 wk
Fewtrell, 2002, UK | • RCT Parallel Double-blind | Inclusion criteria: | Supplemented preterm formula (egg-lipids) (n=95) vs. crtl preterm formula (n=95) vs. HM (RS) (n=88) | NR dose; mean 33 (SD=17) d in crtl gp vs. mean 31 (SD=21) d in supplemented formula | • Bayley's MDI & PDI: NS PDI & MDI between formula gps at 18 mo | Numico Research
{2129} | • Jadad total: 5 [Grade: A] | Preterm infants < 1,750 g; GA < 37 wk; free of congenital malformations known to affect neurodevelopment; mothers decided not to BF by 10 d of age; tolerant of enteral feeding at the time of enrolment | | | • Knobloch, Passamanick & Sherrard's Developmental Screening Inventory: NS between formula gps at 9 mo
| • Schulz: Adequate | Exclusion criteria: | | | • Growth: S↓wt, L in LCPUFA than in pb at 9 & 18 mo CA; NS in HC at 9, 18 mo CA
| | NR
| | Enrolled/Completed: n=283/240
| | Mean Age
| | • Maternal: NR
| | • Child: BF crtl = 30.3 (2.4) wk; FF Crtl = 30.3 (2.0) wk; FF LCPUFA = 30.4 (2.3) wk
Fewtrell, 2004, UK | • RCT Parallel Double-blind | Inclusion criteria: | ↑ DHA/EPA (borage, tuna fish oil) formula (n=122) vs. Crtl formula (n=116) | Preterm formula until 2 kg or discharge, then postdischarge formula until 9 mo after term | • Bayley's MDI & PDI: NS formula gps in MDI & PDI at 18 mo | H.J. Heinz Company, Ltd
{2938} | • Jadad total: 5 [Grade: A] | Healthy preterm infants with BW ≤ 2,500g, GA < 35 wks, receiving at least some of their enteral feeds as formula milk during NICU stay | | | • Growth patterns: S↑Δwt,ΔL in LCPUFA than in crtl at 9 mo; NS in HC at 9 mo; NS in GP at 18 mo
| • Schulz: Adequate | Exclusion criteria:
| | Congenital malformations known to affect growth or neurodevelopment
| | Enrolled/Completed: n=238/199
| | Mean Age:
| | • Maternal: crtl = 28.5 (5.7) y; LCPUFA= 29.0 (4.6) y
| | • Child: crtl= 13.9 (10.4) d; LCPUFA 14.3 (9.6) d
Field, 2000, Canada, | • RCT Parallel | Inclusion criteria | Supplemented preterm formula (DHA+AA derived from SCO) (n=15) vs. Crtl preterm formula (n=12) vs. HM (RS) (n=17) | LCPUFA formula (0.35 wt% DHA, 0.49 wt% AA) from 8 to 42 d of age; | • Growth patterns: S↓Δwt in HM than in LCPUFA & pb at 28 d; NS in L, HC at 35 d | Wyeth Nutrionals;
{2191} | • Jadad total: 1 [Grade: C] | Preterm infants GAs between 27 & 36 wks size appropriate for GA & receive 100% of daily fluid & energy requirements enterally by d 14 of life | | | | Natural Sciences & Engineering Research Council of Canada; Medical Research Council of Canada
| • Schulz: Unclear | Exclusion criteria:
| | Infants with major congenital malformation, documented systemic or congenital infection, significant neonatal morbidity or acute illness that precludes oral feeding; mixed feeding; corticosteroid use; RBC & plasma transfusion; or IV lipid emulsion beyond d 8
| | Enrolled/Completed: n=44/44
| | Mean Age:
| | • Maternal: NR
| | • Child: BF = 32 ± 2wk; Ctrl F = 31 ± 2 wk; F + LCPUFA = 32 ± 2 wk
Ghebremeskel, 1999, UK | • RCT Parallel | Inclusion criteria: | LCPUFA preterm formula (DHA+AA derived from egg-TG) (n=7) vs. LCPUFA formula+HM (n=14) vs. Crtl preterm formula (n=8) vs. Crtl formula+ HM (n=12) vs. HM (RS) (n=20) | LCPUFA formula+HM (0.85+-0.25wt% DHA); Crtl formula+HM 0.55+-0.25wt% DHA); LCPUFA formula (0.30wt% DHA) for a mean of 11 wk (range 7–15 wk) | • Growth patterns: NS in wt, L, HC at ≈11 wk among 5 grps | The Christopher H.R. Reeves Charitable Trust; Milupa
{2262} | • Jadad total: 2 [Grade: C] | Healthy preterm infants
| • Schulz: Unclear | Exclusion criteria:
| | Congenital malformations; metabolic disorders
| | Enrolled/Completed: n=61/35
| | Mean Age:
| | • Maternal: NR
| | • Child: GA = 29.5 wks ± 2.4 wks
Gibson, 1997, Australia | • RCT Parallel Double-blind | Inclusion criteria: | DHASCO (DHA-rich algal oil) 5 different doses (n=12 vs. n=10 vs. n=12 vs. n=10 vs. n=8) | Maternal DHA doses: 0 gvs. 0.2 g vs. 0.4 gvs. 0.9 g vs. 1.3 g). HM (DHA content: 0.21% vs. 0.35% vs. 0.46% vs. 0.86% vs. 1.13% of FA) | • VEP: NS VEP at 12 & 16 wks | Martek Biosciences, NH & MRC
{2959} | • Jadad total: 3 [Grade: B] | Mothers of term infants (> 37 wks GA), who intended to BF for ≥ 12 wks; infants were healthy, AGA, apgar > 7 @ 5 min | | | • Bayley's MDI & PDI: NS in PDI at 12 mo & 24 mo; S correlation between MDI & DHA in infants's diet at 1 y; NS at 2 y
| • Schulz: Unclear | Exclusion criteria: NR | | | • BMK: No correlation VEP & DHA HM, infant plasma or RBC LCPUFA; S correlation between MDI & DHA status (RBC & plasma at 12 wks) at 1 y
| | Enrolled/Completed: n=52/50
| | Mean Age:
| | • Maternal: 30 ± 4 y
| | • Child: GA = 39 – 40 ± 1 wks
Gobel, 2003 Germany | • RCT Parallel | Inclusion criteria: | Olive/soybean oil emulsion (DHA + ALA) (n=24) vs. Soybean oil emulsion (DHA + ALA) (n=21) | IV lipid infusion olive/soybean oil emulsion (DHA 0.23% + ALA 2.0%); IV lipid infusion soybean oil emulsion (DHA 0.34% & ALA 6.99%) for 7 d | • Safety | Deutsche Forschungsemeinschaft, Bonn, Germany; Baxter SA, Maurepas, France
{1516} | • Jadad total: 2 [Grade: C] | Healthy preterm infants, GA between 28 wk + 0 d & 36 wk + 6 d, admission to the intensive care nursery of the study centers within 24 h of birth, & expected requirment for parental nutrition providing at least 80% of total energy intake from the duration of study
| • Schulz: Unclear | Exclusion criteria:
| | Severe malformation of visceral organs, kidneys, lung, or brain or inborn errors of metabolism
| | Enrolled/Completed: n=45/33
| | Mean Age:
| | • Maternal: NR
| | • Child: gp O GA = 220 d ±16.5 d, gp S GA = 224 d ±12.8 d
Groh-Wargo, 2002, US, Canada | • RCT Parallel | Inclusion criteria: | Supplemented preterm formula (DHA+AA derived from egg-TG) (n=18) vs. Supplemented preterm formula (DHA+AA derived from fish oil) (n=18) vs. Crtl preterm formula (n=21) | Preterm formula (0.26 wt% DHA, 0.42 wt% AA) until term, then postdischarge formula until 1 y CA | • Growth patterns: NS in GP at 12 mo CA | Abbott Laboratories, GCRC NIH
{1538} | • Abstract | FF preterm infants, 750–1,800g < 33 wk gestation
| | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=57/NR
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Guesnet, 1999, France | • RCT Parallel | Inclusion criteria: | Supplemented formula (DHA+high EPA) (n=23) vs. supplemented (DHA +low EPA) (n=24) vs. crtl formula (n=22) vs. HM (RS) (n=15) | DHA 0.45%, EPA 0.35%, AA 0.05% vs. DHA 0.45% vs. EPA 0.10%, AA 0.05% vs. no DHA or EPA or AA for 6 wks | • RBC & plasma PUFAs correlation with growth: S (-) correlation betweenΔL & plasma & RBC EPA at birth | Bledina-sa, Gpe Danon Paris, French Ministry of Cooperation in Mauritius & the University of Mauritius
{1650} | • Jadad total: 2 [Grade: C] | Singleton healthy term infants (between 37–42 weeks gestation), appropriate weight for GA after a healthy pregnancy
| • Schulz: Unclear | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=98/83
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Helland, 2001 Norway | • RCT Parallel Double-blind | Inclusion criteria: | Cod liver oil (n=301) vs. corn oil (n=289) | 10 mL/d oil (1183 mg DHA, 803 mg EPA, 27.5 mg AA /10 ml) from entry to 3 mo after delivery | • Duration of gestation: NS in GA | Peter Møller, Avd. Orkla ASA & “Adtieselskabet Freia Chocoladefabriks Medicinske Fond.”
{111,39} | • Jadad total: 4 [Grade: A] | Healthy women with single pregnancies between 19 to 35 y of age, & nulli or primipara who intended to BF their infants & none have taken any supplements of n-3 fatty acids earlier during the pregnancy | | | • Birth weight, L, HC: NS in birth wt, birth L, & HC (grp 1 vs. grp 2)
| • Schulz: Unclear | Exclusion criteria: | | | • Growth patterns: NS between gps in wt, L & HC at 6 wks & 3, 6, 9 & 12 mo
| | Premature births, birth asphyxia, infections & anomalies in the infants requiring special attention | | | • Fagan test: NS novelty preference (Fagan test) at 6 & 9 mo
| | Enrolled/Completed: n=590/341 | | | • EEG: NS EEGs scores between grps (3 mo)
| | Mean Age | | | • K-ABC: Cod liver oil > Mental Processing K-ABC score than corn oil (4 y)
| | • Maternal: cod liver oil SD = 28.6 (3.4) y, corn oil SD = 27.6 (3.2) y;
| | • Child: cod liver oil GA SD = 279.6 (9.2) d; corn oil SD = 279.2 (9.3) d
Hoffman, 2003, US | • RCT Parallel | Inclusion criteria: | Supplemented formula (DHA+AA derived from SCO) (n=33) vs. crtl formula (n=35) | LCPUFA formula (0.36 wt% DHA, 0.72 wt% AA) after weaning at 4–6 mo to 12 mo of age | • VEP: S better sweep VEP & DHA+AA at 12 mo | NIH
{2958} | • Jadad total: 3 [Grade:B] | Singleton term infants & infants with BW appropriate for GA | | | • Acuity card procedure: NS DHA+AA & FPL at 4,6,9, & 12 mo
| • Schulz: Adequate | Exclusion criteria: | | | • Growth patterns: NS in wt, L, HC, wt-for-L at 4, 6, 9 & 12 mo
| | Family hx of milk-protein allergy, genetic or familial eye disease, vegetarian or vegan maternal diet, maternal metabolic disease, maternal anemia, maternal infection, congenital malformation or infection, & any perinatal event that resulted in NICU | | | • BMK: S better sweep VEP at 12 mo & RBC DHA; Σ n-3, n-3/n-6, DHA/DPA, n-6 unsaturation index; S poorer sweep VEP at 12 mo & RBC LA, AA; NS FPL & RBC n-3 or n-6 FA
| | Enrolled/Completed: n=68/61
| | Mean Age:
| | • Maternal: NR
| | • Child: 4–6 mo
Innis, 1997, US, Canada | • RCT Parallel | Inclusion criteria: | Formula 1 (cow milk- protein based) (n=69) vs. Formula 2 (cow milk- protein based) (n=70) vs. HM (n=99) | Formula 1 (18.0% LA, 1.9% ALA, with LA/ALA ratio of 9.5:1) & Formula 2 (34.2% LA, 4.7% ALA, with an LA/ALA ratio of 7.3:1) for 3 mo | • Acuity card procedur: NS FPL at 90 d of age | Mead Johnson Research Center
{374} | • Jadad total: 2 [Grade: C] | Full term healthy infants (37–41 wk), with a BW > 2,500g to< 4500g, < 14 d old, mother had chosen to either exclusively BF or FF for 3 mo | | | • Growth patterns: NS in wt, L, & HC at 3 mo
| • Schulz: Unclear | Exclusion criteria: | | | • BMK: NS visual acuity & plasma & RBC CPG DHA
| | BF infants recieving formula later than 6 d after birth; infants with congenital problems or disease considered likely to interfere with normal feeding or nutrient metabolism; with feeding intolerance; poor milk or formula intake; or with abnormal eye exam (as judged by infant's physician)
| | Enrolled/Completed: n=238/191
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Innis, 2002, Canada, US | • RCT Parallel Double-blind | Inclusion criteria: | DHA+AA formula (SCO) (n=66) vs. DHA formula (n=66) vs. crtl fornula (n=62) | LCPUFA formula (0.14% DHA + 0.27%AA or 0.15% DHA) for at least 28 d, then unsupplemented term formula to 57 wks PMA | • Growth patterns: S↑Δwt in DHA+AA than in crtl at 40 wks PMA; S↑ wt, L, wt-to-L in DHA+AA than in DHA at 48 wks PMA; S↑ wt, wt-to-L in DHA+AA than in crtl at 48 wk PMA; NS in HC at 48, 57 wks PMA | Mead Johnson Nutritionals
{80,2279} | • Jadad total: 3 [Grade: B] | Healthy VLBW (846–1,560g) FF preterm infants | | | • Teller acuity card procedure: NS in FPL visual acuity at 48 & 57 wks PCA
| • Schulz: Unclear | Exclusion criteria: | | | • BMK: S (+) correlation betweenΔwt & RBC PE AA at 8 wks; S (+) correlation between wt, L & RBC PE AA at 8 wks
| | Preterm infants SGA, >24 days postnatal age when full enteral feeds ≥375 kJ/kg/day achieved, had necrotizing enterocolitis or other gastrointestinal disease, impaired visual or ocular status, or a hx of underlying disease or congenital malformation that could interfere with growth
| | Enrolled/Completed: n=194/121
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Jensen, 1997, US | • RCT Parallel | Inclusion criteria: | Formula 1 (CSHPCo) (n=20) vs. Formula 2 (CSHPCo) (n=20) vs. Formula 3 (CSHPCo) (n=20) vs. Formula 4 (CSHPCo) (n=20) | Formula 1 (15.6% –17.6% LA, 0.4% ALA); Formula 2 (15.6% –17.6% LA, 1% ALA); Formula 3 (15.6% –17.6% LA, 1.7% ALA); Formula 4 (15.6% –17.6% LA, 3.2% ALA) for 4 mo | • Growth patterns: S↓wt in F4 than in F1 at 4 mo; NS in L, HC, TST, & SST at 4 & 8 mo | US dept of Agriculture, Agriculture Research Services; Mead-Johnson Nutritional Group, Foundation Fighting Blindness, Research to Prevent Blindness, Inc. & Retina Research Foundation
{350,82} | • Jadad total: 2 [Grade: C] | Healthy full term infants whose mothers had elected not to breast feed | | | • VEP: NS latency VEP among gps at 120 & 240 d; NS amplitude VEP among gps at 120 & 240 d
| • Schulz: Unclear | Exclusion criteria: | | | • BMK: S (+) correlation between wt at 4 mo & plasma AA at 120d; NS correlations between wt & plasma n-3 at 4 mo; S correlation between plasma DHA & PDI; NS correlation between RBC DHA & PDI; NS plasma & RBC PL DHA & amplitude at 120 & 240 d
| | NR | | | • Bayley's: NS in PDI & MDI at 12 mo
| | Enrolled/Completed: n=80/63
| | Mean Age:
| | • Maternal: NR
| | • Child: Formula 1 GA = 39.8 ± 1.4 wk; Formula 2 GA = 39.6 ± 1.8 wk; Formula 3 GA = 39.6 ± 2.0 wk; Formula 4 GA = 39.6 ± 1.5 wk; BF GA = 40.2 ± 1.2 wk
Jensen, 1999, US | • RCT Parallel | Inclusion criteria: | algal DHA (n=42) vs. fish oil derived DHA (n=42) vs. Crtl grp. (n=42) | Breast-feeding maternal intake of 200–250 mg DHA/d for 4 mo after delivery | • Transient VEP (120 & 240 d post delivery): NS in VEP latency & sweep VEP acuity | Mead Johnson Nutritionals & NRICGP
{240} | • Abstract | Healthy full term infants | | | • Teller Acuity Card Procedure: NS
| | Exclusion criteria: | | | • Growth patterns: NS in wt, L & HC at 4–8 mo
| | NR | | | • BMK: NS correlation visual function & infant plasma PL DHA at 120 d
| | Enrolled/Completed: n=126/NR
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Jorgensen, 1996, 1998, Denmark | • RCT Parallel | Inclusion criteria: | Formula 1 (DHA+EPA -fish oil) (n=15) vs. Formula 2 (DHA+EPA, -fish oil, & GLA - borage oil) (n=13) vs. Crtl formula (n=11) vs. HM (RS) (n=17) | Formula 1 (0.3wt% DHA, 0.4wt% EPA); Formula 2 (0.3wt% DHA, 0.4wt% EPA, 0.5wt% GLA) for 3 mo | • Sweep VEP: NS effect of DHA on visual acuity at 4 mo | Food Technology Research & Development Program; DanoChemo AS; BASF Health & Nutrition, Swedish Medical Research Council
{1159} | • Jadad total: 2 [Grade: C] | For FF & BF infants; uncomplicated pregnancy, term delivery (GA 37–42 weeks); BW between 2700 & 4500g; Apgar score >7 after 5 min & no neonatal diseases. For FF infants, termination of BF prior to 30 days of age without using a DHA supplemented formula. | | | • Growth patterns: NS in wt, L, HC, GV at 1, 2, & 4 mo
| • Schulz: unclear | Exclusion criteria: | | | • BMK: NS visual acuity at 4 mo & RBC DHA, EPA, or AA; S (-) correlation visual acuity & RBC CPG LA
| | Infant hospitalization; serious illness during the study period; formula intolerance (vomiting/diarrhea)
| | Enrolled/Completed: n=39/37
| | Mean Age:
| | • Maternal: NR
| | • Child: Gp 1 (DHAGF) = 25.8 d; Gp 2 (DHAF) = 23.8 d; gp 3 (STF) = 22.5 d
Koletzko, 1995, Germany | • RCT Parallel Double-blind | Inclusion criteria: | LCPUFA Prematil (Milupa) formula (egg-lipid, evening primrose oil) (n=9) vs. Crtl formula (n=10) vs. HM (RS) (n=8) | LCPUFA formula (0.5 % AA, 0.03% EPA, 0.3% DHA, vitamin E 20 mg/L) for 3 wks | • Growth patterns: NS in wt, L, HC at 3 wks | Deutsche Forschungs-gemeinschaft, & Milupa AG
{455} | • Jadad total: 2 [Grade: C] | Healthy preterm infants with BW ≤1850 a /= 130 ml milk/ Kg /day | | | • Visual acuity Teller's test: NS difference in visual acuity across at 3 wks
| • Schulz: Unclear | Exclusion criteria:
| | Need for artificial ventilation or an oxygen supply with FiO2 > 0.30 at the time of enrollment or during the study; apparent GI, hepatic, & metabolic abnormalities; & septicemia
| | Enrolled/Completed: n=27/27
| | Mean Age:
| | • Maternal: NR
| | • Child: BF SD GA = 32.6 wk (1.9); FF no LCPUFA SD GA = 34.2 wk (2.3); FF+ LCPUFA SD GA = 33.8 wk (1.9)
Koletzko, 2003, Germany | • RCT Parallel Double-blind | Inclusion criteria: | LCPUFA formula (egg, black currant seed oil, low EPA fish oil) (n=15) vs. crtl formula (n=15) vs. HM (RS) (n=19) | 0.57 mol DHA+ 0.1 mol AA formula + vitamin E during 28 d | • Growth patterns: NS wt, L, HC at 28 d | Deutsche Forschungsgemeinschaft, Bonn, Germany; Nestec S.A; Vevey, Switzerland; & NestleAlete Gmb, Munich, Germany
{940} | • Jadad total: 3 [Grade: B] | Preterm infants in stable condition with BW < 1800g
| • Schulz: Unclear | Exclusion criteria:
| | Artificial ventilation or oxygen supply with FiO2 > 0.3 at time of enrollment & presence of genetic GI or metabolic disorders.
| | Enrolled/Completed: n=49/33
| | Mean Age:
| | • Maternal: NR
| | • Child: full PCA = 35 ± 2 wk; crtl BF = 26±14 d; FF 39 ± 22 d; F + LCPUFA-F = 39 ± 24 d
Laivuori, 1993, Finland | • RCT parallel design | Inclusion criteria: | MaxEPA (fish oil) (n=3) vs. Preglandin (primrose oil) (n=4) vs. placebo (maize oil, olive oil) (n=5) | Max EPA (180 mg EPA, 120 mg DHA, 680 mg fish oils), Preglandin (375 mg LA, 45 mg GLA), placebo (500 mg each oil); 10 capsules | • Effect on BP, proteinuria & edema: NS (grp 1 vs. grps 2–3) | NR
{547} | • Jadad total: 2 [Grade: C] | Preeclamptic women admitted to hospital between 26 & 37 wks of gestation
| • Schulz: Adequate | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=18/12
| | Mean Age:
| | • Maternal: Primerose oil = 32 y (23–40), Fish oil = 30.3 y (24–40), Placebo = 30.2 y (26–32)
| | • Child: NR
Lapillone, 1997, France | • RCT Parallel | Inclusion criteria: | LCPUFA formula (DHA+AA derived from fish oil) (n=16) vs. Crtl formula (n=17) | LCPUFA preterm formula (0.37wt% DHA, 0.05wt% EPA) until 40 wk CA, then LCPUFA term formula (0.45wt% DHA, 0.09wt% EPA) until 4 mo CA | • Growth patterns: NS in GP at 4 mo CA | NR
{1760} | • Abstract | Preterm infants appropriate for GA, (29.3 wk)
| | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=33/NR
| | Mean Age:
| | • Maternal: NR
| | • Child: GA = 29.3 ±1.6 wk
Lapillonne, 2000, France | • RCT Parallel | Inclusion criteria: | LCPUFA formula (DHA+EPA+AA derived from fish oil) (n=12) vs. Crtl formula (n=12) | LCPUFA formula (0.31wt% DHA, 0.08wt% EPA, 0.03wt% AA) from 3 d to 4 mo of age | • Growth patterns: S↑ HC in crtl than in LCPUFA & HM at 4mo; NS in wt, L, at 2, 4 mo | Blé dina-sa
{1621} | • Jadad total: 1 [Grade: C] | Term infants appropriate for GA & born with a BW of > 2800g; free of neonatal morbidity
| • Schulz: Unclear | Exclusion criteria:
| | Hx of maternal cocaine or alcohol abuse, or born to mothers with a hx of diabetes, hyperlipidaemia, abnormal dietary pattern (strict vegetarian or vegan)
| | Enrolled/Completed: n=NR/24
| | Mean Age
| | • Maternal: NR
| | • Child: GA = 40.1 ± 0.8 wk;
Lucas, 1999, UK & Australia | • RCT Parallel Double-blind | Inclusion criteria: | LCPUFA (egg lipids) formula (n=154) vs. crtl formula (n=155) vs. HM (RS) (n=138) | 0.30% AA + 0.32% DHA formula from 1^st^ wk age until 6 mo | • Bayley's MDI & PDI: NS at 18 mo | Nestec Ltd (Switzerland)
{270} | • Jadad total: 5 [Grade: A] | FF gp: women giving birth to healthy singletons of appropriate size for GA & of at least 37 wk gestation, mothers who decided on FF after birth; BF crtl gp: plan to BF for at least 6 wk | | | • Knobloch, Passamanick & Sherrard's test: NS in KPS at 9 mo
| • Schulz: Adequate | Exclusion criteria: | | | • Growth patterns: NS in wt, L, HC, MAC, SST at 6, 9, 18 mo
| | Congenital abnormalities affecting development; BF pts were excluded from analysis if BF< 6 mo
| | Enrolled/Completed: n=447/354
| | Mean Age:
| | • Maternal: FF Crtl = 27.5 ± 5.23 y; FF LCPUFA = 27.0 ± 5.12 y; BF=30.6 ± 4.34 y
| | • Child: NR
Makrides, 1995, Australia | • RCT Parallel | Inclusion criteria: | Supplemented formula (DHA+ EPA, derived from fish oil, and AA derived from primrose oil) (n=13*) vs. Crtl formula (n=19*) vs. HM (n=47*) | LCPUFA formula (0.36 wt% DHA+0.58 wt% EPA+0.01 wt% AA); | • Growth patterns: NS in wt, L, HC at 6, 16, 30 wks | Children's Medical Research Foundation, Nestle Australia, Scotia Pharmaceuticals UK & Flinders Medical Research Foundation
{477} | • Jadad total: 2 [Grade: C] | Healthy infants of 37–42 weeks gestation, appropriate weight for gestation | | | • VEP: S improved visual acuity of DHA+GLA at 16 & 30 wk
| • Schulz: Unclear | Exclusion criteria: | | | • BMK: NS correlation of RBC LCPUFA & GP; S correlation RBC DHA & VEP acuity at 16 & 30 wks of age
| | Mothers with hx of lipid metabolism disorders, IDDM, drug or ETOH abuse
| | Enrolled/Completed: n=89/79
| | Mean Age:
| | • Maternal: NR
| | • Child: fully BF GA = 39.8 wk; Partially BF GA = 39.7 wk; pb FF GA = 39.6 wk; Supplemented FF GA = 39.1wk
Makrides, 1999, Australia | • RCT Parallel double-blind | Inclusion criteria: | DHA + AA formula (tuna oil, egg-PL) (n=28) vs. DHA formula (n=27) vs. crtl formula (n=28) vs. HM (RS) (n=63) | DHA+AA formula (0.34%DHA + 0.34%); DHA formula (0.35% DHA) during 12 mo; | • Growth patterns: NS in wt, L, HC at 6, 16, 34 wk, 12 & 24 mo | Nestec Ltd. Switzerland; Australian National Health & Medical Research Council
{229,213} | • Jadad total: 5 [Grade: A] | Healthy white term infants | | | • BMK: S (-) correlation of plasma DHA at 16 wks & wt at 12 mo & 24 mo; S correlation between PDI at 12 mo & plasma AA levels at 12 mo; NS with MDI
| • Schulz: Adequate | Exclusion criteria: | | | • VEP: NS VEP acuity at 16 or 34 wk
| | SGA, evidence of congenital disease, mother had IDDM or hx of drug or ETOH abuse | | | • Bayley's: NS in MDI & PDI at 12 & 24 mo
| | Enrolled/Completed: n=146/114
| | Mean Age:
| | • Maternal: NR
| | • Child: PB formula GA = 39.6 ± 1.5 wk; DHA formula GA = 39.6 ± 1.1 wk; DHA+ AA formula GA = 39.8 ± 1.3 wk; BF GA = 39.3 ± 1.4 wk
Makrides, 2000, Australia | • RCT Parallel | Inclusion criteria: | Formula 10:1 (FAs from CSHPCo) (n=36) vs. Formula 5:1 (FAs from CSHPCo) (n=37) vs. HM (n=103) | Formula 10:1 (16.9 wt% LA, 1.7 wt% ALA); Formula 5:1 (16.6 wt% LA, 3.3 wt% ALA) from 4–6 d to 34 wk of age; | • Growth patterns: NS inΔwt,ΔL,ΔHC between 10:1-F & 5:1-F at 6, 16, 34 wks; S↑ wt at 6 wks & L at 16 wks in 5:1 F | Wyeth Nutritionals International; Australian National Health & Medical Research Council; MS McLeod Research Trust
{220,109} | • Jadad total: 5 [Grade: A] | White term infants | | | • VEP: NS VEP acuity at 16 & 34 wk
| • Schulz: Adequate | Exclusion criteria:
| | SGA; evidence of congenital disease; mother had diabetes requiring insulin; or a hx of drug or ETOH abuse
| | Enrolled/Completed: n=176/145
| | Mean Age:
| | • Maternal: NR
| | • Child: full NBD (formula LA: ALA) 10:1 GA = 39.4 ± 1.2 wks; 5:1 GA = 39.2 ± 1.3 wk; BF GA = 39.5 ± 1.1 wk
Malcolm, 2003, UK | • RCT Parallel Double-blind | Inclusion criteria: | Maternal LCPUFA supplementation capsules (from fish oil) (n=50) vs. Placebo capsules (n=50) | LCPUFA capsules (40.4 wt% DHA, 7.2 wt% EPA) from 15 wk of pregnancy until delivery | • Duration of gestation: NS in GA | Scottish Office Health Department
{12} | • Jadad total: 3 [Grade: B] | Mothers: women at approximately 15 wk of pregnancy; infants: healthy born > 36 wk gestation, with Apgar score of >7 at 5 m & with no visual, medical or developmental disorders | | | • Growth patternss: NS in birth wt, L & HC
| • Schulz: Unclear | Exclusion criteria: | | | • ERG (24 h): NS in b wave implicit time; NS in Naka-Rushton function; NS in log; NS in maximium combined ERG
| | Mothers: diabetes, twin pregnancies, k pre-eclampsic toxemia, hx of abruption or postpartum hemorrhage, allergy to fish products, or a thrombophilic tendency or those receiving drugs affecting thrombocyte function | | | • BMK: NS correlation of max combined ERG & cord blood DHA; NS (-) correlation of log & cord blood AA; S (+) correlation of log & cord RBC proportion DHA & total n-3 FA, n-6/n-3; S correlation of log d & cord RBC quartiles of DHA, AA, total n-3 LCPUFAs
| | Enrolled/Completed:
| | • Mothers: n=100/63
| | • Child: n=60/56
| | Mean Age:
| | • Maternal: NR
| | • Child: fish oil = 279.7 (9.5) d, pb = 279.6 (8.5) d
Martinez, 1999, Brazil | • RCT Parallel | Inclusion criteria: | LCPUFA formula (Egg-TG & primrose oil) (n=20) vs. crtl formula (n=20) vs. HM (n=18) | LCPUFA formula (NR) for 1 mo | • Growth patterns: NS in wt, L, HC at 30 d | Brazilian Research Council; Milupa GmbH & Co.
{2258} | • Jadad total: 1 [Grade: C] | GA betweeen 28 & 34 weeks BW between 900g–1500g, on enteral feeding for 2 days before the beginning of the study
| • Schulz: Unclear | Exclusion criteria:
| | Congenital anomalies; requirements of special care such as sepsis, hyaline membrane disease, patent ductus arteriosus, need for ventilatory support or O2 supplementation
| | Enrolled/Completed: n=58/NR
| | Mean Age:
| | • Maternal: NR
| | • Child: BF = 15.8 ± 1.2 d; FF = 18.0 ± 2.1 d; FF+ LCPUFA = 12.8 ± 1.0 d
McClead, 1985, US | • RCT Parallel | Inclusion criteria: | Modified Liposyn 20% (high ALA) (n=10) vs. Liposyn 20% (low ALA) (n=10) | IV ALA 3 (SD: 1.5)% safflower oil emulsion vs. IV ALA 0.1% safflower oil emulsion for 13 d | • Safety | Abbott Laboratories, Chicago, Illinois
{2550} | • Jadad total: 3 [Grade: B] | Infants in NICU requiring TPN for at least 7 days
| • Schulz: Unclear | Exclusion criteria:
| | Medical conditions that precluded IV fat therapy (e.g. severe hyperbilirubinemia, respiratory distress, thrombocytopenia)
| | Enrolled/Completed: n=23/20
| | Mean Age:
| | • Marternal: NR
| | • Child: NR
Morris, 2000, UK | • RCT Parallel Double-blind | Inclusion criteria: | LCPUFA formula (DHA+AA, from Egg-TG) (n=55*) vs. Crtl formula (n=54*) | LCPUFA formula (0.2 wt% DHA, 0.4 wt% AA) for 12 wk | • Growth patterns: S↑ SST in DHA at 6 wk & 3 mo+ NS at 6 mo & 12 mo; NS in wt, L, HC, MAC, TST at 6 & 12 wk, 6 & 12 mo | Cow & Gate Nutricia Ltd
{2231} | • Jadad total: 3 [Grade: B] | Term infants whose mothers had decided to bottle feed with BW between 2.5–4.5 kg up to age 72 h
| • Schulz: Unclear | Exclusion criteria:
| | Major congenital abnormalities & infants from multiple pregnancies
| | Enrolled/Completed: n=140/109
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
O'Connor, 2001, 2003, US, UK, Chile | • RCT Parallel Double-masked | Inclusion criteria: | DHA+AA (fish/fungal) (n=140)/ vs. DHA+AA (egg-TG/fish) (n=143)/ vs. | NR dose, Inhospital preterm formula until discharge, then postdischarge formula until 12 mo CA | • Growth patterns: NSΔwt,ΔL,ΔHC at 8 wk, 4 mo, 12 mo CA | Ross Products Division, Abbott Lab, US
{126,1507} | • Jadad total: 3 [Grade: B]; | Initiation of enteral feeding by 28^th^ d of life; singleton & twin births, SGA | Crtl formula (n=144) vs. HM (RS) (n=43) | | • Teller Acuity Card Procedure: NS in FPL acuity at 4 mo CA
| • Schulz: Unclear | Exclusion criteria: | | | • VEP: S ↑ VEP acuity in grps1–2 vs. grp3 at 6 mo CA; NS VEP acuity across both DHA+AA grps
| | Serious congenial abnormalities affecting growth & development; major surgery before randomization; perivenricular/ intraventricular hemorrhage > Grade II; maternal incapacity; liquid ventilation' asphyxia resulting in severe & permanent neurologic damage, or uncrtlled systemic infection at the time of enrollment | | | • Bayley's: S↑ PDI score in <1,250 g birth wt fed AA+DHA (egg-TG/fish) than crtl infants; NS score crtl or AA+DHA (fish/fungal) gps; NS Bayley's MDI (12 mo)
| | Enrolled/Completed: n=470/376 | | | • Fagan: M novelty preference look (Fagan test) AA+DHA (egg-TG/fish) > crtl & AA+DHA (fish/fungal) (6 mo)
| | Mean Age: | | | • MacArthur Communicative Development Inventories (9, 14 mo): NS
| | • Maternal: FF-crtl = 27.2 y, FF-fish/fungal = 27.0 y, FF-egg-TG/fish = 27.0 y, HM = 29.7 y | | | • BMK: S (+) correlation rate wt gain & RBC PE AA at 28 d; wt & L S correlated RBC PE AA at 28 d
| | • Child: GA wk (postnatal age d): FF-crtl = 29.6 wk (5.5 d), FF-fish/fungal = 29.8 wk (5.0 d), FF-egg-TG/fish = 29.7 (4.6 d), HM = 29.7 (5.5 d)
Olsen, 1992, Dalby Salvig, 1996, Denmark | • RCT Parallel Double-blind | Inclusion criteria: | Fish oil (n=266) vs. placebo (olive oil) (n=136) vs. no oil (n=131) | 4 capsules/d of 1 g gelatine capsules with fish oil (Pikasol fish oil: 32% EPA, 23% DHA, 2 mg vit E); 2.7 g n-3 FA/d until delivery | • Duration of gestation: S↑ GA in fish oil grp | Danish Medical Research Council, Sygekassernes Helsefond, Weiman's Legat & Michaelsen Fonden
{614,425,531} | • Jadad total: 2 [Grade: C] | All women scheduled to attend for a routine wk 30 GA midwife assessment | | | • Birth weight: NS birth wt
| • Schulz: Inadequate | Exclusion criteria: | | | • BP (baseline; wks 33, 37, 39 & wkly until delivery): NS in BP or rates of GHT & preeclampsia (grp 1 vs. grps 2–3) NS in BP (grp 1 vs. grps 2–3)
| | Hx of placental abruption in previous pregnancy; seroius bleeding episode in the present pregnancy; regular use of prostaglandin inhibitors; multiple pregnancy; allergy to fish & regular intake of fish oil
| | Enrolled/Completed: n=533/402
| | Mean Age:
| | • Maternal: fish oil=29.4 y (4.4); olive oil= 29.7 y (4.3); ctrl=29.1 y (4.1)
| | • Chid: NR
Olsen, 2000, Denmark* | • RCT Parallel Design | Inclusion criteria: | Fish oil (Pikasol) (n=110) vs. placebo (Olive oil) (n=122) | 4 gelatine capsules/d, 32% EPA, 23% DHA, 2mg vit E; 2.7 g of LCPUFA/d | • Preterm delivery: S↑ GA in fish oil gp; S↓% premature deliveries in fish oil gp | Concerted Action & PECO programmes of European Commission, Danish National Research Foundation, Lube Ltd
{66} | • Jadad total: 2 [Grade: C] | Women > 16 wk of gestation with an uncomplicated pregnancy, hx preterm delivery (< 259 d of gestation) | | | • Birth weight: S↑ birth wt in fish oil; NS % IUGR
| • Schulz: Adequate | Exclusion criteria:
| | Diabetes mellitus in or before pregnancy; diagnosed severe fetal malformation or hydrops in current pregnancy; suspicion in current pregnancy, or occurrence in an earlier pregnancy, of placental abruption; drug or alcohol abuse; regular intake of fish oil or of nonsteroidal anti-inflammatory agents or other drugs affecting thrombocyte function or eicosanoid metabolism; allergy to fish products. In the therapeutic trials also high probability of delivering soon after randomization (estimated within one wk)
| | Enrolled/Completed: n=232/228
| | Mean Age:
| | • Maternal: fish oil = 29.3 y (4.87); olive oil = 30.0 y (6.22)
| | • Child: GA = 131.8 d (24.6); GA = 130.5 d (27.7)
Olsen, 2000, Denmark* | • RCT Parallel Design | Inclusion criteria: | Fish oil (Pikasol) (n=141) vs. placebo (Olive oil) (n=139) | 4 gelatine capsules/d, 32% EPA, 23% DHA, 2mg vit E; 2.7 g of LCPUFA/d | • Duration of gestation: S↑ GA in fish oil gp | Concerted Action & PECO programmes of European Commission, Danish National Research Foundation, Lube Ltd
{66} | • Jadad total: 2 [Grade: C] | Women > 16 wk of gestation with an uncomplicated pregnancy, hx IUGR (<5^th^ PC) | | | • Recurrence of IUGR-birth weight: S↑ birth wt in olive oil; NS % IUGR
| • Schulz: Adequate | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=280/263
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Olsen, 2000, Denmark* | • RCT Parallel Design | Inclusion criteria: | Fish oil (Pikasol) (n=184) vs. placebo (Olive oil) (n=202) | 4 gelatine capsules/d, 32% EPA, 23% DHA, 2mg vit E; 2.7 g of LCPUFA/d | • Duration of gestation: NS in GA | Concerted Action & PECO programmes of European Commission, Danish National Research Foundation, Lube Ltd
{66} | • Jadad total: 2 [Grade: C] | Women > 16 wk of gestation with hx GHT | | | • Recurrence GHT, preeclampsia: NS in rates of GHT & preeclampsia (grp 1 vs. grp 2); NS in BP (grp 1 vs. grp 2)
| • Schulz: Adequate | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=386/350
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Olsen, 2000, Denmark* | • RCT Parallel Design | Inclusion criteria: | Fish oil (Pikasol) (n=289) vs. placebo (Olive oil) (n=290) | 4 gelatine capsules/d, 32% EPA, 23% DHA, 2mg vit E; 2.7 g of LCPUFA/d | • Duration of gestation: NS in GA | Concerted Action & PECO programmes of European Commission, Danish National Research Foundation, Lube Ltd
{66} | • Jadad total: 2 [Grade: C] | Women > 16 wk of gestation with current twin pregnancy | | | • GHT, preeclampsia: NS in rates of GHT & preeclampsia (grp 1 vs. grp 2); NS BP (grp 1 vs. grp 2)
| • Schulz: Adequate | Exclusion criteria: | | | • IUGR: NS in birth wt & % IUGR
| | NR
| | Enrolled/Completed: n=579/569
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Olsen, 2000, Denmark* | • RCT Prallel Design | Inclusion criteria: | Fish oil (Pikasol) (n=44) vs. placebo (Olive oil) (n=35) | 9 gelatine capsules/d, 32% EPA, 23% DHA, 2mg vit E; 6.1 g of LCPUFA/d | • Duration of gestation: NS in GA | Concerted Action & PECO programmes of European Commission, Danish National Research Foundation, Lube Ltd
{66} | • Jadad total: 2 [Grade: C] | Women > 16 wk of gestation, threatening preeclampsia current pregnancy
| • Schulz: Adequate | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=79/NR
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Olsen, 2000, Denmark* | • RCT Parallel Design | Inclusion criteria: | Fish oil (Pikasol) (n=36) vs. placebo (Olive oil) (n=27) | 9 gelatine capsules/d, 32% EPA, 23% DHA, 2mg vit E; 6.1 g of LCPUFA/d | • Duration of gestation: S↑ GA in fish oil gp | Concerted Action & PECO programmes of European Commission, Danish National Research Foundation, Lube Ltd
{66} | • Jadad total: 2 [Grade: C] | Women > 16 wk of gestation, suspected IUGR (<10^th^ PC in U/S) | | | • IUGR, birth weight: NS in birth wt & % IUGR
| • Schulz: Adequate | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=63/NR
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Onwude, 1995, UK | • RCT Prallel Double-blind | Inclusion criteria: | Max EPA (EPA+ DHA form fish oil) (n=113) vs. placebo (olive oil)(n=119) | 2.7 g/d (EPA 180 mg, DHA 120 mg), 9 capsules/d until 38 wk GA | • Duration of gestation: NS in GA; NS in % premature deliveries | Yorkshire Region Locally Organised Research, GLAXO & Seven Seas
{480} | • Jadad total: 5 [Grade: A] | Primigravida with abnormal Doppler at 24 wks GA; multigravida with hx of small babies (<PC 3), proteinuric or non-poteinuric GHT or unexplained stillbirth | | | • Proteinuric or non-poteinuric GHT: NS rate of GHT (grp 1 vs. grp 2)
| • Schulz: Adequate | Exclusion criteria: | | | • IUGR, birth weight: NS in birth wt & IUGR recurrence rate (grp 1 vs. grp 2)
| | Hx of diabetes, chronic hypertension, asthma, use of anticoagulants
| | Enrolled/Completed: n=233/230
| | Mean Age:
| | • Maternal: Fish Oil =26.8 y; pb =26.1 y
| | • Child: NR
Ponder, 1992, US | • RCT Parallel | Inclusion criteria: | Similac (soy) formula (n=11) vs. Similac (corn) formula (n=14) vs. HM (RS) (n=18) | 101–125 kcal/kg/d Soy: 4.8g ALA (n-3) vs. Corn: 0.8g ALA during 8 wks | • Growth patterns: NS in wt, L, HC at 3d, 4wk, 8 wks | Ross Laboratories
{1354} | • Jadad total: 1 [Grade: C] | Healthy term infants, 37–42 wk gestation, wt, L & HC btw 5–95^th^ PC
| • Schulz: Unclear | Exclusion criteria:
| | NR
| | Enrolled/Completed: n=NR/43
| | Mean Age:
| | • Maternal: NR
| | • Child: 3 d
Smuts, 2003, US | • RCT Parallel | Inclusion criteria: | DHA-enriched eggs (n=18) vs. ordinary eggs (n=19) vs. placebo | DHA-enriched eggs (135mg DHA/egg); ordinary eggs (18mg DHA/egg) from wk 24–28 until delivery | • Duration or gestation: NS in GA; high | Martek Biosciences Boulder Corporation, Boulder, Colorado
{2896} | • Jadad total: 2 [Grade: C] | Between 24–28 wk pregnant; between ages of 16–35 yr at time of enrollment; were accessible by phone & planned to deliver at study hospital | | | • Birthweight, SGA: Wt, L, & HC at birth ↑ in grp 1 vs. grp 2 (p-value: NR)
| • Schulz: Unclear | Exclusion criteria:
| | Chronic illness, pregnancy induced hypertension, pre-eclampsia, pregnancy induced diabetes, or more than 4 prior pregnancies
| | Enrolled/Completeed: n=73/53
| | Mean Age:
| | • Maternal: low = 21.3 ± 4.8 y; regular = 24.8 ± 7.8 y; high 19.9 ± 4.1 y
| | • Child: NR
Smuts, 2003, US | • RCT Parallel Double-blind Jadad total: 3 [Grade: B] | Inclusion criteria: | DHA-enriched eggs (n=176) vs. ordinary eggs (n=174) | 12 DHA-eggs (133 mg DHA) per wk until birth | • Duration of Gestation: S↑ in GA in High-DHA vs Regular-DHA; NS in premature delivery rate | Omega Tech Inc.
{31} | • Schulz: Inadequate | Pregnant women 16–36 y of age, 24–28 wk of gestation at enrollment, able & willing to consume eggs, access to refrigeration, plan to deliver at Truman Medical Center, singleton gestation | | | • Birth wt, L, HC at birth: NS, NS rate of LBW
| | Exclusion criteria: | | | • Incidence of preeclampsia: NS (grp 1 vs. grp 2)
| | <16 or >36 y of age, weight > 240 lb at baseline, serious illness such as cancer, lupus, hepatitis, serious infectious disease, diabetes or gestational diabetes at baseline, high BP attributed to any cause | | | • BMK: S (+) correlation between infant RBC DHA & GA; NS correlation between maternal RBC DHA & GA
| | Enrolled/Completed: n=350/291
| | Mean Age:
| | • Maternal: Ordinary eggs = 21.6 y (4.2); High-DHA eggs = 21.y Y(4.3)
| | • Child: Ordinary eggs = 271.6 d (15.6); DHA eggs = 274.1 d (13.5)
Vanderhoof, 2000, US | • RCT Parallel Double-Blind | Inclusion criteria: | LCPUFA formula (microbial fermentation) (n=77) vs. crtl formula (n=78) vs. HM (RS) (n=133) | Preterm formula 0.5% AA + 0.35% DHA until 48 wks PCA, then term formula until 92 wks PCA, ad libitum | • Growth patterns: S↑ wt, L, HC, MAC in LCPUFA & crtl than in HM at 40 wk PCA; NS in L, HC at 48 wks PCA; S↑ L, MAC in LCPUFA than in HM at 48 wks PCA; NS in wt, L, HC at 92 wks PCA | Wyeth Nutritionals International
{2143,182,1752} | • Jadad total: 4 [Grade: A] | Premature infants 0–28 d of age, medically stable, BW between 750–2,000g appropriate for GA, had received enteral feedings < 24 h
| • Schulz: Adequate | Exclusion criteria:
| | Significant acute or chronic illnesses, systemic infections, documented major congenital infections, intraventricular hemorrhage more than grade 2, periventricular leukomalacia, neonatal seizures, neonatal meningitis, or maternal substance abuse, BF infants whose mothers were vegans or had hx of metabolic disease that would affect essential fatty acid status were excluded
| | Enrolled/Completed: n=288/153
| | Mean Age:
| | • Maternal: NR
| | • Child: PCA at enrollment: LCPUFA formula = 31.2 ± 2.3 wk; Ctrl Formula = 30.9 ± 2.6 wk; HM = 30.5 ± 2.4 wk
van Wezel-Meijler, 2002, Netherlands | • RCT Parallel Double-blind | Inclusion criteria: | LC PUFA supplemented formula (microalgae, fungi) | Preterm formula: from 2–3 wks of age to 3,000g wt, then Term formula until 6 mo CA | • Bayley's PDI & MDI: S↑ PDI unsupplemented gp vs. supplemented formula at 3, 6, 12 & 24 mo; NS Bayley's MDI at 3, 6, 12 & 24 mo | Numico Research
{40} | • Jadad total: 5 [Grade: A] | Premature infants with gestational age < 34 wk, BW of < 1750 g, normal neurological examination throughout the neonatal period; normal repeated brain ultrasound or showing minor abnormalities such as isolated subependymal haemorrhage & subventricle, with no ventricular dilation; transient periventricular echodensities, without evolution into cysts; any combination of previous findings | (n=22) vs. | | • VEP: NS in VEP (P200 & N300) wave latencies at 3 & 12 mo CA
| • Schulz: Adequate | Exclusion criteria: | Control formula | | • Teller card test: NS mean visual acuity at 3,6,12 mo CA
| | Abnormalities of the CNS (excluding items on inclusion criteria), either congenital or acquired; abnormal neurologic examination; seizure; any systemic disease with potential negative influence on future growth or development (chronic lung disease, congenital abnormalities of other organs than the brain; metabolic disease; congenital infections & endocrine dysfunction; serious nutritional or GI problems preventing initiation of enteral feeding after the first wk of life or complete enteral feeding after the 3^rd^ wk of life | (n=20)
| | Enrolled/Completed: n=55/42
| | Mean Age:
| | • Maternal:
| | • Child: FF control = 30.4 wks
Willatts, 1998, UK | • RCT Parallel | Inclusion criteria: | LCPUFA formula (DHA+AA derived from Egg-TG) (n=27) vs. Crtl formula (n=31) | LCPUFA formula (0.15–0.25 wt% DHA, 0.30–0.40 wt% AA) for 4 mo; | • Growth patterns: NS wt, L, HC at 3 mo | Milupa Ltd.
{2307,2293} | • Jadad total: 3 [Grade: B] | Healthy term infants weight 2,500–4,000 g; gestation 37–42 wk | | | • Cognitive function assessment (3 mo): NS
| • Schulz: Unclear | Exclusion criteria: | | | • Problem solving assessment (9 mo): NS
| | NR
| | Enrolled/Completed: n=58/40
| | Mean Age:
| | • Maternal: Gp 1= 26.2 ± 4.2 y; Gp 2 = 27.7 ± 4.6 y
| | • Child: Gp 1 = 274.2 ± 2.7 d, Gp 2 = 275.2 ± 5.0 d
Woltil, 1999, Netherlands | • RCT Parallel | Inclusion criteria: | LCPUFA preterm formula ↑ n-3 fish oil (n=13) vs. LCPUFA formula ↓n-3 fish oil (n=13) vs. crtl formula (n=75) vs. HM (RS) (n=27) | ↑ fish oil (EPA 0.34 mol; DPA 0.03 mol; DHA 0.43 mol vs.↓fish oil (per 100 mol: EPA 0.17 mol; DPA 0.02 mol; DHA 0.20 mol) until d 42 life | • Growth patterns: NS inΔwt, ΔL, & ΔHC between LCPUFA | Friesland Nutrition
{275,329} | • Jadad total: 2 [Grade: C] | LBW (< 2500g) either solely BF or solely FF | | | • BMK: S (+) correlation between Δwt, ΔL, ΔHC & plasma - RBC DHA at 1 mo
| • Schulz: Unclear | Exclusion criteria:
| | Blood transfusions; blood products; or parenteral lipids.
| | Enrolled/Completed: n=143/128
| | Mean Age:
| | • Maternal: NR
| | • Child: Formula without LCPUFA = 36 wk; Formula with LCPUFA = 37 wk; HM = 35 wk

d = day(s); ERG = electroretinogram; g = gram(s); HM = human milk; mo = month; n = number of participants; NR = not reported; RCT = randomized control trial; RS = reference standard; TG = triglycerides; UK = United Kingdom; US = United States; VEP = visual evoked potential; wk(s) = week(s); LCPUFA = long-chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; GA = gestational age; AGA = weight appropriate for gestational age; F = feeding formula; GP = growth parameters; TST = triceps skinfold thickness; SST = subscapular skinfold thickness; PDI = psychomotor developmental index; MDI = Mental developmental index; S = statistically significant difference; NS = nonsignificant statistical difference; DQ = developmental quotien; RBC = red blood cells; PE = phosphatidyl ethanolamine; HC = head circumference; wt = weight; L = length; gp(s) = group(s); ctrl(s) = control(s)

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; UK = United Kingdom; US = United States; LCPUFA = long chain poly unsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); PDI = psychomotor developmental index; MDI = Mental developmental index; HC = head circumference; wt = weight; L = length; ctrl(s) = control(s)

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; RCT = randomized control trial; RS = reference standard; TG = triglycerides; UK = United Kingdom; US = United States; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; BAEP = brainstem auditory evoked potentials; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); PDI = psychomotor developmental index; MDI = Mental developmental index; HC = head circumference; wt = weight; L = length; ctrl(s) = control(s)

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; US = United States; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; VLBW = very low birth weight; FPL = forced-choice preferential looking; BMK = biomarkers in blood or other tissues; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; TST = triceps skinfold thickness; SST = subscapular skinfold thickness; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); HC = head circumference; wt = weight; L = length; PCA = postconceptional age; RBC = red blood cells; ctrl(s) = control(s)

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; US = United States; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; FPL = forced-choice preferential looking; BMK = biomarkers in blood or other tissues; NICU = neonatal intensive care unit; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; BRS = behavioral rating scales; ERG = electroretinogram; MDI = mental developmental index; PDI = psychomotor developmental index; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s)

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; PMA = postmenstrual age; BW = birth weight; US = United States; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; TST = triceps skinfold thickness; SST = subscapular skinfold thickness; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); SCO = single cell oil; NICU = neonatal intensive unit care; HC = head circumference; wt = weight; L = length; FPL = forced-choice preferential looking

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported;; hx = history; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; LAEP = latency auditory evoked potentials; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); NCT = nerve conduction tests; HC = head circumference; wt = weight; L = length

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; US = United States; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; V(LBW) = very (low birth weight); PC = percentile; GHT = gestational hypertension; f/u = follow-up; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); IUGR = intrauterine growth retardation; wt = weight

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; US = United States; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; V(LBW) = very (low birth weight); FPL = forced-choice preferential looking; BMK = biomarkers in blood or other tissues; GI = gastrointestinal; PC = percentile; ROP = retinopathy of prematurity; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); PCA = postconceptional age; HC = head circumference; wt = weight; L = length

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; RCT = randomized control trial; TG = triglycerides; US = United States; LCPUFA = long chain polyunsaturated fatty acids; PC = percentile; CA = corrected age; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); IUGR = intrauterine growth retardation; wt-for-L = weight for length; PE = phosphatidyl ethanolamine; BPD = bronchopulmonary dysplasia; PC = phosphatidylcholyne; HC = head circumference; wt = weight; L = length

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; LCPUFA = long chain polyunsaturated fatty acids; V(LBW) = very (low birth weight); GHT = gestational hypertension; ↑ = increase/greater; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); MDI & PDI = Bayley's Mental and Psychomotor Indexes; SCO = single cell oil; GP = growth patterns

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trialTG = triglycerides; LCPUFA = long chain polyunsaturated fatty acids; GHT = gestational hypertension;; ↑ = increase/greater; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); BW = birth weight

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month(s); y = year(s); n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized crtl trial; RS = reference standard; TG = triglycerides; LCPUFA = long chain polyunsaturated fatty acids; BMK = biomarkers in blood or other tissues; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s):; GP = growth patterns; HC = head circumference; wt = weight; L = length

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month(s); y = year(s); n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; BAEP = brainstem auditory evoked potentials; BMK = biomarkers in blood or other tissues; PCA = postconceptional age; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; RCT = randomized control trial; RS = reference standard; LCPUFA = long chain polyunsaturated fatty acids; VLBW = very low birth weight; UK = United Kingdom; ↑ = increase/greater; PCA = postconceptional age; MDI & PDI = Bayley's Mental and Psychomotor Indexes; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; SD = standard deviation; CA = corrected age

g = gram(s); h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; RCT = randomized control trial; RS = reference standard; LCPUFA = long chain polyunsaturated fatty acids; UK = United Kingdom; MDI & PDI = Bayley's Mental and Psychomotor Indexes; NICU = neonatal intensive care unit; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; GP = growth patterns

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; RCT = randomized control trial; RS = reference standard; TG = triglycerides; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; BAEP = brainstem auditory evoked potentials; VLBW = very low birth weight; BMK = biomarkers in blood or other tissues; UK = United Kingdom; MDI & PDI = Bayley's Mental and Psychomotor Indexes; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; US = United States; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); IV = intravenous; GP = growth patterns; CA = corrected age

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; LCPUFA = long chain polyunsaturated fatty acids; BMK = biomarkers in blood or other tissues; US = United States; PCA = postconceptional age; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; K-ABC = Kaufman assessment battery for children; PC = phosphatidylcholine; PE = Phosphatidylethanolamine; HC = head circumference; EEG = electroencephalogram; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; ERG = electroretinogram; RCT = randomized control trial; RS = reference standard; TG = triglycerides; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; NIH = National Institute of health; FPL = forced-choice preferential looking; BMK = biomarkers in blood or other tissues; US = United States; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; SCO = single cell oil; NIC = neonatal intensive care; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; NICU = neonatal intensive unit care; BW = birth weight

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; VLBW = very low birth weight; US = United States; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; SCO = single cell oil; PMA = postmenstrual age; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; SGA = small for gestational age; PE = Phosphatidylethanolamine; FPL = forced-choice preferential looking

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; hx = history; tx = treatment; GA = gestational age; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; VLBW = very low birth weight; US = United States; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; PMA = postmenstrual age; CSHPCo = Canola, Safflower, High oleic sunflower, Palm starin, Coconut oils; LA = linoleic acid; ALA = α-linolenic acid; GI = gastrointestinal; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; MDI = mental developmental index; PDI = psychomotor developmental index

NRICGP = National Research Initiative Competitive Grants Program; h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; RCT = randomized control trial; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; BW = birth weight; US = United States; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; SCO = single cell oil; PMA = postmenstrual age; LA = linoleic acid; ALA = α-linolenic acid; GI = gastrointestinal; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; BMK = biomarkers correlations

NRICGP = National Research Initiative Competitive Grants Program; h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; BW = birth weight; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; PMA = postmenstrual age; LA = linoleic acid; GI = gastrointestinal; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; RS = reference standard; PCA = postconceptional age

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; BW = birth weight; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; CA = corrected age; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; GP = growth patterns

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; RCT = randomized control trial; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; MDI = mental developmental index; PDI = psychomotor developmental index; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; MAC = mid arm circumference; KPS = Knobloch, Passmark, and Sherrard's test; ETOH = alcohol abuse

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; GA = gestational age; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; RCT = randomized control trial; VEP = visual evoked potential; LCPUFA = long chain polyunsaturated fatty acids; DHA = docosahexaenoic acid; AA = arachidonic acid; LA = linoleic acid; ALA = α-linolenic acid; PL = phospholipids; CSHPCo = Canola, Safflower, High oleic sunflower, Palm starin, Coconut oils; MDI = mental developmental index; PDI = psychomotor developmental index; IDDM = insulin dependant diabetes mellitus; ETOH = alcohol abuse; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); HC = head circumference; wt = weight; L = length

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; ERG = electroretinogram; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; UK = United Kingdom; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; GI = gastrointestinal; PL = phospholipids; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; PMA = postmenstrual age; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; BW = birth weight; US = United States; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; IV = intravenous; NICU = neonatal intensive care unit; TPN = total parental nutrition; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; SD = standard deviation

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; UK = United Kingdom; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; NICU = neonatal intensive care unit; * = completers; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; MAC = mid arm circumference; SST = subscapular skinfold thickness; TG = triglycerids

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; UK = United Kingdom; DHA = docosahexaenoic acid; AA = arachidonic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; MDI = mental developmental index; PDI = psychomotor developmental index; RS = reference standard

GCRC = General Clinical Research Centers; h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; BP = blood pressure; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

GCRC = General Clinical Research Centers; h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; BP = blood pressure; * Scotland, Sweden, UK, Italy, The Netherlands, Norway, Belgium & Russia; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); IUGR = intrauterine growth retardation

GCRC = General Clinical Research Centers; h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; BP = blood pressure; * Scotland, Sweden, UK, Italy, The Netherlands, Norway, Belgium & Russia; PC = percentile; IUGR = intrauterine growth retardation; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); GHT = gestational hypertension

GCRC = General Clinical Research Centers; h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; BP = blood pressure; * Scotland, Sweden, UK, Italy, The Netherlands, Norway, Belgium & Russia; PC = percentile; pb = placebo; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); IUGR = intrauterine growth retardation

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; BP = blood pressure; PC = percentile; pb = placebo; HC = head circumference; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); LBW = low birth weight

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; BP = blood pressure; pb = placebo; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; LBW = low birth weight

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; DHA = docosahexaenoic acid; AA = arachidonic acid; PCA = postconceptual age; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; MAC = mid arm circumference; BW = birth weight

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; CNS = central nervous system; GI = gastrointestinal; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s); BW = birth weight; MDI = mental developmental index; PDI = psychomotor developmental index; VEP = visual evoked potentials; CA = corrected age

h = hour(s); d = day(s); wk(s) = week(s); mo = month; y = year; n = number of participants; NR = not reported; hx = history; tx = treatment; GA = gestational age; FF = formula fed; BF = breast fed; HM = human milk ; S = significant; RCT = randomized control trial; LCPUFA = long chain polyunsaturated fatty acids; GLA = gammalinolenic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; EPA = eicosapentanoic acid; LA = linoleic acid; ALA = α-linolenic acid; BP = blood pressure CA = corrected age; UK = United Kingdom, ↑ = increase; ↓ = decrease; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length; BMK = biomarkers correlations;

Evidence Table 2. Evidence from observational studies for omega-3 fatty acids in child and maternal health

Author, Year, Location | Study Design | Population Characteristics | Exposure | Timing & Dose of exposure (if appropriate) | Clinical Outcomes Results | Funding Source
Agostini, 2001, Italy | • Single prospective cohort | Inclusion criteria: | HM | HM (FA composition NR) for ≥6 mo vs. HM for <6 mo | • Bayley's PDI & MDI at 12 mo: NS correlation between Bayley's PDI & length of BF; NS correlation between Bayley's PDI & milk FA content; S correlation between Bayley's MDI & milk total fat content at 6 mo, but NS at 12 mo; NS AA, DHA milk content correlation with MDI at 12 mo | NR
{98} | • Quality score: 8 [Grade A] | Healthy term infants, exclusively BF for at least 3 mo
| | Exclusion criteria:
| | NR
| | Enrolled: n=44
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Al, 1995, The Netherlands | • Nested case-control study | Inclusion criteria: | N/A | N/A | • BMK: NS in absolute FA composition (mg/L) of maternal plasma PL (before 16, at 22 & 32 wks GA); severe GHT women (n=17) mean GA & mean birth wt of their babies were S ↓ than mild GHT; during gestation & after delivery NS in maternal FA composition of the severe GHT vs. mild GHT | Nutricia B.V, Zoetermeer, The Netherlands
{55,504} | • Quality score: 11 [Grade A] | Pregnant women < 16 wk gestation, cardiovascular, neurologic, renal or metabolic disease at the beginning of pregnancy; women with no hypertension (controls),or with pregnancy induced hypertension (cases), matched for parity and hospital with three crtls
| | Exclusion criteria:
| | Multiple pregnancy
| | Enrolled: n=208
| | Mean Age:
| | • Maternal: NR
| | • Child: NP GA =279.9 d (0.59), PIH GA = 273.3 d (2.18)
Birch, 1993a, US | • Cross-sectional | Inclusion criteria: | HM/corn-oil based formula | NR | • BMK-visual: LogMAR acuity was S correlated with the ratio [DHA n-3/DPA n-6] in total RBC lipids; FPL acuity LogMAR was S correlated with the ratio DHA n-3/DPA n-6; RBC ratio was S ↑ in HM than in formula fed | NIH; Delta Gamma Foundation of Dallas; Pediatric Subunit; & United Cerebral Palsy Foundation
{567} | • Quality score: 4 [Grade B] | Healthy pre-term infants born at 27–33 wk postconception with wirth BW of 1000–1500 g; AGA.
| | Exclusion criteria:
| | Inability to accept enteral feeds by d 10 of life, respiratory tx > 7 d, congenital infection or malformation, retinopathy of prematurity, or grade 3 or 4 intraventricular hemorrhage
| | Enrolled: n=30
| | Mean Age:
| | • Maternal: NR
| | • Child: 27–33 wk
Birch, 1993b, US | • Cross-sectional | Inclusion criteria: | HM/corn-oil based formula | NR | • BMK-visual: Mean VEP & FPL acuities better in HM than in formula (4 mo); mean RBC DHA/DPA in total RBC lipids was S ↑ HM than in formula gp & stereo acuity was S correlated with the end-product ratio; letter matching (36 mo) was S correlated with ratio, RBC DHA/DPA (4 mo) | NIH; Delta Gamma Foundation of Dallas; Pediatric Subunit; & United Cerebral Palsy Foundation
{567} | • Quality score: 4 [Grade B] | Healthy term infants, AGA
| | Exclusion criteria:
| | Inability to accept enteral feeds by d 10 of life, respiratory tx > 7 d, congenital infection or malformation, retinopathy of prematurity, or grade 3 or 4 intraventricular hemorrhage
| | Enrolled: Gp 1, n=30; Gp 2, n=43
| | Mean Age:
| | • Maternal: NR
| | • Child: 27–33 wk
Cetin, 2002, Italy | • Case-control | Inclusion criteria: | N/A | N/A | • Maternal plasma EPA, DHA & AA, (19–39 wk of gestation): S ↑ maternal plasma EPA in IUGR grp than in pb at ≈28.2(8.0) wk GA; NS in maternal plasma DHA & AA at ≈28.2 (8.0) wk GA | European Economic Community ; Italian Ministry of University & Scientific & Technologic Research (MURST) & CNR
{33} | • Quality score: 5 [Grade B] | Pregnancies with AGA & IUGR fetuses
| | Exclusion criteria:
| | Gestational diabetes; pregnancy-induced hypertension
| | Enrolled: n=21
| | Mean Age:
| | • Maternal: gp 1 AGA = 28.2 y; gp 2: IUGR = 29.6 y
| | • Child: NR
Cheruku, 2002, US | • Cross sectional | Inclusion criteria: | N/A | N/A | • Infant sleep-state pattern –maternal BMK: (postpartum d 1 & 2): Maternal DHA was (-) associated with AS, AS:QS & sleep-wake transition (d 2); maternal DHA (+) associated with wakefulness (D2); n-6:n-3 ratio in maternal plasma was (+) associated with AS, AS:QS &sleep-wake transition (d 1); n-6:n-3 ratio in maternal plasma was (-) associated to wakefulness (d 1) | NIH, US Department of Agriculture, the Donaghue Medical Research Foundation, & the University of Connecticut Research Foundation
{73} | • Quality score: 6 [Grade B] | Healthy pregnant women & infants
| | (n=17)
| | Exclusion criteria:
| | Hx of chronic hypertension, hyperlipidemia, renal or liver, heart, thyroid disease, multiple gestations, or pregnancy-induced complications, pts under tx with drugs during labor affecting respiration of new borns such as magnesium sulfate, & butorphanal, any infants with <4 h of crib time in the 1^st^ & 2^nd^ d postpartum
| | Enrolled: n=17
| | Mean Age
| | • Maternal: High-DHA = 29.20 (5.2) y; low-DH A= 24.28 (5.12) y
| | • Child: High-DHA = 40.4 (0.96) wk; low-DHA = 39.0 (1.86) wk
Craig-Schmidt, 1994, US | • Cross sectional | Inclusion criteria: | N/A | N/A | • BMK: NS among gps in plasma saturated, monosaturated & PUFAs; NS in n-6 or n-3 FA between normal pregnancies & GHT, preeclamsia or CHT; CHT S ↑ AA in plasma PL vs. other gps; NS in plasma PL EPA among the gps; NS in AA/EPA ratio & n-6/n-3 ratio | NR
{503} | • Quality score: 2 [Grade C] | Healthy nulliparous women
| | Exclusion criteria:
| | NR
| | Enrolled: n=36
| | Mean Age:
| | • Maternal: 21 ± 6 y
| | • Child: NR
Elias, 2000, Canada | • Single prospective cohort | Inclusion criteria: | Maternal intake of LCPUFAs during pregnancy | 13.6+-0.9 g/d LCPUFAs at 28 wk of gestation; 12.1± 0.6 g/d LCPUFAs at 35 wk gestation; | • BMK: Maternal plasma TGL AA, S (+) correlated to infant birth wt & L | Molly Towell Perinatal Research Foundation & the National Science & Engineering Research Council of Canada
{143} | • Quality score: 6 [Grade B] | Healthy pregnant women (from 22–24 wk gestation until delivery) & infants
| | Exclusion criteria:
| | Medical or surgical problems influencing lipid metabolism or fetal growth, communicable disease; > 1 fetus, hypermesis, psychological or social problems, illicit drug or alcohol use, cardiac or renal disease, diabetes, epilepsy, respiratory or rheumatoid conditions, cholestasis, hx of high blood cholesterol or tricylglycerol concentrations before pregnancy, HIV infection or AIDS, hepatitis, or tuberculosis
| | Enrolled: n=84
| | Mean Age:
| | • Maternal: NR
| | • Child: GA = 40.0 wk
Ghys, 2002 Netherlands | • Prospective single cohort | Inclusion criteria: | N/A | N/A | • BMK: No correlation between plasma or RBC DHA & AA & cognitive development (4 y) | NR
{38} | • Quality score: 8 [Grade A] | Full-term neonates
| | Exclusion criteria:
| | NR
| | Enrolled: n=128
| | Mean Age:
| | • Maternal: NR
| | • Chid: 47 (1.3) mo
Hofmann, 1998, Germany | • Cross sectional | Inclusion criteria: | N/A | N/A | • BMK: Total FA in plasma TGL during pregnancy were S > in preeclamptic gp vs. crtl; NS between gps in AA plasma TGL during pregnancy; LA (n-6) & DHA (n-3) content in plasma TGL were S ↓ in preeclamptic pts vs. crtls; NS between gps LA & AA (n-6) in plasma PL; DHA plasma PL content was S ↓ in preeclamptic women | NR
{1145} | • Quality score: 6 [Grade B] | Pregnant women with preeclampsia (BP at rest > 140/90 beyond the 20th wk gestation) & healthy pregant women
| | Exclusion criteria:
| | Endocrionological sx affecting the lipide metabolism
| | Enrolled: PE n=14; ctrl n=16
| | Mean Age:
| | • Maternal: PE = 27 y (17–38); ctrl = 28 y (20–39)
| | • Child: PE GA = 36 wk (32–40); ctrl GA = 37 wk (34–40)
Innis, 1994, Canada | • Cross sectional | Inclusion criteria: | HM (n=17) vs. CF (n=18) | HM (0.2+-0.02 wt% DHA, 0.1± 0.01 wt% EPA, 0.5± 0.03 wt% AA) from 14± 2 d to ≥3 mo | • Visual acuity: NS between gps in visual acuity test (14 d & 3 mo) | British Columbia Children's Hospital Investigatorship (SMI)
{521} | • Quality score: 5 [Grade B] | Full term infants (> 37 wk GA at birth), AGA, & if mother decided to BF or FF for >/= 3 mo | | | • BMK: Visual acuity NS to diet or plasma PL, RBC PC or PE concentrations of DHA on entire gp of infants or within the breastfed or formula-fed gp of infants
| | Exclusion criteria:
| | NR
| | Enrolled: n=35
| | Mean Age:
| | • Maternal: NR
| | • Child: BF GA = 39.5 ± 1.0 wk, FF GA = 39.1 ± 1.0 wk
Innis, 2001, Canada | • Prospective single cohort | Inclusion criteria: | HM | HM for at least 3 mo | • BMK: RBC PE DHA (2 mo) was S (+) correlated to visual acuity at 2 & 12 mo, NS at 4 & 6 mo; Infants with RBC PE DHA <8.53g/100g had S ↓ visual acuity at 2 & 12 mo than infants with > 10.78g/100g FA; No correlation between plasma or RBC DHA & AA & cognitive development (4 y) | Medical Research Council (MRC) of Canada & Ross Laboratories, Columbus, Ohio
{112} | • Quality score: 8 [Grade A] | Mothers who committed to only BF heatlhy term infants (no formula or cow's milk) from at least 3 mo, no solid food for at least 1^st^ 4 mo after birth
| | Exclusion criteria:
| | Mothers with substance abuse, metabolic or physiologic problems, infections likely to influence fetal growth, or multiple births & infants with evidence of metabolic or physical abnormality
| | Enrolled: n=83
| | Mean Age:
| | • Maternal: 32.2 y
| | • Child: NR
Jorgensen, 1996, Sweden | • Cross sectional | Inclusion criteria: | HM (n=17) vs. CF (n=16) | HM (0.49+-0.20 to 0.53+-0.56 wt% DHA; 0.13+-0.07 to 0.23+-0.35 wt% EPA; 0.56+-0.12 to 0.44+-0.09 wt% AA) for 4 mo | • BMK: NS correlation between RBC DHA & visual between gps (4 mo); NS correlation between AA levels & visual acuity | Food Technology Research & Development Program (FOTEK),
{422} | • Quality score: 5 [Grade B] | Healthy term AGA BF & FF infants; age: 37–42 wk (n=33) | | | • Visual acuity at 2, 4 mo: Visual acuity S ↑ overtime in both feeding gps, S ↑ increase in HM grp | DanoChemo A/S
| | Exclusion criteria: | | | | Swedish Medical Research Council
| | Major congenital anomaly, severe intra/peri venticular haemorrhage or 5-min APGAR score < 5
| | Enrolled: n=33
| | Mean Age:
| | • Maternal: NR
| | • Child: LBM gp = 28.4 wk; HBM = 28.5 wk
Jorgensen, 2001, Denmark | • Cross-sectional study | Inclusion criteria: | HM | HM (0.35+-0.20 wt% DHA, 0.39+-0.07 wt% EPA, 0.30+-0.07 wt% AA) for ≥14 wk; | • BMK: NS association between AA, EPA, LA & ALA (n-3) with visual acuity | Food Technology Research & Development Program (FOTEK)
{2207} | • Quality score: 9 [Grade A] | Term delivery (37–42 wk); normal BW for GA; uncomplicated pregnancy, delivery, & neonatal period; Apgar score > 8 after 5 min; & fully BF at time of examination (no energy drinks & < 100 mL fromula /d) | | | • HM LA, ALA, AA, EPA & DHA & correlation with visual acuity: S association between visual acuity (VEP) at 4 mo & mother's milk DHA | BASF Health and Nutrition A/S
| | Exclusion criteria:
| | SGA (< 10^th^ PC of BW); strabismus, operation of pyloric stenosis
| | Enrolled: n=39
| | Mean Age:
| | • Maternal: 30.5 (3.9) y
| | • Child: 39.8 (1.2) wk
Krasevec, 2002, Cuba | • Cross sectional | Inclusion criteria: | High-fat fish maternal intake during pregnancy; HM (n=31), Formula+HM (n=22), Formula (n=3) | 454 g/wk maternal fish intake | • Visual acuity scores 99% prediction for 2.5 mo old infants; NS Mean values for visual acuity between HM vs. HM + formula infants | Canadian Bureau of International Education
{72} | • Quality score: 7 [Grade B] | Normal pregnancy, with no medical risks affecting fatty acid metabolism, including heart disease, kidney disease, gestational or other diabetes, hypertension, gallbladder disease, or thyroid disease; resident of Central or Old Havana; ages or 17 to 36 y | | | • BMK: NS correlation visual acuity & any PUFA concentration, ratio of PUFA or gps of PUFAs in infant tissues; NS correlation for full sample & each feeding gp (i.e., exclusively breast milk vs. not exclusively breastfed); NS correlation between PUFA profiles of maternal tissues for exclusively breastfed infants & visual acuity | Vistech Consultants, Dayton Ohio
| | Exclusion criteria:
| | NR
| | Enrolled: n=56
| | Mean Age:
| | • Maternal: f/u gp = 26.8 (4.0) y; ot-f/u gp = 26.9 (5.3) y
| | • Child: f/u gp GA = 40.4 (1.5) wk; not-f/u gp GA = 40.2 (1.1) wk
Leaf, 1996, Australia | • Cross sectional | Inclusion criteria: | HHM (n=9) vs. LHM (n=9) | HM (32 mg/kg/d AA, 17 mg/kg/d DHA) ± “Intralipid 20%” (6.4 mg/kg/d AA, 5.8 mg/kg/d DHA) from birth up to 40 wk PCA | • BMK: S (+) correlation between scotopic b wave implicit time & % DHA in plasma & RBC PL, total n-3 in plasma & RBC PL; S (+) correlation between RBC AA & total n-6 FA & scotopic a-b amplitude; NS relationships were seen between photopic ERGs & plasma or RBC LCPUFAs | NR
{402} | • Quality score: 6 [Grade B] | Healthy preterm infants < 32 wk GA
| | Exclusion criteria:
| | Major congenital anomaly, severe intra/peri venticular haemorrhage or 5-min apgar score < 5
| | Enrolled: n=18
| | Mean Age:
| | • Maternal: NR
| | • Child: LBM = 28.4 wk; HBM = 28.5 wk
Makrides, 1993, Australia | • Cross sectional | Inclusion criteria: | HM (n=8) vs. CF (>70% nutrition from formula)+HM (n=8) | NR | • Visual acuity: HM gp S ↓ logMAR (i.e., better VEP acuity) than formula-fed (5 mo) | Scotia Pharmaceuticals & Nestle Australia
{560} | • Quality score: 4 [Grade B] | Healthy infants born at term with appropriate weight for GA & were approximately 5 mos of age. | | | • BMK: S correlation between logMAR (VEP acuity) & % DHA & LA in RBC PL
| | Exclusion criteria:
| | NR
| | Enrolled: n=16
| | Mean Age:
| | • Maternal: NR
| | • Child: BF = 22.4 (± 3.7) wk; FF = 22.3 (± 4.3) wk
Matorras, 1994, Spain | • Case-control | Inclusion criteria: | N/A | N/A | • BMK: S ↑ maternal plasma EPA in IUGR grp than in pb at delivery; NS in maternal plasma DHA & AA at delivery | Basque Country Government
{494} | • Quality score: 9 [Grade A] | Healthy women at labor with term IUGR & their singleton infants; no malformations or chromosomal abnormalities; no antepartum death; accordancy of GA & pediatric evaluation by means of Dubowitz test & neonatal weight < 10^th^ PC for GA for geographic area (cases); healthy women at labor with term AGA births, neonatal weight > 10^th^ PC (control)
| | Exclusion criteria:
| | NR
| | Enrolled: Mother n=69; infants n=51
| | Mean Age:
| | • Maternal: IUGR = 28.4 ±6.4 y Ctrl = 26.2 ± 6.2 yr
| | • Child: IUGR GA = 39.1 ±1.4 wk; Ctrl GA = 39.4 ±1.3 wk
Reece, 1997 US | • Case-control | Inclusion criteria: | N/A | N/A | • Maternal BMK: RBC LA, AA, DHA S ↑ in preterm vs. 34-wk control+ & term; RBC EPA S ↑ in term controls vs. both preterm & 34-wk control; RBC & plasma n-3/n-6 ratio was S ↑ in term controls vs. preterm; NS RBC n-3/n6 between preterm & 34-wk control; plasma LA S ↑ in preterm & 34-wk crtl vs. term crtl; plasma LA, AA, EPA S ↑ in preterm vs. term crtls | Colorado Agricultural Experiment Station
{53} | • Quality score: 4 [Grade C] | Healthy preterm infants; mean GA 33.9±0.6 wk, (cases); term infants; mean GA 40.2±0.2 wk (control)
| | Exclusion criteria:
| | Cases (preterm): recognised causes of preterm birth, including uterine abnormalities, intrauterine infection, substance abuse, multiple gestations, pregnancy-onset hypertension, or other medical disorders; Controls (term): recognized medical problems, multiple gestations, multiple parity, pregnancy-onset hypertension, recognized substance abuse
| | Enrolled: n=71
| | Mean Age:
| | • Maternal: Cases = 22 y; Controls = 24 y
| | • Child: Cases GA = 40.2 wk; Controls GA = 33.9 wk
Rocquelin, 2003, Congo, Burkina Faso | • Cross-national | Inclusion criteria: | HM | HM from Congo (0.15+-0.07 wt% DHA, 0.12+-0.06 wt% AA) vs. HM from Burkina Faso (0.08+-0.05 wt% DHA, 0.21+-0.08 wt% AA) for 5 mo | • Growth patterns: S↓ wt-for-age & wt-for height z-scores & wt gain (g) in Burkina Faso than in Congo; NS birth wt, age, wt gain of predominantly breastfed to complementary fed infants in Burkina Faso | Institut National de la Recherche Agronomique
{3} | • Quality score: 5 [Grade B] | Healthy term infants from Congo & healthy term infants from Burkina faso
| | Exclusion criteria:
| | NR
| | Enrolled: Congo n=102; Burkina faso n=101
| | Mean Age:
| | • Maternal: NR
| | • Child: Congo = 4.9 (± 0.3) mo; Burkina faso = 5.1 (± 0.2) mo
Rump, 2001, Netherlands | • Cross-sectional | Inclusion criteria: | N/A | N/A | • BMK: NS correlation between maternal plasma FA at 11 (8) wk GA & at delivery & GA | Dutch Organization for Scientific Research; University Hospital of Maatricht. FA analysis by Nutricia Research, Zoetemeer, Netherlands
{144} | • Quality score: 9 [Grade A] | Healthy singleton term infants, GA of< 16 wk at entry, a diastolic BP < 90mm Hg, & no signs of cardiovascular, neurologic, renal or metabolic disorders at the time of recruitment
| | Exclusion criteria:
| | Infants with unknown gestational age or BW, born prematurely, or who died & of mothers with diabetes or pregnancy-induced hypertension.
| | Enrolled: n=627
| | Mean Age:
| | • Maternal: SGA: 28.9 (± 4.1) y; AGA 10–25 PC: 28.9 (± 4.6) y; 25–75 PC: 29.5 (± 4.2); 75–90 PC: 29.3 (± 4.2y); LGA: 29.4 (± 3.9) y
| | • Child: SGA: 40.1 (± 1.3) wk; AGA 10–25 PC: 40.0 (±1.0) wk; AGA 25–75 PC: 40.1 (± 1.2) wk; AGA 75–90 PC: 40.6 (± 1.2) wk; LGA: 40.4 (± 1.3) wk
Shouk, 1999, Egypt | • Case-control | Inclusion criteria: | N/A | N/A | • BMK: AA in plasma was S > in preeclamptic women vs. crtl; NS between gps LA & ALA (n-3) content | NR
{243} | • Quality score: 7 [Grade B] | Pregnant women with severe preeclampsia in 3^rd^ T; healthy pregnant women without proteinuria or hx of renal disease, not on medications & no hx of obstetric complications
| | Exclusion criteria:
| | NR
| | Enrolled: n=45
| | Mean Age:
| | • Maternal: Preeclampsia gp: 29 (20–40) y
Vilbergsson, 1991, Sweden | • Cross sectional | Inclusion criteria: | N/A | N/A | • BMK: S↓ maternal plasma DHA & AA in SGA grp than in crtl at 34 weeks GA & at delivery | Gothenburg Medical Society; Gothenburg Masonic Order Orphanage Foundation; Faculty of Medicine, Gothenburg University
{633,505} | • Quality score: 7 [Grade B] | Healthy pregnant women at risk of IUGR (cases); healthy pregnant women at no risk of IUGR (crtl)
| | Exclusion criteria:
| | Diabetics
| | Enrolled: n=48
| | Mean Age:
| | • Maternal: NR
Wang, 1991, US | • Cross sectional | Inclusion criteria: | N/A | N/A | • BMK: Total PUFA, LA (n-6), ALA (n-3) & EPA plasma of normal pregnant women was S > preeclamptic pts; NS between gps plasma AA & DHA; S > EPA & DHA in normal pregnant women vs. nonpregnant | Glaxo, Inc., Research Triangle Park, North Carolina
{59} | • Quality score: 5 [Grade B] | Healthy normal & preeclamptic pregnant women (not on a regimen of aspirin tx) at term & nonpregnant women
| | Exclusion criteria:
| | NR
| | Enrolled: n=30
| | Mean Age:
| | • Maternal: NR
Williams, 2001, UK | • Prospective cohort | Inclusion criteria: | N/A | N/A | • Stereoacuity (3.5 y): BF was S correlated to foveal (adult) stereacuity; maternal oily fish intake during pregnancy was S correlated with foveal stereoacuity | Medical Research Council, Wellcome Trust, Ministry of Agriculture, Food & Fisheries, Departments of Health & Enviroment, Milupa, National Eye Research Centre
{153} | • Quality score: 9 [Grade A] | Healthy full-term BF infants; term infants never BF | | | • BMK: S correlation between child's stereoacuity at 3.5 y & antenatal mother's RBC DHA content
| | Exclusion criteria:
| | Strabilsmus, reduced vision, high refractive error, missing dietary data, GA < 37 wk
| | Enrolled: BF n=101; non-BF n=101
| | Mean Age:
| | • Maternal: NR
| | • Child: NR
Xiang, 2000, Sweden | • Single prospective cohort | Inclusion criteria: | HM | NR | • BMK: LA, ALA in maternal milk S ↑ during 3 mo; DHA in maternal milk S ↓ during 3 mo; AA/DHA in maternal milk S correlated with infants' rate ↑ HC at 1 & 3 mo; AA/DHA in maternal milk S correlated with infants' brain wt gain at 1 & 3 mo | Wenner-Gren Centre Foundation
{202} | • Quality score: 5 [Grade B] | Healthy mother-infant pairs
| | Exclusion criteria:
| | NR
| | Enrolled: n=19
| | Mean Age:
| | • Maternal: 29.5 y
| | • Child: 40.1 wk

N/A = not applicable; US = United States; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); NR = not reported; (A)GA = (appropriate for) gestational age; GA = gestational age; IUGR = intrauterine growth retardation; PIH = pregnancy induced hypertension; HM = human milk; PT = preterm; FT = full term; RBC = red blood cells; FA = fatty acids; PL = phospholipids; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; LA = linoleic Acid; ALA = alpha-linolenic acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; DGLA = dihomo-gama-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

N/A = not applicable; US = United States; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); NR = not reported; (A)GA = (appropriate for) gestational age; GA = gestational age; IUGR = intrauterine growth retardation; PIH = pregnancy induced hypertension; HM = human milk; PT = preterm; FT = full term; RBC = red blood cells; FA = fatty acids; PL = phospholipids; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; LA = linoleic Acid; ALA = alpha-linolenic acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; DGLA = dihomo-gama-linolenic acid; BF = breast fed; tx = treatment; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s)

N/A = not applicable; US = United States; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); g = grams; NR = not reported; N/A = not applicable; AGW = infants with appropriate gestational weight; GA = gestational age; HM = Human milk; (B)W = (birth) weight; (B)L = (birth) length; RBC = red blood cells; (LC)PUFA = (long chain) polyunsaturated fatty acids; PE = phosphatidylethanolamine; FA = fatty acids; LA = linoleic Acid; ALA = alpha-linolenic acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; DGLA = dihomo-gama-linolenic acid; tx = treatment; IUGR = intrauterine growth retardation; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

N/A = not applicable; US = United States; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); g = grams; NR = not reported; N/A = not applicable; AGW = infants with appropriate gestational weight; GA = gestational age; HM = Human milk; (B)W = (birth) weight; (B)L = (birth) length; (LC)PUFA = (long chain) polyunsaturated fatty acids; PE = phosphatidylethanolamine; FA = fatty acids; LA = linoleic Acid; ALA = alpha-linolenic acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; DGLA = dihomo-gama-linolenic acid; hx = history; HIV = human immuno-deficiency virus; AIDS = acquired immune deficiency syndrome; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

N/A = not applicable; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); g = grams; NR = not reported; (A)GA = (appropriate for) gestational age; GA = gestational age; PCA = post-conceptual age; HM = human milk; PT = preterm; BF = breast fed; FF = formula fed; CF = control formula; FT = full term; CA = corrected age; RBC = red blood cells; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; (LC)PUFA = (long chain) polyunsaturated fatty acids; FA = fatty acids; DHA = docosahexaenoic acid; AA = arachidonic acid; DPA = docosapentaenoic acid; HC = head circumference; BP = blood pressure; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); AGA = adequate for gestational age

N/A = not applicable; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); g = grams; NR = not reported; (A)GA = (appropriate for) gestational age; HM = breast milk; BF = breast fed; FF = formula fed; (B)W = (birth) weight; L = length; HC = head circumference; PT = preterm; RBC = red blood cells; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; PC = phosphatidylcholine; PE = phosphatidylethanolamine; (LC)PUFA = (long chain) polyunsaturated fatty acids; FA = fatty acids; PL = phospholipids; DHA = docosahexaenoic acid; LA = linoleic Acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; DGLA = dihomo-gama-linolenic acid; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s)

N/A = not applicable; US = United States; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); g = grams; SEC = socioeconomic class; NR = not reported; (A)GA = (appropriate for) gestational age; IUGR = intrauterine growth retardation; CF = control formula; PIH = pregnancy induced hypertension; HM = breast milk; BF = breast fed; FF = formula fed; (B)W = (birth) weight; L = length; HC = head circumference; PT = preterm; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; PC = phosphatidylcholine; PE = phosphatidylethanolamine; (LC)PUFA = (long chain) polyunsaturated fatty acids; FA = fatty acids; PL = phospholipids; DHA = docosahexaenoic acid; LA = linoleic Acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; DGLA = dihomo-gama-linolenic acid; PC = percentile; f/u = follow-up; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

N/A = not applicable; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); g = grams; NR = not reported; HM = human milk; BF = breast fed; FF = formula fed; (B)W = (birth) weight; (B)L = (birth) length; HC = head circumference; Δ = change; RBC = red blood cells; FA = fatty acids; LA = linoleic Acid; ALA = alpha-linolenic acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; PL = phospholipids; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); ERG = electroretinogram; VEP = visual evoked potential; HHM = high intake of human milk; LHM = low intake of human milk

N/A = not applicable; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); g = grams; NR = not reported; (A)GA = (appropriate for) gestational age; IUGR = intrauterine growth retardation; RBC = red blood cells; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; PL = phospholipids; PC = percentile; IUGR = intrauterine growth retardation; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

N/A = not applicable; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); g = grams; NR = not reported; (A)GA = (appropriate for) gestational age; SGA = small for gestational age; IUGR = intrauterine growth retardation; HM = human milk; BF = breast fed; FF = formula fed; (B)W = (birth) weight; (B)L = (birth) length; HC = head circumference; BRW = brain weight; Δ = change; GP = growth parameters; RBC = red blood cells; PDI = psychomotor developmental index; MDI = mental developmental index; FA = fatty acids; GLA = gammalinolenic acid; LA = linoleic Acid; ALA = alpha-linolenic acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; PL = phospholipids; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

N/A = not applicable; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); g = grams; WG = weight gain; WFA Z-score = weight-for-age Z-score; WFH Z-score = weight-for-height Z-score; HFA Z-score = height-for-age Z-score; GA = gestational age; NR = not reported; (A)GA = (appropriate for) gestational age; GP = growth parameters; IUGR = intrauterine growth retardation; HM = human milk; CF = control formula; RBC = red blood cells; FA = fatty acids; LA = linoleic Acid; DHA = docosahexaenoic acid; AA = arachidonic acid; BP = blood pressure; hx = history; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

N/A = not applicable; US = United States; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); NR = not reported; N/A = not applicable; HM = human milk; PT = preterm; FT = full term; RBC = red blood cells; HM = human milk; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; (LU)PUFA = (long chain) polyunsaturated fatty acids; LA = linoleic Acid; ALA = alpha-linolenic acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; DGLA = dihomo-gama-linolenic acid; GLA = gamma-liolenic acid; BRW = brain weight; tx = treatment; IUGR = intrauterine growth retardation; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); ctrl(s) = control(s)

N/A = not applicable; US = United States; n = number of participants; y = years; mo= month(s); wk(s) = week (s); d= day (s); hr (s) = hour (s); NR = not reported; N/A = not applicable; HM = human milk; PT = preterm; FT = full term; RBC = red blood cells; HM = human milk; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; (LU)PUFA = (long chain) polyunsaturated fatty acids; LA = linoleic Acid; ALA = alpha-linolenic acid; EPA = eicosapentaenoic acid; DHA = docosahexaenoic acid; AA = arachidonic acid; DGLA = dihomo-gama-linolenic acid; GLA = gamma-liolenic acid; BRW = brain weight; S = statistically significant difference; NS = nonsignificant statistical difference; gp(s) = group(s); RBC = red blood cells; ctrl(s) = control(s); HC = head circumference; wt = weight; L = length

## Safety Profile Tables

### Preterm Infants

Summary Table 1: Studies reporting adverse events (e.g., side effects) and contraindications in relation to dietary intake of omega-3 fatty acids

Author, Year, Location: Length & Design | Study groups | | Safety data
| Group 1 (n)/Group 4 (n) | Group 2(n)/Group 3(n)
Preterm infants
McClead, 1985, US:1-3 wks paralle RCT^ 287 ^ | Safflower oil emulsion ‘high ALA’ (n=10)Φ | Safflower oil emulsion ‘low ALA’ (n=10) | ALA 3 (SD: 1.5)% safflower oil emulsion (high ALA) No adverse events/effects ALA 0.1% safflower oil emulsion (low ALA) Tachycardia: n=1, tachycardia and tachypnea (secondary to presumed sepsis): n=1
Birch, 1992 US: 6 mo parallel RCT ^ 212 ^ | n-3 FA-enriched F soy/marine oil (n=22)/ Non-randomized HM(n=10) | Control F soy oil (n=20)/ Control F corn oil (n=18) | NS diet-induced differences in neonatal morbidity, bleeding time, growth of the LBW infants, or other AE
Koletzko, 1995, Germany: 3 wks parallel RCT ^ 251 ^ | n-3 FA-enriched F primrose oil (n=9) | Control F (n=10)/Non-randomized HM (n=8) | NS between-arm differences in gastric residuals, spitting & abdominal distention (rare occurrence), or other adverse events ascribable to feeding

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; ALA = alpha linolenic acid; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; AA = arachidonic acid; Length = intervention length; Design = research design; n = sample size; pts = study participants; NR = not reported; NS = nonsignificant statistical difference; n/a = not applicable; pb = placebo; grp = group; wk = week(s); mo = month; wt = weight; +p<.05 or significant with 95% confidence interval; ++p<.01; +++p<.001; ++++p<.0001; FA = fatty acids; PD = preterm delivery; LBW = low birth weight; ICU = intensive care unit; SCN = special care nursery; GD = gestational diabetes; HM = human milk; NEC = necrotizing enterocolitis; F = formula ; IVH = Intra-ventricular haemorrhage; PCA: post-conception age; SIDS = sudden infant death syndrome; TG = triglyceride; Φ = completed (otherwise enrolled); AE = adverse events

Summary Table 2: Studies reporting adverse events (e.g., side effects) and contraindications in relation to dietary intake of omega-3 fatty acids

Author, Year, Location: Length & Design | Study groups | | Safety data
| Group 1 (n)/Group 4 (n) | Group 2(n)/Group 3(n)
Preterm infants
Vanderhoof, 1999, US, Canada: 17 wks parallel RCT^ 218 ^ | n-3 FA-enriched F triglycerides derived from microbial fermentation (n=77) | Control F (source NR) (n=78)/Non-randomized HM: (n=133) | [underlined: F (DHA 0.35%) vs. F(control) vs. HM (grp 1 vs. grp 2 vs. grp 3)] [underlined: Events at 48 wks PCA (17 wks of feeding)] Death (due to SIDS & NEC): n=1 vs. n=1 vs. n=0 (NS) Diarrhea: n=10 vs. n=8 vs. n=4; S (grp 1 vs. grp 3)+ Flatulence: n=12 vs. n=3 vs. n=7; S (grp 1 vs. grps 2-3)+ Jaundice: n=5 vs. n=1 vs. n=13; S (grp 2 vs. grp 3)+ Milk intolerance: n=0 vs. n=3 vs. n=0; S (grp 2 vs. grps 1,3)+ Anemia: n=12 vs. n=25 vs. n=28; S (grp 1 vs. grps 2-3)+ [underlined: Events leading to discontinuation at 48 wks PCA] All: n=11 vs. n=11 vs. n=8 (NS) Diarrhea: n=1 (grp 1 vs. grp 2 vs. grp 3) Vomiting n=1 (grps 1-2) vs. n=3 NEC: n=2 (grps 1-2) vs. vs. n=0 Abdominal pain: n=1 vs. n=0 vs. n=1 Ileus: n=2 vs. n=0 vs. n=1 Infections: n=0 vs. n=1 (grps 2-3) Milk intolerance: n=2 vs. n=5 vs. n=1 Cerebral necrosis or hemorrhage: n=0 (grps 1-2) vs. n=1 Rash: n=0 vs. n=1 vs. n=0 Constipation: n=1 vs. n=0 (grps 2-3) Esophageal reflux: n=1 vs. n=0 (grps 2-3) NS between-arm differences in respiratory, cardiovascular, gastrointestinal, hemic, lymphatic, or urogenital system events; n=2 deaths due to SIDS & NEC not diet related [underlined: At 92 wks PCA (60 weeks of feeding)] ≥ 1 AE: 96.1% vs. 93.6% vs. 86.5% Bradycardia: 40.3% vs. 33.3% vs. 37.6% Apnea: 36.4% vs. 24.4% vs. 32.3% Infection: 32.5% vs. 35.9% vs. 23.3% Pharyngitis: 23.4% vs. 20.5% vs. 17.3% Otitis media: 23.4% vs. 19.2% vs. 12.0% Bilirubinemia: 22.1% vs. 11.5% vs. 13.5% Anemia: 19.5% vs. 32.1% vs. 21.8% Flatulence: 16.9% vs. 5.1% vs. 5.3% Vomiting: 15.6% vs. 16.7% vs. 6.8% Hypoxia: 15.6% vs. 11.5% vs. 13.5% Bronchiolitis: 15.6% vs. 7.7% vs. 7.5% Ileus: 14.3% vs. 10.3% vs. 9.8% Oral moniliasis: 14.3% vs. 7.7% vs. 6.0% Diarrhea: 13.0% vs. 15.4% vs. 5.3% Rhinitis: 13.0% vs. 12.8% vs. 6.0% Rash: 13.0% vs. 10.3% vs. 11.3% Cardiovascular event: 11.7% vs. 16.7% vs. 7.5% Enlarged abdomen: 11.7% vs. 10.3% vs. 13.5% Irritability: 11.7% vs. 10.3% vs. 9.8% Increased cough: 11.7% vs. 1.3% vs. 4.5% Pneumonia: 9.1% vs. 14.1% vs. 7.5%

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; ALA = alpha linolenic acid; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; AA = arachidonic acid; Length = intervention length; Design = research design; n = sample size; pts = study participants; NR = not reported; NS = nonsignificant statistical difference; n/a = not applicable; pb = placebo; grp = group; wk = week(s); mo = month; wt = weight; +p<.05 or significant with 95% confidence interval; ++p<.01; +++p<.001; ++++p<.0001; FA = fatty acids; PD = preterm delivery; LBW = low birth weight; ICU = intensive care unit; SCN = special care nursery; GD = gestational diabetes; HM = human milk; NEC = necrotizing enterocolitis; F = formula ; IVH = Intra-ventricular haemorrhage; PCA: post-conception age; SIDS = sudden infant death syndrome; TG = triglyceride; Φ = completed (otherwise enrolled); AE = adverse events

Summary Table 3: Studies reporting adverse events (e.g., side effects) and contraindications in relation to dietary intake of omega-3 fatty acids

Author, Year, Location: Length & Design | Study groups | | Safety data
| Group 1 (n)/Group 4 (n) | Group 2(n)/Group 3(n)
Preterm infants
O’Connor, 2001, US, UK, Chile: 14 mo parallel RCT ^ 207 ^ | n-3 FA-enriched F fish/fungal oil (n=140) | n-3 FA-enriched F egg-TG/fish oil (n=143)/ Control F coconut/safflower oil (n=144) | Between-arm differences in death, chronic lung disease, systemic infection, hospital readmission, and feeding intolerance: NS [underlined: F with fish/fungal oil (DHA 0.27% + EPA 0.08%)] Symptoms of feeding intolerance leading to withdrawal: 14%,died: n=3, serious adverse event (n ≥ 1): 46%, hospital readmission (n ≥ 1): 39% [underlined: F with egg-TG/fish oil (DHA 0.24% + EPA 0%)] Symptoms of feeding intolerance leading to withdrawal: 8%, died: n=6, serious adverse event (n ≥ 1): 47%, hospital readmission (n ≥ 1): 43% [underlined: Control F with coconut/safflower oil (no DHA or EPA)] Symptoms of feeding intolerance leading to withdrawal: 13%, died: n=6, serious adverse event (n ≥ 1): 44%, hospital readmission (n ≥ 1): 38%
Innis, 2002, US, Canada: 4 wks parallel RCT ^ 201 ^ | n-3 FA-enriched F alga/fungal oil (n=66) | n-3 FA-enriched F alga oil (n=66)/ Control F (source NR) (n=62) | Between-arm differences in SAE, retinopathy of prematurity, IVH, NEC, or sepsis: NS [underlined: F with alga/fungal oil (DHA 0.33% + AA 0.60%)] NEC: n=0, sepsis: n=24, SAE: n=4 [underlined: F with alga oil (DHA 0.34%)] NEC: n=2, sepsis: n=31, SAE: n=3, death: n=1 (due to SIDS) [underlined: Control F (source: NR; no DHA, EPA, or AA)] NEC: n=1, sepsis: n=24, SAE: n=4, death: n=1 (due to SIDS)
Clandinin, 2002, Canada, US: 20 wks parallel RCT ^ 193 ^ | n-3 FA-enriched F fish/single-cell oil (n=130) | n-3 FA-enriched F single-cell oil (n=112)/ Control F (source NR) (n=119) | NS between-arm differences in adverse events or concomitant medical conditions Well tolerated, although > infants had gas in grp 2 vs. grp 3 at 40-44 wks PCA, but not at 48-57 wks PCA

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; ALA = alpha linolenic acid; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; AA = arachidonic acid; Length = intervention length; Design = research design; n = sample size; pts = study participants; NR = not reported; NS = nonsignificant statistical difference; n/a = not applicable; pb = placebo; grp = group; wk = week(s); mo = month; wt = weight; +p<.05 or significant with 95% confidence interval; ++p<.01; +++p<.001; ++++p<.0001; FA = fatty acids; PD = preterm delivery; LBW = low birth weight; ICU = intensive care unit; SCN = special care nursery; GD = gestational diabetes; HM = human milk; TG = triglyceride; NEC = necrotizing enterocolitis; F = formula ; IVH = Intra-ventricular haemorrhage; PCA: post-conception age; SIDS = sudden infant death syndrome; AE = adverse events; SAE = serious adverse events Φ = completed (otherwise enrolled)

Summary Table 4: Studies reporting adverse events (e.g., side effects) and contraindications in relation to dietary intake of omega-3 fatty acids

Author, Year, Location: Length & Design | Study groups | | Safety data
| Group 1 (n)/Group 4 (n) | Group 2(n)/Group 3(n)
Preterm infants
Fewtrell, 2002, UK: 4 wks parallel RCT ^ 273 ^ | n-3 FA enriched F primrose oil/egg lipids (n=95) | Control F (source NR) (n=100)/Non-randomized HM (n=88) | [underlined: n-3 FA-enriched F vs. control F vs. HM] Death: 4.2% vs. 0% vs. 2.3% (NS) NEC: 5.3% vs. 2% vs. 0% (NS; withdrew before 3 wks) Systemic infection: 5.3% vs. 7% vs. 2.3% (NS) Skin sepsis: 13% vs. 8% vs. 8% (NS) IVH: 8.4% vs. 3% vs. 9.9% (NS) Pulmonary haemorrhage: 2.1% vs. 1% vs. 0% (NS) N ventilated: 51% vs. 50% vs. 48% (NS) Periventricular leukomalacia: 3.1% vs. 4% vs. 3.7% (NS) Patent ductus arteriosus: 6.3% vs. 7% vs. 2.5% (NS) Retrolental fibroplasia: 2.1% vs. 3% vs. 0% (NS) Retinopathy of prematurity: NR (NS) Mean n of d abdominal distension: NR (NS) Mean n of d nappy rash reported: NR (NS) Mean n of stools per d (grp 1 vs. grp 2): 1.96 vs. 2.12; S+ [underlined: 4 deaths in n-3 FA-enriched F] n=1 early death due to NEC(d 9), and n=3 late deaths (d 46-135) due to chronic lung disease [underlined: Follow-up data on AE] NS Between-arm differences in the incidence of respiratory tract infections and eczema, n of doctor visits and hospital admissions, between discharge and 18 mo follow-up: NR
Koletzko, 2003, Germany: 4 wks parallel RCT ^ 257 ^ | n-3 FA enriched F black currant seed oil/fish oil/egg lipids (n=15) | Control F (source NR) (n=15)/Non-randomized HM (n=19) | Frequency of gastric residuals, vomiting, or stools: NR (NS)

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; ALA = alpha linolenic acid; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; AA = arachidonic acid; Length = intervention length; Design = research design; n = sample size; pts = study participants; NR = not reported; NS = nonsignificant statistical difference; n/a = not applicable; pb = placebo; grp = group; wk = week(s); mo = month; wt = weight; +p<.05 or significant with 95% confidence interval; ++p<.01; +++p<.001; ++++p<.0001; FA = fatty acids; PD = preterm delivery; LBW = low birth weight; ICU = intensive care unit; SCN = special care nursery; GD = gestational diabetes; HM = human milk; NEC = necrotizing enterocolitis; F = formula ; IVH = Intra-ventricular haemorrhage; PCA: post-conception age; SIDS = sudden infant death syndrome; TG = triglyceride; AE = adverse events; SAE = serious adverse events Φ = completed (otherwise enrolled)

Summary Table 5: Studies reporting adverse events (e.g., side effects) and contraindications in relation to dietary intake of omega-3 fatty acids

Author, Year, Location: Length & Design | Study groups | | Safety data
| Group 1 (n)/Group 4 (n) | Group 2(n)/Group 3(n)
Preterm infants
Gobel, 2003, Germany: 1 wk parallel RCT ^ 286 ^ | Olive/soybean oil emulsion (n=24) | Soybean oil emulsion (n=21) | No SAE NS between-arm differences in AE [underlined: Olive/soybean oil emulsion (DHA 0.23% + ALA 2.0%)] Bradycardia: n = 7 (29%) Gastroesophageal reflux: n = 7 (29%) Hyperbilirubinemia: n = 5 (20.8%) Apnea: n = 4 (16.7%) [underlined: Soybean oil emulsion (DHA 0.34% and ALA 6.99%)] Bradycardia: n = 6 (28.6%) Gastroesophageal reflux: n = 5 (23.8%) Hyperbilirubinemia: n = 3 (14.3%) Apnea: n = 2 (9.6%)
Fewtrell, 2004, UK: 42 wks parallel RCT ^ 258 ^ | n-3 FA enriched F starflower and tuna fish oil (n=122) | Control F Sunflower/canola oil (n=116) | [underlined: n-3 FA-enriched F (grp 1) vs. control F (grp 2)] Death: 0% vs. 1%; NS NEC: 4% vs. 2%; NS Systemic infection: 9% vs. 7%; NS Skin infections: NR; NS IVH: 7% vs. 8%; NS Pulmonary haemorrhage: 0% vs. 1%; NS n ventilated: 38% vs. 38%; NS Median d ventilated: 4 (3-8) vs. 2 (2-5); S+ Periventricular leukomalacia: NR; NS Patent ductus arteriosus: NR; NS Retinopathy of prematurity: NR; NS Required respiratory assistance: 8% vs. 5%; NS Median d with umbilical catheters: 4 (3-6) vs. 3 (2-5); S+ Mean n of stools per d: 3 vs. 3; NS Mean n of d abdominal distension reported: NR; NS [underlined: Follow-up data on AE] Between-arm differences in the incidence of respiratory tract infections & eczema, n of doctor visits & hospital admissions, between discharge & 18 mo follow-up: NR (NS) Stool frequency & consistency between the arms were similar

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; ALA = alpha linolenic acid; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; AA = arachidonic acid; Length = intervention length; Design = research design; n = sample size; pts = study participants; NR = not reported; NS = nonsignificant statistical difference; n/a = not applicable; pb = placebo; grp = group; wk = week(s); mo = month; wt = weight; +p<.05 or significant with 95% confidence interval; ++p<.01; +++p<.001; ++++p<.0001; FA = fatty acids; PD = preterm delivery; LBW = low birth weight; ICU = intensive care unit; SCN = special care nursery; GD = gestational diabetes; HM = human milk; NEC = necrotizing enterocolitis; F = formula ; IVH = Intra-ventricular haemorrhage; PCA: post-conception age; SIDS = sudden infant death syndrome; TG = triglyceride; Φ = completed (otherwise enrolled); AE = adverse events; SAE = serious adverse events

## Term Infants

Summary Table 6: Studies reporting adverse events (e.g., side effects) and contraindications in relation to dietary intake of omega-3 fatty acids

Author, Year, Location: Length & Design | Study groups | | Safety data
| Group 1 (n)/Group 4 (n) | Group 2(n)/Group 3(n)
Term infants
McClead, 1985, US: 1-3 wks parallel RCT ^ 287 ^ | Safflower oil emulsion ‘high ALA’ (n=10)Φ | Safflower oil emulsion ‘low ALA’ (n=10) | [underlined: ALA 3 (SD: 1.5)% safflower oil emulsion (high ALA)] No AE [underlined: ALA 0.1% safflower oil emulsion (low ALA)] Tachycardia & tachypnea (2nd to fluid overload): n=1
Decsi, 1995, Germany: 12 wks parallel RCT ^ 261 ^ | n-3 FA enriched F egg lipids evening primrose oil (n=12) Φ | Control F (n=10) | F-s well tolerated & no serious adverse events reported except for minor dermatological symptoms such as seborrhoeic & diaper dermatitis
Auestad, 1997, US: 16-48 wks parallel RCT ^ 104 ^ | n-3 FA enriched F fish oil (n=43)/Non-randomized HM (n=63) Φ | n-3 FA enriched F egg lipids (n=46)/Control F Oil blend: coconut safflower & soy (n=45) | aT 12 mo (cataracts, viral meningitis, pyloric stenosis, phenylketonuria, anisometropia) were not related to F intake At 39 mo, NS between-arm differences in the % of those with ≥ 1 hospitalization, pressure equalization tubes for chronic otitis media, and ≥ 3 prescriptions for antibiotics [underlined: F (fish oil: DHA 0.23%)F (fish oil: DHA 0.23%)] SIDS: n=1 (unrelated to study participation), F-intolerance: n=4, ≥ 3 prescriptions for antibiotics: 57%, pressure equalization tubes for chronic otitis media: 6%, ≥1 hospitalization: 12% [underlined: F (egg lipids: DHA 0.12% + AA 0.43%)] Cataracts: n=1, F-intolerance: n=9, ≥3 prescriptions for antibiotics: 46%, pressure equalization tubes for chronic otitis media: 11%, ≥1 hospitalization: 29% [underlined: F (coconut, safflower, & soy oils; no DHA or AA)] Viral meningitis: n=1, pyloric stenosis: n=1, F-intolerance: n=2, ≥3 prescriptions for antibiotics: 62%, pressure equalization tubes for chronic otitis media: 8%, ≥ 1 hospitalization: 19% [underlined: HM] Phenylketonuria: n=1, anisometropia: n=1, ≥3 prescriptions for antibiotics: 66%, pressure equalization tubes for chronic otitis media: 4%, ≥ 1 hospitalization: 14%

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; ALA = alpha linolenic acid; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; AA = arachidonic acid; E-EPA = ethyl eicosapentaenoate; Length = intervention length; Design = research design; n = sample size; pts = study participants; NR = not reported; NS = nonsignificant statistical difference; n/a = not applicable; pb = placebo; grp = group; wk = week(s); mo = month; wt = weight; +p<.05 or significant with 95% confidence interval; ++p<.01; +++p<.001; ++++p<.0001; FA = fatty acids; PD = preterm delivery; LBW = low birth weight; ICU = intensive care unit; SCN = special care nursery; GD = gestational diabetes; HM = human milk; NEC = necrotizing enterocolitis; F = formula; IVH = intra-ventricular haemorrhage; PL = phospholipid; TG = triglyceride; SIDS = sudden infant death syndrome; AE = adverse events; SAE = serious adverse events; Φ = completed (otherwise enrolled)

Summary Table 7: Studies reporting adverse events (e.g., side effects) and contraindications in relation to dietary intake of omega-3 fatty acids

Author, Year, Location: Length & Design | Study groups | | Safety data
| Group 1 (n)/Group 4 (n) | Group 2(n)/Group 3(n)
Term infants
Birch, 1998, US: 17 wks parallel RCT ^ 182 ^ | n-3 FA enriched F single-cell oils (n=27)/Non-randomized HM (n=29) | n-3 FA enriched F single-cell oils (n=26)/Control F (n=26) | [underlined: F (grp 1) vs. F (grp 2) vs. F (grp 3) vs. HM (grp 4)] Illness unrelated to protocol: At 6 wks: n=0 vs. n=1 vs. n=0 vs. n=1 At 17 wks: n=1 vs. n=0 (grps 2-4) At 52 wks: n=2 vs. n=0 (grps 2-4) Signs of lactose intolerance At 6 wks: n=1 vs. n=2 vs. n=3 vs. n=2
Lucas, 1999, UK: 6-24 wks parallel RCT ^ 265 ^ | n-3 FA enriched F egg PL-TG fractions (n=154) | Control F (source NR) (n=155)/Non-randomized HM (n=138) | [underlined: F (DHA 0.32% + AA 0.30%) vs. F (control; no DHA or EPA)] By 9 mo of follow-up Withdrawals due to AE: n=17 vs. n=19; NS Mild AE: n=5 vs. n=8; NS Moderate AE: n=12 vs. n=8; NS Severe AE: n=0 vs. n=3; NS Constipation: n=1 vs. n=0; NS Gastroenteritis: n=1 vs. n=0; NS Pyloric stenosis: n=1 vs. n=0; NS Vomiting: n=7 vs. n=7; NS Median crying time (min/day): 53 vs. 40; NS Odds of having an event (grp 1 relative to grp 2) by 9 mo Prescribed antibiotics: OR=1.3, 95% CI: 0.8, 2.2 (NS) Respiratory infections: OR=1.1, 95% CI: 0.5, 2.4 (NS) Gastroenteritis: OR=0.8, 95% CI: 0.5, 1.5 (NS) Visit to medical practitioner: OR=1.8, 95% CI: 0.8, 4.2 (NS) Eczema: OR=1.2, 95% CI: 0.7, 2.1 (NS) Asthma: OR=0.8, 95% CI: 0.3, 2.5 (NS) Wheeze: OR=1.1, 95% CI: 0.6, 1.8 (NS)
Makrides, 1999, Australia: 16 wks parallel RCT ^ 205 ^ | n-3 FA enriched F tuna oil (n=27)/Non-randomized HM (n=63) | n-3 FA enriched F egg-PL fraction (n=28)/Control F (n=28) | At 6 &16 wks of feeding: NS between-arm % of infants with restlessness, rash, vomiting, diarrhea, & constipation NR (NS) Of the 32 withdrawn infants (formula-fed: 15 and HM: 17), n=2 AE; n=11 cataracts (HM) & n=1 (DHA 0.35% or grp 1) - unrelated unspecified medical problem

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; ALA = alpha linolenic acid; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; AA = arachidonic acid; E-EPA = ethyl eicosapentaenoate; Length = intervention length; Design = research design; n = sample size; pts = study participants; NR = not reported; NS = nonsignificant statistical difference; n/a = not applicable; pb = placebo; grp = group; wk = week(s); mo = month; wt = weight; +p<.05 or significant with 95% confidence interval; ++p<.01; +++p<.001; ++++p<.0001; FA = fatty acids; PD = preterm delivery; LBW = low birth weight; ICU = intensive care unit; SCN = special care nursery; GD = gestational diabetes; HM = human milk; NEC = necrotizing enterocolitis; F = formula; IVH = intra-ventricular haemorrhage; PL = phospholipid; TG = triglyceride; Φ = completed (otherwise enrolled); AE = adverse events; SAE = serious adverse events

Summary Table 8: Studies reporting adverse events (e.g., side effects) and contraindications in relation to dietary intake of omega-3 fatty acids

Author, Year, Location: Length & Design | Study groups | | Safety data
| Group 1 (n)/Group 4 (n) | Group 2(n)/Group 3(n)
Term infants
Morris, 2000, UK: 12 wks parallel RCT ^ 268 ^ | n-3 FA enriched F TG-form (n=54) Φ | Control F (source NR) (n=55) | At 6 wks [underlined: n-3 FA enriched F (DHA 0.20%)] n=2 (‘vomiting’) n=2 (‘slow to feed’ and ‘hungry’) [underlined: Control F] n=3 (‘hungry’, ‘not satisfied’, and ‘erratic’) At 12 wks [underlined: n-3 FA enriched F (DHA 0.20%)] n=1 (‘not satisifed’) [underlined: Control F] n=1 (‘colic’) NS between-arm difference in stool consistency NS between-arm difference in frequency of consultations with primary care team, hospital admissions, gastrointestinal disturbances, stools, upper respiratory infections, & allergic reactions
Makrides, 2000, Australia: 34 wks parallel RCT ^ 266 ^ | High ‘ALA’ F Palm, canola, coconut, & soy oils (n=37) | Low ’ALA’ F Oleic, coconut, soy, & safflower oils (n=36)/Non-randomized HM (n=103) | At 6 & 16 wks of age NS in reported frequency of infant restlessness, rash, vomiting, diarrhea, or constipation In HM: n=4 infants had recurrent illnesses unrelated to the trial & withdrew
Auestad, 2001, US: 48 wks 2 parallel RCT ^ 227 ^ | n-3 FA-enriched F fish/fungal (n=82)/Non-randomized HM (n=165) | n-3 FA-enriched F egg-TG (n=80)/Control F coconut, soy, & safflower oils (n=77) | F intolerance by 48 wks of age NS frequency of spitting up, vomiting, & consistency of stools F intolerance leading to withdrawals: n=14 (fish/fungal F arm) n=13 (egg-TG F arm) n=16 (control F)
Jensen, 2002, US: 16 wks parallel RCT ^ 203 ^ | F1 canola, palm, coconut oils (n=20)/F4 palm, coconut, safflower oils (n=20) | F2 palm, coconut, canola oils (n=20)/F3 sunflower, palm, coconut oil (n=20) | Dietary protein hypersensitivity n=2 (F3: ALA 0.95% arm)

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure; n-3 = omega-3 fatty acids; n-6 = omega-6 fatty acids; ALA = alpha linolenic acid; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; AA = arachidonic acid; E-EPA = ethyl eicosapentaenoate; Length = intervention length; Design = research design; n = sample size; pts = study participants; NR = not reported; NS = nonsignificant statistical difference; n/a = not applicable; pb = placebo; grp = group; wk = week(s); mo = month; wt = weight; +p<.05 or significant with 95% confidence interval; ++p<.01; +++p<.001; ++++p<.0001; FA = fatty acids; PD = preterm delivery; LBW = low birth weight; ICU = intensive care unit; SCN = special care nursery; GD = gestational diabetes; HM = human milk; NEC = necrotizing enterocolitis; F = formula; IVH = intra-ventricular haemorrhage; ; PL = phospholipid; TG = triglyceride; Φ = completed (otherwise enrolled); AE = adverse events; SAE = serious adverse events

## Listing of Included Studies for Evidence Tables

Agostoni C, Marangoni F, Giovannini M, Galli C, Riva E. Prolonged breast-feeding (six months or more) and milk fat content at six months are associated with higher developmental scores at one year of age within a breast-fed population. Adv Exp Med Biol. 2001;501:137-141. [pmid: 11787675].
Agostoni C, Riva E, Trojan S, Bellu R, Giovannini M. Docosahexaenoic acid status and developmental quotient of healthy term infants.[comment]. Lancet. 1995;346(8975):638. [pmid: 7651024].
Agostoni C, Trojan S, Bellu R, Riva E, Giovannini M. Neurodevelopmental quotient of healthy term infants at 4 months and feeding practice: the role of long-chain polyunsaturated fatty acids. Pediatr Res. 1995;38(2):262-266. [pmid: 7478826].
Agostoni C, Trojan S, Bellu R, Riva E, Bruzzese M G, Giovannini M. Developmental quotient at 24 months and fatty acid composition of diet in early infancy: a follow up study. Arch Dis Child. 1997;76(5):421-424. [pmid: 9196357].
Al M D, von Houwelingen A C, Hasaart T H, Hornstra G. The relationship between the essential fatty acid status of mother and child and the occurrence of pregnancy-induced hypertension. Intermediate results of a prospective longitudinal study. World Rev Nutr Diet. 1994;76:110-113. [pmid: 7856218].
Al M D, van Houwelingen A C, Badart-Smook A, Hasaart T H, Roumen F J, Hornstra G. The essential fatty acid status of mother and child in pregnancy-induced hypertension: a prospective longitudinal study. Am J Obstet Gynecol. 1995;172(5):1605-1614. [pmid: 7755079].
Auestad N, Halter R, Hall R T, Blatter M, Bogle M L, Burks W, et al. Growth and development in term infants fed long-chain polyunsaturated fatty acids: a double-masked, randomized, parallel, prospective, multivariate study. Pediatrics. 2001;108(2):372-381. [pmid: 11483802].
Auestad N, Montalto M B, Hall R T, Fitzgerald K M, Wheeler R E, Connor W E, et al. Visual acuity, erythrocyte fatty acid composition, and growth in term infants fed formulas with long chain polyunsaturated fatty acids for one year. Ross Pediatric Lipid Study. Pediatr Res. 1997;41(1):1-10. [pmid: 8979282].
Auestad N, Scott D T, Janowsky J S, Jacobsen C, Carroll R E, Montalto M B, et al. Visual, cognitive, and language assessments at 39 months: a follow-up study of children fed formulas containing long-chain polyunsaturated fatty acids to 1 year of age. Pediatrics. 2003;112(3 Pt 1):e177-e183. [pmid: 12949309].
Birch E, Birch D, Hoffman D, Hale L, Everett M, Uauy R. Breast-feeding and optimal visual development. J Pediatr Ophthalmol Strabismus. 1993;30(1):33-38. [pmid: 8455123].
Birch D G, Birch E E, Hoffman D R, Uauy R D. Retinal development in very-low-birth-weight infants fed diets differing in omega-3 fatty acids. Invest Ophthalmol Vis Sci. 1992;33(8):2365-2376. [pmid: 1386065].
Birch E E, Birch D G, Hoffman D R, Uauy R. Dietary essential fatty acid supply and visual acuity development. Invest Ophthalmol Vis Sci. 1992;33(11):3242-3253. [pmid: 1399429].
Birch E E, Garfield S, Hoffman D R, Uauy R, Birch D G. A randomized controlled trial of early dietary supply of long-chain polyunsaturated fatty acids and mental development in term infants. Dev Med Child Neurol. 2000;42(3):174-181. [pmid: 10755457].
Birch E E, Hoffman D R, Castaneda Y S, Fawcett S L, Birch D G, Uauy R D. A randomized controlled trial of long-chain polyunsaturated fatty acid supplementation of formula in term infants after weaning at 6 wk of age. Am J Clin Nutr. 2002;75(3):570-580. [pmid: 11864865].
Birch E E, Hoffman D R, Uauy R, Birch D G, Prestidge C. Visual acuity and the essentiality of docosahexaenoic acid and arachidonic acid in the diet of term infants. Pediatr Res. 1998;44(2):201-209. [pmid: 9702915].
Bougle D, Denise P, Vimard F, Nouvelot A, Penneillo M J, Guillois B. Early neurological and neuropsychological development of the preterm infant and polyunsaturated fatty acids supply. Clin Neurophysiol. 1999;110(8):1363-1370. [pmid: 10454271].
Bulstra-Ramakers M T, Huisjes H J, Visser G H. The effects of 3g eicosapentaenoic acid daily on recurrence of intrauterine growth retardation and pregnancy induced hypertension. Br J Obstet Gynaecol. 1995;102(2):123-126. [pmid: 7756203].
Carlson S E, Cooke R J, Rhodes P G, Peeples J M, Werkman S H, Tolley E A. Long-term feeding of formulas high in linolenic acid and marine oil to very low birth weight infants: phospholipid fatty acids. Pediatr Res. 1991;30(5):404-412. [pmid: 1684416].
Carlson S E, Cooke R J, Werkman S H, Tolley E A. First year growth of preterm infants fed standard compared to marine oil n-3 supplemented formula. Lipids. 1992;27(11):901-907. [pmid: 1491608].
Carlson S E, Ford A J, Werkman S H, Peeples J M, Koo W W. Visual acuity and fatty acid status of term infants fed human milk and formulas with and without docosahexaenoate and arachidonate from egg yolk lecithin. Pediatr Res. 1996;39(5):882-888. [pmid: 8726246].
Carlson S E, Rhodes P G, Rao V S, Goldgar D E. Effect of fish oil supplementation on the n-3 fatty acid content of red blood cell membranes in preterm infants. Pediatr Res. 1987;21(5):507-510. [pmid: 2954026].
Carlson S E, Werkman S H. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until two months. Lipids. 1996;31(1):85-90. [pmid: 8649239].
Carlson S E, Werkman S H, Cooke R J, Peeples J M, Tolley E A. Docosahexaenoate (DHA) and eicosapentaenoate (EPA) status of preterm infants: relationship to the Fagantest of Infant Intelligence and the Bayley Scale of Mental Development. FASEB Journal. 1990;4:A1156.
Carlson S E, Werkman S H, Peeples J M, Cooke R J, Tolley E A. Arachidonic acid status correlates with first year growth in preterm infants. Proc Natl Acad Sci U S A. 1993;90(3):1073-1077. [pmid: 8430076]. [pmcid: 45813].
Carlson S E, Werkman S H, Rhodes P G, Tolley E A. Visual-acuity development in healthy preterm infants: effect of marine-oil supplementation. Am J Clin Nutr. 1993;58(1):35-42. [pmid: 8317386].
Carlson S E, Werkman S H, Tolley E A. Effect of long-chain n-3 fatty acid supplementation on visual acuity and growth of preterm infants with and without bronchopulmonary dysplasia. Am J Clin Nutr. 1996;63(5):687-697. [pmid: 8615350].
Cetin I, Giovannini N, Alvino G, Agostoni C, Riva E, Giovannini M, et al. Intrauterine growth restriction is associated with changes in polyunsaturated fatty acid fetal-maternal relationships. Pediatr Res. 2002;52(5):750-755. [pmid: 12409524].
Cheruku S R, Montgomery-Downs H E, Farkas S L, Thoman E B, Lammi-Keefe C J. Higher maternal plasma docosahexaenoic acid during pregnancy is associated with more mature neonatal sleep-state patterning. Am J Clin Nutr. 2002;76(3):608-613. [pmid: 12198007].
Clandinin M T V. Safety of formulas with docosahexaenoic acid (DHA) and arachidonic acid (ARA) from single-cell and marine sources for low-birth-weight infants (LBW). J Pediatr Gastroenterol Nutr. 2002;34(4):484.
Clandinin M T V. Growth and development of very-low-birth-weight infants (VLBW) is enhanced by formulas supplemented with docosahexaenoic acid (DHA) and arachidonic acid (ARA). J Pediatr Gastroenterol Nutr. 2002;34(4):479.
Craig-Schmidt M C, Carlson S E, Crocker L, Sibai B M. Plasma total phospholipid arachidonic acid and eicosapentaenoic acid in normal and hypertensive pregnancy. World Rev Nutr Diet. 1994;76:126-129. [pmid: 7856222].
D'Almeida A, Carter J P, Anatol A, Prost C. Effects of a combination of evening primrose oil (gamma linolenic acid) and fish oil (eicosapentaenoic + docahexaenoic acid) versus magnesium, and versus placebo in preventing pre-eclampsia + docahexaenoic acid) versus magnesium, and versus placebo in preventing pre-eclampsia. Women Health. 1992;19(23):117-131. [pmid: 1492408].
de Groot R H, Hornstra G, van Houwelingen A C, Roumen F. Effect of alpha-linolenic acid supplementation during pregnancy on maternal and neonatal polyunsaturated fatty acid status and pregnancy outcome. Am J Clin Nutr. 2004;79(2):251-260. [pmid: 14749231].
De Groot R H M, Adam J, Jolles J, Hornstra. Alpha-linolenic acid supplementation during human pregnancy does not effect cognitive functioning. Prostaglandins Leukot Essent Fatty Acids. 2004;70(1):41-47. [pmid: 14643178].
Decsi T, Koletzko B. Growth, fatty acid composition of plasma lipid classes, and plasma retinol and alpha-tocopherol concentrations in full-term infants fed formula enriched with omega-6 and omega-3 long-chain polyunsaturated fatty acids. Acta Paediatr. 1995;84(7):725-732. [pmid: 7549287].
Dunstan J A, Mori T A, Barden A, Beilin L J, Holt P G, Calder P C, et al. Effects of n-3 polyunsaturated fatty acid supplementation in pregnancy on maternal and fetal erythrocyte fatty composition. Eur J Clin Nutr. 2004;58(3):429-437. [pmid: 14985680].
Elias S L, Innis S M. Infant plasma trans, n-6, and n-3 fatty acids and conjugated linoleic acids are related to maternal plasma fatty acids, length of gestation, and birth weight and length.[comment]. Am J Clin Nutr. 2001;73(4):807-814. [pmid: 11273857].
Faldella G, Govoni M, Alessandroni R, Marchiani E, Salvioli G P, Biagi P L, et al. Maturation of the visual cortex in relation to dietary intake of polyenoic fatty acids in preterm infants. Bambini e Nutrizione. 1995;2(3):116-120.
Faldella G, Govoni M, Alessandroni R, Marchiani E, Salvioli G P, Biagi P L, et al. Visual evoked potentials and dietary long chain polyunsaturated fatty acids in preterm infants. Arch Dis Child Fetal Neonatal Ed. 1996;75(2):F108-F112. [pmid: 8949693].
Fewtrell M S, Morley R, Abbott R A, Singhal A, Isaacs E B, Stephenson T, et al. Double-blind, randomized trial of long-chain polyunsaturated fatty acid supplementation in formula fed to preterm infants. Pediatrics. 2002;110(1):73-82. [pmid: 12093949].
Fewtrell M S, Abbott R A, Kennedy K, Singhal A, Morley R, Caine E, et al. Randomized, double-blind trial of long-chain polyunsaturated fatty acid supplementation with fish oil and borage oil in preterm infants. J Pediatr. 2004;144(4):471-479. [pmid: 15069395].
Field C J, Thomson C A, Aerde Jv, Parrott A, Euler A, Lien E, et al. Lower proportion of CD45R0+ cells and deficient interleukin-10 production by formula-fed infants, compared with human-fed, is corrected with supplementation of long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr. 2000;31(3):291-299. [pmid: 10997375].
Ghebremeskel K, Burns L, Costeloe K, Burden T J, Harbige L, Thomas B, et al. Plasma vitamin A and E in preterm babies fed on breast milk or formula milk with or without long-chain polyunsaturated fatty acids. Int J Vitam Nutr Res. 1999;69(2):83-91. [pmid: 10218144].
Ghys A, Bakker E, Hornstra G, van den H M. Red blood cell and plasma phospholipid arachidonic and docosahexaenoic acid levels at birth and cognitive development at 4 years of age. Early Hum Dev. 2002;69(12):83-90. [pmid: 12324186].
Gibson R A, Neumann M A, Makrides M. Effect of increasing breast milk docosahexaenoic acid on plasma and erythrocyte phospholipid fatty acids and neural indices of exclusively breast fed infants. Eur J Clin Nutr. 1997;51(9):578-584. [pmid: 9306083].
Gobel Y, Koletzko B, Bohles H J, Engelsberger I, Forget D, Le Brun A, et al. Parenteral fat emulsions based on olive and soybean oils: a randomized clinical trial in preterm infants. J Pediatr Gastroenterol Nutr. 2003;37(2):161-167. [pmid: 12883303].
Groh-Wargo S, Moore J J, Catalano P, Thomas A, O'Connor D L, Lerner E. Docosahexaenoic acid (DHA) and arachidonic acid (AA) supplementation does not change body composition in preterm (PT) infants. Pediatr Res. 2002;51(4):380A.
Guesnet P. Blood lipid concentrations of docosahexaenoic and arachidonic acids at birth determine their relative postnatal changes in term infants fed breast milk or formula.[comment]. Am J Clin Nutr. 1999;70(2):292-298. [pmid: 10426708].
Helland I B, Saugstad O D, Smith L, Saarem K, Solvoll K, Ganes T, et al. Similar effects on infants of n-3 and n-6 fatty acids supplementation to pregnant and lactating women. Pediatrics. 2001;108(5):E82. [pmid: 11694666].
Helland I B, Smith L, Saarem K, Saugstad O D, Drevon C A. Maternal supplementation with very-long-chain n-3 fatty acids during pregnancy and lactation augments children's IQ at 4 years of age. Pediatrics. 2003;111(1):e39-e44. [pmid: 12509593].
Hoffman D R, Birch E E, Birch D G, Uauy R D. Effects of supplementation with omega 3 long-chain polyunsaturated fatty acids on retinal and cortical development in premature infants. Am J Clin Nutr. 1993;57(5 Suppl):807S-812S. [pmid: 8475899].
Hoffman D R, Birch E E, Birch D G, Uauy R. Fatty acid profile of buccal cheek cell phospholipids as an index for dietary intake of docosahexaenoic acid in preterm infants. Lipids. 1999;34(4):337-342. [pmid: 10443966].
Hoffman D R, Birch E E, Birch D G, Uauy R, Castaneda Y S, Lapus M G, et al. Impact of early dietary intake and blood lipid composition of long-chain polyunsaturated fatty acids on later visual development. J Pediatr Gastroenterol Nutr. 2000;31(5):540-553. [pmid: 11144440].
Hoffman D R, Birch E E, Castaneda Y S, Fawcett S L, Wheaton D H, Birch D G, et al. Visual function in breast-fed term infants weaned to formula with or without long-chain polyunsaturates at 4 to 6 months: a randomized clinical trial. J Pediatr. 2003;142(6):669-677. [pmid: 12838196].
Hofmann M, Bahlmann F, Pollow K, Brockerhoff P. Phospholipid and triglycerid composition in patients with preeclampsia compared with normal pregnancies - Deficiency of essential polyunsaturated fatty acids. Geburtshilfe Frauenheilkd 1998; 58(9).
Innis S M, Adamkin D H, Hall R T, Kalhan S C, Lair C, Lim M, et al. Docosahexaenoic acid and arachidonic acid enhance growth with no adverse effects in preterm infants fed formula. J Pediatr. 2002;140(5):547-554. [pmid: 12032520].
Innis S M, Akrabawi S S, Diersen-Schade D A, Dobson M V, Guy D G. Visual acuity and blood lipids in term infants fed human milk or formulae.[erratum appears in Lipids Lipids 1997; Apr;32(4):457]. Lipids. 1997;32(1):63-72. [pmid: 9075195].
Innis S M, Gilley J, Werker J. Are human milk long-chain polyunsaturated fatty acids related to visual and neural development in breast-fed term infants?. J Pediatr. 2001;139(4):532-538. [pmid: 11598600].
Innis S M, Nelson C M, Rioux M F, King D J. Development of visual acuity in relation to plasma and erythrocyte omega-6 and omega-3 fatty acids in healthy term gestation infants. Am J Clin Nutr. 1994;60(3):347-352. [pmid: 8074064].
Jensen C L, Prager T C, Fraley J K, Chen H, Anderson R E, Heird W C. Effect of dietary linoleic/alpha-linolenic acid ratio on growth and visual function of term infants.[comment]. J Pediatr. 1997;131(2):200-209. [pmid: 9290604].
Jensen C L, Prager T C, Zou Y, Fraley J K, Maude M, Anderson R E, et al. Effects of maternal docosahexaenoic acid supplementation on visual function and growth of breast-fed term infants. Lipids. 1999;34(Suppl):S225. [pmid: 10419159].
Jorgensen M H, Hernell O, Hughes E L, Michaelsen K F. Is there a relation between docosahexaenoic acid concentration in mothers' milk and visual development in term infants?. J Pediatr Gastroenterol Nutr. 2001;32(3):293-296. [pmid: 11345178].
Jorgensen M H, Hernell O, Lund P, Holmer G, Michaelsen K F. Visual acuity and erythrocyte docosahexaenoic acid status in breast-fed and formula-fed term infants during the first four months of life. Lipids. 1996;31(1):99-105. [pmid: 8649242].
Jorgensen M H, Holmer G, Lund P, Hernell O, Michaelsen K F. Effect of formula supplemented with docosahexaenoic acid and gamma- linolenic acid on fatty acid status and visual acuity in term infants. J Pediatr Gastroenterol Nutr. 1998;26(4):412-421. [pmid: 9552137].
Koletzko B, Edenhofer S, Lipowsky G, Reinhardt D. Effects of a low birthweight infant formula containing human milk levels of docosahexaenoic and arachidonic acids. J Pediatr Gastroenterol Nutr. 1995;21(2):200-208. [pmid: 7472907].
Koletzko B, Sauerwald U, Keicher U, Saule H, Wawatschek S, Bohles H et al. Fatty acid profiles, antioxidant status, and growth of preterm infants fed diets without or with long-chain polyunsaturated fatty acids: A randomized clinical trial. Eur J Nutr 2003; 42(5).
Krasevec J M, Jones P J, Cabrera-Hernandez A, Mayer D L, Connor W E. Maternal and infant essential fatty acid status in Havana, Cuba. Am J Clin Nutr. 2002;76(4):834-844. [pmid: 12324298].
Laivuori H, Hovatta O, Viinikka L, Ylikorkala O. Dietary supplementation with primrose oil or fish oil does not change urinary excretion of prostacyclin and thromboxane metabolites in pre-eclamptic women. Prostaglandins Leukot Essent Fatty Acids. 1993;49(3):691-694. [pmid: 8248275].
Lapillonne A. Erythrocyte fatty acid composition in term infants fed human milk or a formula enriched with a low eicosapentanoic acid fish oil for 4 months. Eur J Pediatr. 2000;159(12):49-53. [pmid: 10653329].
Lapillonne A, Picaud JC, Chirouze V, Claris O, Rochette de Lempdes JB. Supplementation of preterm formulas (PTF) with a low EPA fish oil: Effect on polyunsaturated fatty acids(PUFAS) status and growth. J Pediatr Gastroenterol Nutr 1997; 24(4).
Leaf A, Gosbell A, McKenzie L, Sinclair A, Favilla I. Long chain polyunsaturated fatty acids and visual function in preterm infants. Early Hum Dev. 1996;45(12):35-53. [pmid: 8842638].
Lim M. Formulas with docosahexaenoic acid (DHA) and arachidonic acid (ARA) for low-birth weight infants (LBW) are safe. Pediatr Res. 2002;51(4):319A.
Lucas A, Stafford M, Morley R, Abbott R, Stephenson T, MacFadyen U, et al. Efficacy and safety of long-chain polyunsaturated fatty acid supplementation of infant-formula milk: a randomised trial.[comment]. Lancet. 1999;354(9194):1948-1954. [pmid: 10622297].
Makrides M, Neumann M A, Jeffrey B, Lien E L, Gibson R A. A randomized trial of different ratios of linoleic to alpha-linolenic acid in the diet of term infants: effects on visual function and growth.[comment]. Am J Clin Nutr. 2000;71(1):120-129. [pmid: 10617956].
Makrides M, Neumann M A, Simmer K, Gibson R A. Dietary long-chain polyunsaturated fatty acids do not influence growth of term infants: A randomized clinical trial. Pediatrics. 1999;104(3 Pt 1):468-475. [pmid: 10469771].
Makrides M, Neumann M A, Simmer K, Gibson R A. A critical appraisal of the role of dietary long-chain polyunsaturated fatty acids on neural indices of term infants: a randomized, controlled trial. Pediatrics. 2000;105(1 Pt 1):32-38. [pmid: 10617701].
Makrides M, Neumann M A, Gibson R A. Perinatal characteristics may influence the outcome of visual acuity. Lipids. 2001;36(9):897-900. [pmid: 11724461].
Makrides M, Neumann M, Simmer K, Pater J, Gibson R. Are long-chain polyunsaturated fatty acids essential nutrients in infancy?[comment]. Lancet. 1995;345(8963):1463-1468. [pmid: 7769900].
Makrides M, Simmer K, Goggin M, Gibson R A. Erythrocyte docosahexaenoic acid correlates with the visual response of healthy, term infants. Pediatr Res. 1993;33(4 Pt 1):425-427. [pmid: 8479826].
Malcolm C A, Hamilton R, McCulloch D L, Montgomery C, Weaver L T. Scotopic electroretinogram in term infants born of mothers supplemented with docosahexaenoic acid during pregnancy. Invest Ophthalmol Vis Sci. 2003;44(8):3685-3691. [pmid: 12882824].
Martinez F E, Santos M Md, Sieber V M, Camelo J S J, Ferlin M L S, Goncalves A L, et al. Growth and nitrogen balance in preterm infants fed formula with long chain polyunsaturated fatty acids. Nutr Res. 1999;19(10):1497-1505.
Matorras R, Perteagudo L, Nieto A, Sanjurjo P. Intrauterine growth retardation and plasma fatty acids in the mother and the fetus. Eur J Obstet Gynecol Reprod Biol. 1994;57(3):189-193. [pmid: 7713295].
McClead R E Jr, Meng H C, Gregory S A, Budde C, Sloan H R. Comparison of the clinical and biochemical effect of increased alpha-linolenic acid in a safflower oil intravenous fat emulsion. J Pediatr Gastroenterol Nutr. 1985;4(2):234-239. [pmid: 2859362].
Morris G, Moorcraft J, Mountjoy A, Wells J C K. A novel infant formula milk with added long-chain polyunsaturated fatty acids from single-cell sources: a study of growth, satisfaction and health. Eur J Clin Nutr. 2000;54(12):883-886. [pmid: 11114686].
O'Connor D L J. Growth and development of premature infants fed predominantly human milk, predominantly premature infant formula, or a combination of human milk and premature formula. J Pediatr Gastroenterol Nutr. 2003;37(4):437-446. [pmid: 14508214].
O'Connor D L, Hall R, Adamkin D, Auestad N, Castillo M, Connor W E, et al. Growth and development in preterm infants fed long-chain polyunsaturated fatty acids: a prospective, randomized controlled trial. Pediatrics. 2001;108(2):359-371. [pmid: 11483801].
Olsen S F, Secher N J, Tabor A, Weber T, Walker J J, Gluud C. Randomised clinical trials of fish oil supplementation in high risk pregnancies Fish Oil Trials In Pregnancy (FOTIP) Team. BJOG. 2000;107(3):382-395. [pmid: 10740336].
Olsen S F, Sorensen J D, Secher N J, Hedegaard M, Henriksen T B, Hansen H S, et al. Randomised controlled trial of effect of fish-oil supplementation on pregnancy duration.[comment]. Lancet. 1992;339(8800):1003-1007. [pmid: 1349049].
Olsen S F, Sorensen J D, Secher N J, Hedegaard M, Henriksen T B, Hansen H S, et al. [Fish oil supplementation and duration of pregnancy. A randomized controlled trial]. [Danish]. Ugeskr Laeger. 1994;156(9):1302-1307. [pmid: 8009754].
Onwude J L, Lilford R J, Hjartardottir H, Staines A, Tuffnell D. A randomised double blind placebo controlled trial of fish oil in high risk pregnancy. Br J Obstet Gynaecol. 1995;102(2):95-100. [pmid: 7756226].
Ponder D L, Innis S M, Benson J D, Siegman J S. Docosahexaenoic acid status of term infants fed breast milk or infant formula containing soy oil or corn oil. Pediatr Res. 1992;32(6):683-688. [pmid: 1287559].
Reece M S, McGregor J A, Allen K G, Harris M A. Maternal and perinatal long-chain fatty acids: possible roles in preterm birth.[comment]. Am J Obstet Gynecol. 1997;176(4):907-914. [pmid: 9125620].
Riemersma R, Armstrong R, Kelly RW, editors. Diersen-Schade DA, Hansen JW, Harris CL, Merkel KL, Wisont KD, Boettcher JA et al. Docosahexaenoic acid plus arachidonic acid enhance preterm infant growth, Champaign; USA AOCS Press, 1998.
Rocquelin G, Tapsoba S, Kiffer J, Eymard-Duvernay S. Human milk fatty acids and growth of infants in Brazzaville (The Congo) and Ouagadougou (Burkina Faso). Public Health Nutr. 2003;6(3):241-248. [pmid: 12740073].
Rump P, Mensink R P, Kester A D, Hornstra G. Essential fatty acid composition of plasma phospholipids and birth weight: a study in term neonates.[comment]. Am J Clin Nutr. 2001;73(4):797-806. [pmid: 11273856].
Salvig J D, Olsen S F, Secher N J. Effects of fish oil supplementation in late pregnancy on blood pressure: a randomised controlled trial. Br J Obstet Gynaecol. 1996;103(6):529-533. [pmid: 8645644].
Scott D T, Janowsky J S, Carroll R E, Taylor J A, Auestad N, Montalto M B. Formula supplementation with long-chain polyunsaturated fatty acids: are there developmental benefits?. Pediatrics. 1998;102(5):E59. [pmid: 9651414].
Shouk T A, Omar M N, Fayed S T. Essential fatty acids profile and lipid peroxides in severe pre-eclampsia. Ann Clin Biochem. 1999;36(Pt 1):62-65. [pmid: 10370762].
Smuts C M, Borod E, Peeples J M, Carlson S E. High-DHA eggs: feasibility as a means to enhance circulating DHA in mother and infant. Lipids. 2003;38(4):407-414. [pmid: 12848286].
Smuts C M, Huang M, Mundy D, Plasse T, Major S, Carlson S E. A randomized trial of docosahexaenoic acid supplementation during the third trimester of pregnancy. Obstet Gynecol. 2003;101(3):469-479. [pmid: 12636950].
Uauy R D, Birch D G, Birch E E, Tyson J E, Hoffman D R. Effect of dietary omega-3 fatty acids on retinal function of very-low-birth-weight neonates. Pediatr Res. 1990;28(5):485-492. [pmid: 2255573].
Uauy R, Hoffman D R, Birch E E, Birch D G, Jameson D M, Tyson J. Safety and efficacy of omega-3 fatty acids in the nutrition of very low birth weight infants: soy oil and marine oil supplementation of formula. J Pediatr. 1994;124(4):612-620. [pmid: 7908693].
Vanderhoof J, Gross S, Hegyi T. A multicenter long-term safety and efficacy trial of preterm formula supplemented with long-chain polyunsaturated fatty acids. J Pediatr Gastroenterol Nutr. 2000;31(2):121-127. [pmid: 10941962].
Vanderhoof J, Gross S, Hegvi T, Clandinin T, Porcelli P, DeCristofaro J et al. A new arachidonic acid (ARA) and docosahexanoic acid (DHA) supplemented preterm formula: growth and safety assessment. Pediatr Res 1997;242A, #1440.
Vanderhoof J, Gross S, Hegyi T, Clandinin T, Porcelli P, DeCristofaro J, et al. Evaluation of a long-chain polyunsaturated fatty acid supplemented formula on growth, tolerance, and plasma lipids in preterm infants up to 48 weeks postconceptional age. J Pediatr Gastroenterol Nutr. 1999;29(3):318-326. [pmid: 10467999].
Vilbergsson G, Samsioe G, Wennergren M, Karlsson K. Essential fatty acids in pregnancies complicated by intrauterine growth retardation. Int J Gynaecol Obstet. 1991;36(4):277-286. [pmid: 1684761].
Vilbergsson G, Wennergren M, Samsioe G, Percy P, Percy A, Mansson J E, et al. Essential fatty acid status is altered in pregnancies complicated by intrauterine growth retardation. World Rev Nutr Diet. 1994;76:105-109. [pmid: 7856217].
Voigt R G, Jensen C L, Fraley J K, Rozelle J C, Brown F R III, Heird W C. Relationship between omega3 long-chain polyunsaturated fatty acid status during early infancy and neurodevelopmental status at 1 year of age. J Hum Nutr Diet. 2002;15(2):111-120. [pmid: 11972740].
Wang Y P, Kay H H, Killam A P. Decreased levels of polyunsaturated fatty acids in preeclampsia.[comment]. Am J Obstet Gynecol. 1991;164(3):812-818. [pmid: 1900662].
Werkman S H, Carlson S E. A randomized trial of visual attention of preterm infants fed docosahexaenoic acid until nine months. Lipids. 1996;31(1):91-97. [pmid: 8649241].
Wezel-Meijler G, van der Knaap M S, Huisman J, Jonkman E J, Valk J, Lafeber H N. Dietary supplementation of long-chain polyunsaturated fatty acids in preterm infants: effects on cerebral maturation. Acta Paediatr. 2002;91(9):942-950. [pmid: 12412870].
Willatts P, Forsyth J S, DiModugno M K, Varma S, Colvin M. Influence of long-chain polyunsaturated fatty acids on infant cognitive function. Lipids. 1998;33(10):973-980. [pmid: 9832076].
Willatts P, Forsyth J S, DiModugno M K, Varma S, Colvin M. Effect of long-chain polyunsaturated fatty acids in infant formula on problem solving at 10 months of age. Lancet British edition. 1998;352(9129):688-691.
Williams C, Birch E E, Emmett P M, Northstone K. Avon Longitudinal Study of Pregnancy and Childhood Study Team Stereoacuity at age 3.5 y in children born full-term is associated with prenatal and postnatal dietary factors: a report from a population-based cohort study. Am J Clin Nutr. 2001;73(2):316-322. [pmid: 11157330].
Woltil H A, van Beusekom C M, Okken-Beukens M, Schaafsma A, Muskiet F A, Okken A. Development of low-birthweight infants at 19 months of age correlates with early intake and status of long-chain polyunsaturated fatty acids. Prostaglandins Leukot Essent Fatty Acids. 1999;61(4):235-241. [pmid: 10574647].
Woltil H A, van Beusekom C M, Schaafsma A, Muskiet F A, Okken A. Long-chain polyunsaturated fatty acid status and early growth of low birth weight infants. Eur J Pediatr. 1998;157(2):146-152. [pmid: 9504790].
Xiang M, Alfven G, Blennow M, Trygg M, Zetterstrom R. Long-chain polyunsaturated fatty acids in human milk and brain growth during early infancy. Acta Paediatr. 2000;89(2):142-147. [pmid: 10709881].