# Appendix C. Data Assessment and Data Abstraction Forms

## Relevance Assessment Form

Please respond to each question.* Use the comments box to identify duplicate reports, a key review whose references should be checked, anomalies, etc.

a. Inclusion criteria:
  1. Does this report describe a study involving human participants?
  YES Can't Tell NO
  2. Does this study evaluate the role of: a. omega-3 fatty acid intake (diet and/or supplementation) as an intervention/exposure; or b. omega-3 or omega-6/omega-3 fatty acid content of biomarkers?
  YES Can't Tell NO
  3. Is the purpose of the study to investigate the effect (e.g., efficacy, effectiveness, adverse events) of maternal or child intake (via diet, supplementation, or human milk) of omega-3 fatty acids on, or the association of the omega-3 or omega-6/omega-3 fatty acid content of maternal, child or placental biomarkers with: a. visual function, cognitive development, neurological development, or growth patterns in (preterm* or term) infants; b. the incidence of retinopathy of prematurity in preterm infants; c. the duration of gestation in women with or without a history of preterm birth; d. the incidence of preeclampsia (gestational hypertension); or e. the incidence of births of infants small for gestational age?
  YES Can't Tell NO
b. Exclusion criterion:
  1. If this is a narrative or systematic review, opinion piece or editorial, letter, guideline or policy paper, etc., does it exclusively describe studies already reported elsewhere (i.e., it does not present any empirical evidence published for the first time)?
  YES Can't Tell NO
c. Context:
  2. The study appears to also or instead concern omega-3 fatty acids as an intervention/exposure associated with the following human health/disease domains (select at least one option; click on all that apply):
  __transplantation __neurology
  __cancer __eye health
  __mental health __none of the above
  3. Is this report written in English?
  YES NO
  4. Comments (write “only biomarkers”if it exclusively investigates “the omega-3 or omega-6/omega-3 fatty acid content in biomarkers”): BOX

Note: *Preterm = gestational duration less than 37 weeks

## Level of Evidence Assessment

1. Is this a Randomized Controlled Trial (for efficacy questions only) or an observational study (i.e., prospective cohort, case-control study, cross-sectional) for Biomarkers association questions?

YES NO

## Data Abstraction Form

Instructions: Please answer each question. Selecting response options means clicking on them. A text box (“BOX”) requires that you provide specific data, and allows you to provide clarification, as needed (e.g., when the available data are not straightforward). When data are not reported (= NR), the question does not apply (= N/A), you cannot tell what/where the data are in the report (= CT), the data are not broken down (= NBD) to permit the required abstraction (e.g., by study group), or you have no comment to make (= NC), type the code in the BOX.

‘Participants’ refers to study participants. ‘Group’ refers to a study group, arm or cohort or, in a crossover design, a study phase. Often, you will be asked to abstract ‘full’ sample data as well as by group. If requested group data are not available, abstract full sample data and label it as such.

If more than one report describes this study, draw on each to abstract study data. This means that, for question 2, record all of the relevant report Refid#s, and for question 3, record all of the relevant reports' data. When you are abstracting data from multiple reports for a given study, point out any inconsistencies.

If the research report describes more than one unique study, answer in this eForm all the questions for the first reported study while immediately notifying the review manager that another data abstraction form is required.

BOX = single box at end of list

All abstractors access each level, for verification possibilities.

Each abstractor assigned level(s), and Refids

1. Initials of reviewer: BOX
2. Reference identification #s (Refid#s) of all report(s) referring to this study, including duplicate reports, data-splitting reports, additional follow-ups, re-analyses, etc.: BOX
3. First author's last name, year of publication, country(s) in which study conducted (from each relevant report), [# study sites] (e.g., Smith, 1988, Canada [1 site]): BOX
4. Number of unique, review-relevant studies that this report describes (if more than one, notify review manager): BOX

Publication status, per report/Refid# referring to this study (e.g., Refid 3000=journal publication, Refid 6=conference abstract):

- Peer-reviewed journal publication
- Journal publication
- Conference abstract/poster
- Book
- Book chapter
- HTA/technical report
- Thesis
- Unpublished document
- Study sponsor's internal report
- Internet document/material
- Other
- BOX

Identity of funding source(s), including category per source (e.g., government, industry, private/non-industry, hospital), and what each provided: BOX

Question(s) addressed (select all that apply):

Pregnancy question(s), with clinical outcomes, investigated ( select all that apply ):

What is the evidence that intake of omega-3 fatty acids influences the duration of gestation in women with or without a history of a previous preterm birth (gestational duration less than 37 weeks)?

What is the evidence that maternal intake of omega-3 fatty acids influences the incidence of preeclampsia, eclampsia or gestational hypertension?

What is the evidence that maternal intake of omega-3 fatty acids influences the incidence of births of human infants small for gestational age?

None of the above

Pregnancy question(s), with biomarker outcomes, investigated ( select all that apply ):

What is the evidence that the duration of gestation in women with or without a history of a previous preterm birth is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?

What is the evidence that the incidence of preeclampsia, eclampsia or gestational hypertension is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?

What is the evidence that the incidence of births of human infants small for gestational age is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?

None of the above

Growth patterns question(s), with clinical outcomes, investigated (select all that apply):

What is the evidence that maternal intake of omega-3 fatty acids during pregnancy influences growth patterns in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences growth patterns in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of infant formula influences growth patterns in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, and together with the omega-3 fatty acid content of infant formula, influences growth patterns in term or preterm human infants?

What is the evidence that intake of omega-3 fatty acids from sources other than maternal breast milk or infant formula supplemented with omega-3 fatty acids, by term or preterm human infants, influences growth patterns?

None of the above

Growth patterns question(s), with biomarker outcomes, investigated ( select all that apply ):

What is the evidence that term or preterm human infants' growth patterns are associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?

What is the evidence that term or preterm human infants' growth patterns are associated with the omega-3 or omega-6/omega-3 fatty acid content of fetal biomarkers during pregnancy?

What is the evidence that term or preterm human infants' growth patterns are associated with the omega-3 or omega-6/omega-3 fatty acid content of child biomarkers?

None of the above

Neurological development question(s), with clinical outcomes, investigated ( select all that apply ):

What is the evidence that maternal intake of omega-3 fatty acids during pregnancy influences neurological development in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences neurological development in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of infant formula influences neurological development in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, and together with the omega-3 fatty acid content of infant formula, influences neurological development in term or preterm human infants?

What is the evidence that intake of omega-3 fatty acids from sources other than maternal breast milk or infant formula supplemented with omega-3 fatty acids, by term or preterm human infants, influences neurological development?

None of the above

Neurological development question(s), with biomarker outcomes, investigated ( select all that apply ):

What is the evidence that term or preterm human infants' neurological development is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?

What is the evidence that term or preterm human infants' neurological development is associated with the omega-3 or omega-6/omega-3 fatty acid content of fetal biomarkers?

What is the evidence that term or preterm human infants' neurological development is associated with the omega-3 or omega-6/omega-3 fatty acid content of child biomarkers?

None of the above

Visual function question(s), with clinical outcomes, investigated ( select all that apply ):

What is the evidence that maternal intake of omega-3 fatty acids during pregnancy influences visual function in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences visual function in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of infant formula influences visual function in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, and together with the omega-3 fatty acid content of infant formula, influences visual function in term or preterm human infants?

What is the evidence that intake of omega-3 fatty acids from sources other than maternal breast milk or infant formula supplemented with omega-3 fatty acids, by term or preterm human infants, influences visual function?

None of the above

Visual function question(s), with biomarker outcomes, investigated ( select all that apply ):

What is the evidence that term or preterm human infants' visual function is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?

What is the evidence that term or preterm human infants' visual function is associated with the omega-3 or omega-6/omega-3 fatty acid content of fetal biomarkers?

What is the evidence that term or preterm human infants' visual function is associated with the omega-3 or omega-6/omega-3 fatty acid content of child biomarkers?

None of the above

Cognitive development question(s), with clinical outcomes, investigated ( select all that apply ):

What is the evidence that maternal intake of omega-3 fatty acids during pregnancy influences cognitive development in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, influences cognitive development in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of infant formula influences cognitive development in term or preterm human infants?

What is the evidence that the omega-3 fatty acid content of maternal breast milk, with or without known maternal intake of omega-3 fatty acids, and together with the omega-3 fatty acid content of infant formula, influences cognitive development in term or preterm human infants?

What is the evidence that intake of omega-3 fatty acids from sources other than maternal breast milk or infant formula supplemented with omega-3 fatty acids, by term or preterm human infants, influences cognitive development?

None of the above

Cognitive development question(s), with biomarker outcomes, investigated ( select all that apply ):

What is the evidence that term or preterm human infants' cognitive development is associated with the omega-3 or omega-6/omega-3 fatty acid content of maternal biomarkers during pregnancy?

What is the evidence that term or preterm human infants' cognitive development is associated with the omega-3 or omega-6/omega-3 fatty acid content of fetal biomarkers?

What is the evidence that term or preterm human infants' cognitive development is associated with the omega-3 or omega-6/omega-3 fatty acid content of child biomarkers?

None of the above

Adverse events question(s) investigated ( select all that apply ):

What is the evidence for the risk, in pregnant women, of short and long-term adverse events related to their intake of omega-3 fatty acids?

What is the evidence for the risk, in breastfeeding women, of short and long-term adverse events related to their intake of omega-3 fatty acids?

What is the evidence for the risk, in term or preterm human infants, of short and long-term adverse events related to maternal intake of omega-3 fatty acids during pregnancy?

What is the evidence for the risk, in term or preterm human infants, of short and long-term adverse events related to their intake of omega-3 fatty acids after birth (e.g., maternal breast milk, infant formula supplemented with omega-3 fatty acids)?

What is the evidence that these adverse events, or any contraindications, are associated with the intake of specific sources (e.g., marine, plant), types (e.g., EPA, DHA, ALA) or doses of omega-3 fatty acids, including in specific populations such as diabetics?

None of the above

Study design (select one):

a. RCT parallel design
b. RCT crossover design
c. RCT factorial design
d. Controlled clinical trial (non-RCT)
e. Multiple prospective cohorts
f. At least one prospective cohort and one retrospective cohort
g. Case-control
h. Cross-sectional
i. Before-after (pre-post)
j. Single prospective cohort
k. Single retrospective cohort
l. Case series (noncomparative)
m. Case study
n. Sequential
o. Cross-national ecological analysis
p. Other: BOX

Any notable details (e.g., restricted randomization; blocking size) or problems (i.e., no or inappropriate run-in or washout procedures or durations; study stopped prematurely): BOX

Full sample eligibility criteria (e.g., population [e.g., pregnant women and/or children; permitted vs mandated/required characteristics/experiences/histories, including health status, complications, medications, etc.) (complete both):

Inclusion criteria: BOX

Exclusion criteria: BOX

Were the same eligibility criteria employed with reference to each study group? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a single group study)

Adequacy of reporting of eligibility criteria (select one):

a. Likely adequate (= not inadequate)
b. Likely inadequate (= missing, incomplete or conflicting data)

Adequacy of eligibility criteria:

a. Likely adequate (= not inadequate)
b. Likely inadequate (e.g., the inclusion criteria will not lead to the study of the target population the investigators intend to study; populations with characteristics/experiences/histories outside the investigators' intended scope, yet who show the same characteristics/experiences/histories as the target population, have not been identified as requiring exclusion)

Sample sizes (by population, if appropriate) (complete all):

Total # individuals screened: BOX

# selected/allocated participants (full [e.g., n=12]; by group [e.g., group 1 n=5; group 2 n=7]): BOX

# completers (= final followup)/total (full; per group) (e.g., group 1: n=4/5; group 2: n=6/7): BOX

Settings (complete both):

Type(s) of setting (e.g., tertiary care hospital vs. community facility) (full; by group): BOX

Proportion of participants in relatively controlled (e.g., inpatients) settings during study (full; by group): BOX

Study period (complete all):

Intervention length (d, wk, mo, y) (by group only if it varies): BOX

Timing of intervention (e.g., beginning the 3^rd^ day of life, for 4 mo; beginning the 5^th^ wk of pregnancy, until delivery): BOX

Study duration, including units (h, d, wk, mo) (includes intervention length + run-in period duration, washout duration[s], etc.): BOX

Run-in duration/protocol: BOX

Washout duration/protocol: BOX

Did participants in each study group receive the intervention/exposure for the same length of time? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a cross-sectional survey)

Was the same study procedure employed with reference to each study group? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable

Were participants in each study group assessed at the same number of followups, and with the same timing, during the study (select one)?

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a cross-sectional survey)

Number and timing of followups (i.e., specify corrected age [mos] and/or actual mos of age), and any definition of the ‘length of followup required to observe an/no impact of the exposure/intervention:’ BOX

Adverse events, and losses to followup (complete both):

# withdrawals vs. # dropouts, with reasons (full; by group): BOX

Adverse events/side effects and contraindications (full; by group): BOX

Basic population characteristics (maternal and/or children) (complete all):

Mean age (mean (range) y) of all relevant participants at study onset (full; by group, by population): BOX

Percentage of male children (full; by group): BOX

Maternal racial composition (proportions: full; by group) (e.g., Caucasian 50%, Asian 50% per group) BOX

Children's racial composition (proportions: full; by group) (e.g., Caucasian 50%, Asian 50% per group) BOX

Maternal socioeconomic status (i.e., employment status, income, marital status, education) (full; by group): BOX

Maternal health history prior to current pregnancy (complete all) (if this study does not specifically investigate a maternal population, click [underlined: here]):

Gynecologic history (e.g., STD, uterine anomalies, cervical incompetence) (full, by group): BOX

Obstetric history (i.e., n gestations, deliveries, abortions, live births, premature births, multiple gestations; complications, pre/eclampsia, gestational hypertension or gestational diabetes in previous pregnancies) (full, by group): BOX

Medical conditions (full, by group): BOX

Medications/treatments (full, by group): BOX

Breastfeeding history, including difficulties (full; by group): BOX

Alcohol (ab)use, especially during previous pregnancies/breastfeeding (full, by group): BOX

Smoking tobacco use or exposure, especially during previous pregnancies/breastfeeding (full, by group): BOX

Illicit drug use, especially during previous pregnancies/breastfeeding (full, by group): BOX

Other (e.g., domestic violence) (full, by group): BOX

Maternal health status of current pregnancy/breastfeeding (complete all):

Age at conception AND at delivery (specify) (full, by group): BOX

Obstetric history of current pregnancy (full, by group): BOX

Medical conditions, including psychiatric conditions (full, by group): BOX

All medication/treatments (e.g., prescription and non-prescription) (dose/frequency) (full, by group): BOX

Supplement use (vitamins, minerals) and/or CAM therapies prior to study onset: BOX

Alcohol (ab)use (full, by group): BOX

Smoking tobacco use or exposure (full, by group): BOX

Illicit drug use (full, by group): BOX

Other (e.g., domestic violence) (full, by group): BOX

Child's pre-study health history (complete all) (if this study does not specifically investigate a child population, click [underlined: here]):

Prenatal history (i.e., GA, complications during pregnancy, delivery and/or labor anomalies, etc) (full, by group): BOX

Neonatal history (e.g., asphyxia, intracranial hemorrhage, kernicterus, TORCH, hydrocephalus, congenital cataracts, coriorretinitis) (full, by group): BOX

Pediatric history (i.e., medical conditions, immunizations, etc.) (full, by group): BOX

Weight (W), height (H) and head circumference (HC) at birth, with percentiles (Pc) (full; by group): BOX

Medications/treatments (with dose/frequency) (full, by group): BOX

Other (e.g., exposure to toxic material) (full, by group): BOX

Child's health status at study baseline (complete all):

Current weight (Pc) (full, by group): BOX

Current height (Pc) (full, by group): BOX

Current head circumference (Pc) (full, by group): BOX

Growth patterns (percentile pattern, to study baseline) (full, by group): BOX

Visual function (full, by group): BOX

Cognitive developmental status (e.g., language) (full, by group): BOX

Neurodevelopmental status (full, by group): BOX

Medical conditions (full, by group): BOX

Medications/treatments (e.g., prescription and non-prescription drugs), with dose/frequency (full, by group): BOX

Supplement use (vitamins, minerals) and/or CAM therapies prior to study onset: BOX

Other (full, by group): BOX

Describe the method(s)/test(s) used to assess the child's visual development (full, by group; at each evaluation) (e.g., visual acuity, electroretinogram, etc): BOX

Describe the method(s)/test(s) used to assess the child's cognitive developmental status (full, by group; at each evaluation) [e.g., Bayley's mental developmental index (<2 years of age), Weschler (WPPSI, > 2 years of age), and WISC (> 7 years of age)]: BOX

Describe the method(s)/test(s) used to assess the child's neurological development status (full, by group; at each evaluation) [e.g., Bayley's motor developmental index (< 2 years of age), Peabody (>2 years of age)]: BOX

Maternal n-3 intake (pre-study/baseline) (complete all):

Pre-study/baseline total maternal (daily, weekly or monthly) n-3 intake via diet and/or supplementation, with amount per n-3 type (EPA, DHA, ALA), and source (e.g., fish servings; walnuts; flaxseed oil) (by group) (e.g., group 1: 1.8g/d EPA, 1.2g/d DHA, from 3 fish oil capsules/d; and, NR [likely EPA &/or DHA], from 1–2 fish servings/wk; group 2: 0g/d EPA, 0g/d DHA, water placebo; and, NR, 0 fish servings/wk): BOX

Pre-study/baseline total (daily, weekly or monthly) maternal dietary n-6/n-3 intake (by group) (e.g., group 1: 15/1; group 2: 10/1): BOX

Pre-study/baseline % (daily, weekly or monthly) maternal caloric/energy intake from fat (by group): BOX

Absolute and relative n-3 fatty acid content of the pre-study/baseline maternal diet (full; by group): BOX

Types of pre-study/baseline maternal diet (proportion of participants on each diet: in full; by group):

High fish diet

Fish-vegetarian diet

Low fish diet

Low fat diet

High fat diet

Mediterranean diet

Other

Unclear

Not reported

BOX

How was the pre-study maternal dietary intake of n-3, n-6 and n-6/n-3 evaluated/estimated (select all that apply)?

Nutritionist-administered quantitative food-frequency survey(s)

Nutritionist-administered semi-quantitative food-frequency survey(s)

Self-administered quantitative food-frequency survey(s)

Self-administered semi-quantitative food-frequency survey(s)

Parent-administered quantitative food-frequency survey(s)

Parent-administered semi-quantitative food-frequency survey(s)

Direct measurement(s) of food intake

Survey(s) (e.g., 24-hour recall): BOX

Survey(s), yet no details provided

Other: BOX

Unclear

Not reported

Not applicable

Maternal total amount of dietary n-3 intake ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Total amount of maternal n-3 intake from supplementation ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Total amount of maternal n-3 intake from diet and supplementation ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal dietary n-6/n-3 intake ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

% Maternal caloric/energy intake ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's n-3 intake (pre-study/baseline) (complete all):

Pre-study/baseline child's total (daily, weekly or monthly) n-3 intake via breast milk, diet (source) and/or formula/supplementation, with amount per n-3 type (EPA, DHA, ALA) (by group): BOX

Pre-study/baseline child's total (daily, weekly or monthly) dietary n-6/n-3 intake (by group) (e.g., group 1: 15/1; group 2: 10/1): BOX

Pre-study/baseline % (daily, weekly or monthly) child's caloric/energy intake from fat (by group): BOX

Child's types of pre-study/baseline diet (proportion of participants on each diet: in full; by group):

High fish diet

Fish-vegetarian diet

Low fish diet

Low fat diet

High fat diet

Mediterranean diet

Other

Unclear

Not reported

BOX

Absolute and relative n-3 fatty acid content of the pre-study/baseline child's diet (full; by group): BOX

How was the pre-study child's dietary intake of n-3, n-6 and n-6/n-3 evaluated/estimated (select all that apply)?

Nutritionist-administered quantitative food-frequency survey(s)

Nutritionist-administered semi-quantitative food-frequency survey(s)

Self-administered quantitative food-frequency survey(s)

Self-administered semi-quantitative food-frequency survey(s)

Parent-administered quantitative food-frequency survey(s)

Parent-administered semi-quantitative food-frequency survey(s)

Direct measurement(s) of food intake

Survey(s) (e.g., 24-hour recall): BOX

Survey(s), yet no details provided

Other: BOX

Unclear

Not reported

Not applicable

BOX

Total amount of child's n-3 intake via breast milk ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's total amount of dietary n-3 intake ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's total amount of n-3 intake from supplementation/formula ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Total amount of child's n-3 intake from breast milk, diet and supplementation/formula ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's total dietary n-6/n-3 intake ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's (daily, weekly or monthly) % caloric/energy intake from fat ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Pre-study/baseline maternal biomarkers data (by biomarker: e.g., breast milk, placental blood, RBCs; for DHA, EPA, AA, AA/EPA, AA/DHA, AA/EPA+DHA levels, with units (e.g., % total fatty acids; absolute amount) (full; by group): BOX

Maternal DHA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal EPA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal EPA+DHA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal AA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal AA/DHA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal AA/EPA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal AA/EPA+DHA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Pre-study/baseline child's biomarkers data (by biomarker: e.g., cord blood, RBCs; for DHA, EPA, AA, AA/EPA, AA/DHA, AA/EPA+DHA levels, with units (e.g., % total fatty acids; absolute amount) (full; by group): BOX

Child's DHA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's EPA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's EPA+DHA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's AA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's AA/DHA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's AA/EPA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's AA/EPA+DHA status (per biomarker) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

ON-STUDY

How was maternal on-study dietary intake of n-3 or n-6/n-3 evaluated/estimated (select all that apply)?

Nutritionist-administered quantitative food-frequency survey(s)

Nutritionist-administered semi-quantitative food-frequency survey(s)

Self-administered quantitative food-frequency survey(s)

Self-administered semi-quantitative food-frequency survey(s)

Parent-administered quantitative food-frequency survey(s)

Parent-administered semi-quantitative food-frequency survey(s)

Direct measurement(s) of food intake

Survey(s) (e.g., 24-hour recall): BOX

Survey(s), yet no details provided

Other: BOX

Unclear

Not reported

Not applicable

How was child's on-study dietary intake of n-3 or n-6/n-3 evaluated/estimated (select all that apply)?

Nutritionist-administered quantitative food-frequency survey(s)

Nutritionist-administered semi-quantitative food-frequency survey(s)

Self-administered quantitative food-frequency survey(s)

Self-administered semi-quantitative food-frequency survey(s)

Parent-administered quantitative food-frequency survey(s)

Parent-administered semi-quantitative food-frequency survey(s)

Direct measurement(s) of food intake

Survey(s) (e.g., 24-hour recall): BOX

Survey(s), yet no details provided

Other: BOX

Unclear

Not reported

Not applicable

On-study GROUP 1 (highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all):

total (daily, weekly or monthly) maternal n-3 dose via supplementation during pregnancy and/or breastfeeding, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., pregnancy = 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via diet during pregnancy and/or breastfeeding, with amount per n-3 type, source, frequency and timing of delivery (e.g., breastfeeding = NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., pregnancy = NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via all sources (diet+supplementation) during pregnancy and/or breastfeeding, per n-3 type (e.g., pregnancy = NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) maternal n-6 and/or n-6/n-3 intake from diet+supplementation during pregnancy and/or breastfeeding: BOX

type, source and total (daily, weekly or monthly) maternal intake of other mandated or permitted exposures during pregnancy and/or breastfeeding (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (maternal) (e.g., n=24/21): BOX

total (daily, weekly or monthly) child's n-3 intake amount via breast milk, with amount per n-3 type; source, frequency and timing of delivery: BOX

total (daily, weekly or monthly) child's n-3 dose via supplementation/formula, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients: BOX

total (daily, weekly or monthly) child's n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) child's n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) child's n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) child's intake of other mandated or permitted exposures (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (child) (e.g., n=24/21): BOX

On-study GROUP 2 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) maternal n-3 dose via supplementation during pregnancy and/or breastfeeding, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., pregnancy = 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via diet during pregnancy and/or breastfeeding, with amount per n-3 type, source, frequency and timing of delivery (e.g., breastfeeding = NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., pregnancy = NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via all sources (diet+supplementation) during pregnancy and/or breastfeeding, per n-3 type (e.g., pregnancy = NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) maternal n-6 and/or n-6/n-3 intake from diet+supplementation during pregnancy and/or breastfeeding: BOX

type, source and total (daily, weekly or monthly) maternal intake of other mandated or permitted exposures during pregnancy and/or breastfeeding (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (maternal) (e.g., n=24/21): BOX

total (daily, weekly or monthly) child's n-3 intake amount via breast milk, with amount per n-3 type; source, frequency and timing of delivery: BOX

total (daily, weekly or monthly) child's n-3 dose via supplementation/formula, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients: BOX

total (daily, weekly or monthly) child's n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) child's n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) child's n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) child's intake of other mandated or permitted exposures (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (child) (e.g., n=24/21): BOX

On-study GROUP 3 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) maternal n-3 dose via supplementation during pregnancy and/or breastfeeding, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., pregnancy = 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via diet during pregnancy and/or breastfeeding, with amount per n-3 type, source, frequency and timing of delivery (e.g., breastfeeding = NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., pregnancy = NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via all sources (diet+supplementation) during pregnancy and/or breastfeeding, per n-3 type (e.g., pregnancy = NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) maternal n-6 and/or n-6/n-3 intake from diet+supplementation during pregnancy and/or breastfeeding: BOX

type, source and total (daily, weekly or monthly) maternal intake of other mandated or permitted exposures during pregnancy and/or breastfeeding (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (maternal) (e.g., n=24/21): BOX

total (daily, weekly or monthly) child's n-3 intake amount via breast milk, with amount per n-3 type; source, frequency and timing of delivery: BOX

total (daily, weekly or monthly) child's n-3 dose via supplementation/formula, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients: BOX

total (daily, weekly or monthly) child's n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) child's n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) child's n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) child's intake of other mandated or permitted exposures (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (child) (e.g., n=24/21): BOX

On-study GROUP 4 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) maternal n-3 dose via supplementation during pregnancy and/or breastfeeding, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., pregnancy = 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via diet during pregnancy and/or breastfeeding, with amount per n-3 type, source, frequency and timing of delivery (e.g., breastfeeding = NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., pregnancy = NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via all sources (diet+supplementation) during pregnancy and/or breastfeeding, per n-3 type (e.g., pregnancy = NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) maternal n-6 and/or n-6/n-3 intake from diet+supplementation during pregnancy and/or breastfeeding: BOX

type, source and total (daily, weekly or monthly) maternal intake of other mandated or permitted exposures during pregnancy and/or breastfeeding (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (maternal) (e.g., n=24/21): BOX

total (daily, weekly or monthly) child's n-3 intake amount via breast milk, with amount per n-3 type; source, frequency and timing of delivery: BOX

total (daily, weekly or monthly) child's n-3 dose via supplementation/formula, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients: BOX

total (daily, weekly or monthly) child's n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) child's n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) child's n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) child's intake of other mandated or permitted exposures (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (child) (e.g., n=24/21): BOX

On-study GROUP 5 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) maternal n-3 dose via supplementation during pregnancy and/or breastfeeding, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., pregnancy = 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via diet during pregnancy and/or breastfeeding, with amount per n-3 type, source, frequency and timing of delivery (e.g., breastfeeding = NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., pregnancy = NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via all sources (diet+supplementation) during pregnancy and/or breastfeeding, per n-3 type (e.g., pregnancy = NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) maternal n-6 and/or n-6/n-3 intake from diet+supplementation during pregnancy and/or breastfeeding: BOX

type, source and total (daily, weekly or monthly) maternal intake of other mandated or permitted exposures during pregnancy and/or breastfeeding (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (maternal) (e.g., n=24/21): BOX

total (daily, weekly or monthly) child's n-3 intake amount via breast milk, with amount per n-3 type; source, frequency and timing of delivery: BOX

total (daily, weekly or monthly) child's n-3 dose via supplementation/formula, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients: BOX

total (daily, weekly or monthly) child's n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) child's n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) child's n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) child's intake of other mandated or permitted exposures (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (child) (e.g., n=24/21): BOX

On-study GROUP 6 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) maternal n-3 dose via supplementation during pregnancy and/or breastfeeding, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., pregnancy = 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via diet during pregnancy and/or breastfeeding, with amount per n-3 type, source, frequency and timing of delivery (e.g., breastfeeding = NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., pregnancy = NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) maternal n-3 exposure via all sources (diet+supplementation) during pregnancy and/or breastfeeding, per n-3 type (e.g., pregnancy = NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) maternal n-6 and/or n-6/n-3 intake from diet+supplementation during pregnancy and/or breastfeeding: BOX

type, source and total (daily, weekly or monthly) maternal intake of other mandated or permitted exposures during pregnancy and/or breastfeeding (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (maternal) (e.g., n=24/21): BOX

total (daily, weekly or monthly) child's n-3 intake amount via breast milk, with amount per n-3 type; source, frequency and timing of delivery: BOX

total (daily, weekly or monthly) child's n-3 dose via supplementation/formula, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients: BOX

total (daily, weekly or monthly) child's n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) child's n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) child's n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) child's intake of other mandated or permitted exposures (e.g., vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (child) (e.g., n=24/21): BOX

protocol (e.g., what is mandated vs. permitted), with method and target values, to modify daily, weekly or monthly n-6 or n-6/n-3 maternal intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet) (by population, by group): BOX

protocol (e.g., what is mandated vs. permitted), with method and target values, to modify daily, weekly or monthly child's n-6 or n-6/n-3 intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet) (by population, by group): BOX

Briefly describe whether there was a clearly planned and instituted difference, between study groups, in their (daily, weekly or monthly) total-gram n-3 and/or n-6/n-3 intake (by population): BOX

Briefly describe whether there was a clearly planned and instituted equivalence, across study groups, of (daily, weekly or monthly) caloric/energy intake from study-relevant exposures/interventions (by population): BOX

Briefly describe any problems with compliance whereby notable deviations (e.g., decreases) from the planned amounts of intake (e.g., frequency of breastfeeding, formula, servings) in one or more of the study groups violated the difference(s) established a priori between study groups for n-3 and/or n-6/n-3 intake or the equivalence established a priori across study groups for caloric/energy intake (full; by group; by population): BOX

Briefly describe whether, and which, study groups/participants were asked to maintain their (pre-study/baseline) background diet while on-study (full; by group; by population): BOX

Briefly describe whether, and how, without specific instruction to do so, or with specific instruction not to do so, participants' (pre-study/baseline) background diet was altered while on-study (full; by group): BOX

Briefly describe whether, and which, study groups/participants were asked to maintain their (pre-study/baseline) therapies/medications while on-study (full; by group): BOX

n-3: Briefly describe whether, and how, without specific instruction to do so, or with specific instruction not to do so, participants' (pre-study/baseline) therapies/medication were altered while on-study (full; by group): BOX

Briefly describe any evidence of selection bias: BOX

Child's prenatal history ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's neonatal history (up to 28 days of age) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's pediatric history ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's weight (Pc) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's height (Pc) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's head circumference (Pc) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's growth patterns (percentile's profile) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's medications/treatments: ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's visual function ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's cognitive developmental history and/or status ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's neurodevelopmental history and/or status ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Child's use of other licit (prescription and non-prescription) drugs, supplements (e.g., vitamins, minerals) and/or complementary/alternative therapies (specify) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal age at conception and at delivery ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline were taken into consideration in the study analysis: BOX

Maternal gynaecologic history ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Number of premature deliveries: ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

History of eclampsia/preeclampsia ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

History of gestational hypertension ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal obstetric history ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline were taken into consideration in the study analysis: BOX

Maternal obstetric history of current pregnancy ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal medical status ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal medication and/or treatment types and doses during pregnancy and/or breast-feeding (clarify) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal use of other licit (prescription and non-prescription) drugs, supplements (e.g., vitamins, minerals) and/or complementary/alternative therapies during current pregnancy and/or breastfeeding ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal (ab)use of alcohol, illicit drugs and/or use or exposure to smoking tobacco during current pregnancy and/or breastfeeding ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Maternal socioeconomic status (i.e., employment status, income, marital status, and education) (specify) ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Name of n-3(-containing) product (e.g., Almarin, Coromega, Eiconol; Efamed, Epagis, MaxEPA, Menhaden oil, ResQ, Omacor, Ropufa, Similac, Enfalac, Isomil, etc.): BOX

Manufacturer (per product): BOX

Purity data (per product): BOX

Presence of other, potentially active agents in n-3 product (per product): BOX

n-3 composition (%) of the exposure (e.g., 18% EPA, 12% DHA in each fish oil capsule) (per product): BOX

Reported method(s) to maintain the freshness (i.e., preclude rancidity) of n-3 exposures/interventions (e.g., added anti-oxidants to capsules, with fish oil exposure, to minimize oxidation): BOX

Reported method(s) to eliminate methylmercury from fish or its products/derivatives: BOX

Note any descriptions of inappropriate methods of lipid extraction/preparation (e.g., failure to extract blood after a [overnight] fasting period; failure to collect blood in EDTA- or EGTA-containing vials): BOX

Note any descriptions of inappropriate methods of lipid storage (e.g., failure to store samples at –70 to –80 degrees C if not analyzed immediately): BOX

Note any descriptions of inappropriate methods of lipid analysis (e.g., failure to conduct lab measurements on coded samples by technicians blinded to participants' identity and allocation; failure to use a standard protocol [e.g., Bligh & Dyer] requiring, for example, purging samples with nitrogen, or using thin-layer chromatography or gas liquid chromatography): BOX

Adequacy of method to deodorize smell of especially fish oil exposure (select one):

Adequate = reported that study participants could not reliably guess which exposure they received

Inadequate = reported that participants could reliably guess which exposure they received

Unclear = incomplete or conflicting data reported

Not reported = no method reported, or method reported but no data reported

Not applicable = did not use an exposure requiring or permitting such a method (e.g., flaxseed; full fish servings)

If this is a controlled study, briefly describe whether clinical outcome data from all study groups (e.g., active vs placebo) were simultaneously entered into data analysis: BOX

If this is a controlled study, briefly describe whether biomarker data from all study groups (e.g., active vs placebo) were simultaneously entered into data analysis: BOX

Data were analyzed according to which criterion (select one)?

Intention-to-treat (all randomized/enrolled)

Those receiving at least one dose/serving

Those completing the study (i.e., with final follow-up data)

Unclear

Other: BOX

Was the study adequately powered to detect a difference? BOX

Any further comments about the study: BOX

## Quality Assessment Form—Randomized Controlled Trials

1. Randomization: Was the study described as randomized (i.e. including words such as

randomly, random, randomization)? Yes = 1 No = 0 =___

A trial reporting that it is ‘randomized’ is to receive one point. Trials describing an appropriate method of randomization (table of random numbers, computer generated) receive an additional point.

Appropriate = 1 Not appropriate = 0 = ___

However, if the report describes the trial as randomized and uses an inappropriate method of randomization (e.g. date of birth, hospital numbers), a point is deducted.

TOTAL POINTS: 0 1 2 [underlined: SCORE]= ___

• Double-blinding: Was the study described as double-blind?

Yes = 1 No = 0 =___

A trial reporting that it is ‘double-blind’ is to receive one point. Trials that describe an appropriate method of double-blinding (identical placebo: color, shape, taste) are to receive an additional point. Yes = 1 No = 0 = ___

However, if the report describes the trial as double-blind and uses an inappropriate method (e.g. comparison of tablets vs. injection with no dummy), a point is deducted.

TOTAL POINTS: 0 1 2 [underlined: SCORE]= ___

3. Withdrawals and dropouts: Was there a description of withdrawals and dropouts?

Yes = 1 No = 0 [underlined: SCORE]= ___

A trial reporting the number of and reasons for withdrawals or dropouts is to receive one point. If there is no description, no point is given.

[underlined: JADAD TOTAL SCORE]= ___

4. Adequacy of Allocation Concealment: ( select one ):

-Central randomization; numbered or coded bottles or containers; drugs prepared by a pharmacy, serially numbered, opaque, sealed envelopes, etc ADEQUATE

-Alternation; reference to case record # or date of birth, etc INADEQUATE

-Allocation concealment is not reported, or, fits neither category UNCLEAR

## Quality Assessment (Internal Validity) Forms—Designs Other than an RCT

Controlled Study Designs

DESIGN CASE-CONTROL STUDY (Newcastle-Ottawa, with assessment of an additional confounder)

1. Is the case definition adequate?
  a. yes, with independent validation (e.g., clinical/research diagnostic criteria) (1 point)
  b. yes: e.g., record linkage or based on reports
  c. no description
2. Representativeness of the cases
  a. consecutive or obviously representative series of cases (1 point)
  b. potential for selection biases, or not stated
3. Selection of controls
  a. community controls (1 point)
  b. hospital controls
  c. no description
4. Definition of controls
  a. no history of disease (requires clinical/research diagnostic criteria to determine this) (1 point)
  b. no description of source
5. Comparability of cases and controls on the basis of the design or analysis:
  a. study controls for maternal background diet (omega-6/omega-3 fatty acid intake) at baseline and in possible changes during “intervening period” (1 point)
  b. study fails to control for this confounding influence
6. Comparability of cases and controls on the basis of the design or analysis:
  a. study controls for age and sex (only child) at baseline (1 point)
  b. study fails to control for this confounding influence
7. Comparability of cases and controls on the basis of the design or analysis:
  a. study controls for maternal obstetric history (e.g., Gestational age) or child's health status (at birth) at baseline and in possible changes during “intervening period” (1 point)
  b. study fails to control for this confounding influence
8. Comparability of cases and controls on the basis of the design or analysis:
  a. study controls for child's pre/term status and/or maternal socieconomic status at baseline (1 point)
  b. study fails to control for this confounding influence
9. Comparability of cases and controls on the basis of the design or analysis:
  a. study controls for maternal smoking status at baseline and in possible changes during “intervening period” (1 point)
  b. study fails to control for this confounding influence
10. Ascertainment of exposure
  a. validated method used to extract, prepare, store and analyze lipid data where appropriate in cases/controls (1 point)
  b. Inappropriate method
  c. no description
11. Same method of ascertainment for cases and controls
  a. yes (1 point)
  b. no
12. Non-response rate (blood samples analyzed)
  a. same rate for both groups (1 point)
  b. non respondents described
  c. rate different and no designation

DESIGN: (MULTIPLE-GROUP) CROSS SECTIONAL STUDY

1. Control for selection bias
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
2. Description of the same validated method to distinguish the study populations (i.e., to confirm pre/term status, presence or absence of pre-eclampsia, etc.)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
3. Homogeneity of the target population
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Comparability of study groups on the basis of the design or analysis: age and sex (only child)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Comparability of study groups on the basis of the design or analysis: omega-3 fatty acid intake in recent (last 6 months) background diet (maternal)
6. a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
7. Comparability of study groups on the basis of the design or analysis: omega-6 fatty acid intake, or omega-6/omega-3 fatty acid intake ratio, in recent (last 6 months) background diet (maternal)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
8. Comparability of study groups on the basis of the design or analysis: current smoker status (maternal)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Comparability of study groups on the basis of the design or analysis: Gestational age (maternal)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
10. Comparability of study groups on the basis of the design or analysis: pre/term status (child)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
11. Description of a validated primary clinical outcome measure(s)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
12. Description of the same appropriate methods used to extract, prepare, store and analyze lipid data from all study populations
  a. No inappropriate descriptions = 1
  b. At least one inappropriate description = 0
  c. Different methods used for different study groups = 0
  d. Unable to determine for one or more of the methods = 0

Uncontrolled Study Designs

DESIGN: SINGLE PROSPECTIVE COHORT STUDY (Modified Newcastle-Ottawa)

1. Representativeness of the exposed cohort
  a. Truly or somewhat representative of the average individual at no (or elevated) risk/potential for a given outcome (defined by the report) in the community = 1
  b. Selected group of users e.g., nurses, volunteers = 0
  c. No description of the derivation of the cohort = 0
2. Ascertainment of exposure
  a. Validated dietary assessment questionnaire or structured interview = 1
  b. Written self-report = 0
  c. No description = 0
3. Demonstration that outcome of interest was not present at start of study
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Description of a validated method to quantify the amount, per type, of omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Assessment of outcome
  a. Independent blind assessment = 1
  b. Record linkage = 1
  c. Self-report = 0
  d. No description = 0
6. Was followup long enough for outcomes to occur?
  a. Yes (maternal: until delivery) = 1
  b. No = 0
  c. Unable to determine = 0
7. Adequacy of followup of cohort
  a. Complete followup, all subjects accounted for = 1
  b. Subjects lost to followup unlikely to introduce bias, small number lost, at least 90% followup, or description provided of those lost = 1
  c. Followup rate of less than 90% and no description of those lost = 0
8. Analytic control for confounding: age and sex (child)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Analytic control for confounding: omega-6 fatty acid intake or omega-6/omega-3 fatty acid intake ratio
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
10. Analytic control for confounding: smoking history (maternal)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

## Applicability Indices

For studies involving at least one target maternal population.

Assign ‘I’ to a target study population of otherwise “healthy” North American (or similar) pregnant women or mothers of preterm or term infants representing a somewhat broad socio-demographic spectrum (i.e., age, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15).

Assign ‘II’ to a target study population of otherwise ‘healthy’ North American (or similar) of pregnant women or mothers of preterm or term infants, yet representing a more circumscribed socio-demographic picture (e.g., Asian-American/Canadian), and likely eating a diet “somewhat different” from that of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio notably less than 15, yet likely not reaching a value of 4, such as observed in Japan).

Assign ‘III’ to a target study population of pregnant women or mothers of preterm or term infants representing a population whose socio-demographic characteristics are notably “atypical” of a broad spectrum North American population, and eating a diet that is “notably different” from that of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio perhaps reaching a value of 4, such as observed in Japan, or 38–50, as observed in urban India).

Assign ‘X’ when applicability cannot be ascertained due to incomplete or conflicting reporting of the details concerning the target study population, particularly relating to the background diet.

For studies involving a target population with or without a known elevated risk for a particular pregnancy and/or infant outcome

Assign ‘I’ to a target study population of otherwise “healthy” North American (or similar) of pregnant women or mothers of preterm or term infants, with or without a known elevated risk for pregnancy or child's outcomes (e.g., IUGR), representing a somewhat broad socio-demographic spectrum (i.e., age, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio of at least 15).

Assign ‘II’ to a target study population of otherwise “healthy” North American (or similar) of pregnant women or mothers of preterm or term infants, with or without a known elevated risk for pregnancy or child's outcomes (e.g., IUGR), yet representing a more circumscribed socio-demographic picture (e.g., Asian-American/Canadian), and likely eating a diet “somewhat different” from that of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio notably less than 15, yet likely not reaching a value of 4, as observed in Japan).

Assign ‘III’ to a target study population of otherwise “healthy” of pregnant women or mothers of preterm or term infants, with or without a known elevated risk for pregnancy or child's outcomes (e.g., IUGR), yet representing a very circumscribed population whose socio-demographic characteristics are “notably atypical” of a broad spectrum North American population, and eating a diet that is “notably different” from that of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio perhaps reaching a value of 4, such as observed in Japan, or 38–50, as observed in urban India).

Assign ‘X’ when applicability cannot be ascertained due to incomplete or conflicting reporting of the details concerning the target study population, particularly relating to the background diet.