# Appendix A. Search Strategies

## Search Strategy 1

Ovid interface for Medline, MEDLINE(R) In-Process & Other Non-Indexed Citations, Embase, Cochrane Central Register of Controlled Trials, CDSR, DARE

1. exp growth/
2. exp child development/
3. Gestational Age/
4. (Gestat$ and (age$ or durat$ or week$)).tw.
5. Infant, Premature/
6. exp Infant, Low Birth Weight/
7. (Prematur$ or preterm or pre-term).mp.
8. ((Infant$ or baby) adj3 (low adj3 (birthweight or weight))).mp.
9. ((Infant$ or baby or birth) adj3 (prematur$ or gestational age)).mp.
10. (newborn or neonatal).mp.
11. Retinopathy of Prematurity/
12. retrolental fibroplasia$.mp.
13. Retinopathy of Prematurity.tw.
14. or/1–13
15. Fetal Growth Retardation/
16. exp “Embryo and Fetal Development”/
17. exp Fetus/
18. ((fetal or fetus or intrauterine) adj3 (growth or develop$)).mp.
19. or/15–18
20. Pre-Eclampsia/
21. Preeclamp$.mp.
22. (Pregnan$ adj10 Toxemia$).mp.
23. ((Gestation$ or pregnan$) and (hypertens$ or toxemia$)).mp.
24. gestat$.mp.
25. 24 and (child$ or newborn$ or infan$ or neonat$ or baby or babies or pediatr$ or paediatr$).tw.
26. or/20–23,25
27. exp fatty acids, omega-3/
28. fatty acids, essential/
29. Dietary Fats, Unsaturated/
30. linolenic acids/
31. exp fish oils/
32. (n 3 fatty acid$ or omega 3).tw.
33. docosahexa?noic.tw,hw,rw.
34. eicosapenta?noic.tw,hw,rw.
35. alpha linolenic.tw,hw,rw.
36. (linolenate or cervonic or timnodonic).tw,hw,rw.
37. menhaden oil$.tw,hw,rw.
38. (mediterranean adj diet$).tw.
39. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
40. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
41. (fish adj2 oil$).tw.
42. (cod liver oil$ or marine oil$ or marine fat$).tw.
43. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
44. (fish consumption or fish intake or (fish adj2 diet$)).tw.
45. diet$ fatty acid$.tw.
46. or/27–45
47. dietary fats/
48. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
49. random$.tw.
50. exp clinical trials/ or evaluation studies/
51. follow-up studies/ or prospective studies/
52. or/48–51
53. 47 and 52
54. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
55. (omega 3 or n 3).mp.
56. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
57. 55 and 56
58. 46 or 53 or 54 or 57
59. 14 and 58
60. limit 59 to all child <0 to 18 years>
61. 19 and 58
62. limit 61 to human
63. 26 and 58
64. limit 63 to human
65. or/60,62,64

## Search Strategy 2

CAB Health on Silverplatter

#1 growth in SU

#2 “postnatal-development” in SU

#3 “cognitive-development” in SU

#4 child* develop* in ti,ab,id

#5 psychomotor develop* in ti,ab,id

#6 (Gestat* and (age* or durat* or week*)) in ti,ab,id

#7 premature infants in SU

#8 low birth weight infants in SU

#9 (Prematur* or preterm or pre-term) in ti,ab,id

#10 (newborn* or neonatal*) in ti,ab,id

#11 ((Infant* or baby or babies or birth*) near3 (prematur* or gestational age)) in ti,ab,id

#12 ((Infant* or baby or babies) near3 (low near3 (birthweight or weight))) in ti,ab,id

#13 retinopathy in SU

#14 Retinopathy of Prematurity in ti,ab,id

#15 retrolental fibroplasia* in ti,ab,id

#16 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 or #13 or #14 or #1535419

#17 fetal growth in SU

#18 gestation period in SU

#19 explode embryonic development in SU

#20 explode fetus in SU

#21 ((fetal or fetus or intrauterine) near3 (growth or develop*)) in ti,ab,id

#22 #17 or #18 or #19 or #20 or #214221

#23 Preeclampsia in SU

#24 pregnancy toxaemia in SU

#25 Preeclamp* in ti,ab,id

#26 Pre-eclamp* in ti,ab,id

#27 Toxemia*in ti,ab,id

#28 ((Gestation* or pregnan*) and hypertens*) in ti,ab,id

#29 pregnancy-induced hypertens* in ti,ab,id

#30 (gestat* in ti,ab,id) and ((child* or newborn* or infan* or neonat* or baby or babies or pediatr* or paediatr* or human) in ti,ab,id)+A71

#31 #23 or #24 or #25 or #26 or #27 or #28 or #29 or #304754

#32 baby* or babies* or newborn* or infan* or neonat* or preschool* or pre-school* or child*115761

#33 (#22 or #31 or (#16 and #32)) and (man in od)16359

#34 omega 31043

#35 (“essential-fatty-acids” in SU) or (“linolenic-acid” in SU)1895

#36 (“docosahexaenoic-acid” in SU) or (“eicosapentaenoic-acid” in SU)1440

#37 explode “plant-oils” in SU

#38 explode “fish-oils” in SU

#39 “fish-consumption” in SU

#40 “polyenoic-fatty-acids” in SU

#41 “polyunsaturated-fats” in SU

#42 “dietary-fat” in SU

#43 (n 3 fatty acid* or omega 3) in ti,ab,id

#44 (docosahexanoic or docosahexaenoic) in ti,ab,id

#45 (eicosapentanoic or eicosapentaenoic) in ti,ab,id

#46 (alpha linolenic)in ti,ab,id

#47 (linolenate or cervonic or timnodonic) in ti,ab,id

#48 (mediterranean diet) in ti,ab,id

#49 ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or menhaden) and oil*) in ti,ab,id

#50 (walnut* or butternut* or soybean* or pumpkin seed*) in ti,ab,id

#51 (fish oil* or cod liver oil* or marine oil* or marine fat*) in ti,ab,id

#52 (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov*) in ti,ab,id

#53 (fish consumption or fish intake) in ti,ab,id

#54 (diet* fatty acid*) in ti,ab,id

#55 (ropufa or maxepa or omacor or efamed or resq or epagis or almarin or coromega) in ti,ab,id

#56 ((omega 3 or n 3) and (polyunsaturated fat* or pufa or dha or epa or long chain or longchain or lc*)) in ti,ab,id

#57 “long-chain-fatty-acids” in SU

#58 (fish and diet) in ti,ab,id

#59 (explode “essential-oils” in SU) or (explode “olive-oil” in SU) or (explode “palm-oils” in SU) or (explode “plant-oils” in SU) or (explode “seed-oils” in SU)7742

#60 explode “fish-liver-oils” in SU

#61 (“long-chain-fatty-acids” in SU) or (((omega 3 or n 3) and (polyunsaturated fat* or pufa or dha or epa or long chain or longchain or lc*)) in ti,ab,id) or ((ropufa or maxepa or omacor or efamed or resq or epagis or almarin or coromega) in ti,ab,id) or ((diet* fatty acid*) in ti,ab,id) or ((n 3 fatty acid* or omega 3) in ti,ab,id) or (“dietary-fat” in SU) or (“polyunsaturated-fats” in SU) or (“polyenoic-fatty-acids” in SU) or (“fish-consumption” in SU) or (explode “fish-oils” in SU) or (explode “plant-oils” in SU) or ((“docosahexaenoic-acid” in SU) or (“eicosapentaenoic-acid” in SU)) or ((“essential-fatty-acids” in SU) or (“linolenic-acid” in SU)) or (omega 3) or ((fish consumption or fish intake) in ti,ab,id) or ((salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov*) in ti,ab,id) or ((fish oil* or cod liver oil* or marine oil* or marine fat*) in ti,ab,id) or ((walnut* or butternut* or soybean* or pumpkin seed*) in ti,ab,id) or (((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or menhaden) and oil*) in ti,ab,id) or ((mediterranean diet) in ti,ab,id) or ((linolenate or cervonic or timnodonic) in ti,ab,id) or ((alpha linolenic)in ti,ab,id) or ((eicosapentanoic or eicosapentaenoic) in ti,ab,id) or ((docosahexanoic or docosahexaenoic) in ti,ab,id) or (explode “fish-liver-oils” in SU) or ((explode “essential-oils” in SU) or (explode “olive-oil” in SU) or (explode “palm-oils” in SU) or (explode “plant-oils” in SU) or (explode “seed-oils” in SU)) or ((fish and diet) in ti,ab,id)

#62 ((explode “almond-oil” in SU) or (explode “castor-oil” in SU) or (explode “coconut-oil” in SU) or (explode “cottonseed-oil” in SU) or (explode “groundnut-oil” in SU) or (explode “jojoba-oil” in SU) or (explode “linseed-oil” in SU) or (explode “maize-oil” in SU) or (explode “melon-seed-oil” in SU) or (explode “mustard-oil” in SU) or (explode “palm-kernel-oil” in SU) or (explode “rapeseed-oil” in SU) or (explode “rice-oil” in SU) or (explode “safflower-oil” in SU) or (explode “sesame-oil” in SU) or (explode “soyabean-oil” in SU) or (explode “sunflower-oil” in SU) or (explode “tung-oil” in SU) or (explode “wheat-germ-oil” in SU)) or ((“cod-liver-oil” in SU) or (“menhaden-oil” in SU))

#63 #61 or #62

#64 #33 and #63