# Appendixes

Appendix A. Search Strategies

Appendix B. Letter to Industry Representatives

Appendix C. Data Assessment and Data Abstraction Forms

Appendix D. Modified QUOROM Flow Chart

Appendix E. Evidence Tables

Appendix F. List of excluded studies (no RCTs)

Appendix G. Interventional Formula's Content

Appendix H. Listing of Excluded Studies at Level 2 and 3 Screening

Appendix I. Additional Acknowledgements