# Abbreviations

AA (20:4 n-6) | Arachidonic acid
AI | Adequate Intake
ALA (18:3 n-3) | Alpha linolenic acid
cAMP | Cyclic adenosine monophosphate
C5a | Complement fragment 5a
COX | Cyclooxygenase
DHA (22:6 n-3) | Docosahexaenoic acid
DTS | Dense tubular system
EAR | Estimated Average Requirement
EFA | Essential fatty acid
EPA (20:5 n-3) | Eicosapentaenoic acid
GLA (18:3 n-6) | Gamma linolenic acid
HDL | High density lipoprotein
IFN | Interferon
IgE | Immunoglobulin E
IL | Interleukin
LA (18:2 n-6) | Linoleic acid
LC PUFA | Long-chain polyunsaturated fatty acid
LDL | Low density lipoprotein
LT | Leukotriene
PG | Prostaglandin
PPAR | Peroxisome proliferator activated receptor
PUFA | Polyunsaturated fatty acid
RCT | Randomized Controlled Trial
RDA | Recommended Dietary Allowances
SREBP | Sterol regulatory element binding protein
Tg | Triglycerides
TNF | Tumor necrosis factor
Tx | Thromboxane
VLDL | Very low density lipoprotein