# Summary Table

Summary Table 1: Association between omega-3 fatty acid intake and onset of age-related macular degeneration (observational study)

Summary Table 1: Association between omega-3 fatty acid intake and onset of age-related macular degeneration (observational study)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Cho, 2001, US: 10–12 y single prospective cohort study ^79^ | By 1994, women (n=71,486) & men (n=41,474) ≥50 y of age | | Total quality: 5 [Grade: B] | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

ARMD = age-related macular degeneration

Summary Table 2: Association between omega-3 fatty acid intake and onset of age-related macular degeneration (observational studies)

Summary Table 2: Association between omega-3 fatty acid intake and onset of age-related macular degeneration (observational studies)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Seddon, 2001, US: case-control study ^82^ | Advanced ARMD cases (n=349) | Controls (n= 504) | Total quality: 8 [Grade: A] | II
Ouchi, 2002, Japan: case-control study ^81^ | Advanced ARMD cases (n=11) | Healthy controls (n=10) | Total quality: 0 [Grade: C] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

RBC = red blood cells;

ARMD = age-related macular degeneration

Summary Table 3: Association between omega-3 fatty acid intake and onset of age-related macular degeneration (observational studies)

Summary Table 3: Association between omega-3 fatty acid intake and onset of age-related macular degeneration (observational studies)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Mares-Perlman, 1995, US: retrospective population-based cohort study ^80^ | n=1,968 participants with exposure & clinical outcome data; 344 total ARMD diagnoses, including n=314 with early ARMD (i.e., soft distinct drusen [n=196]; retinal pigment epithelial degeneration [n=142]; increased retinal pigment [n=236]) & n=30 with late ARMD (i.e., geographic atrophy [n=9] vs exudative ARMD [n=21]) | | Total quality: 6 [Grade: B] | I
Smith, 2000, Australia: single population cross-sectional study ^83^ | n=2,900 with exposure & clinical outcome data; n=228 total ARMD diagnoses, including n=182 with early ARMD (i.e., soft indistinct or reticular drusen vs retinal pigmentary abnormalities) & n=46 with late ARMD (i.e., neovascular vs atrophic) | | Total quality: 5 [Grade: B] | III
Heuberger, 2001, US: single population cross-sectional study ^84^ | n=7,883 with exposure & clinical outcome data; pts ages 40–79 y included in analyses for early ARMD (n=644) & pts ages >60 y included in analyses for late ARMD (n=53) | | Total quality: 5 [Grade: B] | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

ARMD = age-related macular degeneration

Summary Table 4: Omega-3 fatty acid intake to slow the progression of age-related macular degeneration (RCT)

Summary Table 4: Omega-3 fatty acid intake to slow the progression of age-related macular degeneration (RCT)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Scorolli, 2002, Italy: 3 mo parallel RCT ^76^ | PDT + 200 mg/d vitamin E + 600 mg/d LA + 200 mg/d ALA + 200 mg/d DHA (n=20) | PDT alone (n=15) | Jadad total: 2 [Grade: C]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

LA = linoleic acid;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

d = day(s);

wk = week(s);

mo = month;

wt = weight;

Δ = change;

PDT = photodynamic therapy;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear)

Summary Table 5: Association between omega-3 fatty acid intake and decreasing the rate of progression to advanced forms of age-related macular degeneration (observational study)

Summary Table 5: Association between omega-3 fatty acid intake and decreasing the rate of progression to advanced forms of age-related macular degeneration (observational study)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Seddon, 2003, US: 4.6 y (mean) single prospective cohort study ^60^ | n=261 ARMD pts, 101 of whom progressed to advanced ARMD | | Total quality: 8 [Grade: A] | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

d = day(s);

wk = week(s);

mo = month;

wt = weight;

Δ = change;

ARMD = age-related macular degeneration

Summary Table 6: Omega-3 fatty acids to slow the progression of retinitis pigmentosa (RCT)

Summary Table 6: Omega-3 fatty acids to slow the progression of retinitis pigmentosa (RCT)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Hoffman, 2004, US: 4 y parallel RCT ^73^ | 400 mg/d DHA (n=23) | 400 mg/d corn/soy oil triglyceride placebo (n=21) | Jadad total: 4 [Grade: A]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

RBC = red blood cells;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear)

Summary Table 7: Omega-3 fatty acids to slow the progression of retinitis pigmentosa (quasi-experimental studies)

Summary Table 7: Omega-3 fatty acids to slow the progression of retinitis pigmentosa (quasi-experimental studies)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Dagnelie, 2000, US, Canada & 7 other countries: 6 mo comparative before-after study ^77^ | Lutein (40 mg/d for 9 wk, 20 mg/d thereafter) + 500 mg/d DHA + vitamin B complex (dose not reported) + 600 mg/d digestive enzymes (n=10) | lutein alone (40 mg/d for 9 wk, 20 mg/d thereafter) (n=10) | Total quality: 2 [Grade: C] | III
Hoffman, 1995, US: 6 wk noncomparative before-after study (Study 1) ^70^ | 3 g/day purified fish oil (0.7 g/day DHA, 1.3 g/day EPA) (n=3) | | Total quality: 4 [Grade: C] | X
Hoffman, 1995, US: 3 wk noncomparative before-after study (Study 2) ^70^ | EPA ethyl ester (dose not reported) (n=3) | | Total quality: 3 [Grade: C] | X

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change

Summary Table 8: Omega-3 fatty acids intake to slow the progression of proliferative retinopathy and clinically significant macular edema in patients with diabetic retinopathy (quasi-experimental study)

Summary Table 8: Omega-3 fatty acids intake to slow the progression of proliferative retinopathy and clinically significant macular edema in patients with diabetic retinopathy (quasi-experimental study)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Sorokin, 1997, Russia: 3 mo noncomparative before-after study ^75^ | 4g/d DHA+EPA (n=48) | | Total quality: 1 [Grade: C] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

d = day(s);

wk = week(s);

mo = month;

wt = weight;

Δ = change

Summary Table 9: Association between omega-3 fatty acid intake and onset of age-related cataracts (observational studies)

Summary Table 9: Association between omega-3 fatty acid intake and onset of age-related cataracts (observational studies)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Cumming, 2000, Australia: single population cross-sectional study ^86^ | Elderly urban dwellers (median age: 65 y) (n=2,900) | | Total quality: 5 [Grade: B] | III
Arnarsson, 2002, Iceland: single population cross-sectional study ^85^ | Pts ≥50 y of age (n=1,045) | | Total quality: 5 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change

Summary Table 10: Omega-3 fatty acids intake to slow the progression of age-related cataracts (quasi-experimental study)

Summary Table 10: Omega-3 fatty acids intake to slow the progression of age-related cataracts (quasi-experimental study)

Author, Year, Location: Length & Design | Study groups^1^ | | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Suzuki, 2001, Japan: 3 mo noncomparative before-after study ^78^ | 0.54 g/d DHA (n=14/15 pts with cataract) | | Total quality: 2 [Grade: C] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

d = day(s);

wk = week(s);

mo = month;

wt = weight;

Δ = change

Summary Table 11: Interventional studies reporting adverse events (e.g., side effects) or contraindications

Summary Table 11: Interventional studies reporting adverse events (e.g., side effects) or contraindications

Author, Year, Location: Length & Design | Study groups^ 1^ | | Safety data
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Hoffman, 2004, US: 4 y RCT ^73^ | 400 mg/d DHA (n=23) | 400 mg/d corn/soy oil triglyceride placebo (n=21) | [underlined: Placebo group (n=6 pts)]: bruising* (n=2 events); a sinusitis (n=1) preceding prolonged epistaxis (n=1); prolonged bleeding (n=1); eructation (i.e., burp back; n=1); nausea (n=1); & flatulence (n=1); [underlined: DHA group (n=4 pts)]: eructation (n=1 event); acne* (n=1); headache* (n=2); ear infection* (n=1); fatigue* (n=1); & weight gain* (n=1).

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

* Established that “not study related;”

** No explicit description that adverse events specifically linked to exposure, only that associated with participants in a specific study group;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month