# Summary Matrix

Summary Matrix 1: Study quality and applicability of evidence regarding the association of omega-3 fatty acid intake and onset of age-related macular degeneration (all designs)

Summary Matrix 1: Study quality and applicability of evidence regarding the association of omega-3 fatty acid intake and onset of age-related macular degeneration (all designs)

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Cho | 2001 | >111k
| | | | | Mares-Perlman | 1995 | 1968
| | | | | Heuberger | 2001 | 7883
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Seddon | 2001 | 853
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Smith | 2000 | 2900 | Ouchi | 2002 | 21

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment;

k = 1000's

Summary Matrix 2: Study quality and applicability of evidence regarding the association of omega-3 fatty acid intake and progression of retinitis pigmentosa (all designs)

Summary Matrix 2: Study quality and applicability of evidence regarding the association of omega-3 fatty acid intake and progression of retinitis pigmentosa (all designs)

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | Hoffman^A^ | 2004 | 44
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | | | | Dagnelie | 2000 | 20

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment;

k = 1000's

Summary Matrix 3: Study quality and applicability of evidence regarding the association of omega-3 fatty acid intake and onset of age-related cataracts (observational studies)

Summary Matrix 3: Study quality and applicability of evidence regarding the association of omega-3 fatty acid intake and onset of age-related cataracts (observational studies)

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Cumming | 2000 | 2900
| | | | | Arnarsson | 2002 | 1045

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment;

k = 1000's