# Listing of Included Studies for Evidence Tables

Arnarsson A, Jonasson F, Sasaki H, Ono M, Jonsson V, Kojima M, et al. Risk factors for nuclear lens opacification: the Reykjavik Eye Study. Dev Ophthalmol. 2002;35:12-20. [pmid: 12061269].
Cho E, Hung S, Willett W C, Spiegelman D, Rimm E B, Seddon J M, et al. Prospective study of dietary fat and the risk of age-related macular degeneration. Am J Clin Nutr. 2001;73(2):209-18. [pmid: 11157315].
Cumming R G, Mitchell P, Smith W. Diet and cataract. The Blue Mountains Eye Study. Ophthalmology. 2000;107(3):450-6. [pmid: 10711880].
Dagnelie G, Zorge I S, McDonald T M. Lutein improves visual function in some patients with retinal degeneration: a pilot study via the Internet. Optometry. 2000;71(3):147-64. [pmid: 10970259].
Heuberger R A, Mares-Perlman J A, Klein R, Klein B E K, Millen A E, Palta M. Relationship of dietary fat to age-related maculopathy in the Third National Health and Nutrition Examination Survey. Arch Ophthalmol. 2001;119(12):1833-8. [pmid: 11735796].
Hoffman D R, Locke K G, Wheaton D H, Fish G E, Spencer R, Birch D G. A randomized, placebo-controlled clinical trial of docosahexaenoic acid supplementation for X-linked retinitis pigmentosa. Am J Ophthalmol. 2004;137(4):704-18. [pmid: 15059710].
Hoffman D R, Uauy R, Birch D G. Metabolism of omega-3 fatty acids in patients with autosomal dominant retinitis pigmentosa. Exp Eye Res. 1995;60(3):279-89. [pmid: 7789408].
Mares-Perlman J A, Brady W E, Klein R, VandenLangenberg G M, Klein B E, Palta M. Dietary fat and age-related maculopathy. Arch Ophthalmol. 1995;113(6):743-8. [pmid: 7786215].
Ouchi M, Ikeda T, Nakamura K, Harino S, Kinoshita S. A novel relation of fatty acid with age-related macular degeneration. Ophthalmologica. 2002;216(5):363-7. [pmid: 12424405].
Scorolli L, Scalinci S Z, Limoli P G, Morara M, Vismara S, Scorolli L, et al. [Photodynamic therapy for age related macular degeneration with and without antioxidants]. [French]. Can J Ophthalmol. 2002;37(7):399-404. [pmid: 12518724].
Seddon J M, Cote J, Rosner B. Progression of age-related macular degeneration: association with dietary fat, transunsaturated fat, nuts, and fish intake. Arch Ophthalmol. 2003;121(12):1728-37. [pmid: 14662593].
Seddon J M, Rosner B, Sperduto R D, Yannuzzi L, Haller J A, Blair N P, et al. Dietary fat and risk for advanced age-related macular degeneration. Arch Ophthalmol. 2001;119(8):1191-9. [pmid: 11483088].
Smith W, Mitchell P, Leeder S R. Dietary fat and fish intake and age-related maculopathy. Arch Ophthalmol. 2000;118(3):401-4. [pmid: 10721964].
Sorokin E L, Smoliakova G P, Bachaldin I L. [Clinical efficacy of eiconol in patients with diabetic retinopathy]. [Russian]. Vestn Oftalmol. 1997;113(4):37-9. [pmid: 9381643].
Suzuki H, Morikawa Y, Takahashi H. Effect of DHA oil supplementation on intelligence and visual acuity in the elderly. World Rev Nutr Diet. 2001;88:68-71. [pmid: 11935973].
Wheaton D H, Hoffman D R, Locke K G, Watkins R B, Birch D G. Biological safety assessment of docosahexaenoic acid supplementation in a randomized clinical trial for X-linked retinitis pigmentosa. Arch Ophthalmol. 2003;121(9):1269-78. [pmid: 12963609].