# Listing of Excluded Studies at Level 2 Screening

Papers to appear in forthcoming issues. Gynecol Oncol 1998; 71(1): 147. Not a first publication of empirical evidence (e.g., review).
Ahn J, Wong J T, Molday R S. The effect of lipid environment and retinoids on the ATPase activity of ABCR, the photoreceptor ABC transporter responsible for Stargardt macular dystrophy. J Biol Chem. 2000;275(27):20399-20405. Not involving human participants. [pmid: 10767284].
Anderson R E, Maude M B, Lewis R A, et al. Abnormal plasma levels of polyunsaturated fatty acid in autosomal dominant retinitis pigmentosa. Exp Eye Res. 1987;44(1):155-159. No omega-3 fatty acid intervention/exposure. [pmid: 2951269].
Bazan N G. The metabolism of omega-3 polyunsaturated fatty acids in the eye: the possible role of docosahexaenoic acid and docosanoids in retinal physiology and ocular pathology. [Review] [56 refs]. Progress in Clinical & Biological Research. 1989;312(95):112. Not a first publication of empirical evidence (e.g., review).
Bazan N G, Scott B L. Docosahexaenoic acid metabolism and inherited retinal degenerations. [Review] [53 refs]. Progress in Clinical & Biological Research. 1987;247(103):118. Not a first publication of empirical evidence (e.g., review).
Bazan N G, Scott B L, Reddy T S, et al. Decreased content of docosahexaenoate and arachidonate in plasma phospholipids in Usher's syndrome. Biochemical & Biophysical Research Communications. 12-15. 1986;141(2):600-604. No omega-3 fatty acid intervention/exposure. [pmid: 2948509].
Birkle DL, Bazan NG. The arachidonic acid cascade and phospholipid and docosahexaenoic acid metabolism in the retina. Progress in Retinal Research 1986; pp 309–335. Not a first publication of empirical evidence (e.g., review).
Block K I. Multiple molecular targets in oncology and integrative care. Integr Cancer Ther. 2003;2(3):209-211. Not a first publication of empirical evidence (e.g., review). [pmid: 15035881].
Bloomgarden Z T. Inflammation and insulin resistance. Diabetes Care. 2003;26(6):1922-1926. Not a first publication of empirical evidence (e.g., review). [pmid: 12766135].
Bloomgarden Z T. International Diabetes Federation Meeting, 1997: Nephropathy, retinopathy, and glycation. Diabetes Care. 1998;21(9):1560-1566. Not a first publication of empirical evidence (e.g., review). [pmid: 9727909].
Blumenkranz M S, Russell S R, Robey M G, et al. Risk factors in age-related maculopathy complicated by choroidal neovascularization. Ophthalmology. 1986;93(5):552-558. No omega-3 fatty acid intervention/exposure. [pmid: 2425325].
Cardiac groups revise angina management guidelines. Am J Health Syst Pharm 2003;60(1):12. Not a first publication of empirical evidence (e.g., review).
Converse C A, Hammer H M, Packard C J, et al. Plasma lipid abnormalities in retinitis pigmentosa and related conditions. Trans Ophthalmol Soc U K. 1983;103(Pt 5):508-512. No omega-3 fatty acid intervention/exposure. [pmid: 6591588].
Das U N. Abrupt and complete occlusion of tumor-feeding vessels by gamma-linolenic acid. Adv Nutr Res. 2002;18(78):662-664. Not a first publication of empirical evidence (e.g., review).
Delton-Vandenbroucke I, Grammas P, Anderson RE. A role for cerebral and retinal endothelial cells in the supply of docosahexaenoic acid to the brain and the retina?. Lipids 1999;34 Suppl(S117). Not involving human participants.
Ernest I, Linner E, Svanborg A. Carbohydrate-rich, fat-poor diet in diabetes. Am J Med. 1965;39(4):594-600. No omega-3 fatty acid intervention/exposure. [pmid: 5319129].
Futterman S, Downer J L, Hendrickson A. Effect of essential fatty acid deficiency on the fatty acid composition, morphology, and electroretinographic response of the retina. Invest Ophthalmol. 1971;10(2):151-156. Not involving human participants. [pmid: 5545761].
Glickman R D. The origin of photo-oxidative stress in the aging eye. Prog Brain Res. 2001;131:699-712. Not a first publication of empirical evidence (e.g., review). [pmid: 11420981].
Goldberg J, Flowerdew G, Smith E, et al. Factors associated with age-related macular degeneration. An analysis of data from the first National Health and Nutrition Examination Survey. Am J Epidemiol. 1988;128(4):700-710. No omega-3 fatty acid intervention/exposure. [pmid: 3421236].
Gong J, Rosner B, Rees D G, et al. Plasma docosahexaenoic acid levels in various genetic forms of retinitis pigmentosa. Invest Ophthalmol Vis Sci. 1992;33(9):2596-2602. No omega-3 fatty acid intervention/exposure. [pmid: 1386350].
Grober U. Orthomolecular medicine: Usefulness of micronutrients in diabetes mellitus. Deutsche Apotheker Zeitung. 2002;142(7):46-52. Not a first publication of empirical evidence (e.g., review).
Hankinson S E, Stampfer M J, Seddon J M, et al. Nutrient intake and cataract extraction in women: a prospective study. BMJ. 1992;305(6849):335-339. No omega-3 fatty acid intervention/exposure. [pmid: 1392884]. [pmcid: 1882980].
Harding C O, Gillingham M B, van Calcar S C, et al. Docosahexaenoic acid and retinal function in children with long-chain 3-hydroxyacyl-CoA dehydrogenase deficiency. J Inherit Metab Dis. 1999;22(3):276-280. Not related to predefined eye health outcomes. [pmid: 10384386].
Hoffman D R, Wheaton D, Locke K G, et al. Rod ERG function and erythrocyte docosahexaenoic acid (DHA) in X-linked retinitis pigmentosa (XLRP). Invest Ophthalmol Vis Sci. 1997;38:S797. No omega-3 fatty acid intervention/exposure.
Hoffman D R, Birch D G. Docosahexaenoic acid in red blood cells of patients with X-linked retinitis pigmentosa. Invest Ophthalmol Vis Sci. 1995;36(6):1009-1018. No omega-3 fatty acid intervention/exposure. [pmid: 7730010].
Hoffman D R, Birch G. Omega 3 fatty acid status in patients with retinitis pigmentosa. [Review] [35 refs]. World Review of Nutrition & Dietetics. 1998;83(52):60. Not a first publication of empirical evidence (e.g., review).
Hoffman DR, Birch DG, Simopoulos AP. omega3 Fatty acid status in patients with retinitis pigmentosa. The return of omega3 fatty acids into the food supply 2001;52–60. Not a first publication of empirical evidence (e.g., review).
Hoffman D R, Demar J C, Heird W C, et al. Impaired synthesis of DHA in patients with X-linked retinitis pigmentosa. J Lipid Res. 2001;42(9):1395-1401. Not related to predefined eye health outcomes. [pmid: 11518758].
Hoffman D R, Uauy R, Birch D G. Red blood cell fatty acid levels in patients with autosomal dominant retinitis pigmentosa. Exp Eye Res. 1993;57(3):359-368. No omega-3 fatty acid intervention/exposure. [pmid: 8224023].
Holman R T, Bibus D M, Jeffrey G H, et al. Abnormal plasma lipids of patients with Retinitis pigmentosa. Lipids. 1994;29(1):61-65. No omega-3 fatty acid intervention/exposure. [pmid: 8139397].
Houtsmuller A J, Zahn K J, Henkes H E. Unsaturated fats and progression of diabetic retinopathy. Doc Ophthalmol. 4-15. 1980;48(2):363-371. No omega-3 fatty acid intervention/exposure. [pmid: 6995054].
Hruby K. Is retinitis pigmentosa absolutely incurable?. Klin Monatsbl Augenheilkd. 1988;192(4):358-359. No omega-3 fatty acid intervention/exposure. [pmid: 2969995].
Hruby K, Billek G. VERSORGUNG DER RETINA MIT (N-3) DOCOSAHEXAENSÄURE. Forum DR Med, 11 Jahrgang 1987;7/8(14). Not a first publication of empirical evidence (e.g., review).
Hruby K, Wiesflecker J. [Dry senile maculopathy: prevention and treatment in risky cases]. Klin Monatsbl Augenheilkd. 1983;182(6):570-575. No omega-3 fatty acid intervention/exposure. [pmid: 6876656].
Huq L, McLachlan T, Hammer H M, et al. An increased incidence of apolipoprotein E2/E2 and E4/E4 in retinitis pigmentosa. Lipids. 1993;28(11):995-998. No omega-3 fatty acid intervention/exposure. [pmid: 8277830].
Igal R A, Rhoads J M, Coleman R A. Neutral lipid storage disease with fatty liver and cholestasis. Journal of Pediatric Gastroenterology & Nutrition. 1997;25(5):541-547. Not a first publication of empirical evidence (e.g., review). [pmid: 9360211].
Innis S M, Sprecher H, Hachey D, et al. Neonatal polyunsaturated fatty acid metabolism. PUFA in Infant Nutrition: consensus and controversies, 7 9, November, 1996, Barcelona, Spain. 1999;34(2):139-149. Not a first publication of empirical evidence (e.g., review).
Ito T, Nakano M, Yamamoto Y, et al. Hemoglobin-induced lipid peroxidation in the retina: a possible mechanism for macular degeneration. Archives of Biochemistry & Biophysics. 2-1. 1995;316(2):864-872. Not involving human participants. [pmid: 7864645].
Jeffrey B G, Weisinger H S, Neuringer M, et al. The role of docosahexaenoic acid in retinal function. Symposium on PUFA in maternal and child health, Kansas City, Missouri, USA, 10 13 September 2000. 2001;36(9):859-871. Not a first publication of empirical evidence (e.g., review).
Jones D B, Carter R D, Haitas B, et al. Low phospholipid arachidonic acid values in diabetic platelets. British Medical Journal Clinical Research Ed. 1-15. 1983;286(6360):173-175. No omega-3 fatty acid intervention/exposure. [pmid: 6401517]. [pmcid: 1546357].
Kahn H A, Leibowitz H M, Ganley J P, et al. The Framingham Eye Study. II. Association of ophthalmic pathology with single variables previously measured in the Framingham Heart Study. Am J Epidemiol. 1977;106(1):33-41. No omega-3 fatty acid intervention/exposure. [pmid: 141882].
Kliffen M, Mooy C M, Luider T M, et al. Analysis of carbohydrate structures in basal laminar deposit in aging human maculae. Invest Ophthalmol Vis Sci. 1994;35(7):2901-2905. No omega-3 fatty acid intervention/exposure. [pmid: 8206707].
Kligler B, Lynch D. An integrative approach to the management of type 2 diabetes mellitus. Alternative Therapies in Health & Medicine. 2003;9(6):2. Not a first publication of empirical evidence (e.g., review).
Kurlak L O, Stephenson T J. Plausible explanations for effects of long chain polyunsaturated fatty acids (LCPUFA) on neonates. Archives of Disease in Childhood Fetal and Neonatal edition. 1999;80(2):F148-F154. Not a first publication of empirical evidence (e.g., review). [pmid: 10325796].
Lachance P A, Nakat Z, Jeong W S. Antioxidants: an integrative approach. Adv Nutr Res. 2001;17(10):835-838. Not a first publication of empirical evidence (e.g., review).
Lee J, Jiao X, Hejtmancik J F, et al. The metabolism of fatty acids in human Bietti crystalline dystrophy. Invest Ophthalmol Vis Sci. 2001;42(8):1707-1714. No omega-3 fatty acid intervention/exposure. [pmid: 11431432].
Leger C L, Fouret G, Bouvier S, et al. Docosahexaenoic acids and development of the retina. OCL Oleagineux, Corps Gras, Lipides. 1995;2(1):45-51. Not related to predefined eye health outcomes.
Leske M C, Chylack L T, Wu S Y. The Lens Opacities Case-Control Study. Risk factors for cataract. Arch Ophthalmol. 1991;109(2):244-251. No omega-3 fatty acid intervention/exposure. [pmid: 1993036].
Locke KG, Hoffman DR, Wheaton DH et al. Description of ongoing trial with fatty acid supplementation in X-linked retinitis pigmentosa. J.Opthalmic Photogr 1997;1927-31. Not a first publication of empirical evidence (e.g., review).
Lopez-Espinoza I, Howard-Williams J, Mann J I, et al. Fatty acid composition of platelet phospholipids in non-insulin-dependent diabetics randomized for dietary advice. Br J Nutr. 1984;52(1):41-47. No omega-3 fatty acid intervention/exposure. [pmid: 6743640].
MacDonald IM. What are your patients reading? Can J Ophthalmol 4-20-0143;37(3):141–43. Not a first publication of empirical evidence (e.g., review).
MacDonald I M, Hebert M, Yau R J, et al. Effect of docosahexaenoic acid supplementation on retinal function in a patient with autosomal dominant Stargardt-like retinal dystrophy. Br J Ophthalmol. 2004;88(2):305-306. Not related to predefined eye health outcomes. [pmid: 14736799]. [pmcid: 1772019].
Mares-Perlman J A, Brady W E, Klein B E, et al. Diet and nuclear lens opacities. Am J Epidemiol. 1995;141(4):322-334. No omega-3 fatty acid intervention/exposure. [pmid: 7840110].
McColl A J, Converse C A. Lipid studies in retinitis pigmentosa. Prog Lipid Res. 1995;34(1):1-16. Not a first publication of empirical evidence (e.g., review). [pmid: 7644551].
McLachlan T, McColl A J, Collins M F, et al. A longitudinal study of plasma n-3 fatty acid levels in a family with X-linked retinitis pigmentosa. Biochem Soc Trans. 1990;18(5):905-906. Not related to predefined eye health outcomes. [pmid: 2150655].
McLaren D S. A trawl through the current nutrition literature. Adv Nutr Res. 2002;18(4):361-363. Not a first publication of empirical evidence (e.g., review).
McMillan D E. Hemorheologic therapy to control diabetic vascular disease. Clin Hemorheol. 1992;12(6):787-796. Not a first publication of empirical evidence (e.g., review).
Minerva. Br Med J 1994; 308(6926):484. Not a first publication of empirical evidence (e.g., review).
Mori T A, Vandongen R, Masarei J R. Fish oil-induced changes in apolipoproteins in IDDM subjects. Diabetes Care. 1990;13(7):725-732. Not related to predefined eye health outcomes. [pmid: 2201495].
Muhlemann M F, Manku M S, Leonard T J, et al. Essential fatty acids in the plasma phospholipids of patients with atopic cataracts. Br J Dermatol. 1987;116(2):179-182. No omega-3 fatty acid intervention/exposure. [pmid: 3828213].
Myrup B, Bregengaard C, Petersen L R, et al. Platelet aggregation and fatty acid composition of platelets in type 1 diabetes mellitus. Clin Chim Acta. 1991;204(13):251-262. No omega-3 fatty acid intervention/exposure. [pmid: 1819468].
Newsome D A, Anderson R E, May J G, et al. Clinical and serum lipid findings in a large family with autosomal dominant retinitis pigmentosa. Ophthalmology. 1988;95(12):1691-1695. No omega-3 fatty acid intervention/exposure. [pmid: 3266001].
Niwa Y, Tominaga K, Yoshida K. Successful treatment of severe atopic dermatitis-complicated cataract and male infertility with a natural product antioxidant. Int J Tissue React. 1998;20(2):63-69. Not related to predefined eye health outcomes. [pmid: 9638503].
Odes H S. The pharmacological treatment of inflammatory bowel diseases: Recent concepts and advances. Archives of Gastroenterohepatology. 1993;12(34):170-173. Not a first publication of empirical evidence (e.g., review).
Osborne N N, Chidlow G, Wood J P M, et al. Expectations in the treatment of retinal diseases: Neuroprotection. Curr Eye Res. 2001;22(5):321-332. Not a first publication of empirical evidence (e.g., review). [pmid: 11605607].
Pedersen O, Gaede P. Intensified multifactorial intervention and cardiovascular outcome in type 2 diabetes: The Steno-2 study. Metabolism: Clinical & Experimental. 2003;52(8 SUPPL 1):19-23. Not a first publication of empirical evidence (e.g., review).
Pratt S. The way forward. Round Table Series - Royal Society of Medicine 2001; pp 40–47. Not a first publication of empirical evidence (e.g., review).
Rapp L M, Maple S S, Choi J H. Lutein and zeaxanthin concentrations in rod outer segment membranes from perifoveal and peripheral human retina. Invest Ophthalmol Vis Sci. 2000;41(5):1200-1209. No omega-3 fatty acid intervention/exposure. [pmid: 10752961].
Rotstein N P, Aveldano M I, Politi L E. Essentiality of docosahexaenoic acid in retina photoreceptor cell development. Lipids. 1999;34(Suppl):S115. Not involving human participants. [pmid: 10419114].
Rudman D, Cohan M E. Polyunsaturated fatty acids and the health of the elderly. [Review] [79 refs]. World Review of Nutrition & Dietetics. 1991;66(143):160. Not a first publication of empirical evidence (e.g., review).
Ruiz-Sanz J I, Aldamiz-Echevarria L, Arrizabalaga J, et al. Polyunsaturated fatty acid deficiency during dietary treatment of very long-chain acyl-CoA dehydrogenase deficiency. Rescue with soybean oil.[erratum appears in J Inherit Metab Dis. 2002 Aug;25(4):268]. J Inherit Metab Dis. 2001;24(4):493-503. Not related to predefined eye health outcomes. [pmid: 11596652].
Sanders T A, Haines A P, Wormald R, et al. Essential fatty acids, plasma cholesterol, and fat-soluble vitamins in subjects with age-related maculopathy and matched control subjects. Am J Clin Nutr. 1993;57(3):428-433. No omega-3 fatty acid intervention/exposure. [pmid: 8438779].
Sax H C. Are dietary fats anti-tumor agents?. Jpen: Journal of Parenteral & Enteral Nutrition. 2002;26(5):290. Not a first publication of empirical evidence (e.g., review). [pmid: 12216708].
Schaefer E J, Robins S J, Patton G M, et al. Red blood cell membrane phosphatidylethanolamine fatty acid content in various forms of retinitis pigmentosa. J Lipid Res. 1995;36(7):1427-1433. No omega-3 fatty acid intervention/exposure. [pmid: 7595066].
Scorolli L, Godano A, Martini E. [Changes induced by zinc and docosahexenoic acid in acute NaIO3 poisoning]. [French]. Bulletins et Memoires de la Societe Francaise d Ophtalmologie. 1986;97(312):318. Not involving human participants.
Serhiienko O O. [The experimental and clinical aspects of eicosapentaenoic amd docosahexaenoic acids (a review of the literature and the author's own data)]. [Review] [31 refs] [Ukrainian]. Likarska Sprava. 1995;5:661-66. Not a first publication of empirical evidence (e.g., review).
Shimizu H, Sato N, Tanaka Y, et al. Effect of eicosapentaenoic acid ethyl on urine albumin excretion in NIDDM [7]. Diabetes Care. 1993;16(10):1406-1408. Not related to predefined eye health outcomes. [pmid: 8269805].
Simonelli F, Libondi T, Romano N, et al. Fatty acid composition of membrane phospholipids of cataractous human lenses. Ophthalmic Res. 1996;28 Suppl 1(101):104. No omega-3 fatty acid intervention/exposure.
Simonelli F, Manna C, Romano N, et al. Evaluation of fatty acids in membrane phospholipids of erythrocytes in retinitis pigmentosa patients. Ophthalmic Res. 1996;28(2):93-98. No omega-3 fatty acid intervention/exposure. [pmid: 8792359].
Simonelli F, Milone A, Iura A, et al. [Possible role of altered levels of plasma docosahexaenoic acid in the pathogenesis of retinitis pigmentosa. Preliminary results]. [Italian]. Bollettino - Societa Italiana Biologia Sperimentale. 1990;66(9):893-898. Not related to predefined eye health outcomes.
Simopoulos AP. The return of omega3 fatty acids into the food supply. 1. Land-based animal food products and their health effects. 1998, xii + 240 pp. Not a first publication of empirical evidence (e.g., review).
Sinclair AJ, Weisinger HS, Vingrys AJ et al. Dietary n-3 fatty acid manipulation and retinal function. Essential fatty acids and eicosanoids: invited papers from the Fourth International Congress, Edinburgh, Scotland, UK, July 20 24, 1997/1998;162–167. Not involving human participants.
Stephens R J, Negi D S, Short S M, et al. Lipid peroxidation and retinal phototoxic degeneration. Basic Life Sci. 1988;49(283):289. Not involving human participants.
Stevens D L. The use of complementary and alternative therapies in diabetes. Clinics in Family Practice. 2002;4(4):911-928. Not a first publication of empirical evidence (e.g., review).
Stojceva-Taneva O, Polenakovic M, Grozdanovski R, et al. Lipids, protein intake, and progression of diabetic nephropathy. Nephrology Dialysis Transplantation. 2001;16(SUPPL. 6):90-91. No omega-3 fatty acid intervention/exposure.
Tan M H, Rittmaster R S, Reddy S K, et al. Research in the division. Nova Scotia Medical Journal. 1990;69(3):95-97. Not a first publication of empirical evidence (e.g., review).
Taylor A. Long-term intake of vitamins and carotenoids and odds of early age-related cortical and posterior subcapsular lens opacities. Am J Clin Nutr. Mar. 2002;75(3):540-9. No omega-3 fatty acid intervention/exposure. [pmid: 11864861].
Tuna N, Frankhauser S, Goetz F C. Total serum fatty acids in diabetes: relative and absolute concentrations of individual fatty acids. Am J Med Sci. 1968;255(120):131. No omega-3 fatty acid intervention/exposure.
Uauy Dagach R, Valenzuela A. Marine oils: the health benefits of n-3 fatty acids. First international conference on East West perspectives on functional foods. 1996;54(11):S102-S108. Not a first publication of empirical evidence (e.g., review).
Uauy R, Mena P, Rojas C. Essential fatty acids in early life: structural and functional role. Acta Hist Rerum Nat Tech 2000;University of Glasgow, UK, 29 June-2 July, 1999. Proceedings-of-the-Nutrition-Society. 2000;59(1):3-15. Not a first publication of empirical evidence (e.g., review). [pmid: 10828169].
Uauy R, Peirano P, Hoffman D, et al. Role of essential fatty acids in the function of the developing nervous system. Lipids. 1996;31(3 SUPPL.):S167-S176. Not a first publication of empirical evidence (e.g., review). [pmid: 8729114].
van Kuijk F J, Buck P. Fatty acid composition of the human macula and peripheral retina. Invest Ophthalmol Vis Sci. 1992;33(13):3493-3496. No omega-3 fatty acid intervention/exposure. [pmid: 1464494].
Varga M, Gabriel I, Follmann P. [Treatment of senile maculopathy with etaretin]. Klin Monatsbl Augenheilkd. 1986;188(6):622-624. No omega-3 fatty acid intervention/exposure. [pmid: 3761970].
Waitzman M B. Prostaglandins and diabetic retinopathy. Exp Eye Res. 8-10. 1973;16(4):307-313. No omega-3 fatty acid intervention/exposure. [pmid: 4741256].
Weiss H, Kosmath B. [Therapeutic use of phosphatides in retinal diseases. Preliminary communication on the behaviour of visual acuity in macular disease and retinitis pigmentosa]. Klin Monatsbl Augenheilkd. 1971;158(2):278-285. No omega-3 fatty acid intervention/exposure. [pmid: 5555605].
Williams L L, Horrocks L A, Leguire L E, et al. Serum fatty acid proportions in retinitis pigmentosa may be affected by a number of factors. Progress in Clinical & Biological Research. 1989;314(49):56. No omega-3 fatty acid intervention/exposure.