# References and Included Studies

1 USDA. Individual fatty acid intakes: Results from the 1995 Continuing Survey of Food Intakes by Individuals (data table set 4). 1995.
2 Institute of Medicine. Dietary Reference Intakes: Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids (Macronutrition). The National Academies Press, 2002.
3 Simopoulos A P, Leaf A, Salem N Jr. Essentiality of and recommended dietary intakes for omega-6 and omega-3 fatty acids. Ann Nutr Metab. 1999;43(2):127-30. [pmid: 10436312].
4 Fallon S Enig MG. “Tripping Lightly Down the Prostaglandin Pathways”. 2001. Price-Pottenger Nutrition Foundation.
5 Nair J, Vaca C E, Velic I, et al. High dietary omega-6 polyunsaturated fatty acids drastically increase the formation of etheno-DNA base adducts in white blood cells of female subjects. Cancer Epidemiol Biomarkers Prev. 1997;6(8):597-601. [pmid: 9264272].
6 James MJ, Gibson RA, Cleland LG. Dietary polyunsaturated fatty acids and inflammatory mediator production. [Review][33 refs]. Am J Clin Nutr 2000;71(1:Suppl):Suppl-8S.
7 Krummel D. Nutrition in cardiovascular disease. In: Mahan LK, Escot-Sump S, editors. Krause's food, nutrition, and diet therapy. W.B. Saunder Company, 1966.
8 Omega-3 long-chain polyunsaturated fatty acids and health benefits. Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (Nutriscience), 2003.
9 Consensus workshop on dietary assessment: nutrition monitoring and tracking the year 2000 objectives. Hyattsville, MD: National Center for Health Statistics, 1994.
10 USDA National Nutrient Database for Standard Reference. [Release 16] Available at: http://www.nal.usda.gov/fnic/foodcomp[underlined: ; Accessed November 3, 2003] 2003. US Department of Agriculture Agricultural Research Service.
11 World Health Organization. Vision 2020: Report on world sight 2002. 2002.
12 Congdon N, O'Colmain B, Klaver C C, et al. Causes and prevalence of visual impairment among adults in the United States. Arch Ophthalmol. 2004;122(4):477-85. [pmid: 15078664].
13 National Center on Birth Defects and Developmental Disabilities. Vision impairment. 2004.
14 Sarma U, Brunner E, Evans J, et al. Nutrition and the epidemiology of cataract and age-related maculopathy. Eur J Clin Nutr. 1994;48(1):1-8. [pmid: 8200325].
15 Carroll P B, Herskowitz R D, Goodman A D, et al. Rapid onset of severe retinopathy, cataracts and neuropathy in young patients with diabetes mellitus. Acta Paediatr. 1992;81(4):355-8. [pmid: 1606400].
16 National Center for Vision and Child Development. Statistics on children with visual impairments. Lighthouse International 2000, 2000.
17 Economic costs associated with mental retardation, cerebral palsy, hearing loss, and vision impairment--United States, 2003. MMWR Morb Mortal Wkly Rep 2004;53(3): 57–9.
18 Kempen J H, O'Colmain B J, Leske M C, et al. The prevalence of diabetic retinopathy among adults in the United States. Arch Ophthalmol. 2004;122(4):552-63. [pmid: 15078674].
19 Klein R, Klein B E, Moss S E, et al. The Wisconsin Epidemiologic Study of Diabetic Retinopathy. XV. The long-term incidence of macular edema. Ophthalmology. 1995;102(1):7-16. [pmid: 7831044].
20 Allikmets R, Shroyer N F, Singh N, et al. Mutation of the Stargardt disease gene (ABCR) in age-related macular degeneration. Science. 1997;277(5333):1805-7. [pmid: 9295268].
21 Seddon J M, Ajani U A, Sperduto R D, et al. Dietary carotenoids, vitamins A, C, and E, and advanced age-related macular degeneration. Eye Disease Case-Control Study Group. JAMA. 1994;272(18):1413-20. [pmid: 7933422].
22 A randomized, placebo-controlled clinical trial of high-dose supplementation with vitamins C E beta carotene and zinc for age-related macular degeneration and vision loss: AREDS report no. 8. Arch Ophthalmol 2001; 119 (10): 1417–36.
23 Harding J J, van Heyningen R. Epidemiology and risk factors for cataract. Eye. 1987;1(Pt 5):537-41. [pmid: 3328701].
24 Klein B E, Klein R, Jensen S C, et al. Hypertension and lens opacities from the Beaver Dam Eye Study. Am J Ophthalmol. 1995;119(5):640-6. [pmid: 7733190].
25 Jacques P F, Chylack L T Jr. Epidemiologic evidence of a role for the antioxidant vitamins and carotenoids in cataract prevention. Am J Clin Nutr. 1991;53(1 Suppl):352S-355S. [pmid: 1985409].
26 Robertson J M, Donner A P, Trevithick J R. Vitamin E intake and risk of cataracts in humans. Ann N Y Acad Sci. 1989;570:372-82. [pmid: 2629606].
27 Innis S M. Perinatal biochemistry and physiology of long-chain polyunsaturated fatty acids. J Pediatr. 2003;143(4 Suppl):S1-S8. [pmid: 14597908].
28 Birch E, Birch D, Hoffman D, et al. Breast-feeding and optimal visual development. J Pediatr Ophthalmol Strabismus. 1993;30(1):33-8. [pmid: 8455123].
29 Birch E E, Hoffman D R, Uauy R, et al. Visual acuity and the essentiality of docosahexaenoic acid and arachidonic acid in the diet of term infants. Pediatr Res. 1998;44(2):201-9. [pmid: 9702915].
30 Hoffman D R, Birch E E, Birch D G, et al. Impact of early dietary intake and blood lipid composition of long-chain polyunsaturated fatty acids on later visual development. J Pediatr Gastroenterol Nutr. 2000;31(5):540-53. [pmid: 11144440].
31 Stone W L, Farnsworth C C, Dratz E A. A reinvestigation of the fatty acid content of bovine, rat and frog retinal rod outer segments. Exp Eye Res. 1979;28(4):387-97. [pmid: 446567].
32 Bazan N G, Gordon W C, Rodriguez de Turco E B. Docosahexaenoic acid uptake and metabolism in photoreceptors: retinal conservation by an efficient retinal pigment epithelial cell-mediated recycling process. Adv Exp Med Biol. 1992;318:295-306. [pmid: 1386177].
33 Bazan N G, Rodriguez de Turco E B, Gordon W C. Pathways for the uptake and conservation of docosahexaenoic acid in photoreceptors and synapses: biochemical and autoradiographic studies. Can J Physiol Pharmacol. 1993;71(9):690-8. [pmid: 8313233].
34 Tinoco J, Miljanich P, Medwadowski B. Depletion of docosahexaenoic acid in retinal lipids of rats fed a linolenic acid-deficient, linoleic acid-containing diet. Biochim Biophys Acta. 1977;486(3):575-8. [pmid: 851547].
35 Rodriguez de Turco E B, Gordon W C, Bazan N G. Rapid and selective uptake, metabolism, and cellular distribution of docosahexaenoic acid among rod and cone photoreceptor cells in the frog retina. J Neurosci. 1991;11(11):3667-78. [pmid: 1834810].
36 Gibson N J, Brown M F. Lipid headgroup and acyl chain composition modulate the MI-MII equilibrium of rhodopsin in recombinant membranes. Biochemistry. 1993;32(9):2438-54. [pmid: 8443184].
37 Brown M F. Modulation of rhodopsin function by properties of the membrane bilayer. Chem Phys Lipids. 1994;73(12):159-80. [pmid: 8001180].
38 Litman B J, Niu S L, Polozova A, et al. The role of docosahexaenoic acid containing phospholipids in modulating G protein-coupled signaling pathways: visual transduction. J Mol Neurosci. 2001;16(23):237-42. [pmid: 11478379].
39 Clandinin M T, Cheema S, Field C J, et al. Dietary fat: exogenous determination of membrane structure and cell function. FASEB J. 1991;5(13):2761-9. [pmid: 1916101].
40 Neuringer M, Connor W E, Lin D S, et al. Biochemical and functional effects of prenatal and postnatal omega 3 fatty acid deficiency on retina and brain in rhesus monkeys. Proc Natl Acad Sci U S A. 1986;83(11):4021-5. [pmid: 3459166]. [pmcid: 323657].
41 Neuringer M, Connor W E, Van Petten C, et al. Dietary omega-3 fatty acid deficiency and visual loss in infant rhesus monkeys. J Clin Invest. 1984;73(1):272-6. [pmid: 6317716]. [pmcid: 425011].
42 Moriguchi K, Yuri T, Yoshizawa K, et al. Dietary docosahexaenoic acid protects against N-methyl-N-nitrosourea-induced retinal degeneration in rats. Exp Eye Res. 2003;77(2):167-73. [pmid: 12873446].
43 Murayama K, Yoneya S, Miyauchi O, et al. Fish oil (polyunsaturated fatty acid) prevents ischemic-induced injury in the mammalian retina. Exp Eye Res. 2002;74(6):671-6. [pmid: 12126941].
44 Vingerling J R, Dielemans I, Bots M L, et al. Age-related macular degeneration is associated with atherosclerosis. The Rotterdam Study. Am J Epidemiol. 1995;142(4):404-9. [pmid: 7625405].
45 von Schacky C, Angerer P, Kothny W, et al. The effect of dietary omega-3 fatty acids on coronary atherosclerosis. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 1999;130(7):554-62. [pmid: 10189324].
46 Simopoulos AP. Importance of the ratio of Omega-6/Omega-3 essential fatty acids: Evolutionary aspects. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 1–22.
47 Kang JX. The importance of Omega-6/Omega-3 fatty acid ratio in cell function: The gene transfer of Omega-3 fatty acid desaturase. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 23–36.
48 Yehuda S. Omega-6/Omega-3 ratio and brain-related functions. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 37–56.
49 de Lorgeril M, Salen P. Dietary prevention of coronary heart disease: Focus on Omega-6/Omega-3 essential fatty acid balance. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 57–73.
50 Pella D, Dubnov G, Singh RB, et al. Effects of an Indo-Mediterranean diet on the Omega-6/Omega-3 ratio in patients at high risk of coronary artery disease: The Indian paradox. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 74–80.
51 Dubnov G, Berry EM. Omega-6/Omega-3 fatty acid ratio: The Israeli paradox. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 81–91.
52 Zampelas A, Paschos G, Rallidis L, et al. Linoleic acid to alpha-linolenic acid ratio: From clinical trials to inflammatory markers of coronary artery disease. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 92–108.
53 Hamazaki T, Okuyama H. The Japan Society for Lipid Nutrition recommends to reduce the intake of linoleic acid: A review and critique of the scientific evidence. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 109–132.
54 Chajès V, Bournoux P. Omega-6/Omega-3 polyunsaturated fatty acid ratio and cancer. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 133–51.
55 Cleland LG, James MJ, Proudman SM. Omega-6/Omega-3 fatty acids and arthritis. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 152–68.
56 Simopoulos A P. Essential fatty acids in health and chronic disease. Am J Clin Nutr. 1999;70(3 Suppl):560S-569S. [pmid: 10479232].
57 Kris-Etherton P M, Taylor D S, Yu-Poth S, et al. Polyunsaturated fatty acids in the food chain in the United States. Am J Clin Nutr. 2000;71(1 Suppl):179S-188S. [pmid: 10617969].
58 Sugano M, Hirahara F. Polyunsaturated fatty acids in the food chain in Japan. Am J Clin Nutr. 2000;71(1 Suppl):189S-196S. [pmid: 10617970].
59 Hibbeln J R, Makino K K, Martin C E, et al. Smoking, gender, and dietary influences on erythrocyte essential fatty acid composition among patients with schizophrenia or schizoaffective disorder. Biol Psychiatry. 2003;53(5):431-41. [pmid: 12614996].
60 Seddon J M, Cote J, Rosner B. Progression of age-related macular degeneration: association with dietary fat, transunsaturated fat, nuts, and fish intake. Arch Ophthalmol. 2003;121(12):1728-37. [pmid: 14662593].
61 McAuley L, Pham B, Tugwell P, et al. Does the inclusion of grey literature influence estimates of intervention effectiveness reported in meta-analyses?. Lancet. 2000;356(9237):1228-31. [pmid: 11072941].
62 Moher D, Pham B, Lawson M L, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
63 Jadad AR. Randomised controlled trials. London: BMJ Publishing Group, 1998.
64 Moher D, Cook D J, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
65 Berlin J A. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
66 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
67 Schulz K F, Chalmers I, Hayes R J, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
68 Deeks J J, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-173. [pmid: 14499048].
69 Downs S H, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-84. [pmid: 9764259].
70 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 3rd Symposium on Systematic Reviews: Beyond the Basics, July 2000 in Oxford. 2000.
71 Schachter H, Reisman J, Tran K, et al. Health Effects of Omega-3 Fatty Acids on Asthma. Evidence Report/Technology Assessment No. 91 (Prepared by University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021). Rockville MD: Agency for Healthcare Research and Quality, 2004. AHRQ Publication No. 04-E013-2.
72 Hoffman D R, Uauy R, Birch D G. Metabolism of omega-3 fatty acids in patients with autosomal dominant retinitis pigmentosa. Exp Eye Res. 1995;60(3):279-89. [pmid: 7789408].
73 Hoffman D R, Locke K G, Wheaton D H, et al. A randomized, placebo-controlled clinical trial of docosahexaenoic acid supplementation for X-linked retinitis pigmentosa. Am J Ophthalmol. 2004;137(4):704-18. [pmid: 15059710].
74 Wheaton D H, Hoffman D R, Locke K G, et al. Biological safety assessment of docosahexaenoic acid supplementation in a randomized clinical trial for X-linked retinitis pigmentosa. Arch Ophthalmol. 2003;121(9):1269-78. [pmid: 12963609].
75 Sorokin E L, Smoliakova G P, Bachaldin I L. [Clinical efficacy of eiconol in patients with diabetic retinopathy]. [Russian]. Vestn Oftalmol. 1997;113(4):37-9. [pmid: 9381643].
76 Scorolli L, Scalinci S Z, Limoli P G, et al. [Photodynamic therapy for age related macular degeneration with and without antioxidants]. [French]. Can J Ophthalmol. 2002;37(7):399-404. [pmid: 12518724].
77 Dagnelie G, Zorge I S, McDonald T M. Lutein improves visual function in some patients with retinal degeneration: a pilot study via the Internet. Optometry. 2000;71(3):147-64. [pmid: 10970259].
78 Suzuki H, Morikawa Y, Takahashi H. Effect of DHA oil supplementation on intelligence and visual acuity in the elderly. World Rev Nutr Diet. 2001;88:68-71. [pmid: 11935973].
79 Cho E, Hung S, Willett W C, et al. Prospective study of dietary fat and the risk of age-related macular degeneration. Am J Clin Nutr. 2001;73(2):209-18. [pmid: 11157315].
80 Mares-Perlman J A, Brady W E, Klein R, et al. Dietary fat and age-related maculopathy. Arch Ophthalmol. 1995;113(6):743-8. [pmid: 7786215].
81 Ouchi M, Ikeda T, Nakamura K, et al. A novel relation of fatty acid with age-related macular degeneration. Ophthalmologica. 2002;216(5):363-7. [pmid: 12424405].
82 Seddon J M, Rosner B, Sperduto R D, et al. Dietary fat and risk for advanced age-related macular degeneration. Arch Ophthalmol. 2001;119(8):1191-9. [pmid: 11483088].
83 Smith W, Mitchell P, Leeder S R. Dietary fat and fish intake and age-related maculopathy. Arch Ophthalmol. 2000;118(3):401-4. [pmid: 10721964].
84 Heuberger R A, Mares-Perlman J A, Klein R, et al. Relationship of dietary fat to age-related maculopathy in the Third National Health and Nutrition Examination Survey. Arch Ophthalmol. 2001;119(12):1833-8. [pmid: 11735796].
85 Arnarsson A, Jonasson F, Sasaki H, et al. Risk factors for nuclear lens opacification: the Reykjavik Eye Study. Dev Ophthalmol. 2002;35:12-20. [pmid: 12061269].
86 Cumming R G, Mitchell P, Smith W. Diet and cataract. The Blue Mountains Eye Study. Ophthalmology. 2000;107(3):450-6. [pmid: 10711880].
87 Hamazaki T, Sawazaki S, Itomura M, et al. The effect of docosahexaenoic acid on aggression in young adults. A placebo-controlled double-blind study. J Clin Invest. 1996;97(4):1129-33. [pmid: 8613538]. [pmcid: 507162].
88 Stephens R J, Negi D S, Short S M, et al. Lipid peroxidation and retinal phototoxic degeneration. Basic Life Sci. 1988;49:283-9. [pmid: 2977946].