# Results

## Results of Literature Search

Regardless of its source, the progress of each bibliographic record through the stages of the systematic review is illustrated in the modified QUOROM flow chart (Appendix D ^‡‡^) Ideally, a record included an abstract and key words, in addition to a citation. When a citation was discovered, for example through a manual search of a reference list, its complete bibliographic record was sought (e.g., Pubmed) and then entered into the first level of relevance screening.

‡‡ Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

Of 507 records entered into the initial screening for relevance, 395 were excluded. Reflecting the specific eligibility criteria, the reasons for exclusion were: a) not a first publication of empirical evidence (e.g., a review; n = 93); b) not involving human participants (n = 206); c) no omega-3 fatty acid focus (i.e., intervention/exposure; n = 80); and, d) not related to predefined eye health outcomes (n = 16). All reports having passed this level of screening were then retrieved and subjected to a more detailed relevance assessment.

A second relevance screening then excluded 96 reports for the following reasons: a) not a first publication of empirical evidence (e.g., a review; n = 39); b) not involving human participants (n = 8); c) no omega-3 fatty acid focus (i.e., intervention/exposure; n = 39); and, d) not related to predefined eye health outcomes (n = 10).

In total, 16 reports, describing 16 unique studies, were deemed relevant for the systematic review, with two different studies presented in one report^72^ and one study described in two reports.^73,^ ^74^ To avoid confusion in the text, evidence tables, summary tables and figures, the report by Hoffman et al.^73^ is used to refer to the single study described by two reports.^73,^ ^74^ One report^73^ described efficacy data, whereas the second^74^ presented safety data. Another report by Hoffman and colleagues,^72^ which outlined two different studies, yielded two evidence tables (Appendix E *). As stated earlier, the listing of studies excluded as a result of the appraisal of full reports is presented at the end of this document.

* Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

## Report and Study Design Characteristics of Included Studies

Sixteen unique studies, described in 16 published journal reports, met eligibility criteria and were included in the systematic review. Any study that may have at best indirectly or superficially addressed a research question is identified in the appropriate section of this Chapter.

Each of the included studies was described by at least one published report. All but two reports were written in English, with one requiring translation from Russian (Sorokin et al.)^75^ and the other from French (Scorolli et al.).^76^

Three categories of research design (two RCTs, five quasi-experimental designs, and nine observational studies), including seven different design types overall, are represented in the review. These consisted of two parallel arm RCTs,^73,^ ^76^ one comparative before-after design,^77^ four noncomparative before-after studies,^72,^ ^75,^ ^78^ two single prospective cohort studies,^60,^ ^79^ one retrospective population-based cohort study,^80^ two case control studies,^81,^ ^82^ and four single population cross-sectional studies.^83–86^ It should be recalled that the Hoffman et al. report^72^ described two noncomparative before-after studies.

The question examining the role of omega-3 fatty acids in preventing age-related macular degeneration (ARMD) was addressed by two case-control studies,^81,^ ^82^ one single prospective cohort,^79^ one retrospective population based cohort,^80^ and two single population cross-sectional designs.^83,^ ^84^ One RCT investigated the role of omega-3 fatty acids in slowing the progression of ARMD,^76^ while a single prospective cohort study examined their influence on slowing the progression to advanced ARMD.^60^ One RCT,^73^ one comparative before-after study,^77^ and two noncomparative before-after studies^72^ assessed the impact of omega-3 fatty acids on slowing the progression of RP. One noncomparative before-after study^75^ included outcomes permitting it to be classified as evaluating, in diabetics, the omega-3 fatty acids' potential to prevent proliferative retinopathy and slow the progression of clinically significant macular edema. Two single population cross-sectional studies observed whether omega-3 fatty acids prevent age-related cataracts.^85,^ ^86^ Finally, a noncomparative before-after design investigated the impact of omega-3 fatty acids on slowing the rate of progression of age-related cataracts.^78^

Of the 16 relevant studies, eight concerned primary prevention of either ARMD^79–84^ or age-related cataracts.^85,^ ^86^ The remainder focused on secondary prevention.^60,^ ^72,^ ^73,^ ^75–78^ A single interventional study solicited reports of adverse events from study participants, and described these results.^73,^ ^87^

The remainder of this chapter is organized by eye disease/visual impairment. If a question is not represented in the report, there was no evidence that met eligibility criteria. Safety data are presented last. We begin with ARMD.

## What is the Evidence for Efficacy of Omega-3 Fatty Acids in Preventing Age-related Macular Degeneration?

As observed in Summary Tables 1 to 3 (below), derived from Evidence Table 3 (Appendix E ^§§^), six observational studies met eligibility criteria in investigating omega-3 fatty acids' possible value in preventing ARMD. These investigations concerning primary prevention were published between 1995 and 2002.

§§ Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

### Overview of Relevant Studies

Cho et al. evaluated the association between total fat intake and the development of age-related ARMD in a single prospective cohort study that was part of the Nurses' Health Study and the Health Professionals Follow Up Study (n=72,489) (Summary Table 1).^79^ Participants were followed for 10 to 12 years in the US. Intake of omega-3 fatty acids and total fish intake, as a source of omega-3 fatty acids, were assessed using a food frequency questionnaire completed at various times during the followup. The primary outcome was self-reported ARMD, with a visual loss of 20/30 or worse.

Seddon et al. conducted an analysis of the dietary intake/maculopathy data from the Eye Disease Case Control Study.^82^ A total of 853 patients were enrolled, of which 349 were cases. The cases and controls were selected between 1986 and 1990 from five large ophthalmology centers in the US. Enrolled at the same time as cases, controls (n=504) were selected from the same study base. The outcome of interest was advanced ARMD, which was confirmed photographically and by review of medical records. A food frequency questionnaire yielded data reflecting total fat intake as well as intake by type of fat.

Ouchi et al. conducted a very small case control study in Japan.^81^ Cases (n=11) exhibited advanced (i.e., exudative) ARMD in that they all showed signs of choroidal neovascularization. Where “healthy” controls (n=10) were drawn from was not described. Fish intake frequency was evaluated to estimate, by proxy, omega-3 fatty acid intake. At the same time, the investigators performed a cross-sectional analysis of fatty acid fractions (e.g., EPA, DHA) in the red blood cells (RBCs) and plasma of cases and controls. The assessment of the diet-ARMD relationship was secondary to their focus on possible between-group differences in biomarkers data.

Mares-Perlman et al.'s retrospective population-based cohort (n=2,152; ages 45–84 years) study investigated the relationship of dietary fat intake and both early and late forms of ARMD as part of the Beaver Dam Eye Study.^80^ A total of 2,152 persons (90%) participated, with 1,968 participants providing both gradable fundus photographs and dietary intake data. Fundus photographs were taken from 1988 through 1990, while dietary history data were collected from 1978 through 1980. Fish intake was used as evidence for omega-3 fatty acid intake. Dietary intake data pertained to the year prior to the interview (n=2,152) and 10 years prior to the interview (n=2,003).

Smith et al.'s (single population) cross-sectional study assessed the association between the dietary intake of fat and ARMD in a survey of vision and common eye diseases in Australia (n=3,654), as part of the Blue Mountains Eye study.^83^ Assessed by macular photography, ARMD was defined as early or late. The amounts and types of dietary intake were measured via a semi-quantitative questionnaire.

Analyzing data collected in the Third National Health and Nutrition Examination Survey (NHANES III) (n=7,883), Heuberger et al. investigated the relationship between the dietary intake of fat and ARMD in a (single population) cross-sectional study.^84^ Non-mydriatic single eye fundus photography was used to assess ARMD status. ARMD was divided into early and late lesions in a way that was similar to the methodology employed by Smith et al.^83^ A food frequency questionnaire and a 24-hour recall method permitted the collection of data concerning total fat intake as well as specific dietary sources of fat. Patterns of fish consumption were estimated based on responses to a single item in the food frequency questionnaire.

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. Two (single population) cross-sectional studies,^83,^ ^84^, two case control studies,^81,^ ^82^ one retrospective population-based cohort study^80^ and one single prospective cohort study^79^ were deemed relevant (Summary Tables 1 through 3; Evidence Table 3: Appendix E ***).

*** Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

Cho et al.'s single prospective cohort study was sponsored by the National Eye Institute (US), and the investigators clearly defined their US source population and final sample.^79^ Inclusion and exclusion criteria were also well described by Cho et al.^79^ Smith and colleagues' (single population) cross-sectional study's source population (Australia), final sample, inclusion and exclusion criteria were not explicitly defined, although reference was made to a previous base study.^83^ The sponsoring agencies were the Australian Department of Health and Family Services as well as the Save Sight Institute of The University of Sydney. Seddon et al.'s case control study was sponsored by the National Eye Institute (US).^82^ The source population and final sample were explicitly defined, and the inclusion and exclusion criteria were clearly described.

The source population and final sample investigated in Mares-Perlman et al.'s retrospective population-based cohort study were clearly defined.^80^ This work was funded by the National Institutes of Health (US). Ouchi et al. performed a very small case-control study (n=21) in Japan, and whose funding source was not provided.^81^ Neither their source population nor their inclusion and exclusion criteria were adequately described. The US study by Heuberger et al. employed a single population cross-sectional design.^84^ While its source population and final sample were highlighted to some extent, more detail is contained in another research report. The inclusion criteria were broad and they were described in moderate detail. This study was supported by the National Institutes of Health as well as Research to Prevent Blindness.

Population characteristics. Cho et al.'s single prospective cohort study included as its source population the study sample of the Nurses' Health Study, which enrolled 121,700 females aged 30 to 55 years in 1976, and the study sample of the Health Professionals Follow Up Study, which included 51,529 health professionals aged 40 to 75 years in 1986.^79^ Because ARMD is rare in young individuals, the baseline population was restricted to women 50 years or age or older (age assessed as of 1984; n=55,865) and men ages 50 years of age or older as of 1986 (n=33,357). Also excluded were those patients who did not complete a baseline food frequency questionnaire or who completed it inadequately, those with implausible energy intakes, those who reported ARMD or non-melanoma/non-skin cancer, and those not responding to ARMD status questions at followup.

At baseline, Cho et al.'s total sample population included 42,743 women and 29,746 men.^79^ Additional patients were added every 2 years, increasing the total sample, by 1994, to 71,486 women and 41,474 men. The average baseline age of their full sample was 56 years. Their racial and other demographic characteristics were not provided in the report. A total of 567 cases of ARMD were documented: 351 in women (over 635,873 person-years of followup in the 12-year cohort) and 216 in men (over 300,242 person-years of followup in the 10-year cohort). Confirmation of the diagnosis was attempted in all cases via medical record review or by contacting the patient's ophthalmologist. A subset of patients had retinal photographs taken to further document the diagnosis.

Smith et al.'s Blue Mountains Eye Study investigated vision and common eye diseases in an Australian urban population of 3,654 people who were 49 years of age or older.^83^ The 145-item food frequency questionnaire was returned by 3,267 participants, with 2,900 useable questionnaires. A total of 312 cases of ARMD were identified, 228 of who had adequately filled out the food frequency questionnaire. Other baseline demographic information for this study was not provided (i.e., age, gender, race, geographic details).

Seddon et al.'s Eye Disease Case Control Study was designed to identify potential risk factors for a number of retinal disorders, including advanced ARMD.^82^ Cases and controls were selected between May 1986 and December 1990 from five large urban US ophthalmic centers. Eligible cases needed to be between 55 and 80 years of age, and with exudative ARMD identified within 1 year of enrollment. There were 426 eligible cases, of which 349 agreed to participate in the study. Their average age was 71 years, and 58% were female. Controls were identified from the same study base as the cases. Of the 646 controls who were eligible for inclusion, 504 agreed to participate. Their average age was 68 years, and 58% were female. The distribution of reasons for non-participation was similar across cases and controls, and cases and controls were frequency matched for age, sex and source clinic. The sample included only six non-white subjects with advanced ARMD, and so the study was essentially restricted to a white population.

Mares-Perlman and colleagues' Beaver Dam Eye Study population was located in south central Wisconsin.^80^ A 50% sample of the non-institutionalized Beaver Dam Eye Study participants were used for the nutritional aspect of the study (n=2,429). Some had moved or died (n=24), some could not be located (n=6) and some could not respond to verbal interviews (n=23). Of the remaining potential subjects, 90% agreed to participate (n=2,152). All participants provided data concerning dietary intake in the past year, and a total of 93% (n=2,003) were able to supply dietary information from 10 years preceding the interview. Of these 2,003 patients, 1,968 had gradable fundus photographs. The mean age of the sample was 61 years, and the vast majority were white participants.

The Ouchi paper provided few details regarding the source or sampled population.^81^ The paper only revealed that there were eight male and three female ARMD patients (average age 65.8 years), in addition to eight male and two female controls (average age: 64.4 years). No other data regarding the source or study population were described.

The NHANES III Survey was conducted from January 1988 through December 1994.^84^ It included a nationally representative sample of the non-institutionalized civilian US population. There was purposeful over-sampling of black subjects, Mexican-Americans and adults over 60 years of age. The sample was restricted to those between the ages of 40 and 79 years. A total of 7,405 patients between 40 and 79 years of age were included in the analysis for early ARMD, of whom 644 had the disease. Only patients 60 years of age or older were included in the analysis for late ARMD (n=4294), of whom 53 had the disease. The percentages of patients who did not meet eligibility criteria, who refused to participate or who did not adequately respond to the questionnaire, were not provided. Baseline demographic characteristics were not reported but the analysis was presented as having controlled for them.

Intervention/exposure characteristics. The definition of the exposure varied across studies. Some reported specific omega-3 fatty acid intake, others provided total omega-3 fatty acid intake data, while a third approach measured overall or specific fish consumption as a proxy for omega-3 fatty acid intake.

Cho et al. used a 130-item food frequency questionnaire to assess dietary intake in the previous year.^79^ Estimates of participants'omega-3 fatty acid intake (e.g., EPA, DHA) over the followup period were divided into quintiles according to the energy-adjusted cumulative average omega-3 fatty acid intake. Total fish intake and the type of fish intake were also observed. Smith et al.'s sparse details included reference to a base study, which had used a 145-item food frequency questionnaire previously validated and modified to assess the Australian diet.^88^ Estimates of specific omega-3 fatty acid intake were not provided, with the exposure being the number of servings of fish per unit time. Seddon et al.^82^ employed a food frequency questionnaire to calculate energy-adjusted consumption scores as quintiles of intake in a manner similar to what Cho et al. did.^79^ The exposure was defined in two ways: as total omega-3 fatty acid consumption and as number of fish servings per week.

The dietary food questionnaire used by Mares-Perlman et al. in the Beaver Dam Study was described in some detail.^80^ Total intake of fish and shellfish served as proxies for omega-3 fatty acid intake. Ouchi et al. defined their exposure as fish intake frequency per week, and data were obtained via a questionnaire.^81^ Additional details were neither provided nor referenced. It was impossible to ascertain whether the intake being referred to was “current” or “typical/in the past.” Heuberger et al. implemented a 24-hour recall method, while also dividing intake into quintiles based on total energy. A 66-item food frequency questionnaire permitted the estimation of the monthly consumption of fish.

Outcome characteristics. Across included studies, ARMD outcomes were invariably measured dichotomously, that is, as the presence or absence of the disease. What differed somewhat between studies was the exact definition of ARMD and how it was actually measured.

Cho et al. defined the primary outcome as any ARMD decreasing vision to 20/30 or worse.^79^ It was a self-reported assessment, although reviews of medical records or ophthalmologic consultations were relied upon to verify the diagnosis. Although their precise definition of ARMD subtypes was not provided, in their analysis ARMD was divided into: early and dry, wet and advanced, and wet and advanced with geographic atrophy. Of note, none of the “ARMD-negative” self-reports were subjected to any confirmatory tracking or followup.

Smith et al.^83^ and Heuberger et al.^84^ followed the Wisconsin age-related maculopathy grading system, which divides ARMD into early, late atrophic and late neovascular stages. Stereoscopic macular photography was used to determine ARMD category. Seddon et al. explicitly defined ARMD as exudative and advanced, which they defined as visual acuity being worse than 20/20 or drusen in either eye plus evidence of choroidal neovascularization.^82^ ARMD was determined by screening photography lists and reviewing medical records.

Mares-Perlman et al. defined early ARMD as soft or involving reticular drusen or any drusen in the presence of retinal pigment epithelial changes.^80^ Advanced ARMD required the identification of geographic atrophy or choroidal neovascularization. Outcomes were established using photography. Ouchi et al. identified ARMD as exudative, in the presence of choroidal neovascularization, via fundoscopic examination along with both fluorescein angiography and indocyanine green angiography.^81^ Diagnoses were confirmed, over 6 months, on the basis of disease progression.

Study quality and applicability. Of the six included studies, only the case-control study by Seddon et al. achieved the highest possible total quality grade of A (Summary Matrix 1).^82^ Four studies, including Cho et al.'s single prospective cohort study,^79^ Mares-Perlman et al.'s retrospective population-based cohort study,^80^ and the single population cross-sectional studies by Smith et al.^83^ and Heuberger et al.,^84^ attained a total quality grade of B. Ouchi et al.'s case-control study failed to achieve even one study quality point, which yielded a total quality grade of C. The studies by Cho et al.,^79^ Mares-Perlman et al.,^80^ and Heuberger et al.^84^ each attained an applicability rating of I, which indicates the highest generalizability to the North American population. By virtue of their inclusion of an almost exclusively white population, the Seddon et al. study's applicability rating was II.^82^ Both Smith et al.^83^ and Ouchi et al.'s^81^ studies received the lowest applicability rating of III. All three studies receiving an applicability rating of I also attained a total quality grade of B.^79,^ ^80,^ ^84^ It should be noted that the latter three studies employed different research designs.

### Qualitative Synthesis of Individual Study Results

To prepare their multivariate analysis, Cho et al. divided fat intake into quintiles.^79^ Confounders (see below) were explicitly described and entered into the analysis. While intake of LA, AA, EPA, DHA, white-meat fish or dark-meat fish (e.g., mackerel, salmon, sardines, bluefish, swordfish) intake were not significantly associated with ARMD based on multivariate analysis, consumption of canned tuna fish (RR: 0.61; 95%CI: 0.45, 0.83) and of all fish (RR: 0.65; 95%CI: 0.46, 0.91) each showed a statistically significant inverse relationship with ARMD. Individuals who ate any type of fish more than four times per week had a lower risk of ARMD than those who ate it fewer than or equal to three times per month (RR: 0.65, 95%CI: 0.46–0.91). Subgroup analyses of data following the classification of ARMD cases (early vs dry vs wet ARMD), and for advanced ARMD (i.e., wet ARMD, and early and dry ARMD with geographic atrophy) revealed results similar to the situation where ARMD cases were combined (data not reported).

Fat intake was divided into quintiles, and confounders (see below) were included in Smith et al.'s multivariate analysis.^83^ They found that only for low fish intake (i.e., 1–3 times/month vs < 1/month; OR: 0.23 95%CI [0.08–0.63]) did the exposure appear to act in protective fashion with respect to late ARMD. This pattern contradicts results from unadjusted analyses concerning fish intake and late ARMD. The latter revealed a significant protective effect across all intensities of the exposure, albeit without suggesting a dose-dependent relationship. Results of multivariate and univariate analysis basically agreed that no significant inverse association existed between fish intake and early ARMD.

An appropriate multivariate analysis, with confounders explicitly described (see below), was conducted by Seddon et al.^82^ They found that combined EPA and DHA intake was not protective against advanced ARMD. Then, when the data were stratified for LA consumption, only the test for trend (p<0.05) suggested that combined EPA and DHA intake might protect against advanced ARMD for those exclusively consuming lesser amounts of LA (i.e., ≤5.5 g/day vs ≥5.6 g/day). Multivariate analyses, on the other hand, did not indicate that any intensity of fish intake, for those consuming greater or lesser amounts of LA, protected against advanced ARMD. The exact same pattern regarding a significant test for trend (p<0.05) associated exclusively with a lesser consumption of LA, compared with no significant multivariate analytic associations for either greater or lesser amounts of LA consumption, was observed for fish intake (≥2 servings/week vs <1 serving/week) and advanced ARMD.

In the Beaver Dam Eye Study, Mares-Perlman et al. collected data on several covariates (see below), which were then entered into multivariate analysis.^80^ The investigators found that, while the direction of the results suggested a possible protective role for seafood consumption in both early and late forms of ARMD, neither of these associations was statistically significant. Tests for trend likewise failed to support a protective role of seafood consumption in both forms of ARMD.

Ouchi et al. only conducted univariate analyses.^81^ They observed that fish intake frequency (per week) did not differ between patients with advanced ARMD and controls. This was the only study of the six included ones which analyzed biomarkers data. Statistically significant between-group differences in plasma fatty acid fractions were not found. Using RBC composition data, DHA (p=0.006) and AA levels (p=0.001) were significantly higher in advanced ARMD patients compared with controls. The meaning of these results is unclear.

Heuberger et al. divided the exposure data into quintiles, and conducted an appropriate multivariate analysis, including explicitly described confounders (see below).^84^ They found that fish intake frequency was not associated with early or late ARMD.

### Impact of Covariates and Confounders

Except for the Ouchi study,^81^ which did not purport to study the influence of any covariates, an extensive assessment of covariates was performed in these six included studies. In the Cho et al. investigation, covariates included age, race, smoking, body mass index, energy, lutein and zeaxanthin intake, alcohol intake, physical activity, postmenopausal hormone use and occupation.^79^ A direct calculation of sun exposure was not included, however. Smith et al. adjusted for age, sex, current smoking and family history of late ARMD.^83^ Seddon et al. assessed the impact of age, sex, clinical center, education, caretenoid intake, measured systolic blood pressure, self-reported physical activity level, alcohol intake, body mass index, smoking status, and total caloric intake.^82^ Mares-Perlman et al.^80^ evaluated gender, smoking history, alcohol intake, time spent outdoors, dietary caretenoid intake, history of diabetes, cardiovascular disease and hypertension.

Covariates studied by Heuberger et al. were extensive.^84^ They included age, sex, smoking status, hypertension, HDL and cholesterol levels, physical activity, eye color and estrogen use. They also examined serum levels of C-reactive protein, fibrinogen, triglycerides, LDL cholesterol, caretenoids, and vitamins E, C, and A. The analysis was then conducted, taking into account comorbid conditions (cardiovascular disease, diabetes, and hypertension) in an attempt to reduce any biases from recent dietary modifications related to their presence.

The statistical analyses in the five studies where covariates were entered into multivariate analysis did not necessarily control for all of the same factors, measure them in the exact same way (e.g., smoking status) or enter them into their analysis in the same or similar stepwise fashion. Moreover, the studies did not measure omega-3 fatty acid intake in the same way. That said, the studies did not observe the same patterns of result concerning the protective role of omega-3 fatty acid intake and ARMD. Thus, it was not possible to establish which covariables had the most consistently strong influences on study outcomes.

## What is the Evidence for Efficacy of Omega-3 Fatty Acids in Slowing the Progression of Age-related Macular Degeneration?

As observed in Summary Table 4 (below), derived from Evidence Table 1 (Appendix E †††), a single RCT published in 2002 met eligibility criteria in investigating the question of omega-3 fatty acids' possible value in slowing the progression of ARMD.^76^

††† Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

### Overview of Relevant Study's Characteristics and Results

The only study addressing this question was a small, poorly designed RCT (n=35; 21 males; average age: 72 years) conducted by Scorolli et al. at a single university center in Bologna, Italy.^76^ Patients with bilateral exudative ARMD, yet who were not myopic, were randomized to receive either: 1) photodynamic therapy (PDT) as well as 48 hours before the laser application, and for the 3 months following this therapy, an oral “cocktail” of 200 mg/day of antioxidant vitamin E in addition to 1000 mg/day PUFA from 600 mg/day LA, 200 mg/day ALA and 200 mg/day DHA (n=20); or 2) PDT alone (n=15). Neither the delivery of vitamin E and PUFAs, nor the energy/calories from these sources, was controlled for using some form of placebo, for example. This failure to control for the supplementation in a research design, that also failed to permit the effects of vitamin E, the omega-6 fatty acid (i.e., LA) and omega-3 fatty acids (i.e., ALA, DHA) from being teased apart, made it impossible to ascribe any possible clinical benefits to either or both of the omega-3 fatty acid components. How the exposure was delivered (e.g., capsules) was also not described. The two main outcomes were visual acuity and retinal metabolic function. Visual acuity was measured with an Early Treatment Diabetic Retinopathy Study (ETDRS) chart in logMAR (i.e., minimum angle of resolution) units. Retinal metabolic function was assessed as recovery time after the Magder flicker test. The latter measures retinal metabolic function after a bright macular light stimulus. Both outcomes were measured 20, 40 and 60 days after the PDT. Only univariate analyses were conducted.

The RCT report did not describe many trial elements. It did not define a source population or identify the number of screened patients, those who were excluded, or those who withdrew. It did, however, delineate the inclusion and exclusion criteria. Inclusion criteria included the presence of a neovascular membrane under the fovea in one eye which had a logMAR visual acuity between 0.7 and 0.3. Exclusion criteria included age under 55 years, prior ocular surgery, and a history of (other) retinal disease. No details concerning allowable, restricted or taken cointerventions were provided. There was no mention of compliance. No key covariates were measured. There were no descriptions of an a priori sample size estimation, power given the present sample, or a plan for interim analysis. Neither the identity of the manufacturers nor the purity of the exposure materials were identified

This trial received a Jadad total quality score of 2, indicating low quality, and an allocation concealment rating of Unclear. The lowest ranking was assigned with respect to applicability (i.e., III). Given the existence of only one relevant study, a summary matrix was considered unnecessary.

The recovery time after macular flash was significantly shorter in the PDT plus antioxidant/PUFA group compared with the PDT alone group at 20 days only (p<0.001). There was a trend to improvement at 40 days for the treated group but it was not significant. This trend was even smaller at 60 days. There was no difference in visual acuity between the two groups at any time point.

## What is the Evidence that Omega-3 Fatty Acids Decrease the Rate of Progression to Advanced Forms of Age-related Macular Degeneration?

As observed in Summary Table 5 (below), derived from Evidence Table 3 (Appendix E ^‡‡‡^), one single prospective cohort study published in 2003 met eligibility criteria in investigating the question of omega-3 fatty acids' possible value in decreasing the rate of progression to advanced forms of ARMD.^60^

‡‡‡ Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

### Overview of Relevant Study's Characteristics and Results

As part of the Progression of ARMD Study, Seddon et al. analyzed data from a single prospective cohort involving 261 patients drawn from a Boston hospital-based retina practice specializing in ARMD.^60^ Of the 397 patients eligible for the study between May 1988 and July 1989, 92% were enrolled. Of the 366 enrollees, 36 did not complete the study and their data were not analyzed. Subjects were 60 years of age or older (mean: 72.8 years) and were primarily white (99.9%). The patients had non-exudative ARMD at entry into the cohort, and had to have at least one eye with best corrected vision of 20/200 or better. Any patient with cancer other than non-melanoma skin cancer was excluded for fear that this diagnosis would alter the recent diet. The average followup time was 4.6 years (from less than 1 year to more than 7 years). Nineteen people were censored because of loss to followup and eight patients' data were not used because of inadequate or missing answers. All 27 patients did not differ significantly from the others with regards to age or education, although more women than men were lost to followup.

Exposure status was assessed via a validated food frequency questionnaire. Fish intake was used as a proxy for omega-3 fatty acid intake. The questionnaire was mailed to patients before their first study visit and they were asked about their average consumption in the previous year. Review, coding and entry of data were masked.

The outcome was defined as progression to either geographic atrophy or neovascular disease. It was assessed by stereo fundus photographs and graded using a 5-point system. The system was modified from the one used during the Age Related Eye Disease Study (AREDS). Inter-grader reliability was assessed and was deemed to be good to very good (weighted kappa of 0.84). Any progression to grade 4 (extensive geographic atrophy) or grade 5 (an exudative choroidal neovascular membrane), or from grade 4 to grade 5 at any followup visit was considered a positive outcome. Each patient could only progress once in the followup period, counting only the first eye that progressed. Regression was not considered to be an option.

The Seddon et al. study received a total quality grade of A and an applicability rating of II, with the latter due to its almost exclusively white population.

From a final sample of 261 patients with ARMD, 101 progressed to advanced ARMD. A Cox proportional hazards analysis was performed, controlling for many covariates. Adjustments were made for age, gender, total energy intake and protein intake, number of years of education, smoking status, body mass index (BMI), systolic blood pressure, cardiovascular disease, self-reported alcohol intake and physical activity. Individual nutrients reported in the AREDS were also controlled for, including zinc, and vitamins C and E. The analysis also stratified for LA intake falling above or below the median.

The results indicated that fish intake did not affect the progression of ARMD to an advanced form overall, or in the high LA consumption group, but did protect against its advancement in the low (below median consumption) LA consumption group (RR: 0.36; 95%CI 0.14, 0.95).

## What is the Evidence for Efficacy of Omega-3 Fatty Acids in Slowing the Progression of Retinitis Pigmentosa?

As observed in Summary Tables 6 and 7 (below), derived from Evidence Tables 1 and 2 (Appendix E §§§), four studies, including one RCT,^73^ one comparative before-after study,^77^ and two noncomparative before-after studies,^72^ met eligibility criteria in investigating the question of omega-3 fatty acids' possible value in slowing the progression of retinitis pigmentosa. The two noncomparative before-after studies were described in a single report.^72^ These quasi-experimental studies were published between 1995 and 2004.

§§§ Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

### Overview of Relevant Studies

Hoffman et al. conducted a 4-year RCT comparing 400 mg/day DHA (n=23) and an identical looking and tasting gelatin placebo capsule (n=21), containing 400 mg/day corn/soy oil triglyceride, among male patients (mean age: 16 years; range 4–38 years) with X-linked retinitis pigmentosa (XLRP).^73^ Arguing that low levels of DHA in XLRP might influence retinal function, they aimed to elevate DHA RBC concentrations and to determine the effects of supplementation on the progression of XLRP. Patients were primarily recruited from an RP registry in the southwestern part of the US. The primary outcome was cone electroretinography (ERG) response to a 31 Hertz (Hz) flicker. Secondary ocular outcomes included rod ERG response, Humphrey visual field, fundus photography, visual acuity, dark adaptation, responses to a visual activity questionnaire and a patient opinion survey. Covariates assessed were age, race, body weight, and gene mutation. Safety outcomes (i.e., adverse events) were complemented by data from analyses of serum samples for: fatty acid content, antioxidants, total antioxidant capacity, platelet aggregation, alanine aminotransferase activity, and lipoprotein lipid profiles. Outcomes were assessed every 6 months. Descriptions in the report did not reveal inappropriate methods of handling or analyzing lipid samples.

Dagnelie et al. performed a comparative before-after study over 6 months involving 20 volunteers, recruited over the internet from an RP list, who were then divided into two groups.^77^ One group (n=10) received lutein alone (40 mg/day for 9 weeks, 20 mg/day thereafter), while the second group (n=10) received lutein (40 mg/day for 9 weeks, 20 mg/day thereafter) plus 500 mg/day DHA, vitamin B complex (dose not reported) and 600 mg/day digestive enzymes. The study aimed to study the impact of lutein supplementation. Ten patients were not discouraged from on-study consumption of additional, prestudy supplements (e.g., vitamin A palmitate and/or beta carotene), thereby further compounding the failure to give a placebo to the “lutein alone” group to control for the supplementation received by the other group. Only 13 of the 16 patients were specifically identified with RP, with the remaining three patients (n=2 in lutein alone group) exhibiting other retinal degenerations outside the focus of the present review. The primary outcomes were self-tested visual acuity and central visual acuity evaluated weekly for 14 weeks and bi-weekly thereafter. Age, gender eye color and RP disease type were also recorded.

Hoffman et al. performed two small studies of omega-3 fatty acid supplementation, where visual function was a secondary outcome.^72^ Although controls were included in each trial, they received the same supplementation as did the two studies' respective autosomal dominant RP (Study 2: attributable to rhodopsin mutations) patient groups. Controls' results were also never provided. For the purposes of the present review, it was thus decided to examine only the data from the RP patients, effectively making each of these designs a noncomparative before-after study. Several ocular parameters were measured in each study, including ERG, visual acuity and visual fields. But, only ERG results were reported. Covariates were not assessed in either study.

In both studies, the diet of participants was modified first, so as to reduce possible variability in on-study background omega-3 fatty acid intake.^72^ Then, in Study 1, three autosomal dominant RP patients were given a 3 g/day oral dose of a purified fish oil (0.7 g/day DHA, 1.3 g/day EPA) concentrate for 6 weeks. In Study 2, three autosomal dominant RP patients were given a purified preparation of EPA (i.e., EPA ethyl ester; 99.4% purity; dose not reported) for 3 weeks. In each study, 0.2 mg/g tert-butyl-hydroquinone and 2 mg/g tocopherols were added, as antioxidants, to maintain the exposure's freshness. Whether or not capsules were used to deliver the exposures is unclear. A key focus of each study was the impact of supplementation on RBC fatty acid contents.

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. The inclusion/exclusion criteria in Hoffman et al.'s RCT were well documented, and randomization was discussed in detail.^73^ Masking was implied but not explicitly detailed. Compliance was measured as RBC DHA content. A sample size calculation and descriptions of losses to followup were provided. An intention-to-treat analysis was undertaken. No details regarding interim analysis were provided. Numerous funding sources were identified (see Evidence Table 1: Appendix E ****).

**** Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

Dagnelie et al.'s eligibility criteria were poorly detailed.^77^ Their funding source was not provided.^77^ These investigators provided few details regarding the selection criteria. Selection criteria for Hoffman et al.'s two small studies were sparse.^72^ Their research was supported by the National Retinitis Pigmentosa Foundation Inc (US) and by the National Eye Institute.^72^

Population characteristics. Male patients with XLRP in Hoffman et al.'s RCT were recruited from the Southwest Eye Registry of the Retina Foundation and from clinical centers supported by the Foundation for Fighting Blindness.^73^ Eligibility criteria included a retina specialist's diagnosis of RP, a family history consistent with X-linked inheritance, a large amplitude cone response, and a baseline diet that did not purposefully include large amounts of omega-3 fatty acids. Fifty-two individuals were assessed for eligibility and 44 were randomized.

The source population in the Dagnelie et al. study^77^ study was not clearly documented.^77^ The sample came from an internet RP list, yet further details regarding recruitment were not provided. Of the 30 listed patients who initially showed interest, 20 decided to enroll in the study. Of these 20, four did not provide sufficient data and hence the final analyzed sample included 16 participants. The patients came from nine different countries, with 60% from the US (n=7) and Canada (n=5). Age and gender were noted in the study. The genetics of RP inheritance was varied.

In Hoffman et al.'s two noncomparative before-after studies, the source populations were not described at all.^72^ In the fish oil study (Study 1), the mean age was 31.7 years (n=2/3 male). In the EPA study (Study 2), the mean age was 29.3 years (n=2/3 female). For Study 2, the rhodopsin gene mutations were documented.

Intervention/exposure characteristics. Hoffman et al.'s RCT report clearly defined the intervention received by both study groups and its method of delivery via capsules.^73^ The daily dose of two 500 mg capsules provided a total fat content of 1000 mg/day for both study groups. Those patients taking the DHA content essentially received about 10 mg of DHA per kilogram of body weight per day. The DHA-enriched oil came from a single-cell algal source and was provided as a highly purified triacylglycerol. The investigators provided descriptions concerning the purity of their omega-3 fatty acid contents, and their source company (Martek Biosciences Corporation, US).

The purity of Hoffman et al.'s noncomparative before-after Study 2 exposure was identified, as was the source of their omega-3 fatty acid contents for both studies (Fish Oils Test Materials Program, US).^72^ Dagnelie et al. mentioned the names of manufacturers of their supplements, yet no purity data were supplied.^77^ These same investigators did not report compliance data.

In the three studies that evaluated the fatty acid content of biomarkers, no notable inappropriate methods to extract, prepare, store or analyze lipids were described.^72,^ ^73^ No study report in the whole review included details as to whether, or how, the presence of methylmercury was tested or eliminated from an omega-3 fatty acid exposure.

Outcome characteristics. Visual outcomes were recorded annually and the total duration of the Hoffman et al. RCT was 4 years.^73^ Their primary outcome was cone ERG response amplitudes to a 31 Hz flicker under maximal pupil dilation. Rod response was assessed as a secondary outcome. A Humphrey visual field 30–2 was also performed and the mean defect was the specific outcome used. Fundus photos were taken as per the ETDRS protocol, and grading was completed. The Visual Activities Questionnaire was also given to all patients. A patient survey of the perceived benefit of the intervention was included. Additional outcomes included specific biological safety data: total fatty acid content, and their relative ratios, vitamin A and E levels (in ug/dL), total antioxidant capacity in synthetic vitamin E equivalents, platelet aggregation (impedance units), alanine aminotransferase activity (in U/L) and lipoprotein lipid profiles (mg/dL). Patients were also requested to report all adverse events.

In the Dagnelie study, the investigators created six visual acuity charts in the form of Microsoft Word ™ files.^77^ Patients were instructed to use the six charts in rotation on their monitor at arm's length and not to change the working distance. Patients entered the number of letters seen in this binocular test on a weekly report form. For central visual field testing, the patients had to create their own field via instructions given to them. The field area seen was recorded by the patient and submitted via the internet. Participants submitted data each week for 26 weeks and included subjective data on glare, dark and light adaptation, night vision, color vision, depth perception, peripheral vision, and adverse event data with respect to allergy or irritation in the eyes. Each subjective answer was binary, but a more detailed questionnaire was filled out at the end of the study (using a non-validated scale).

In the two Hoffman et al. noncomparative before-after studies, best corrected visual acuity was performed using Bailey-Lovie eye charts.^72^ The better eye was then used for the rest of the testing. Kinetic visual fields were obtained with Goldman IV4e spot sizes. Full field ERGs were obtained and the protocol followed international standards.

Study quality and applicability. While the Hoffman et al. RCT received a total quality grade of A and an applicability rating of II (i.e., only males were enrolled), the three quasi-experimental studies by Dagnelie et al.^77^ and Hoffman et al.^72^ each attained a total quality grade of C (Summary Matrix 2). Of the latter three studies, only the one conducted by Dagnelie et al. received an applicability grade (i.e., III).^77^ Hoffman et al.'s two studies did not provide sufficient information to permit determinations of applicability.^72^ These studies were therefore excluded from the summary matrix.

### Qualitative Synthesis of Individual Study Results

By the fourth year of Hoffman et al.'s RCT, the average loss of cone function in the DHA supplementation group was 25% lower than what was observed in the control group; but, this difference was not statistically significant.^73^ Given that five patients were deemed noncompliant based on RBC levels of DHA, secondary analyses were performed to explore the relationship between DHA RBC level and ERG progression. None of the results achieved a level of statistical significance, however. Rod ERG loss was 48% lower in the DHA group compared with the control group, yet this difference was also not statistically significant. The rod and cone loss showed effect modification by age. Specifically, the rod functional loss was significantly reduced in the prepuberty group supplemented with DHA compared with placebo (p=0.04), and the cone functional loss was significantly reduced compared with placebo in the post-puberty group supplemented with DHA (p=0.038).

Visual field, acuity and dark adaptation outcomes did not differ between the groups.^73^ Fundus photographs showed significantly less progression in the DHA group when compared with placebo (p=0.04). Visual activity questionnaire results were not different in the two groups, but significantly more patients receiving DHA supplementation felt their treatment had benefited them compared with placebo patients. Stratification for genetic mutation status did not yield between-group differences.^73^ There were no between-group differences in the results relating to the biological safety assessment. Self-reported adverse event data for the Hoffman et al. RCT are provided in association with the last question in this Chapter.

In the Dagnelie et al. study, there were statistically significant improvements in visual acuity and kinetic visual fields for the 16 participants (p=0.05).^77^ Analysis by supplement type (lutein alone vs lutein plus omega-3 fatty acids plus vitamin B and enzymes) failed to observe a significant difference for either outcome, but there was a trend for improvement in both outcomes for the lutein alone group. Either way, given the study design it was impossible to isolate the specific impact of the omega-3 fatty acids on clinical outcomes. Dagnelie et al.'s study report did not present outcome data organized to allow for a meaningful investigation of only those data from patients with specific types of RP.^77^ In Hoffman et al.'s two noncomparative before-after studies, the ERG results showed no statistically significant before-after changes.^72^

### Impact of Covariates and Confounders

In Hoffman et al.'s RCT, age, race and body weight were recorded.^73^ A gene mutation analysis was also performed, distinguishing between the RPGR mutation and the RP24 mutation. Dagnelie et al. measured age, race, country of origin, baseline supplementation, type of RP and the genetic component of RP.^77^ However, there was a paucity of detail concerning the regression models designed to assess the influence of these possible covariates. In Hoffman et al.'s two noncomparative before-after studies' reports, age, gender and rhodopsin gene mutation data were provided.^72^ However given the extremely small sample sizes within each study, meaningful effect modification analysis could not be performed.

## What is the Evidence for Efficacy of Omega-3 Fatty Acids in Slowing the Progression of Proliferative Retinopathy in Patients with Diabetic Retinopathy?

## What is the Evidence for Efficacy of Omega-3 Fatty Acids in Slowing the Progression of Clinically Significant Macular Edema in Patients with Diabetic Retinopathy?

As observed in Summary Table 8 (below), derived from Evidence Table 2 (Appendix E ^††††^), a noncomparative before-after study published in 1997 met eligibility criteria in investigating two questions. Given that 12 patients with diabetes were identified with proliferative retinopathy, this study was included in the review. As well, this study constitutes at best an indirect investigation of the question of omega-3 fatty acids' possible value in slowing the progression of clinically significant macular edema in patients with diabetic retinopathy. The impact of the intervention on macular edema was not directly evaluated although conditions associated with macular edema were observed. Given that this study investigates each of the two questions in limited fashion, it is systematically reviewed only once.

†††† Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

### Overview of Relevant Study's Characteristics and Results

Sorokin et al. evaluated 48 patients (n=20 males; mean age: 56 years) with diabetic retinopathy (DR), 14 of whom had type I diabetes.^75^ There were also 12 non-diabetic controls, whose data were not pertinent to the present review. Although it is likely that the sample was selected from the investigators' institution, this was not explicitly stated. Patients were divided into four groups, based on degree of severity: 1) “Preclinical” (i.e., DR detected only by angiography; n=12); “Manifest DR” (i.e., microaneurysms; n=10); 3) “Exudating DR” (i.e., lipid exudation; n=14); and, 4) “Proliferative DR” (n=12). Few other details were provided. With respect to the diagnostic evaluation of the patients, it should be noted that, of the four stages, only stage 4 meets North American standards. All patients received a standard daily dose of 4 g of Eiconol (DHA+EPA) for 3 months. The method of delivery was not indicated, however. No other details concerning the omega-3 fatty acid intervention (e.g., purity; how freshness was maintained) were described.

Primary and secondary outcomes were not distinguished. Moreover, the serum concentrations of cholesterol and triglyceride, whose data were provided, were not relevant to this review. Another outcome was the microcirculation of the bulbar conjunctiva, which the authors described as a proxy for retinal microcirculation. However, in North America this is not considered standard diagnostic practice, and hence this outcome was not considered relevant for this review. A third outcome entailed the fluorometric assessment of fluorescein leakage (measured as concentration) into the vitreous, a relevant but proxy outcome for diabetic retinopathy in North America. The fourth outcome was evaluated using the photostress test, which measures photoreceptor recovery after light stimulation. This is also a proxy outcome. Finally, there was a before-after clinical comparison of the eye fundus, which is a North American gold standard. However, neither the details of the method of exam (e.g., clinic recording, photographs) nor the quantification of the results were provided in the report. No confounders were investigated.

Results indicated that 36.7+/-2.8% of patients demonstrated a larger number of functioning capillaries within 1 mm of the “field of vision.” It is unclear exactly to what the investigators were referring by this term. A decrease of 24.1+/-1.9% in the presumed vitreous permeability of fluorescein dye was found among 72.7+/-1.7% of patients with exudative and proliferative DR. The photostress test showed that the original visual acuity factor reduced by 0.3+/-0.05 among 39.1+/-1.4 % of the treated patients when compared to their baseline level (p<0.05). Although details are sparse with respect to these data or the results of tests of significance, these outcomes were described as having been improved in patients who took the supplements, but especially in those patients with the least advanced forms of diabetic retinopathy. There was also a “more intense resolution of diabetic hemorrhages” after the administration of the intervention (data not reported). This study received a total quality grade of C and an applicability rating of III. The latter was assigned because of the background diet of the study participants.

## What is the Evidence for Efficacy of Omega-3 Fatty Acids in Preventing Age-related Cataracts?

As observed in Summary Table 9 (below), derived from Evidence Table 3 (Appendix E ‡‡‡‡), two single population cross-sectional studies met eligibility criteria in investigating the question of omega-3 fatty acids' possible value in preventing age-related cataracts.^85,^ ^86^ These studies were published in 2000 and 2002.

‡‡‡‡ Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

### Overview of Relevant Studies' Characteristics and Results

As part of the Blue Mountains Eye Study, Cumming et al. conducted a (single) population-based cross-sectional study examining several diet variables and the three main types of cataract in elderly urban dwellers.^86^ A door to door census of the region was undertaken. All permanent residents of the area were invited to attend a local clinic for a detailed eye examination if they were born in 1942 or earlier. Of the 4,433 eligible people identified, 3,654 attended the study clinic between January 1992 and January 1994. Of the participating patients, 3,267 completed the questionnaire and 2,900 (median age: 65 years; range: 49–97 years) provided usable data on nutrient intake.

Photographic assessments of dilated pupils were used to establish cataract status. The method employed a Topcon slit lamp camera system and followed an established protocol (i.e., Beaver Dam Study). A 145-item food frequency questionnaire, modified for the Australian diet, was also employed.^86^ Cataracts were assessed as nuclear, cortical or posterior subcapsular. Two masked graders assessed the photographs and established an inter-rater agreement between 0.57 and 0.79. The method of adjudication was not discussed.

The only assessment for omega-3 fatty acid intake was by distant proxy, namely, via descriptions of the intake of broccoli and spinach, each of which contains small amounts of omega-3 fatty acids (i.e., ALA). Data relating to PUFA consumption could not be used to indicate omega-3 fatty acid intake, given that omega-3 and omega-6 fatty acid types of PUFA were not distinguished. Several covariates that were established by interview-assisted questionnaire, including risk factors for cataract, were controlled for: smoking history, education, use of oral or inhaled corticosteroids, a history of diabetes or hypertension. Sun related damage was assessed visually by examining subjects' arms, hands and faces and was recorded on an ordinal scale. The study was supported by the Australian Department of Health and Family Services and the Save Sight Institute, University of Sydney.

As part of the Reykjavik Eye Study (August to October 1996), Arnarsson et al. included 1,045 persons in a single population cross-sectional study examining risk factors for nuclear lens opacities.^85^ The source and sample populations were clearly described. A random sample was taken from the population census. It included 1,700 citizens from Reykjavik who were at least 50 years of age. Of the 1,379 individuals who were eligible and could be located, 1,045 of them were interviewed and examined. All were Caucasian. Further demographic details of the overall baseline population were not provided. Patients underwent an eye examination that included slit and retroilluminated images of the lens, using a Nidek camera. Whether or not all patients' pupils were dilated was not stated. Patients also filled in an in-depth questionnaire. Cataract was assessed via anterior segment photographs. The diagnosis and grading of nuclear lens opacities followed the Kanazawa Medical University (KMU) system, which roughly follows the Lens Opacity Classification System II (LOCS II) system. All grades of nuclear lens opacity were combined to afford an analysis evaluating the presence, or absence, of cataract. The method of adjudication, the number of evaluators, and whether they were masked, were not described in this paper.

A 26-item food frequency questionnaire was employed.^85^ Several proxies for omega-3 fatty acid intake were studied, including consumption of cod-liver oil, fish, plant oil, herring, sardines, and shrimp. Several covariates were controlled for, including ultraviolet (UV) exposure (typical outdoor exposure over time, and cumulated). The latter was a covariate that was controlled for only by Mares-Perlman et al.^80^ in their ARMD study (see above). Other factors assessed in Arnarsson et al.'s study were: age, asthma, diabetes, cardiovascular disease, smoking, alcohol consumption, pseudoexfoliation glaucoma, computer usage, infrared light exposure, iris color, hyperopia, glaucoma, use of antihypertensive medication, and the use of cholesterol lowering drugs, systemic corticosteroids or allopurinol.^85^ These covariables were measured via interview, examination and by questionnaire. The study was performed at the Department of Ophthalmology in Reykjavik in cooperation with the Department of Ophthalmology, Kanazawa Medical University. Although the funding source for this study was not given, it is well known that this study had been funded by the National Medical Research funding agency of Iceland.

Each study received a total quality grade of B and an applicability rating of III, the latter indicating little potential for their results to be meaningfully extrapolated to the North American population (Summary Matrix 3).

The Reykjavik Eye Study data presented by Arnarsson et al. revealed no statistically significant associations between nuclear cataract and the consumption of omega-3 fatty acid foods or oils obtained from fish or seafood.^85^ The Blue Mountains Eye Study found an inverse association between consumption of all PUFA content and cortical cataract.^86^ However, this observation cannot be used to address the research question for the reason described earlier. There was no association between the consumption of broccoli or spinach and nuclear cataract.

## What is the Evidence for Efficacy of Omega-3 Fatty Acids in Slowing the Rate of Progression of Age-related Cataracts?

As observed in Summary Table 10 (below), derived from Evidence Table 2 (Appendix E ^§§§§^), one noncomparative before-after study published in 2001 met eligibility criteria in investigating the question of omega-3 fatty acids' possible value in slowing the rate of progression of age-related cataracts.^78^

§§§§ Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

### Overview of Relevant Study's Characteristics and Results

Among the studies included in this review, only one even indirectly addressed the question of the relationship between omega-3 fatty acid consumption and the slowing of the progression of age-related cataracts. It was a noncomparative before-after study conducted by Suzuki et al.^78^ Fifteen volunteers were given a daily supplement of DHA. Fourteen of these individuals had pre-existing cataract at the time of supplementation. Of these participants, three also had glaucoma. The fifteenth subject exclusively exhibited glaucoma. The source population was not well described, however. Study participants were drawn from 30 volunteers (mean age: 72 years; range: 58–74 years) participating in a dementia study. All lived in a nursing home for the aged. Visual acuity was measured before and after DHA supplementation, although this focus was secondary to the assessment of dementia (i.e., the primary outcome). However, the study did not explicitly measure changes in cataract status; rather, it measured visual acuity in patients with cataract. Covariates were not measured. A funding source was not provided.

Participants each received six capsules per day containing a total of 0.54 g odorless DHA oil for 3 months. They maintained their normal diet, ingesting approximately 0.73 g/day DHA and 0.53 g/day EPA. While the manufacturer of the exposure was identified (Sugo, Co.), purity data were not described. As well, the method by which the oil was deodorized was not provided. No mention was made of whether anything had been added to the oil to maintain its freshness.

The outcome was visual acuity, measured using Landolt's rings, before and after 3 months of supplementation. No measurements or photographs of cataracts were taken at any time in this study. No covariates were assessed. This study received a total quality grade of C and an applicability rating of III.

Results indicated that vision improved in 10 of 15 patients, while nine of 14 patients with cataracts showed an improvement in vision (no results of tests of significance reported). Given the nature of the outcome, however, it remains unknown whether the cataracts themselves were reduced.

## What is the Evidence for the Risk of Short and Longterm Adverse Events Related to the Intake of Omega-3 Fatty Acids?

Adverse events are often underreported in study reports; therefore, failure to report any does not constitute evidence that none occurred. That said, no report of an interventional study in our review explicitly stated that no exposure-related events had been observed. A number of interventional studies, employing various populations, interventions/exposures and followup durations, did not report either having solicited adverse effects data from study participants or having received such reports.^72,^ ^75,^ ^76,^ ^78^ Dagnelie et al. asked patients to report adverse effects, yet no data were supplied.^77^ The use of interventional “cocktails” containing multiple active ingredients in the Dagnelie et al.^77^ and Scorolli et al.^76^ studies would have prevented the meaningful attribution of any specific harms to the intake of omega-3 fatty acids, had they been observed and reported. Only Hoffman et al.'s RCT investigation of the impact of DHA supplementation on XLRP both solicited and reported the occurrence of adverse effects.^73^

Ten study participants reported only short-term, minor adverse events over the 4 years of Hoffman et al.'s trial with XLRP patients.^73^ No patients were forced to withdraw from the study due to any of these effects. Six placebo group patients (age range: 13–32 years) and four patients receiving 400 mg/day DHA (age range: 9–19 years) noted some adverse effects. Placebo group patients described: bruising (n=2 events), with post-event followup revealing that both instances were related to physical contact sports; a sinusitis (n=1) preceding prolonged epistaxis (n=1); prolonged bleeding (n=1), although a post-event bleeding time test revealed that bleeding time was within normal limits; eructation (i.e., “burp back;” n=1); nausea (n=1); and, flatulence (n=1). The nausea lasted less than a week, and both the eructation and flatulence were related to the consumption of the corn/soy oil contents. One instance each of apnea, fainting and a “weird feeling” were established as unrelated to the study by parents or family physician.

The DHA group reported a single case of eructation related to capsule consumption.^73^ Other adverse events included: acne (n=1 event); headache (n=2); ear infection (n=1); fatigue (n=1); and, weight gain (n=1). The participants' parents or family physician described the latter five effects as normal events of adolescence.

Half of the 10 patients with adverse event reports each experienced more than one adverse event during the course of the 4-year trial.^73^ However, only one of these circumstances (i.e., a sinusitis, then prolonged epistaxis in a patient receiving placebo) was identified in the study report. Seven of the youngest patients initially had to take four half-sized capsules to achieve their daily DHA dose because they had difficulty swallowing the regular capsules. Over time, however, these patients were able to swallow their daily dose via two full-sized capsules like the other study participants.

Given this safety profile, it appears that DHA intake was associated with few minor, mainly, gastrointestinal effects. The doses of oil and DHA from this intervention would be considered low, when compared to other interventional studies trying to influence respiratory^71^ or mental health outcomes with omega-3 fatty acids. Finally, Hoffman et al.'s biological safety assessment (i.e., plasma antioxidant capacity; vitamin A concentration; whole blood platelet aggregation; liver function enzyme activity; plasma lipoprotein lipid profiles) indicated that this low dose DHA was not associated with any identifiable safety risk.^73^ However, while significant between-group differences on these safety outcomes were not observed, both study groups exhibited lower platelet aggregation and vitamin E values than the laboratory reference standards.^73^ Finally, plasma vitamin E levels exhibited a nonsignificant trend towards lower concentrations in the last 2 years of the study, suggesting that future interventional studies should surveil these on-study values.