# Methods

## Overview

The UO-EPC's evidence report on omega-3 fatty acids in eye health is based on a systematic review of the scientific-medical literature to identify, and synthesize the results from, studies addressing key questions. Together with content experts, UO-EPC staff identified specific issues integral to the review. A Technical Expert Panel (TEP) helped refine the research questions as well as highlighted key variables requiring consideration in the evidence synthesis. Evidence tables presenting key study-related characteristics were developed and are found in the Appendices. In-text summary tables were derived from the evidence tables. The methodological quality and generalizability of the included studies were appraised, and individual study results were summarized.

## Key Questions Addressed In This Report

The purpose of this evidence report was to synthesize information from relevant studies to address the following questions, organized by type of eye disease/visual impairment and identified by type of question (in parentheses):

Degenerative Diseases of the Retina—Macular Degeneration:

- What is the evidence for efficacy of omega-3 fatty acids in preventing age-related macular degeneration?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of age-related macular degeneration?
- What is the evidence that omega-3 fatty acids decrease the rate of progression to advanced forms of macular degeneration?
  - What is the evidence that omega-3 fatty acids decrease the rate of progression to advanced forms of macular degeneration in diabetics?
  - What is the evidence that omega-3 fatty acids decrease the rate of progression to advanced forms of macular degeneration in patients with cataracts?
- What is the evidence that omega-3 fatty acids decrease the rate of progression of advanced forms of macular degeneration?
  - What is the evidence that omega-3 fatty acids decrease the rate of progression of advanced forms of macular degeneration in diabetics?
  - What is the evidence that omega-3 fatty acids decrease the rate of progression of advanced forms of macular degeneration in patients with cataracts?

Degenerative Diseases of the Retina—Retinitis Pigmentosa:

- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of retinitis pigmentosa (i.e., an inherited retinal dystrophy)?

Vascular Diseases of the Retina—Retinal Vein or Retinal Artery Occlusions:

- What is the evidence for efficacy of omega-3 fatty acids in preventing retinal vein occlusion?
- What is the evidence for efficacy of omega-3 fatty acids in preventing retinal artery occlusion?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of retinal vein occlusion?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of retinal artery occlusion?

Vascular Diseases of the Retina in Diabetics:

- What is the evidence for efficacy of omega-3 fatty acids in preventing proliferative retinopathy in diabetics?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of proliferative retinopathy in diabetics?
- What is the evidence for efficacy of omega-3 fatty acids in preventing clinically significant macular edema in patients with diabetic retinopathy?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of clinically significant macular edema in patients with diabetic retinopathy?

Cataracts:

- What is the evidence for efficacy of omega-3 fatty acids in preventing age-related cataracts?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the rate of progression of age-related cataracts?
  - What is the evidence for efficacy of omega-3 fatty acids in slowing the rate of progression of age-related cataracts in diabetics?
  - What is the evidence for efficacy of omega-3 fatty acids in slowing the rate of progression of age-related cataracts in patients with age-related macular degeneration?
- What is the evidence that omega-3 fatty acids decrease the rate of cataract surgery in ageing populations?

Adverse Events:

- What is the evidence for the risk of short- and longterm adverse events related to the intake of omega-3 fatty acids?

The overarching goal was to identify and systematically review whatever evidence exists within the eligibility boundaries established for this review in consultation with our TEP and in light of the topics being addressed by SC-RAND and Tufts-NEMC EPCs. These boundaries are delineated in the Eligibility Criteria section (below). More details concerning the questions are provided in conjunction with the description of the Analytic Framework (below). We were also guided collectively by ODS, our TEP and our UO-EPC review team content experts to examine, where data permitted, the possible influence on efficacy, association or safety evidence of the following potential covariates:

- intervention/exposure length;
- type(s) of omega-3 fatty acid (e.g., ALA, EPA, DHA);
- source of the omega-3 fatty acids (e.g., marine, plant, nut), including the specific source (e.g., mackerel as an oily fish);
- delivery format (e.g., whole food servings, capsules, pourable or spreadable oils);
- dose/serving size, including the precision/control of its delivery (e.g., per-day specific, minimum, maximum or range of numbers of capsules, whole food servings or bottle-pourable liters);
- type of processing used to purify the intervention/exposure and/or to maintain the experimental blind (e.g., ethyl esterification; adding an anti-oxidant to stabilize/preserve oils; adding flavor to oils; [vacuum] deodorization);
- amount/dose of omega-6 fatty acid intake either added as a separate cointervention or identified as being present in the background diet, thereby establishing a specific, minimum, maximum or range of allowable or mandated on-study omega-6/omega-3 fatty acid intake;
- the identity of the manufacturer and/or certain characteristics of their product(s) (i.e., purity; presence of other potentially active agents that have not been added intentionally: e.g., methylmercury content);
- the prestudy/baseline or on-study omega-3 or omega-6/omega-3 fatty acid content of blood lipid biomarkers;
- absolute or relative omega-3 fatty acid content of the prestudy/baseline diet;
- omega-6/omega-3 fatty acid content in the prestudy/baseline diet, with the study population's country of origin as a possible surrogate measure of the omega-6/omega-3 fatty acid content of the background diet; and,
- any study subpopulations (e.g., minority; ethnic; genetic, including diabetics).
- Furthermore, where data permitted, the following factors with the potential to influence eye health outcomes were also investigated (see Appendix C * Data Abstraction form for more detail):
  * Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm
- primary diagnosis of eye disease/visual impairment, including which eye(s);
- stage/severity and prognosis (e.g., wet vs dry age-related macular degeneration);
- current age, age at onset, age at diagnosis (duration) and etiology;
- concurrent conditions, or general health status (e.g., diabetes, high blood pressure, myopia);
- history/current surgeries, therapies and medication for primary diagnosis, including responses;
- history/current lutein, beta carotene, antioxidant, other supplement or complementary/alternative medicine (CAM) use (e.g., vitamins, minerals);
- additional medication/treatments (e.g., insulin);
- key sociodemographic factors (e.g., marital status, education, income, employment status) and race/ethnicity;
- other notable characteristics/conditions (e.g., pregnant; blue eyes; oral contraceptive use; steroid use);
- exposure to sunlight; and,
- past/current smoker status, alcohol consumption and illicit drug use.

Current smoker status and alcohol consumption may be important covariates in that they have often been observed to influence various kinds of health status as well as essential fatty acid status, with levels of the latter potentially affecting the former.^59,^ ^60^

## Analytic Framework

An analytic framework was developed to make explicit the review's specific links relating the populations and settings of interest (i.e., the study participants and the eye diseases/visual impairments of interest), the focal exposure or intervention (i.e., omega-3 fatty acids ingested as supplementation and/or from food sources), potential effect-modifying factors, key eye health outcomes, and the possible role played by the omega-3 or omega-6/omega-3 fatty acid content of biomarkers in mediating the intake-outcome relationship (Figure 2). The possibilities of adverse events (e.g., side effects) and contraindications are recognized. In short, the framework outlines the various lines of logic defining the review's research questions. However, not all linkages were investigated.

Figure 2. Analytic Framework for omega-3 fatty acids in eye health. Populations of interest in rectangles. Exposure in oval. Outcomes in rounded rectangles. Covariates in hexagons. Solid connecting arrows indicate associations and effects reviewed in this report

One criterion established in this review is that each researchable question had to be clinically relevant. That is, each question had to involve the investigation of at least one relevant clinical outcome. Likewise, to be eligible for inclusion in the review, each study had to entail an investigation of at least one pertinent clinical outcome. Considering the purpose of the two-year task order is to afford a clinically-relevant research agenda, this decision was judged to be appropriate by both our TEP and our review team.

Each of the clinically-relevant research questions entailed the investigation of the potentially beneficial influence of omega-3 fatty acid intake, via diet and/or supplementation, on eye health-related clinical outcomes in at least one of the following populations of interest:

- those with a current eye disease/visual impairment diagnosis (Population 1);
- those at elevated risk to develop eye disease/visual impairment (Population 2);
- “healthy” individuals who have not been identified as being at elevated risk to develop eye disease/visual impairment (Population 3); or,
- specific subpopulations (e.g., minority, ethnic, genetic) thereof, including those individuals with diabetes (Population 4).

The questions primarily concerned primary or secondary prevention. Primary prevention studies could enroll participants from Populations 2 or 3, each with or without representation from a relevant subpopulation (i.e., Population 4). Secondary prevention studies could involve individuals drawn from Population 1, also with or without representation from a relevant subpopulation (i.e., Population 4).

The possible impact of predefined covariates on efficacy or association data was assessed where data were available (e.g., omega-3 fatty acid source, dose/serving size, exposure/intervention length, and type [e.g., ALA, DHA, EPA, or combinations thereof]; omega-6/omega-3 fatty acid content of the background diet; age; sex). These data are highlighted in question-specific sections titled “Impact of Covariates and Confounders,” which identify those variables in included studies that were observed, by virtue of (failed or no) attempts to control for them either experimentally or analytically, to (in)consistently (fail to) influence clinical outcomes.

Given that each included study had to entail an investigation of at least one pertinent clinical outcome, excluded were studies whose sole focus was to examine the impact of omega-3 fatty acid interventions or exposures on the omega-3 or omega-6/omega-3 fatty acid content of biomarkers, even if the study populations were individuals with eye disease/visual impairment. Data concerning the omega-3 or omega-6/omega-3 fatty acid content of biomarkers were eligible for systematic review only if they were collected in a study evaluating the relationship between the intake of omega-3 fatty acids and pertinent clinical outcomes. This evidence could be important since levels of omega-3 or omega-6/omega-3 fatty acid content in human biomarkers (i.e., composition or concentration) might be found to influence (i.e., predispose; protect) the onset, progression or outcome of eye disease/visual impairment; and, reliable associations between biomarker and clinical effects in interventional studies could suggest a mechanism by which omega-3 fatty acid interventions/exposures bring about improved clinical outcomes. Outcomes of interest included the onset (prevalence, incidence), progression (e.g., change in clinical status, indicating progression to an advanced stage) or outcome (e.g., need for cataract surgery) of eye disease/visual impairment.

## Study Identification

### Search Strategy

The search strategy for this project was designed to be comprehensive and achieve the highest possible recall of relevant clinical studies. The electronic search strategy was developed by an information specialist in consultation with a clinical content expert in eye health, and reviewed by a second information specialist. The eye search concept was combined with the core omega-3 fatty acids search strategy established in collaboration with the project librarians, biochemists, nutritionists, and clinicians from the three EPCs involved in the 2-year, Health Benefits of Omega-3 Fatty Acids project. Consultation among these sources provided the biochemical names and abbreviations of omega-3 fatty acids, names of commercial omega-3 fatty acids products, and food sources of omega-3 fatty acids.

The following electronic databases were searched: Medline (1966 - November Week 2 2003 and updated to February Week 1 2004), Premedline (May 4 2004), Embase (1980 to 2003 Week 48 and updated to 2004 Week 7), the Cochrane Library including the Cochrane Central Register of Controlled Trials (3rd Quarter 2003), and CAB Health (1973-Dec 2003). All databases were searched via the Ovid interface using Search Strategy 1 (Appendix A ^†^), except CAB Health, which was searched through SilverPlatter using Search Strategy 2 (Appendix A *). Searches were not restricted by language of publication, publication type, or study design, except with respect to the MeSH term “dietary fats,” which was limited by study design to increase its specificity. A total of 721 bibliographic records were downloaded, with duplicate records identified and removed using citation management software (Reference Manager®).

† Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

Reference lists of included studies, book chapters, and narrative or systematic reviews retrieved after having passed the first level of relevance screening, were manually searched to identify additional unique references. Through contact with content experts, attempts were made to identify both published and unpublished studies. On behalf of the three EPCs investigating the evidence concerning the health benefits of omega-3 fatty acids, a letter was written to industry representatives to obtain additional evidence (Appendix B *). A member of our TEP, Dr. John Paul SanGiovanni, provided access to numerous publications as well as reference lists from past and in press publications to aid this endeavor. These efforts identified an additional 25 records that were added to the collection for review. A final set of 507 unique references was identified.

### Eligibility Criteria

Published and unpublished studies, written in any language, were eligible for inclusion. Excluding grey literature from systematic reviews of interventions can lead to the overestimation of effect sizes.^61^ Substantial bias in the results of a systematic review pertaining to a complementary/alternative medical (CAM) intervention can ensue from the exclusion of data from reports written in languages other than English.^62^ AHRQ and ODS consider omega-3 fatty acids to be a CAM exposure.

Data from live human study populations or subpopulations (e.g., genetic, minority, ethnic: e.g., for diabetic retinopathy) of any age were required to maximize generalizability. Study populations had to have been assessed using standard methods (e.g., electroretinograms) and diagnostic criteria to establish eye disease/visual impairment. The specific types of population required to address each of the research questions are described with reference to the analytic framework, and those details are not repeated here. Consultation with our TEP finalized the eye diseases/visual impairments of interest based on a list provided initially by ODS.

Studies had to specifically investigate foods or supplements known to contain omega-3 fatty acids of any type (e.g., EPA, ALA), from any source (e.g., fish, walnuts, seed oil), any serving size or dose, delivered in any fashion (e.g., capsules, liquid, PUFA-rich diet) and for any length of time. Studies investigating “PUFAs” or “LC PUFAs,” or even types of diet one might presume would contain marine or land sources of omega-3 fatty acids (e.g., “Mediterranean diet”) at minimum had to highlight at least one source of the omega-3 fatty acid content (e.g., oily fish servings). No restrictions were placed on the types or doses of pre- or on-study cointerventions (e.g., medication, omega-6 fatty acid intake, other dietary supplements).

Given the expectation that the relevant literature would be quite small, no restrictions were placed on the levels of evidence required for inclusion in the review. Nevertheless, it was assumed that, for questions of intervention efficacy or effectiveness, randomized controlled trial (RCT) evidence would carry greater interpretative weight since this research design is the gold standard method to investigate these questions.^63^ RCTs exhibit a greater inherent potential to deal with potentially serious biasing influences (e.g., selection bias; confounding) although a poorly designed or conducted RCT can produce results whose interpretability is no less complicated by the presence of confounding influences, for example, than observations derived from a well-constructed and conducted study employing a design with a lesser intrinsic capacity to control for these biases (e.g., non-RCT; prospective cohort study). For example, not all RCTs succeed, either through an explicit experimental plan or the process of randomization per se, to equally distribute known confounding influences (e.g., background diet; energy/caloric intake from the intervention; types and doses of as-needed medication) across study arms in intervention studies. Here, controlled studies of an observational nature were considered to carry greater interpretative weight than uncontrolled observational ones even though poorly designed or conducted controlled studies (e.g., inappropriate selection of controls in a case-control study) may likewise fail to produce fewer complications for interpretability than well-designed uncontrolled ones. Finally, greater interpretative weight was associated with results obtained from prospective designs.

Pertinent clinical outcomes are described in relation to the analytic framework. As markers of omega-3 fatty acid metabolism, the following fatty acid compositions or concentrations, from any source (e.g., red blood cell [RBC] membranes, plasma phospholipids), were considered relevant: EPA, DHA, AA/EPA, AA/DHA, and AA/EPA+DHA.

### Study Selection Process

The present review employed specific electronic functionality in the form of an internet-based software system, housed on a secure web site. It brings appreciable efficiencies to the systematic review process and the management of a systematic review team. Electronic yields of literature searches are posted to the system for review. Reviewers then submit all of their results of relevance screening, data appraisal or data abstraction directly to the system. The software system automatically conducts an internal comparison of multiple reviewers' responses to screening questions, to determine the eligibility/relevance of a bibliographic record or a full report. As well, the software captures responses to specific requests to abstract pre-specified data (e.g., mean age of study participants; the assessment of a study's internal validity) from pertinent reports. One large advantage associated with using this software is that review team members are able to complete their work from wherever they have Internet access.

Following a calibration exercise, which involved screening five sample records using an electronic form developed and tested especially for this review (Appendix C ^‡^), two reviewers independently screened the title, abstract, and key words from each bibliographic record for relevance by liberally applying the eligibility criteria. A record was retained if it appeared to contain pertinent study information. If the reviewers did not agree in finding at least one unequivocal reason for excluding it, it was entered into the next phase of the review. The reasons for exclusion were noted using a modified QUOROM format (Appendix D *).^64^ The screening process also aimed to determine whether a record might also or instead pertain to any of the other topics being systematically reviewed by the three EPCs in year 2 of the omega-3 fatty acids project.

‡ Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

Print or electronic copies of the full reports for those citations having passed level one screening were then retrieved. After completing a calibration exercise, which involved evaluating five sample reports using the same eligibility criteria (Appendix C *), the rest of the reports were independently assessed by two reviewers. Reports were not masked given the equivocal evidence regarding the benefits of this practice.^65^ To be considered relevant at this second level of screening, all eligibility criteria had to be met.

Disagreements arising at screening level 2 were resolved by forced consensus and, if necessary, third party intervention. Excluded studies are noted as to the reason for their ineligibility in a listing found at the end of this report.

## Data Abstraction

Following a calibration exercise involving two studies, two reviewers independently abstracted the contents of included studies using an electronic Data Abstraction form developed especially for this review (Appendix C *). A third reviewer then verified those data. Data abstracted included the characteristics of the:

- report (e.g., publication status, language of publication, year of publication);
- study (e.g., sample size; research design; number of study arms/groups, cohorts, or phases; funding source);
- population (e.g., age; percent males; diagnosis description, including severity, duration, and comorbid conditions);
- intervention/exposure (e.g., omega-3 fatty acid types, sources, doses, and intervention/exposure length), and comparator(s);
- cointerventions (e.g., concurrent medications, omega-6 fatty acid use);
- withdrawals and dropouts, including reasons;
- clinical outcomes;
- fatty acid content of biomarkers; and,
- adverse events (e.g., side effects).

## Summarizing the Evidence

### Overview

The evidence is presented in three ways. Evidence tables in the Appendices offer a detailed description of the included studies (e.g., study design, population characteristics [e.g., diagnosis], intervention/exposure characteristics [e.g., omega-3 fatty acid types and doses], and “cointerventions” [e.g., background diet, concurrent medication]), with a study represented only once. These tables are organized by research design (Table 1: RCTs; Table 2: quasi-experimental studies [i.e., comparative and noncomparative before-after studies]; Table 3: observational studies [e.g., case-control studies examining the possible association of the intake of omega-3 fatty acids with the onset of eye disease/visual impairment]), with studies arranged alphabetically within each of the three table/design categories.

Question-specific summary tables embedded in the text describe each study addressing a given question in abbreviated fashion, highlighting some key characteristics, including sample size (as measure of the “weight” of the evidence and possible precision of the results), dose and type of omega-3 fatty acids, and comparators' (i.e., comparison groups') specifications. This affords a comparison of all studies addressing a given question. A study can appear in more than one summary table since it can address more than one research question. Also question-specific is each summary matrix, which situates each study in terms of its study quality and its applicability (see below).

### Study Quality

Study quality refers to the internal validity, or methodological soundness, of a study. A systematic review can be faced with great variability in the quality of its included studies. Our approach is not to use a minimal level of quality as an inclusion criterion since this precludes assessing the possible impact of study quality on study results.

A study with low quality can make it difficult to clearly and meaningfully interpret its results, for example, to unequivocally attribute a significant observed benefit exclusively to an intervention/exposure (as opposed to other factors). Since definitions, or standards, of study quality can depend on the type of research design, different constructs were selected to evaluate, from study reports, the quality of RCTs and studies employing other types of research design. One assessor with many years of experience evaluated study quality for all types of design. Time did not permit studies' dual assessment.

Four fundamental quality constructs from two instruments were used to rate the internal validity of RCTs. These tools were chosen collectively by the three EPCs involved in the 2-year task order because they have been validated. The Jadad items^66^ assess the reporting of randomization, double blinding, and, withdrawals and dropouts (Appendix C ^§^). Total scores range from 0 to 5, with a score less than 3 indicating low quality. The reporting of the concealment of a trial's allocation to treatment^67^ yields three grades (A = adequate; B = unclear; C = inadequate) (Appendix C *).

§ Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

The assessment of the quality of studies using designs other than RCTs is complicated by the dearth of validated instruments and the variety of such designs (e.g., non-randomized controlled trials; uncontrolled studies). Nevertheless, a recent systematic review by Deeks et al. identified a number of “best tools” for use with these designs.^68^ Among them were a published instrument developed by Downs and Black^69^ and an unpublished one derived by experts in Newcastle and Ottawa (NOS).^70^ The former validated both design-specific and design-neutral items.

Where case-control and cohort studies were included in the review, the validated NOS was employed. Items applicable to other designs such as non-RCTs, cross-sectional designs, cross-sectional surveys and others were taken from the Downs and Black instrument; or, if the required constructs were not operationalized in this instrument, they were developed as modifications of existing Downs and Black items (e.g., for multiple-group cross-sectional designs) or NOS items (e.g., single prospective cohort studies), borrowed from Jadad's assessment tool (e.g., description of withdrawals/dropouts), or developed outright (Appendix C *).

It should be noted that the items defining the case-control and cohort study assessment tools from the NOS were each used as a whole, although specific guidelines as to which design-specific total scores indicate low or sound quality are unavailable. Likewise, no guidelines exist to mark low or sound study quality based on any subset of Downs and Black's 27-item instrument. As already asserted, a Jadad total quality score of less than 3 indicates low quality. To permit the entry of these quality data into a summary matrix, cutpoints for each type of design were set somewhat arbitrarily to establish three levels of internal validity (see Summary Matrix). The aforementioned items/instruments and their related cutpoints were used in our recently completed evidence report on the Effects of Omega-3 Fatty Acids on Mental Health.

It was decided by our review team that, given the limitations of space, especially in print-based study reports, and the amount of detail that would likely be required to provide all of the details we needed to fully establish that only appropriate methods had been used to extract, prepare, store and analyze lipid content, it was reasonable to appraise these methods by focusing instead on identifying extant descriptions of inappropriate methods. On occasion, the inappropriateness of methods had to be determined by reference to certain protocols.

Pilot-tested exclusively for their ease of use within the data abstraction form were questions designed to informally assess the successful control of study confounding from variables identified by content experts as potential threats to the internal validity of studies pertinent to the review. In their view, these variables required experimental or statistical control to permit an uncomplicated interpretation of study results (Appendix C **). Two important categories of threat in controlled designs come from having study groups vary in terms of key prestudy or baseline characteristics (e.g., background diet; psychotropic medication; severity of a disorder), or from having certain on-study changes (e.g., unexpected stressors; changes in medication type or dose) unrelated to the exposure or intervention, occur unequally across study groups to produce confounding. Even RCTs are not immune to being affected by these threats to internal validity.

** Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

For example, if in a placebo-controlled RCT test of the supplemental prevention efficacy of omega-3 fatty acids, only certain treatment group members' background diets changed appreciably from what was observed at baseline (e.g., decreased fish intake and thus an increased omega-6/omega-3 ratio in the background diet), at which point the two study groups' baseline diets had been deemed comparable, then this on-study inequality could influence study outcomes. Because of this change in background diet, one study group might all of a sudden be receiving a different ratio of omega-6/omega-3 fatty acid intake than what had been set in the study protocol. This would amount to a change in the planned, on-study between-group difference in omega-6/omega-3 fatty acid intake; and, it is this intake ratio which could have the greatest influence on clinical outcomes. In general, contraventions of planned on-study between-group equivalences (e.g., caloric/energy intake; background diet; medication types and doses; severity of disorder; current smoker status; alcohol consumption) or of planned, on-study between-group differences (e.g., amount of omega-3 fatty acid intake) related to events other than the intervention/exposure (e.g., life stressors, which can influence patterns of eating as well as health in general), that is, in variables with the potential to affect eye health outcomes (and biomarker levels), could either “mask” or incorrectly “reveal” clinical benefits depending on the groups in which these unexpected changes occurred. Then, unless statistical adjustments are made, such a scenario could complicate the meaningful interpretation of outcomes.

These informal assessment items were modified to assess single group studies since on-study changes involving the same key variables can also complicate the interpretation of their study results. However, no quality scores were derived from the data abstractors' responses to these questions pertaining to controlled or uncontrolled studies.

### Study Applicability

As specified in the scope of work for this series of evidence reports on the health benefits of omega-3 fatty acids, the primary focus is on the US population. Given the geographical location of the UO-EPC, however, the definition of study applicability was expanded slightly to include Canada as part of a larger North American context. This study's reference point became the “typical” North American.

Also known as external validity, or generalizability, the construct of applicability refers to the degree to which a given study's sample population is sufficiently representative of the population to which one wishes to generalize its results. In the present review, two schemes operationally defined applicability (Appendix C ^††^). One assessed studies involving at least one target population identified with an eye disease/visual impairment, with the other evaluating studies involving a target “undiagnosed” population with or without a known elevated risk for an eye disease/visual impairment.

* Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/tp/03eyetp.htm

With regards to the highest level of applicability (Level I) in the first scheme, the broadest definition of the population of interest is the otherwise “healthy” North American (or similar individual) identified with an eye disease/visual impairment, diagnosed using a standard North American strategy and methodology/nomenclature, possibly receiving “typical” North American medications/treatments for their eye disease/visual impairment, is drawn from a somewhat broad socio-demographic spectrum (i.e., gender, race), and eats a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15: see below for references). For Level I applicability in the second scheme, the broadest definition of the population of interest is the otherwise “healthy” North American (or similar) individual, presenting with or without a known elevated risk for onset of an eye disease/visual impairment, representing a somewhat broad socio-demographic spectrum (i.e., gender, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15).

Together, these Level I definitions represent the respective reference points, with applicability decreasing as the definition of the sample study population narrows in terms of the factors represented in the two schemes. With respect to these schemes applied to studies with either diagnosed or undiagnosed participants, we identified what is likely the most important source of population variability: the background diet of participants leading up to the study, if not also during the study. This rationale is based on the observations that 1) countries (e.g., Japan), regions (e.g., coastal areas) and cultures (e.g., Inuit) can vary considerably in terms of their background diet and thus, their typical intake of omega-6/omega-3 fatty acid content, 2) omega-3 and omega-6 fatty acid contents within the human biosystem compete for enzymes to yield key metabolites with specific effects in the human biosystem and for placement in cell membranes from which to likely have these possible influences (e.g., clinical improvement or prevention) (see Chapter 1), and 3) it is the impact of omega-3 fatty acids on eye health that is being investigated in the present review. For example, the typical North American diet contains an omega-6/omega-3 fatty acid intake ratio of at least 15, while urban India and Japan's corresponding values are 38–50 and 4, respectively.^46–58^

That said, a high background omega-6/omega-3 fatty acid intake ratio, potentially reflected in a corresponding differential in these contents in cell membranes, may make it harder for omega-3 fatty acid supplementation to make a noticeable clinical difference,^71^ although already having considerable omega-3 fatty acid content in the background diet and in cell membranes because of a low omega-6/omega-3 fatty acid intake ratio may make it difficult for the typically small amounts of omega-3 fatty acid supplementation in studies to make a clinical difference (see Discussion). Irrespective of which of these hypotheses may be confirmed elsewhere, the fact that study populations can vary in terms of their typical omega-6/omega-3 fatty acid intake strongly suggests that this potential confounding influence on study outcomes needs to be represented in the applicability schemes whereby the North American value is the reference point.

UK populations represent somewhat of a special case in that, while they can exhibit socio-demographic pictures similarly broad to the ones seen in North American study populations, their somewhat different lifestyle and background diet recommends an applicability value of “II.” However, if participants were drawn from a narrower UK population, then a “III” would be assigned. One experienced assessor evaluated study applicability.

### Summary Matrix

For a given research question, and where possible (e.g., more than one study addressing the question), a summary matrix situates the pertinent studies in terms of their respective study quality (internal validity) and applicability (external validity) values. The Jadad total quality score defined RCTs' internal validity in summary matrices. A three-level format was derived from the range of possible RCT quality scores (A = Jadad total score of 4 or 5; B = Jadad total score of 3; C = Jadad total score of 0, 1 or 2). Given that allocation concealment scores have in the past tended to vary less widely than Jadad total scores, allocation concealment values were entered as superscripts in the summary matrices.^71^ A similar approach was taken for the studies employing other research designs. The following cutpoints were established, albeit without benefit of a validational exercise:

- (quasi-experimental) comparative before-after study: A = total quality score of 8–11; B = 5–7; C = 1–4;
- (quasi-experimental) noncomparative before-after study: A = total quality score of 8–11; B = 5–7; C = 1–4;
- case control study (NOS): A = 8–10; B = 4–7; C = 1–3;
- single prospective cohort study (Modified NOS): A = 8–10; B = 4–7; C = 1–3;
- single population cross-sectional study: A = 7–9; B = 4–6; C = 1–3; and,
- retrospective single population (e.g., population-based) cohort study: A = 7–9; B = 4–6; C = 1–3.

Our recently completed evidence report on the Effects of Omega-3 Fatty Acids on Mental Health employed this approach. The three-level applicability format was established by the 3 EPCs involved in the 2-year project for practical reasons, to permit the incorporation of quality scores within a summary matrix. Studies assigned an “X” (i.e., insufficient information to establish applicability) were excluded from summary matrices.

### Qualitative Data Synthesis

An overarching qualitative synthesis describes the progress of each citation, then report, through the stages of the systematic review. It also highlights certain report and study design characteristics of included studies (e.g., distributions of research design by research question). Then, for each question, a separate qualitative synthesis is derived for included evidence, organized by broad categories of research design (i.e., RCTs vs quasi-experimental designs vs observational studies). A brief study-by-study overview typically introduces the synthesis, followed by a narrative summary of the key defining features of relevant studies (e.g., inclusion/exclusion criteria), including their populations (e.g., diagnosis-related information), intervention/exposures (e.g., types of omega-3 fatty acid), cointerventions (e.g., medication), outcomes, study quality, applicability and results. Whether or not data can be organized according to these subheadings depends on the number of studies addressing a given question and the amount or variety of detail available in the study reports.

Juxtaposing, in turn, all pertinent studies' parameters for a given research question has two key consequences. It allows us to identify the “gaps” in knowledge deemed crucial by content experts to understand the clinical phenomenon (e.g., efficacy of omega-3 fatty acids). That is, data regarding possible confounders may be lacking, making it difficult to interpret study results with unfettered confidence. These gaps point to those variables requiring measurement and experimental or statistical control in future research. Second, it affords an understanding of the definition and extent of the included studies' clinical homogeneity (i.e., population, intervention, cointervention, outcome), which can then inform decisions regarding the appropriateness of meta-analysis. Where strong clinical heterogeneity is observed, it may be important to forego meta-analysis because the “population” to which any point estimate, and measure of precision, might be extrapolated may not exist per se; it, too, is synthetic (e.g., the “average” person with cataracts). Subject to scrutiny in the evaluation of cross-study clinical homogeneity is the ability of each study to control for confounding influences and yield results that can be interpreted without serious reservation. The existence of statistical heterogeneity also plays a role in the decision to do without a quantitative synthesis. Whether or not meta-analysis is considered appropriate, an attempt is made to make sense of the possible influence of covariates and confounders within the context of the qualitative synthesis.

Where eligibility criteria permit, evidence from research designs with a lesser inherent potential to control for biasing influences are used to see whether, collectively, they confirm the picture of efficacy, or association, derived from designs with a greater inherent potential to achieve this goal (see Eligibility Criteria). For the purposes of interpreting results, greater emphasis is placed on the latter, with “greater emphasis” meaning that we assign greater interpretative, not numerical or statistical, weight to these intrinsically stronger designs. Factors other than study design also taken into account in interpreting results include study quality, the number of studies, and whether studies were sufficiently powered.

### Quantitative Data Synthesis

Given the paucity of relevant studies addressing any given question, as well as the variability in the research designs, definitions of the study populations, exposures/interventions or clinical outcomes employed to investigate it, meta-analysis was deemed impossible or inappropriate with respect to each of the questions.