# Introduction

This evidence report by the University of Ottawa's Evidence-Based Practice Center (EPC) concerning the effects of omega-3 fatty acids on eye health is one among several that address topics related to omega-3 fatty acids that were requested and funded by the Office of Dietary Supplements (ODS), National Institutes of Health (NIH), through the EPC program at the Agency for Healthcare Research and Quality (AHRQ). Three EPCs—the Tufts-New England Medical Center (Tufts-NEMC) EPC, the Southern California-RAND (SC-RAND) EPC, and the University of Ottawa EPC (UO-EPC)—each produced evidence reports. To ensure consistency of approach, the three EPCs collaborated on selected methodological elements, including literature search strategies, rating of evidence, and data table design.

The aim of these reports is to summarize the current evidence concerning the health effects of omega-3 fatty acids on the following: cardiovascular diseases, cancer, child and maternal health, eye health, gastrointestinal/renal diseases, asthma, autoimmune diseases, immune-mediated diseases, transplantation, mental health, and, neurological diseases and conditions. In addition to informing the research community and the public on the effects of omega-3 fatty acids on various health conditions, it is anticipated that the findings of the reports will also be used to help define the agenda for future research.

The focus of this report is on eye health outcomes in humans (i.e., eye disease/visual impairment). In this chapter, the metabolism, physiological functions, and sources of omega-3 fatty acids are briefly discussed. This constitutes background material, placing in context the data presented in the evidence report. As well, the description of the U.S. population's intake of omega-3 fatty acids is provided in response to a general question posed within the task order (i.e., project). This introductory material is then complemented by a brief review of the epidemiology and issues (e.g., risk factors) related to the types of eye disease/visual impairment of interest to the review. This brief overview is designed to orient the reader rather than to serve as a comprehensive description.

Chapter 2 describes the methods used to identify, review and synthesize the results from studies concerning omega-3 fatty acids in eye health. Chapter 3 presents the findings of studies meeting eligibility criteria, with discussion points—including recommendations for future research—completing the report in Chapter 4.

## Metabolism and Biological Effects of Essential Fatty Acids

Dietary fat is an important source of energy for biological activities in human beings. It encompasses saturated fatty acids (SFAs), which are usually solid at room temperature, and unsaturated fatty acids (UFAs), which are liquid at room temperature. UFAs can be further divided into monounsaturated (MUFAs) and polyunsaturated fatty acids (PUFAs). PUFAs can be classified, on the basis of their chemical structure, into two groups: omega-3 (n-3) fatty acids and omega-6 (n-6) fatty acids. The omega-3 or n-3 notation means that the first double bond in this family of PUFAs is 3 carbons from the methyl end of the molecule. The same principle applies to the omega-6 or n-6 notation. Despite their differences in structure, all fats contain the same amount of energy (i.e., 9 kcal/g or 37 kJ/g).

Of all fats found in food, two—alpha-linolenic acid (chemical abbreviation: ALA; 18:3 n-3) and linoleic acid (LA; 18:2 n-6)—cannot be synthesized in the human body, yet these are necessary for proper physiological functioning. These two fats are thus called “essential fatty acids” (EFAs). The EFAs can be converted in the liver to long-chain PUFAs (LC PUFAs), which have a higher number of carbon atoms and double bonds. These LC PUFAs retain the omega type (n-3 or n-6) of the parent essential fatty acids.

ALA and LA comprise the bulk of the total PUFAs consumed in a typical North American diet. Typically, LA comprises 89 percent of the total PUFAs consumed, while ALA comprises 9 percent. Smaller amounts of other PUFAs make up the remainder.^1^ Both ALA and LA are present in a variety of foods. For example, LA is present in high concentrations in many commonly used oils, including safflower, sunflower, soy, and corn oil. ALA, which is consumed in smaller quantities, is present in leafy green vegetables and in some commonly used oils, including canola and soybean oil. Some novelty oils, such as flaxseed oil, contain relatively high concentrations of ALA, but these oils are not commonly found in the food supply.

The Institute of Medicine (IOM) suggests that, for adults 19 and older, an adequate intake (AI) of ALA is 1.1–1.6 grams/day (g/d), and 11–17 g/d for LA.^2^ Recommendations regarding AI differ by age and gender groups, and for special conditions such as pregnancy and lactation.

As shown in Figure 1, eicosapentaenoic acid (EPA; 20:5 n-3) and docosahexaenoic acid (DHA; 22:6 n-3) can act as competitors for the same metabolic pathways as arachidonic acid (AA; 20:4 n-6). In human studies, the analyses of fatty-acid compositions in both blood phospholipids and adipose tissue have shown a similar competitive relationship between omega-3 LC PUFAs and AA. General scientific agreement supports an increased consumption of omega-3 fatty acids and reduced intake of omega-6 fatty acids to promote good health. However, for omega-3 fatty acid intake, the specific quantitative recommendations vary widely among countries not only in terms of different units—ratio, grams, total energy intake—but also in quantity.^3^ Furthermore, there remain numerous questions relating to the inherent complexities concerning omega-3 and omega-6 fatty acid metabolism, in particular the relationships between the two fatty acids. For example, it remains unclear to what extent ALA is converted to EPA and DHA in humans, and to what extent the high intake of omega-6 fatty acids compromises any benefits of omega-3 fatty acid consumption. Without the resolution of these two fundamental questions, it remains difficult to study the importance of the omega-6/omega-3 fatty acid ratio.

Figure 1. Classical omega-3 and omega-6 fatty acid synthesis pathways and the role of omega-3 fatty acids in regulating health/disease markers

## Metabolic Pathways of Omega-3 and Omega-6 Fatty Acids

Omega-3 and omega-6 fatty acids share the same pools of enzymes and go through the same oxidation pathways while being metabolized (Figure 1). Once ingested, the parent of the omega-3 fatty acids, ALA, and the parent of the omega-6 fatty acids, LA, can be elongated and desaturated into LC PUFAs. LA is converted into gamma-linolenic acid (GLA; 18:3 n-6), an omega-6 fatty acid that is a positional isomer of ALA. GLA, in turn, can be converted to the long-chain omega-6 fatty acid, AA, while ALA can be converted, to a lesser extent, to the long-chain omega-3 fatty acids, EPA and DHA. However, the conversion from parent fatty acids into LC PUFAs occurs slowly in humans, and conversion rates are not well understood. Because of the slow rate of conversion, and the importance of LC PUFAs to many physiological processes, humans must augment their level of LC PUFAs by consuming foods rich in these important compounds. Meat is the primary food source of AA, and fish is the primary food source of EPA.

The specific biological functions of fatty acids depend on the number and position of double bonds and the length of the acyl chain. Both EPA and AA are 20-carbon fatty acids and are precursors for the formation of prostaglandins (PGs), thromboxane (Tx), and leukotrienes (LTs)—hormone-like agents that are members of a larger family of substances called eicosanoids. Eicosanoids are localized tissue hormones that seem to be one of the fundamental regulatory classes of molecule in most higher forms of life. They do not travel in the blood, but are created in the cells to regulate a large number of processes, including the movement of calcium and other substances into and out of cells, dilation and contraction of muscles, inhibition and promotion of clotting, regulation of secretions including digestive juices and hormones, and, the control of fertility, cell division and growth.^4^

As shown in Figure 1, the long-chain omega-6 fatty acid, AA, is the precursor of a group of eicosanoids including series-2 prostaglandins (PG_2_) and series-4 leukotrienes (LT_4_). The omega-3 fatty acid, EPA, is the precursor to a group of eicosanoids including series-3 prostaglandins (PG_3_) and series-5 leukotrienes (LT_5_). The series-2 prostaglandins and series-4 leukotrienes derived from AA are involved in intense actions (such as accelerating platelet aggregation, and enhancing vasoconstriction and the synthesis of mediators of inflammation) in response to physiological stressors. The series-3 prostaglandins and series-5 leukotrienes derived from EPA are less physiologically potent than those derived from AA. More specifically, the series-3 prostaglandins are formed at a slower rate and work to attenuate excessive series-2 prostaglandins. Thus, adequate production of the series-3 prostaglandins, which are derived from the omega-3 fatty acid, EPA, may protect against heart attack and stroke as well as certain inflammatory diseases like arthritis, lupus and asthma.^4^ In addition, animal studies have demonstrated that omega-3 LC PUFAs, such as EPA and DHA, engage in multiple cytoprotective activities that may contribute to antiarrhythmic mechanisms.^5^ Arrhythmias are thought to be the cause of “sudden death” in heart disease.

In addition to affecting eicosanoid production as described above, EPA also affects lipoprotein metabolism and decreases the production of other compounds—including cytokines, interleukin 1β (IL-1β), and tumor necrosis factor α (TNF-α)—which have pro-inflammatory effects. These compounds exert pro-inflammatory cellular actions that include stimulating the production of collagenase and increasing the expression of adhesion molecules necessary for leukocyte extravasation.^6^ The mechanism responsible for the suppression of cytokine production by omega-3 LC PUFAs remains unknown, although suppression of eicosanoid production by omega-3 fatty acids may be involved. EPA can also be converted into the longer chain omega-3 form of docosapentaenoic acid (DPA, 22:5 n-3), and then further elongated and oxygenated into DHA. EPA and DHA are frequently referred to as VLN-3FA—very long chain n-3 fatty acids. DHA, which is thought to be important for brain development and functioning, is present in significant amounts in a variety of food products, including fish, fish liver oils, fish eggs, and organ meats. Similarly, AA can convert into an omega-6 form of DPA.

Studies have reported that omega-3 fatty acids decrease triglycerides (TG) and very low density lipoprotein (VLDL) in hypertriglyceridemic subjects, concomitant with an increase in high density lipoprotein (HDL). However, they appear to increase or have no effect on low density lipoprotein (LDL). Omega-3 fatty acids apparently lower TG by inhibiting VLDL and apolipoprotein B-100 synthesis, and decreasing post-prandial lipemia.^7^ Omega-3 fatty acids, in conjunction with transcription factors (small proteins that bind to the regulatory domains of genes), target the genes governing cellular TG production and those activating oxidation of excess fatty acids in the liver. Inhibition of fatty acid synthesis and increased fatty acid catabolism reduce the amount of substrate available for TG production.^8^

As noted earlier, omega-6 fatty acids are consumed in larger quantities (> 10 times) than omega-3 fatty acids. Maintaining a sufficient intake of omega-3 fatty acids is particularly important since many of the body's physiologic properties depend upon their availability and metabolism.

## U.S. Population Intake of Omega-3 Fatty Acids

The major source of omega-3 fatty acids is dietary intake of fish, fish oil, vegetable oils (principally canola and soybean), some nuts such as walnuts, and, dietary supplements. Two population-based surveys, the third National Health and Nutrition Examination (NHANES III) 1988-94, and the Continuing Survey of Food Intakes by Individuals 1994-98 (CSFII), are the main sources of dietary intake data for the U.S. population. NHANES III collected information on the U.S. population aged ≥2 months. Mexican Americans and non-Hispanic African-Americans, children ≤ 5 years old, and adults ≥ 60 years old were over-sampled to produce more precise estimates for these population groups. There were no imputations for missing 24-hour dietary recall data. A total of 29,105 participants had complete and reliable dietary recall.

The CSFII 1994-96, popularly known as the “What We Eat in America” survey, addressed the requirements of the National Nutrition Monitoring and Related Research Act of 1990 (Public Law 101–445) for continuous monitoring of the dietary status of the American population. The CSFII 1994-96 utilized an improved data-collection method for 24-hour recall known as the multiple-pass approach. Given the large variation in intake from day-to-day, multiple 24-hour recalls are considered to be best suited for most nutrition monitoring and will produce stable estimates of mean nutrient intake from groups of individuals.^9^ In 1998, the Supplemental Children's Survey, a survey of food and nutrient intake by children under the age of 10 years, was conducted as a supplement to the CSFII 1994-96. The CSFII 1994-96, 1998 surveyed 20,607 people of all ages with over-sampling of low-income population (<130% of the poverty threshold). Dietary intake data from individuals of all ages were collected over two nonconsecutive days via two one-day dietary recalls.

Table 1 reports the NHANES III survey mean intake ± the standard error of the mean (SEM), in addition to the median and range for each omega-3 fatty acid. Distributions of EPA, DPA, and DHA were very skewed; therefore, the means and standard errors of the means should be used and interpreted with caution. Table 2 reports the CSFII survey mean and median intakes for each omega-3 fatty acid, along with SEMs, as reported in the Dietary Reference Intakes from the Institute of Medicine.^2^

Table 1. Estimates of the mean±standard error of the mean (SEM) intake of linoleic acid (LA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), and docosahexaenoic acid (DHA) in the US population, based on analyses of a single 24-hour dietary recall of NHANES III data

| Grams/day | | % Kcal/day
| Mean±SEM | Median (range)1 | Mean±SEM | Median (range)1
LA (18:2 n-6) | 14.1±0.2 | 9.9 (0 – 168) | 5.79±0.05 | 5.30 (0 – 39.4)
ALA (18:3 n-3) | 1.33±0.02 | 0.90 (0 – 17) | 0.55±0.004 | 0.48 (0 – 4.98)
EPA (20:5 n-3) | 0.04±0.003 | 0.00 (0 – 4.1) | 0.02±0.001 | 0.00 (0 – 0.61)
DHA (22:6 n-3) | 0.07±0.004 | 0.00 (0 – 7.8) | 0.03±0.002 | 0.00 (0 – 2.86)

1 The distributions are not adjusted for the over-sampling of Mexican-Americans, non-Hispanic African-Americans, children ≤5 years old, and adults ≥ 60 years old in the NHANES III dataset.

Table 2. Mean, range, median, and standard error of the mean (SEM) of usual daily intakes of linoleic acid (LA), total omega-3 fatty acids (n-3 FA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA) and docosahexaenoic acid (DHA) in the US population, based on CSFII data (1994-1996, 1998)

| Grams/day
| Mean±SEM | Median±SEM
LA (18:2 n-6) | 13.0±0.1 | 12.0±0.1
Total n-3 FA | 1.40±0.01 | 1.30±0.01
ALA (18:3 n-3) | 1.30±0.01 | 1.21±0.01
EPA (20:5 n-3) | 0.028 | 0.004
DPA (22:5 n-3) | 0.013 | 0.005
DHA (22:6 n-3) | 0.057±0.018 | 0.046±0.013

## Dietary Sources of Omega-3 Fatty Acids

Omega-3 fatty acids can be found in many different sources of food, including fish, shellfish, some nuts, and various plant oils. Selected from the USDA website, Table 3 lists the amount of omega-3 fatty acids in some commonly consumed fish, shellfish, nuts, and edible oils.^10^

Table 3. The omega-3 fatty acid content, in grams per 100 g food serving, of a representative sample of commonly consumed fish, shellfish, fish oils, nuts and seeds, and plant oils that contain at least 5 g omega-3 fatty acids per 100 g

Food item | EPA | DHA | ALA
[underlined: Fish (Raw^a^)]
Anchovy, European | 0.6 | 0.9 | -
Bass, Freshwater, Mixed Sp. | 0.2 | 0.4 | 0.1
Bass, Striped | 0.2 | 0.6 | trace
Bluefish | 0.2 | 0.5 | -
Carp | 0.2 | 0.1 | 0.3
Catfish, Channel | trace | 0.2 | 0.1
Cod, Atlantic | trace | 0.1 | trace
Cod, Pacific | trace | 0.1 | trace
Eel, Mixed Sp. | trace | trace | 0.4
Flounder & Sole Sp. | trace | 0.1 | trace
Grouper, Mixed Sp. | trace | 0.2 | trace
Haddock | trace | 0.1 | trace
Halibut, Atlantic and Pacific | trace | 0.3 | trace
Halibut, Greenland | 0.5 | 0.4 | trace
Herring, Atlantic | 0.7 | 0.9 | 0.1
Herring, Pacific | 1.0 | 0.7 | trace
Mackerel, Atlantic | 0.9 | 1.4 | 0.2
Mackerel, Pacific and Jack | 0.6 | 0.9 | trace
Mullet, Striped | 0.2 | 0.1 | trace
Ocean Perch, Atlantic | trace | 0.2 | trace
Pike, Northern | trace | trace | trace
Pike, Walleye | trace | 0.2 | trace
Pollock, Atlantic | trace | 0.4 | -
Pompano, Florida | 0.2 | 0.4 | -
Roughy, Orange | trace | - | trace
Salmon, Atlantic, Farmed | 0.6 | 1.3 | trace
Salmon, Atlantic, Wild | 0.3 | 1.1 | 0.3
Salmon, Chinook | 1.0 | 0.9 | trace
Salmon, Chinook, Smoked^b^ | 0.2 | 0.3 | -
Salmon, Chum | 0.2 | 0.4 | trace
Salmon, Coho, Farmed | 0.4 | 0.8 | trace
Salmon, Coho, Wild | 0.4 | 0.7 | 0.2
Salmon, Pink | 0.4 | 0.6 | trace
Salmon, Pink, Canned^c^ | 0.9 | 0.8 | trace
Salmon, Sockeye | 0.6 | 0.7 | trace
Sardine, Atlantic, Canned in Oil^d^ | 0.5 | 0.5 | 0.5
Seabass, Mixed Sp. | 0.2 | 0.4 | -
Seatrout, Mixed Sp. | 0.2 | 0.2 | trace
Shad, American | 1.1 | 1.3 | 0.2
Shark, Mixed Sp. | 0.3 | 0.5 | trace
Snapper, Mixed Sp. | trace | 0.3 | trace
Swordfish | 0.1 | 0.5 | 0.2
Trout, Mixed Sp. | 0.2 | 0.5 | 0.2
Trout, Rainbow, Farmed | 0.3 | 0.7 | trace
Trout, Rainbow, Wild | 0.2 | 0.4 | 0.1
Tuna, Fresh, Bluefin | 0.3 | 0.9 | -
Tuna, Fresh, Skipjack | trace | 0.2 | -
Tuna, Fresh, Yellowfin | trace | 0.2 | trace
Tuna, Light, Canned in Oil^e^ | trace | 0.1 | trace
Tuna, Light, Canned in Water^e^ | trace | 0.2 | trace
Tuna, White, Canned in Oil^e^ | trace | 0.2 | 0.2
Tuna, White, Canned in Water^e^ | 0.2 | 0.6 | trace
Whitefish, Mixed Sp. | 0.3 | 0.9 | 0.2
Whitefish, Mixed Sp., Smoked | trace | 0.2 | -
Wolffish, Atlantic | 0.4 | 0.3 | trace
[underlined: Shellfish (Raw)]
Abalone, Mixed Sp. | trace | - | -
Clam, Mixed Sp. | trace | trace | trace
Crab, Blue | 0.2 | 0.2 | -
Crayfish, Mixed Sp., Farmed | trace | 0.1 | trace
Lobster, Northern | - | - | -
Mussel, Blue | 0.2 | 0.3 | trace
Oyster, Eastern, Farmed | 0.2 | 0.2 | trace
Oyster, Eastern, Wild | 0.3 | 0.3 | trace
Oyster, Pacific | 0.4 | 0.3 | trace
Scallop, Mixed Sp. | trace | 0.1 | -
Shrimp, Mixed Sp. | 0.3 | 0.2 | trace
Squid, Mixed Sp. | 0.1 | 0.3 | trace
[underlined: Fish Oils]
Cod Liver Oil | 6.9 | 11.0 | 0.9
Herring Oil | 6.3 | 4.2 | 0.8
Menhaden Oil | 13.2 | 8.6 | 1.5
Salmon Oil | 13.0 | 18.2 | 1.1
Sardine Oil | 10.1 | 10.7 | 1.3
[underlined: Nuts and Seeds]
Butternuts, Dried | - | - | 8.7
Flaxseed | | | 18.1
Walnuts, English | - | - | 9.1
[underlined: Plant Oils]
Canola (Rapeseed) | - | - | 9.3
Flaxseed Oil | - | - | 53.3
Soybean Lecithin Oil | - | - | 5.1
Soybean Oil | - | - | 6.8
Walnut Oil | - | - | 10.4
Wheatgerm Oil | - | - | 6.9

Trace = <0.1; - =

0 or no data;

Sp. = species;

a Except as indicated;

b Lox.;

c Solids with bone and liquid;

d Drained solids with bone;

e Drained solids.

## Eye Health: An Increasingly Important Public Health Issue

Eye health is becoming an increasingly important public health concern due primarily to the rapid aging of populations in most countries. Worldwide, it is estimated that 45 million people are blind or visually impaired, and an additional 145 million people have low vision.^11^ Over 80% of these individuals are living in underdeveloped countries. In the US, blindness or low vision affects 3.3 million people over the age of 40, or one in 28 people in that age group.^12^ With the number of people aged 50 years or older expected to increase in upcoming decades, this number is expected to increase to 5.5 million Americans or 76 million people worldwide by the year 2020.^12^

Low vision, or visual impairment, describes individuals whose eyesight cannot be corrected with eyeglasses, contact lenses, medication or surgery.^13^ The World Health Organization (WHO) defines low vision as visual acuity between 20/70 and 20/400 with the best possible correction, or a visual field of 20 degrees or less. Blindness is defined as visual acuity worse than 20/400, with correction, or a visual field of 10 degrees or less. In the US, a person is said to be “legally blind” if they have a visual acuity of 20/2000 or worse with correction, or a visual field of 20 degrees or less.^13^

The specific cause of the visual impairment, particularly blindness, varies by race and/or ethnicity.^12^ Of the approximately one million Americans over the age of 40 who are blind, macular degeneration is its leading cause in the White population, whereas cataracts and glaucoma account for more than 60% of the cases in the Black population. Cataracts are the leading cause of low vision among White, Black and Hispanic persons. Both men and women appear to be equally affected by blindness and visual impairment.^12^

Diabetic eye disease—a group of eye diseases afflicting individuals with diabetes—is also a common cause of visual impairment. Diabetic retinopathy, the most common of these diseases, affects an estimated 5.3 million Americans over the age of 18 and is the leading cause of new cases of blindness in the US, accounting for an estimated 8,000 new cases of blindness each year.^14^ It is the most important cause of visual impairment and blindness in the working age population. Individuals with diabetes are also 60% more likely to develop cataracts during their lifetime than people without diabetes. In addition, cataracts develop at a younger age and progress faster in individuals with diabetes.^15^

Children are less likely to be affected by visual impairment. Data reported by the Lighthouse National Center for Vision and Child Development, based on statistics from the 1994 National Health Interview Survey, indicate that approximately 1% of American children under the age of 18, or over 600,000 children, are visually impaired, indicating that they are blind in one or both eyes, or have difficulty seeing even with corrective lens. The majority of cases of childhood visual impairment are due to developmental or congenital abnormalities.^16^

## Economic Burden of Visual Impairment

The Centers for Disease Control and Prevention have estimated that for all persons born in the year 2000 with a visual impairment, the lifetime cost to the patient, health care system and society, will total $2.5 billion (in 2003 US dollars).^17^ Direct costs, which include doctor visits, prescription drugs, inpatient hospital stays, as well as nonmedical expenses such as home modifications and special education, make up approximately 22% of the cost. Indirect costs, which account for 77% of the cost, include lost wages due to lost work or premature death. These estimates do not, however, include additional expenses such as hospital outpatient or emergency department visits; hence, the actual economic burden of vision impairment is substantial.

## Vascular Diseases of the Retina

Retinal vascular diseases include those eye diseases that affect the blood vessels of the retina and consequently damage the inner to mid retinal tissue. The most common retinal vascular diseases include diabetic eye diseases and vascular occlusions.

### Retinal Vessel Occlusion

Retinal vessel occlusions occur when the retinal arteries (retinal artery occlusion) or retinal veins (retinal vein occlusion) become occluded, decreasing the oxygen supply to the retina. The blockage is usually caused by a blood clot, fat deposit, or fragment of atherosclerotic plaque, and is usually associated with an underlying disorder such as hypertension, diabetes or atherosclerosis. Both retinal vein occlusion and retinal artery occlusion result in a sudden, painless loss of vision in the involved eye. Clinical examination of the eye reveals diffuse ischemia marked by a pale whitening (artery occlusion) or a swelling or edema of the retina with marked tortuosity in vascularity (vein occlusion).

Next to diabetic retinopathy, retinal vein occlusion is the second most common retinal vascular disease. Occlusion of a retinal vein results in variable vision loss depending on its extent and location. There is also an increased risk for developing glaucoma with large occlusions. Treatments for retinal vein occlusions include acetylsalicylic acid and/or laser therapy.

Like retinal vein occlusion, the degree of vision loss in retinal artery occlusion depends on the extent and location of the occlusion. Treatments for retinal artery occlusions, which tend to produce very unsatisfactory results, include inhalation of carbon monoxide/oxygen mixtures to displace the clot, paracentesis, eye pressure lowering agents and, depending on the cause, systemic anticoagulation.

### Diabetic Retinopathy

Diabetic retinopathy is the most common eye complication from diabetes (both type I and type II diabetes) and is a leading cause of blindness in the diabetic population. There are an estimated 10.2 million adults 40 years or older in the US with diabetes, the majority of whom will experience some degree of diabetic retinopathy during the course of their disease.^18^

Diabetic retinopathy occurs when the blood vessels of the retina become damaged. In its earliest stages, the blood vessels may form tiny blebs that often result in microaneurysms that appear as red dots on clinical examination. This mild form of diabetic retinopathy is referred to as nonproliferative retinopathy and is very common in individuals with diabetes. It usually has no effect on vision and, even if detected, it is left untreated. In some instances, however, the weakened capillary walls may become more permeable, losing their ability to control the passage of substances between the blood and the retina, including serum, blood cells, proteins, fats and other large molecules. When this process occurs in the macula, “clinically significant macular edema” results, which is the most common cause of visual loss in diabetic patients. Macular edema can occur at any stage of diabetic retinopathy, although it is more likely to occur in later stages of the disease. Klein et al. found that, over a 10-year period, the incidence of macular edema was 20% in individuals diagnosed with diabetes before the age of 30 and 25% in individuals diagnosed after the age of 30.^19^

In some individuals, diabetic retinopathy progresses to the more advanced form called proliferative retinopathy. This occurs when multiple areas of the retina have lost their blood supply. In response, angiogenic factors are released by the retinal cells to stimulate the development of new blood vessels. These new blood vessels tend to be weak, however, and can result in the leakage of blood into the vitreous humor. Like all hemorrhagic processes, remodeling and scar tissue can result, leading to a severe form of retinal detachment—tractional retinal detachments. Individuals with tractional retinal detachments involving the macula have a very poor prognosis.

## Degenerative Retinal Diseases

### Macular Degeneration

Macular degeneration is a group of diseases characterized by the progressive deterioration of the macula, leading to loss of central vision while peripheral vision is maintained. Age-related macular degeneration is the most common form and is the leading cause of visual loss in adults over the age of 55. Macular degeneration rarely affects younger individuals; however, early-onset forms of macular degeneration do exist, the majority of which are inherited.

Stargardt disease is the most common form of inherited juvenile macular degeneration, with an estimated incidence of 1 in 10,000.^20^ It usually begins to damage the macula of both eyes between the ages of 6 and 20, although symptoms may not be immediately apparent. The disease is usually diagnosed when children begin to complain about dark or hazy spots in the center of their field of vision. It may also take longer for their eyes to adjust from light to dark environments. Clinical examination reveals the presence of a macular lesion surrounded by yellow-white flecks. Progression of the disease is variable; however, once a visual acuity of 20/40 is reached, there is often a rapid progression of the disease. By the age of 50, approximately 50% of individuals with Stargardt's disease will have visual acuities of 20/200 or worse. Generally, night vision is not affected but there may be noticeable loss of color vision in late stages of the disease. Recently, the gene responsible for Stargardt's disease, the ABCR gene, has been isolated.^20^ Mutations in the gene result in a dysfunctional protein necessary for energy transport to and from photoreceptor cells in the retina.

Increasing age is the most important risk factor for developing age-related macular degeneration. One commonly believed pathogenic mechanism involves age-related changes to the retinal pigment epithelium; as people age, the retinal pigment epithelium, the outermost layer of the retina, begins to slowly deteriorate. The retinal pigment epithelium is a critical passageway for nutrients and wastes between the retina and the underlying layer of choroidal blood vessels. When the retinal pigment epithelium begins to deteriorate, the nutritional and waste-removing cycles involving the retina and the underlying layer of blood vessels, which nourish the cones and rods of the retina, is interrupted. This leads to damage to the light-sensitive cells of the macula. Studies have demonstrated that genetic and environmental factors such as smoking and nutrition contribute to the disease.^14,^ ^21^ Women are more likely than men to develop the disease and since they tend to live longer, women are more likely to suffer from severe vision loss due to the disease.

There are two types of macular degeneration, wet and dry. Dry macular degeneration is the most common, accounting for 85% to 90% of cases of macular degeneration.^21^ Dry macular degeneration is associated with the formation of drusen—small yellow spots of acellular debris that form under the basement membrane of the retinal pigment epithelium as a result of interruption of the waste-removing cycles between the retinal and the underlying blood vessels. Almost all individuals over the age of 50 have small drusen in one or both eyes. However, for individuals with large and multiple drusen, symptoms may include decreased central visual quality (resulting in a need for increasingly bright illumination for reading or close-up work), blurry vision, or a blind spot in a person's central vision. The treatment for dry age-related macular degeneration is multivitamins rich in antioxidants.^22^

Although age-related macular degeneration always begins as the dry form, it may progress to the wet form. Wet macular degeneration is less common but accounts for nearly 90% of the severe vision loss experienced by individuals with macular degeneration. It occurs when new choroidal blood vessels, formed to improve the blood supply to the oxygen-deprived retina, rupture and cause bleeding and damage to the surrounding tissue. Loss of vision is usually rapid and severe. Laser treatment may be effective at slowing the rate of vision loss by sealing off the newly-formed leaky vessels.

### Retinitis Pigmentosa

Retinitis pigmentosa is a group of inherited eye diseases that cause degeneration of the photoreceptor cells of the retina. In most forms of retinitis pigmentosa, the rod cells are the first to be affected. Early degeneration of rod cells results in night blindness. Symptoms are most often recognized in children, adolescents and young adults. As the disease progresses throughout an individual's life, and more rod cells degenerate, patients lose their peripheral vision and in advanced cases, their central vision.

## Cataracts

Cataracts are a clouding of the lens of the eye that is severe enough to impair vision. Generally, increasing age is the single greatest risk factor for developing cataracts, with as many as 70% of Americans over the age of 75 having cataracts. Cataracts are caused by changes in the protein fibres that make up the lens of the eye. As a person ages, the protein fibres degenerate, causing the lens to become less flexible, thicker, and subsequently less transparent. Surgery to remove the clouded lens and replace it with a clear lens implant is currently an effective treatment option for cataracts. Cataract surgery is one of the most frequently performed surgeries in the US at this time, and hence is one of the most important economic and health service issues in all Western health care systems.

In addition to the contribution from ageing, damage from free radicals, smoking and exposure to UV light may also contribute to the development of cataracts. Cataract development has also been associated with cardiovascular disease, diabetes and renal and gastrointestinal disease.^23,^ ^24^ For example, individuals with diabetes are 60% more likely to develop a cataract. In addition, a number of epidemiological studies have implicated a role for nutrition in the development of cataracts.^14,^ ^25,^ ^26^

## Omega-3 Fatty Acids and the Eye

The brain and eye are highly enriched with omega-3 fatty acids, which accumulate in these tissues during late fetal and early neonatal life.^27^ A number of studies in preterm and term human infants have suggested that a dietary supply of omega-3 fatty acids is essential for optimal visual development.^28–30^ This evidence is systematically reviewed in our UO-EPC evidence report titled “Effects of Omega-3 Fatty Acids on Child and Maternal Health.”

Very high levels of DHA are present in the retina, specifically in the disk membranes of the outer segments of photoreceptor cells. DHA accounts for over half the total fatty acyl groups present in the phospholipids of rod outer segment membranes, a proportion higher than is found in any other tissues.^31^ Rod outer segments are unique specialized structures composed of stacks of membranous discs that contain photosensitive proteins which detect and respond to light, thereby initiating the visual process. Rod outer segment membranes are constantly being renewed; however, DHA turnover in the retina is surprisingly slow.^32,^ ^33^ Furthermore, high levels of DHA appear to be maintained in the retina despite reductions in dietary intakes of omega-3 fatty acids.^34^

The high DHA content, and its specific and consistent tissue distribution, suggests that DHA has an important functional role in the retina.^35^ Its specific role, however, is not well understood. The role of DHA may be related to its biophysical effects on the cell membrane. DHA influences the biophysical properties of membranes via its high polyunsaturation, and may help to create a membrane that accommodates the dynamic behavior of rhodopsin during the photoreceptive process.^36–38^ In addition, DHA may modulate the activity of membrane bound enzymes and receptors, and the kinetics of membrane transport systems, as well as being a precursor for the synthesis of other biologically active molecules. A recent study suggests that DHA plays a role in modulating G-protein coupled signaling pathways that are involved in visual transduction.^38^

The lipid composition of cell membranes is affected by dietary factors, and the synthesis of phospholipids and their modification via polar head and acyl group turnover are metabolically regulated.^39^ Thus, it is possible that with certain extrinsic (metabolic) and intrinsic (dietary) conditions, a reduction in DHA in the outer segment membranes could occur that would be expected to alter their physical and functional properties. A number of studies have shown that, in animals, dietary deprivation of DHA results in abnormal electroretinograms and visual impairment which is accompanied by lower retinal levels of DHA-phospholipids.^40,^ ^41^ In the eye, omega-3 LC PUFAs are stored mainly in phospholipids. Moreover, animal data suggest that retinal degeneration in rats might be prevented by dietary intake of DHA,^42^ and DHA administered before ischemia may reduce pressure-induced retinal damage in monkeys.^43^

In addition to its role in the development of vision and retinal functioning, it has been suggested that DHA may also be beneficial in eye diseases that are associated with atherosclerosis of the blood vessels that supply the retina.^44^ Analogous to DHA's effect on coronary artery atherosclerosis, DHA may prevent and treat atherosclerosis of the blood vessels of the eye by inhibiting the development of plaques and blood clots.^45^ Pathogenic factors and processes activate fatty acid cleavage enzymes and make them available as a substrate pool for important biological chemicals such as cyclooxygenase, lipoxygenase, aspirin, and endocannabinoid synthetic enzymes.

In the human biosystem, an optimal balance between omega-3 and omega-6 fatty acids is likely essential for normal neuronal function, and it has been suggested that the current imbalance in the omega-6 to omega-3 fatty acid ratio in the North American diet may contribute to some degree to the observed increases in disorders of all kinds.^46–58^ Moreover, different countries and regions vary in terms of the omega-6/omega-3 fatty acid content of their background diet.^46–58^ However, the present review was not conducted to evaluate this hypothesis. Rather, consistent with the rationale for the two-year project investigating the possible health benefits of omega-3 fatty acids, its objective was to systematically review the evidence concerning the influence of omega-3 fatty acids on the onset and progression of specific visual impairments, to aid in the development of a research agenda. Thus, while there appears to be no known biological rationale for a role of omega-3 fatty acids in cataract formation, following consultation with our expert panel, we nevertheless agreed to investigate certain questions concerning this topic that had been posed by the funders of this project.