# Appendix F. Additional Acknowledgements

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgement does not reflect endorsement of this report.

- James Friel, PhD
- Professor,
- Department of Human Nutritional Sciences
- Faculty of Human Ecology
- University of Manitoba
- Winnipeg, MB

- Bill Harris, PhD
- Co-director,
- Lipid and Diabetes Research Center
- Saint Luke's
- Kansas City, MO

- Bruce Holub, PhD
- Professor,
- Department of Human Biology and Nutritional Sciences
- University of Guelph
- Guelph, ON
- (Industry representative)

- Susannah Rowe, MD, MPH
- Department of Ophthalmology,
- Boston University School of Medicine,
- Boston, Mass

- John Paul SanGiovanni, MA, MSc, ScD
- National Eye Institute
- Division of Epidemiology and Clinical Research
- National Institutes of Health
- Bethesda, MD

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

- Mary Chipman, MA
- Director Epidemiology Programs
- Public Health Sciences
- University of Toronto
- Toronto, Ontario

- Eunyoung Cho, ScD
- Epidemiologist Brigham and Women's Hospital;
- Instructor Harvard Medical School
- Boston, MA

- Victor M. Elner, MD, PhD
- Professor of Ophthalmology
- Professor of Pathology
- University of Michigan
- Kellogg Eye Center
- Ann Arbor, MI

- James Friel PhD
- Department of Human Nutritional Sciences
- University of Manitoba
- Winnipeg, Manitoba

- Bill Harris, PhD
- Co-director,
- Lipid and Diabetes Research Center
- Saint Luke's
- Kansas City, MO

- John Paul SanGiovanni, MA, MSc, ScD
- National Eye Institute
- Division of Epidemiology and Clinical Research
- National Institutes of Health
- Bethesda, MD