# Appendix E. Evidence Tables

Evidence Table 1. Randomized controlled trial evidence of effects of omega-3 fatty acids on eye health

Author, Year, Location [n sites]: Length & Design | Eligibility Criteria | Prestudy/ Baseline Population Characteristics | Intervention (Dose/Type/Source/ Delivery) & N Enrolled/Completed | Comparator(s) (Dose/Type/Source/ Delivery) & N Enrolled/Completed | Study Quality (internal validity)/ Applicability (external validity)/ Funding Source
Hoffman, 2004, US [1]: 4 y parallel RCT {1021} | • Inclusion: diagnosed RP, family history consistent with XLRP (ruling out dominant/ recessive RP) | • Enrolled/completed: n=44/41 | • 400 mg/d DHA | • Identical pb capsules, free of n-3, containing corn/soy oil and triglycerides (Martek Biosciences Corporation) | • Jadad total quality score: 4 [Grade: A]
| • Exclusion: Excessive fish intake/fish oil supplementation | • Age (M & range): 16 (4–38) y | • Via 2 500 mg DHASCO oil capsules/d (Martek Biosciences Corporation) | • Capsules/d: NR, though likely matched | • Allocation concealment: Adequate
| | • % Male: 100 | • DHASCO oil contains mainly triacylglycerol, with 40% of its total fatty acids being DHA | • Diet: N/R | • Applicability: II
| | • Race: White (87%), Black (2%), Hispanic (11%) | • Diet: NR | • n=21/19 | • Funding: Foundation Fighting Blindness
| | • Disease: XLRP | • Cointerventions: NR
| | • Duration: NR | • n=23/22
| | • Interventions: NR
| | • Concurrent: NR
| | • Biomarkers (S between-grp differences): NR
Scorolli, 2002, Italy [1]: 3 mo parallel RCT {33} | • Inclusion: Neovascular membrane between 0.3–0.5 mm, VA corrected in logMAR between 0.7-0.3 | • Enrolled/completed: n=35/35 | • 200 mg/d DHA, 200 mg/d linolenic acid | • Photodynamic therapy | • Jadad total quality score: 2 [Grade: C]
| • Exclusion: Age < 55 y, prior surgical intervention, history of retinal disease | • Age (M & range): 72 (55–86) y | • Cointervention: photodynamic therapy, 600 mg/d linoleic acid, 200 mg/d vitamin E | • n=15/15 | • Allocation concealment: Unclear
| | • % Male: 60 | • n=20/20 | | • Applicability: III
| | • Race: NR | | | • Funding: NR
| | • Disease: ARMD
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure;

n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; diet = background diet, including omega-3 or omega-6/omega-3 content; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; n = number of participants; enrolled = n qualified; completed = n completing the study; RCT = randomized controlled trial; y = year; mg = milligram; d = day; grp = group; pb = placebo; S = significant; RP = retinitis pigmentosa; XLRP = X-linked retinitis pigmentosa

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure;

n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; RCT = randomized controlled trial; y = year; mo = month; mg = milligram; d = day; grp = group; S = significant; VA = visual acuity; ARMD = age-related macular degeneration

Evidence Table 2. Quasi-experimental study evidence of effects of omega-3 fatty acids on eye health

Author, Year, Location [n sites]: Length & Design | Eligibility Criteria | Prestudy/Baseline Population Characteristics | Intervention (Dose/Type/Source/Delivery) & N Enrolled/Completed | Comparator(s) (Dose/Type/Source/Delivery) & N Enrolled/Completed | Study Quality (internal validity)/ Applicability (external validity)/Funding Source
Dagnelie, 2000, US, Canada & 7 other countries [1]: 6 mo comparative before-after study {71} | • Inclusion: Belonging to RP mailing list | • Enrolled/completed: n=20/16 | • 500 mg/d DHA from 1 capsule at dinner | • lutein: mo 1,2 40 mg/d, mo 3–6 20 mg/d | • Total study quality: 2 [Grade: C]
| • Exclusion: NR | • Age (M & range): NR | • Carlson Labs “Super DHA 500 mg” | • Diet: NR | • Applicability: III
| | • % Male: NR | • Diet: NR | • n=10/7 | • Funding: FOCUS Foundation
| | • Race: NR | • Cointerventions: lutein: mo 1,2 40 mg/d, mo 3–6 20 mg/d; vitamin B: 1 multi-capsule/d; digestive enzymes: 600mg/d
| | • Disease: RP | • n=10/9
| | • Duration: NR
| | • Interventions: supplements n=14
| | • Concurrent: NR
Hoffman, 1995, Study 1, US [1]: 6 wk non-comparative before-after study {920} | • Inclusion: Good general health, willingness to participate | • Enrolled/completed: n=3/3 | • 3.0 g/d purified fish-oil concentrate (0.7 g/d DHA + 1.3 g/d EPA) | • N/A | • Total study quality: 4 [Grade: C]
| • Exclusion: History of clinically significant bleeding, anti-coagulant therapy, unusual diet | • Age (M & range): NR | • The fish oil contained 24% DHA, 44% EPA, and 0.2 mg/d tertbutylhydroquinone and 2 mg/d tocopherols as antioxidants | | • Applicability: X
| | • % Male: NR | • Diet: Limited intake of n-3 LCPs and α-linolenic acid | | • Funding: National Retinitis Pigmentosa Foundation; National Eye Institute (government); Fish Oil Test Materials Program (Department of Commerce)
| | • Race: NR | • Cointerventions: NR
| | • Disease: adRP | • n=3/3
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Biomarkers (S between-grp differences): NS
Hoffman, 1995, Study 2, US [1]: 3 wk non-comparative before-after study {920} | • Inclusion: Good general health, willingness | • Enrolled/completed: n=3/3 | • Highly purified EPA ethyl ester (99.4%) | • N/A | • Total study quality: 3 [Grade: C]
| • Exclusion: History of clinically significant bleeding, anti-coagulant therapy, unusual diet | • Age (M & range): NR | • Dose & delivery: NR | | • Applicability: X
| | • % Male: NR | • Diet: Limited intake of n-3 LCPs & α-linolenic acid | | • Funding: National Retinitis Pigmentosa Foundation; National Eye Institute (government); Fish Oil Test Materials Program (Department of Commerce)
| | • Race: NR | • Cointerventions: NR
| | • Disease: adRP | • n=3/3
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Biomarkers (S between-grp differences): NR
Sorokin, 1997, Russia [1]: 3 mo non-comparative before-after study {107} | • Inclusion: NR | • Enrolled/completed: n=62/62 | • 4 g/d eiconol (cod-liver oil concentrate, a nutrient additive) | • N/A | • Total study quality: 1 [Grade: C]
| • Exclusion: NR | • Age (M & SD): DR 56 (2) y; Control 57.3 (2) y | • via 4 eiconol capsules/d | | • Applicability: III
| | • % Male: DR 41.7; Control NR | • Eiconol capsules are gelatin capsules containing EPA & DHA (exact composition NR) | | • Funding: NR
| | • Race: NR | • Diet: NR
| | • Disease: DR in 4 grades; preclinical, manifest, exudating, proliferative | • Cointerventions: Hypoglycemic drug
| | • Duration: NR | • N=48/48
| | • Interventions: NR
| | • Concurrent: DR: Type 1 Diabetes n=14, Type 2 Diabetes n=34; Control NR
| | • Biomarkers (S between-grp differences): NR
Suzuki, 2001, Japan [1]: 3 mo non-comparative before-after study {49} | • Inclusion: NR | • Enrolled/completed: n=15/15 | • 0.54 g/d DHA | • N/A | • Total study quality: 2 [Grade: C]
| • Exclusion: NR | • Age (M & range): 72 (58–84) y | • via 6 DHA capsules/d, supplier and composition of capsule NR | | • Applicability: III
| | • % Male: NR | • Diet: approximately 0.73 g/d DHA & 0.53 g/d EPA from normal diet | | • Funding: Bell Rich Co., Ltd.
| | • Race: NR | • Cointerventions: NR
| | • Disease: Cataract | • n=15/15 (14 pts with cataracts; 1 pt only with glaucoma)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: Glaucoma (n=4)

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure;

n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; diet = background diet, including omega-3 or omega-6/omega-3 content; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; RCT = randomized controlled trial; pts = participants; n = number of participants; enrolled = n qualified; completed = n completing the study; wk = week; mo = month; mg = milligram; d = day; grp = group; S = significant; RP = retinitis pigmentosa

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure;

n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; diet = background diet, including omega-3 or omega-6/omega-3 content; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; n = number of participants; enrolled = n qualified; completed = n completing the study; wk = week; g = gram; mg = milligram; d = day; grp = group; S = significant; NS = nonsignificant; adRP = autosomal dominant retinitis pigmentosa; LCP = long-chain polyunsaturated fatty acid

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure;

n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; diet = background diet, including omega-3 or omega-6/omega-3 content; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; n = number of participants; enrolled = n qualified; completed = n completing the study; wk = week; grp = group; S = significant; adRP = autosomal dominant retinitis pigmentosa; LCP = long-chain polyunsaturated fatty acid

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure;

n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; diet = background diet, including omega-3 or omega-6/omega-3 content; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; y = year; mo = month; g = gram; d = day; grp = group; pb = placebo; S = significant; DR = diabetic retinopathy; SD = standard deviation

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure;

n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; diet = background diet, including omega-3 or omega-6/omega-3 content; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; mo = month; y = year; g = gram; d = day; grp = group; S = significant

Evidence Table 3. Observational study evidence for the association between omega-3 fatty acids and eye health

Author, Year, Location [n sites]: Length & Design | Eligibility Criteria | Prestudy/ Baseline Population Characteristics | Intervention (Dose/Type/Source/Delivery) & N Enrolled/Completed | Comparator(s) (Dose/Type/Source/Delivery) & N Enrolled/Completed | Study Quality (internal validity)/ Applicability (external validity)/ Funding Source
Arnarsson, 2002, Iceland [1]: N/A, single population cross-sectional study {37} | • Inclusion: ≥ 50 y age, citizen of Reykjavik | • Enrolled/completed: n=1,045/993 | • n=1,045/993 | • N/A | • Total study quality: 5 [Grade: B]
| • Exclusion: NR | • Age (M & range): NR | | | • Applicability: III
| | • % Male: 44.2 | | | • Funding: NR
| | • Race: White (100%)
| | • Disease: cataract
| | • Duration: N/A
| | • Interventions: NR
| | • Concurrent: NR
Cho, 2000, US [1]: 10–12 y single prospective cohort study {65} | • Inclusion: ≥50 y, (drawn from Nurses' Health Study & Health Professionals F/U study) | • Enrolled/completed: n=112,960/NR | • n=71,486/NR (females) | • N/A | • Total study quality: 5 [Grade: B]
| • Exclusion: Prior diagnosis of AMD or cancer (except non-melanoma skin cancer) | • Age (M & SD): Females: 56 (4) y; Males: 60 (7) y | • n=41,474/NR (males) | | • Applicability: I
| | • % Male: 41 | | | • Funding: National Institutes of Health (government)
| | • Race: NR
| | • Disease: ARMD
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
Cumming, 2000, Australia [1]: N/ A, single population cross-sectional study {497} | • Inclusion: Birth date prior to January 1, 1943 | • Enrolled/completed: 4,433/2,900 | • n=2,900 | • N/A | • Total study quality: 5 [Grade: B]
| • Exclusion: NR | • Age (median & range): 65 (49–97) y | | | • Applicability: III
| | • % Male: NR | | | • Funding: Australian Department of Health & Family Services (government); Save Sight Institute, University of Sydney
| | • Race: NR
| | • Disease: Cataract
| | • Duration: N/A
| | • Interventions: N/A
| | • Concurrent: NR
Heuberger, 2001 US, [1]: N/ A, single population cross-sectional study {471} | • Inclusion: 40–79 y, participated in national health and nutrition examination survey (NHANES III) | • Enrolled/completed: 11,448/7,883 | • n=7,883 pts with exposure & clinical outcome data | • N/A | • Total study quality: 5 [Grade: B]
| • Exclusion: NR | • Age (M & range): NR | | | • Applicability: I
| | • % Male: NR | | | • Funding: National Institutes of Health (government); Research to Prevent Blindness
| | • Race: NR
| | • Disease: ARMD
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: N/A
Mares-Perlman, 1995, US [1]: N/ A retrospective population-based cohort study {1040} | • Inclusion: residents of Beaver Dam Wisconsin (US), between ages 45–84 y, participating in Beaver Dam Eye Study & Nutritional Factors in Eye Disease Study | • Enrolled/completed: n=2,152/1,968 | • n=1,968 pts with exposure & clinical outcome data | • N/A | • Total study quality: 6 [Grade: B]
| • Exclusion: NR | • Age (M & SD): 61 (10) y | | | • Applicability: I
| | • % Male: NR | | | • Funding: National Institutes of Health (government)
| | • Race: NR
| | • Disease: ARMD
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
Ouchi, 2002, Japan [1]: N/ A case-control study {34} | • Inclusion: NR | • Enrolled/completed: n=21/21 | • n=11Advanced ARMD cases | • n=10/10 healthy controls | • Total study quality: 0 [Grade: C]
| • Exclusion: NR | • Age (M & range): AMD 65.8 (55–72) y; control 64.4 (56–71) y | | | • Applicability: III
| | • % Male: 76.2 | | | • Funding: NR
| | • Race: likely Asian
| | • Disease: ARMD
| | • Duration: NR
| | • Concurrent: NR
| | • Biomarkers (S between-grp differences): RBC-AA ARMD > control; RBC-DHA ARMD > control
Seddon, 2001, US [5]: N/ A, case-control study {58} | • Inclusion: cases: 55–80 y, live near clinic, diagnosed ocular disease within 1 y of enrolment, ARMD. Controls: outpts without ARMD from same population | • Enrolled/completed: n=1,036/853 | • n=349 Advanced ARMD cases | • n=504 controls | • Total study quality: 8 [Grade: A]
| • Exclusion: NR | • Age (M & range): cases: 71(55–81) y; controls: 68 (55–80) y | | | • Applicability: II
| | • % Male: 42 | | | • Funding: NIH (government); Lions Eye Research Fund Inc; Research to Prevent Blindness Inc
| | • Race: White (100%)
| | • Disease: ARMD
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
Seddon, 2003, US [1]: 4.6 y (mean) single prospective cohort study {1007} | • Inclusion: Dry ARMD & VA 20/200 or better in ≥ 1 eye, ≥60 y | • Enrolled/completed: n=366/261 | • n=261 ARMD pts | • N/A | • Total study quality: 8 [Grade: A]
| • Exclusion: no English, decreased hearing/ cognitive function | • Age (M & range): 72.8 (NR) y | | | • Applicability: II
| | • % Male: NR | | | • Funding: Foundation Fighting Blindness Inc, Massachusetts Lions Eye Research Fund Inc; Research to Prevent Blindness Inc; the Epidemiology Unit Research Fund, Massachusetts Eye & Ear Infirmary (hospital)
| | • Race: White (99.9%)
| | • Disease: Dry ARMD
| | • Duration: NR
| | • Concurrent: NR
Smith, 2000, Australia [1]: N/A, single population cross-sectional study {78} | • Inclusion: ≥ 49 y of age | • Enrolled/completed: n=3,654/2,900 | • n=2,900 pts with exposure & clinical outcome data | • N/A | • Total study quality: 5 [Grade: B]
| • Exclusion: NR | • Age (M & range): NR | | | • Applicability: III
| | • % Male: NR | | | • Funding: Australian Department of Health & Family Services (government); Save Sight Institute, University of Sydney
| | • Race: NR
| | • Disease: ARMD; early n=240, late n=72, diagnosed using Wisconsin Age-related Maculopathy Grading System
| | • Duration: NR
| | • Concurrent: NR

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; y = year; grp = group; S = significant

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; SD = standard deviation; F/U = followup; n = number of participants; enrolled = n qualified; completed = n completing the study; y = year; grp = group; S = significant; ARMD = age-related macular degeneration

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; CT = cannot tell; enrolled = n qualified; completed = n completing the study; y = year; grp = group; S = significant

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; CT = cannot tell; enrolled = n qualified; completed = n completing the study; y = year; S = significant; ARMD = age-related macular degeneration

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); SD = standard deviation; NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; y = year; grp = group; S = significant; ARMD = age-related macular degeneration

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; y = year; grp = group; S = significant; RBC = red blood cell; ARMD = age-related macular degeneration

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; y = year; grp = group; S = significant; ARMD = age-related macular degeneration

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; y = year; grp = group; S = significant; ARMD = Age-related macular degeneration; VA = visual acuity

* Proceeding from the highest n-3, of lowest n-6/n-3, content of intervention/exposure; n-3 = omega-3 fatty acid(s); n-6 = omega-6 fatty acid(s); length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; dose = daily dose or serving size; biomarkers = fatty acid content of blood lipid biomarkers (i.e., EPA, DHA, AA, EPA/EPA, AA/DHA, AA/EPA+DHA); NR = not reported; N/A = not applicable; n = number of participants; enrolled = n qualified; completed = n completing the study; y = year; S = significant; grp = group; ARMD = age-related macular degeneration