# Appendix C. Data Assessment and Data Abstraction Forms

## Relevance Assessment Form

Please respond to the first 6 questions.*Use the comments box to identify duplicate reports, a key review whose references should be checked, anomalies, etc.

a. Inclusion criteria:

1. Does this report describe a study involving human participants?

YES Can't Tell NO

2. Does this study evaluate the role of omega-3 fatty acid intake (diet and/or supplementation) as an intervention/exposure?

YES Can't Tell NO

3. Is the purpose of the study to investigate the effect (e.g., efficacy) of omega-3 fatty acid intake on: a. (e.g., preventing; slowing the progression of) advanced stage vascular diseases of the retina, or, age-related cataracts; b. slowing the progression of retinitis pigmentosa; c. the rate of cataract surgery in ageing populations; or d. the rate of progression to, or of, advanced forms of macular degeneration?

b. Exclusion criterion:

4. If this is a narrative or systematic review, opinion piece or editorial, letter, guideline or policy paper, etc., does it exclusively describe studies already reported elsewhere (i.e., it does not present any empirical evidence published for the first time)?

YES Can't Tell NO

c. Context:

5. The study appears to also or instead concern omega-3 fatty acids as an intervention/exposure associated with the following human health/disease domains (select at least one option; click on all that apply):

__transplantation

__cancer __mental health

__neurology __none of the above

__child/maternal health

6. Is this report written in English?

YES NO

7. Comments box

*All questions were used in both screening levels.

## Data Abstraction Form

Instructions: Please answer each question. Selecting response options means clicking on them. A text box (“BOX”) requires that you provide specific data, and allows you to provide clarification, as needed (e.g., when the available data are not straightforward). When data are not reported (= NR), the question does not apply (= N/A), you cannot tell what/where the data are in the report (= CT), the data are not broken down (= NBD) to permit the required abstraction (e.g., by study group), or you have no comment to make (= NC), type the code in the BOX.

‘Participants’ refers to study participants. ‘Group’ refers to a study group, arm or cohort or, in a crossover design, a study phase. Often, you will be asked to abstract ‘full’ sample data as well as by group. If requested group data are not available, abstract full sample data and label it as such.

If more than one report describes this study, draw on each to abstract study data. This means that, for question 2, record all of the relevant report Refid#s, and for question 3, record all of the relevant reports' data. When you are abstracting data from multiple reports for a given study, point out any inconsistencies.

If the research report describes more than one unique study, answer in this eForm all the questions for the first reported study while immediately notifying the review manager that another data abstraction form is required.

Initials of reviewer: BOX

Reference identification #s (Refid#s) of all report(s) referring to this study, including duplicate reports, data-splitting reports, additional follow-ups, re-analyses, etc.: BOX

First author's last name, year of publication, country(s) in which study conducted (from each relevant report), [# study sites] (e.g., Smith, 1988, Canada [1 site]): BOX

Number of unique, review-relevant studies that this report describes (if more than one, notify review manager): BOX

Publication status, per report/Refid# referring to this study (e.g., Refid 3000=journal publication, Refid 6=conference abstract):

- Peer-reviewed journal publication
- Journal publication
- Conference abstract/poster
- Book
- Book chapter
- HTA/technical report
- Thesis
- Unpublished document
- Study sponsor's internal report
- Internet document/material
- Other
- BOX

Identity of funding source(s), including category per source (e.g., government, industry, private/non-industry, hospital), and what each provided: BOX

Please select all of the questions this study addresses:

Degenerative Diseases of the Retina: Macular Degeneration

- What is the evidence for efficacy of omega-3 fatty acids in preventing age-related macular degeneration?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of age-related macular degeneration?
- What is the evidence that omega-3 fatty acids decrease the rate of progression to advanced forms of macular degeneration?
  - What is the evidence that omega-3 fatty acids decrease the rate of progression to advanced forms of macular degeneration in diabetics?
  - What is the evidence that omega-3 fatty acids decrease the rate of progression to advanced forms of macular degeneration in patients with cataracts?
- What is the evidence that omega-3 fatty acids decrease the rate of progression of advanced forms of macular degeneration?
  - What is the evidence that omega-3 fatty acids decrease the rate of progression of advanced forms of macular degeneration in diabetics?
  - What is the evidence that omega-3 fatty acids decrease the rate of progression of advanced forms of macular degeneration in patients with cataracts?

### Degenerative Diseases of the Retina: Retinitis Pigmentosa

- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of retinitis pigmentosa (i.e., an inherited retinal dystrophy)?

### Vascular Diseases of the Retina: Retinal Vein or Retinal Artery occlusions

- What is the evidence for efficacy of omega-3 fatty acids in preventing retinal vein occlusion?
- What is the evidence for efficacy of omega-3 fatty acids in preventing retinal artery occlusion?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of retinal vein occlusion?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of retinal artery occlusion?

Vascular Diseases of the Retina in Diabetics:

- What is the evidence for efficacy of omega-3 fatty acids in preventing proliferative retinopathy in diabetics?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of proliferative retinopathy in diabetics?
- What is the evidence for efficacy of omega-3 fatty acids in preventing clinically significant macular edema in patients with diabetic retinopathy?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the progression of clinically significant macular edema in patients with diabetic retinopathy?

Cataracts:

- What is the evidence for efficacy of omega-3 fatty acids in preventing age-related cataracts?
- What is the evidence for efficacy of omega-3 fatty acids in slowing the rate of progression of age-related cataracts?
  - What is the evidence for efficacy of omega-3 fatty acids in slowing the rate of progression of age-related cataracts in diabetics?
  - What is the evidence for efficacy of omega-3 fatty acids in slowing the rate of progression of age-related cataracts in patients with age-related macular degeneration?
- What is the evidence that omega-3 fatty acids decrease the rate of cataract surgery in ageing populations?

Adverse Events:

- What is the evidence for the risk of short and long-term adverse events related to the intake of omega-3 fatty acids?

Study design (select one):

a. RCT parallel design
b. RCT crossover design
c. RCT factorial design
d. Controlled clinical trial (non-RCT)
e. Multiple prospective cohorts
f. At least one prospective cohort and one retrospective cohort
g. Case-control
h. Cross-sectional
i. Before-after (pre-post)
j. Single prospective cohort
k. Single retrospective cohort
l. Case series (noncomparative)
m. Case study
n. Cross-national ecological analysis
o. Other: BOX

Any notable details (e.g., restricted randomization; blocking size) or problems (i.e., no or inappropriate run-in or washout procedures or durations; study stopped prematurely): BOX

Full sample eligibility criteria (e.g., population [e.g., pediatric vs adult, required diagnosis, permitted or mandatory comorbid conditions], intervention(s)/medication(s) [mandated vs permitted], cointervention(s) [mandated vs permitted]) (complete both):

Inclusion criteria: BOX

Exclusion criteria: BOX

Were the same eligibility criteria employed with reference to each study group? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a single group study)

Adequacy of reporting of eligibility criteria (select one):

a. Likely adequate (= not inadequate)
b. Likely inadequate (= missing, incomplete or conflicting data)

Adequacy of eligibility criteria:

a. Likely adequate (= not inadequate)
b. Likely inadequate (e.g., the inclusion criteria will not lead to the study of the target population the investigators intend to study; populations with diagnoses/conditions outside the investigators' intended scope, yet who show the same symptoms/signs as the target population, have not been identified as requiring exclusion)

Sample sizes (by population, if appropriate) (complete all):

Total # individuals screened: BOX

# selected/allocated participants (full [e.g., n=12]; by group [e.g., group 1 n=5; group 2 n=7]): BOX

# completers (= final followup)/total (full; per group) (e.g., group 1: n=4/5; group 2: n=6/7): BOX

Settings (complete both):

Type(s) of setting (e.g., tertiary care hospital vs. community facility) (full; by group): BOX

Proportion of participants in relatively controlled (e.g., inpatients) settings during study (full; by group): BOX

Study period (complete all):

Intervention length (d, wk, mo, y) (by group only if it varies): BOX

Study duration, including units (h, d, wk, mo) (includes intervention length + run-in period duration, washout duration[s], etc.): BOX

Run-in duration/protocol: BOX

Washout duration/protocol: BOX

Did participants in each study group receive the intervention/exposure for the same length of time? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a cross-sectional survey)

Was the same study procedure employed with reference to each study group? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable

Were participants in each study group assessed at the same number of followups, and with the same timing, during the study (select one)?

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a cross-sectional survey)

Number and timing of followups (e.g., at 6 y of age), and any definition of the ‘length of followup required to observe an/no impact of the exposure/intervention:'BOX

Adverse events, and losses to followup (complete both):

# withdrawals vs. # dropouts, with reasons (full; by group): BOX

Adverse events/side effects and contraindications (full; by group): BOX

Basic population characteristics (complete all):

Mean age (mean (range) y) of all relevant participants at study onset (full; by group, by population): BOX

Percentage of males (full; by group): BOX

Racial composition (proportions: full; by group) (e.g., Caucasian 50%, Asian 50% per group) BOX

Level of education (full; by group): BOX

Pre-study/baseline eye, and general, health history ( complete all ):

At/by baseline, primary eye-related diagnosis (e.g., wet vs dry ARMD; nuclear sclerosis vs posterior subcapsular vs cortical vs mixed cataracts; autosomal dominant vs autosomal recessive vs X-linked vs other RP) (full; by group): BOX

Severity (full; by group): BOX

Prognosis (full; by group): BOX

Age at onset, age at diagnosis, and duration (i.e., time since diagnosis) (full; by group): BOX

Diagnostic method and tests (full; by group): BOX

Surgeries/therapies/medications (number; types, doses: e.g., photodynamic therapy; laser photocoagulation; visudyne; ASA; other antiplatelets; drops; vitrectomy), and responses thereto (full; by group): BOX

Lutein, beta carotene, anti-oxidant and other supplement (e.g., vitamins, minerals) intake, or CAM therapies, with (daily, weekly or monthly) source and dose/servings (full; by group): BOX

Concurrent conditions, or general health status (e.g., myopia; hyperopia; uveitis; choroideremia; ocular albinism, cone-rod dystrophy; high blood pressure; diabetes mellitus; cardiac disease; blood dyscrasias; lymphoma; leukemia; hypercoagulation state; clotting disorders; vasculitis; giant cell arteritis; dyslipidemia; renal disease; significant lipid profile), with severity, time since diagnosis, and duration (i.e., time since diagnosis) (full; by group): BOX

Medication/treatments per concurrent condition (e.g., insulin; oral hypoglycemics; estrogen use), with doses/frequency (full; by group): BOX

Exposure to sunlight (full; by group): BOX

Smoking, alcohol (ab)use, and illicit drug use history/status (full; by group): BOX

Other notable characteristics/conditions (e.g., pregnant; blue eyes; oral contraceptive use; steroid use) (full; by group): BOX

Pre-study/baseline n-3 intake (complete all):

Pre-study/baseline total (daily, weekly or monthly) n-3 intake via diet and/or supplementation, with amount per n-3 type (EPA, DHA, ALA), and source (e.g., fish servings; walnuts; flaxseed oil) (by group) (e.g., group 1: 1.8g/d EPA, 1.2g/d DHA, from 3 fish oil capsules/d; and, NR [likely EPA &/or DHA], from 1–2 fish servings/wk; group 2: 0g/d EPA, 0g/d DHA, water placebo; and, NR, 0 fish servings/wk): BOX

Pre-study/baseline total (daily, weekly or monthly) dietary n-6/n-3 intake (by group) (e.g., group 1: 15/1; group 2: 10/1): BOX

Pre-study/baseline % (daily, weekly or monthly) caloric/energy intake from fat (by group): BOX

Absolute and relative n-3 fatty acid content of the pre-study/baseline diet (full; by group): BOX

Types of pre-study/baseline diet (proportion of participants on each diet: in full; by group):

High fish diet

Fish-vegetarian diet

Low fish diet

Low fat diet

High fat diet

Mediterranean diet

Other

Unclear

Not reported

BOX

How was the pre-study dietary intake of n-3, n-6 and n-6/n-3 evaluated/estimated (select all that apply)?

Nutritionist-administered quantitative food-frequency survey(s)

Nutritionist-administered semi-quantitative food-frequency survey(s)

Self-administered quantitative food-frequency survey(s)

Self-administered semi-quantitative food-frequency survey(s)

Parent-administered quantitative food-frequency survey(s)

Parent-administered semi-quantitative food-frequency survey(s)

Direct measurement(s) of food intake

Survey(s) (e.g., 24-hour recall): BOX

Survey(s), yet no details provided

Other: BOX

Unclear

Not reported

Not applicable

Total amount of dietary n-3 intake (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Total amount of n-3 intake from supplementation (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Total amount of n-3 intake from diet and supplementation (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Dietary n-6/n-3 intake (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

% caloric/energy intake from fat (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Pre-study/baseline biomarkers data (by biomarker: e.g., RBCs; for DHA, EPA, AA, AA/EPA, AA/DHA, AA/EPA+DHA levels, with units (e.g., % total fatty acids; absolute amount) (full; by group): BOX

DHA status (per biomarker) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

EPA status (per biomarker) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

EPA+DHA status (per biomarker) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

AA status (per biomarker) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

AA/DHA status (per biomarker) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

AA/EPA status (per biomarker) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

AA/EPA+DHA status (per biomarker) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

ON-STUDY

How was on-study dietary intake of n-3 or n-6/n-3 evaluated/estimated (select all that apply)?

Nutritionist-administered quantitative food-frequency survey(s)

Nutritionist-administered semi-quantitative food-frequency survey(s)

Self-administered quantitative food-frequency survey(s)

Self-administered semi-quantitative food-frequency survey(s)

Parent-administered quantitative food-frequency survey(s)

Parent-administered semi-quantitative food-frequency survey(s)

Direct measurement(s) of food intake

Survey(s) (e.g., 24-hour recall): BOX

Survey(s), yet no details provided

Other: BOX

Unclear

Not reported

Not applicable

On-study GROUP 1 (highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures (e.g., drops; lutein, beta carotene, anti-oxidants; vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

On-study GROUP 2 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures (e.g., drops; lutein, beta carotene, anti-oxidants; vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

On-study GROUP 3 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures (e.g., drops; lutein, beta carotene, anti-oxidants; vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

On-study GROUP 4 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures (e.g., drops; lutein, beta carotene, anti-oxidants; vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

On-study GROUP 5 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures (e.g., drops; lutein, beta carotene, anti-oxidants; vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

On-study GROUP 6 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 and/or n-6/n-3 intake from diet+supplementation: BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures (e.g., drops; lutein, beta carotene, anti-oxidants; vitamins, minerals), with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

protocol (e.g., what is mandated vs. permitted), with method and target values, to modify daily, weekly or monthly n-6 or n-6/n-3 intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet) (by group): BOX

Briefly describe whether there was a clearly planned and instituted difference, between study groups, in their (daily, weekly or monthly) total-gram n-3 and/or n-6/n-3 intake: BOX

Briefly describe whether there was a clearly planned and instituted equivalence, across study groups, of (daily, weekly or monthly) caloric/energy intake from study-relevant exposures/interventions: BOX

Briefly describe any problems with compliance whereby notable deviations (e.g., decreases) from the planned amounts of intake (e.g., supplementation; servings) in one or more of the study groups violated the difference(s) established a priori between study groups for n-3 and/or n-6/n-3 intake or the equivalence established a priori across study groups for caloric/energy intake (full; by group): BOX

Briefly describe whether, and which, study groups/participants were asked to maintain their (pre-study/baseline) background diet while on-study (full; by group): BOX

Briefly describe whether, and how, without specific instruction to do so, or with specific instruction not to do so, participants' (pre-study/baseline) background diet was altered while on-study (full; by group): BOX

Briefly describe whether, and which, study groups/participants were asked to maintain their (pre-study/baseline) therapies/medications (e.g., drops) while on-study (full; by group): BOX

Briefly describe whether, and how, without specific instruction to do so, or with specific instruction not to do so, participants' (pre-study/baseline) therapies/medication (e.g., drops) were altered while on-study (full; by group): BOX

Briefly describe any evidence of selection bias: BOX

Primary eye-related diagnosis (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Severity and prognosis of eye-related condition(s) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Age at onset, age at diagnosis, and duration (i.e., time since diagnosis) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline were taken into consideration in the study analysis: BOX

Surgeries/therapies (number; types) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Medications, with types/doses (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Lutein, beta carotene, anti-oxidant and other supplement (vitamins, minerals) or CAM use, with types/doses ( complete all ):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Concurrent conditions (e.g., diabetes), including severity, age at onset, time since diagnosis, and duration (i.e., time since diagnosis) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Medication/treatments (e.g., estrogen use) per concurrent condition (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Exposure to sunlight (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Smoking, alcohol (ab)use and illicit drug use (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Other characteristics/health status (e.g., blue eyes; oral contraceptives; steroid use) (complete all):

Significant (e.g., p-value; stated result of statistical test) pre-study/baseline between-group difference(s) (specify direction of difference(s): e.g., n-3 > pb): BOX

Significant (e.g., p-value; stated result of statistical test) between-group difference(s) in within-group changes from baseline, to each followup (specify nature of change(s), by followup: e.g., final followup = n-3 > pb): BOX

Specify whether any significant between-group differences at pre-study/baseline or regarding within-group changes from baseline, to each followup, were taken into consideration in the study analysis: BOX

Complete All

Name of n-3 product (e.g., Almarin, Coromega, Eiconol; Efamed, Epagis, MaxEPA, Menhaden oil, ResQ, Omacor, Ropufa, etc.): BOX

Manufacturer (per product): BOX

Purity data (per product): BOX

Presence of other, potentially active agents in n-3 product (per product): BOX

n-3 composition (%) of the exposure (e.g., 18% EPA, 12% DHA in each fish oil capsule) (per product): BOX

Reported method(s) to maintain the freshness (i.e., preclude rancidity) of n-3 exposures/interventions (e.g., added anti-oxidants to capsules, with fish oil exposure, to minimize oxidation): BOX

Reported method(s) to eliminate methylmercury from fish or its products/derivatives: BOX

Note any descriptions of inappropriate methods of lipid extraction/preparation (e.g., failure to extract blood after a [overnight] fasting period; failure to collect blood in EDTA- or EGTA-containing vials): BOX

Note any descriptions of inappropriate methods of lipid storage (e.g., failure to store samples at –70 to –80 degrees C if not analyzed immediately): BOX

Note any descriptions of inappropriate methods of lipid analysis (e.g., failure to conduct lab measurements on coded samples by technicians blinded to participants' identity and allocation; failure to use a standard protocol [e.g., Bligh & Dyer] requiring, for example, purging samples with nitrogen, or using thin-layer chromatography or gas liquid chromatography): BOX

Adequacy of method to deodorize smell of especially fish oil exposure (select one):

Adequate = reported that study participants could not reliably guess which exposure they received

Inadequate = reported that participants could reliably guess which exposure they received

Unclear = incomplete or conflicting data reported

Not reported = no method reported, or method reported but no data reported

Not applicable = did not use an exposure requiring or permitting such a method (e.g., flaxseed; full fish servings)

If this is a controlled study, briefly describe whether clinical outcome data from all study groups (e.g., active vs placebo) were simultaneously entered into data analysis: BOX

If this is a controlled study, briefly describe whether biomarker data from all study groups (e.g., active vs placebo) were simultaneously entered into data analysis: BOX

Data were analyzed according to which criterion (select one)?

Intention-to-treat (all randomized/enrolled)

Those receiving at least one dose/serving

Those completing the study (i.e., with final follow-up data)

Unclear

Other: BOX

Was the study adequately powered to detect a difference? BOX

Any further comments about the study: BOX

THE END

## Quality Assessment Form—Randomized Controlled Trials

1. Randomization: Was the study described as randomized (i.e. including words such as

randomly, random, randomization)? Yes = 1 No = 0 =___

A trial reporting that it is ‘randomized’ is to receive one point. Trials describing an appropriate method of randomization (table of random numbers, computer generated) receive an additional point. Appropriate = 1

Not appropriate = 0 = ___

However, if the report describes the trial as randomized and uses an inappropriate method of randomization (e.g. date of birth, hospital numbers), a point is deducted.

TOTAL POINTS: 0 1 2 [underlined: SCORE]= ___

2. Double-blinding: Was the study described as double-blind?

Yes = 1 No = 0 =___

A trial reporting that it is ‘double-blind’ is to receive one point. Trials that describe an appropriate method of double-blinding (identical placebo: color, shape, taste) are to receive an additional point. Yes = 1 No = 0 =___

However, if the report describes the trial as double-blind and uses an inappropriate method (e.g. comparison of tablets vs. injection with no dummy), a point is deducted.

TOTAL POINTS: 0 1 2 [underlined: SCORE]= ___

3. Withdrawals and dropouts: Was there a description of withdrawals and dropouts?

Yes = 1 No = 0 [underlined: SCORE]= ___

A trial reporting the number of and reasons for withdrawals or dropouts is to receive one point. If there is no description, no point is given.

[underlined: JADAD TOTAL SCORE]= ___

4. Adequacy of Allocation Concealment: ( circle one ):

-Central randomization; numbered or coded bottles or containers; drugs prepared by a pharmacy, serially numbered, opaque, sealed envelopes, etc. ADEQUATE

-Alternation; reference to case record # or date of birth, etc. INADEQUATE

-Allocation concealment is not reported, or, fits neither category. UNCLEAR

## Quality Assessment Form—All Other Study Designs

### CONTROLLED STUDY DESIGNS

#### DESIGN: (QUASI-EXPERIMENTAL) COMPARATIVE BEFORE-AFTER STUDY

1. Description of validated method(s) to identify the target population
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
2. Control for selection bias
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
3. Description of withdrawals/dropouts
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Comparability of study groups on the basis of the design or analysis: exposure to sunlight
  a. Study controls for exposure to sunlight at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
5. Comparability of study groups on the basis of the design or analysis: background diet
  a. Study controls for background diet (omega-6/omega-3 fatty acid intake) at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
6. 6. Comparability of study groups on the basis of the design or analysis: caloric/energy intake
  a. Study controls for caloric/energy intake at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
7. Comparability of study groups on the basis of the design or analysis: smoking history
  a. Study controls for smoking history at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
8. Comparability of study groups on the basis of the design or analysis: comorbid conditions (e.g., diabetes; cardiovascular disease)
  a. Study controls for comorbid conditions at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
9. Description of a validated primary clinical outcome measure(s)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
10. Blind assessments of outcome
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
11. Description of type and amount of omega-3 fatty acid content in the intervention/exposure
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

DESIGN: CASE CONTROL STUDY (Newcastle-Ottawa, with assessment of an additional confounder)

1. Is the case definition adequate?
  yes, with independent validation (e.g., clinical/research diagnostic criteria) (1 point)
  yes: e.g., record linkage or based on reports
  no description
2. Representativeness of the cases
  a. consecutive or obviously representative series of cases (1 point)
  b. potential for selection biases, or not stated
3. Selection of controls
  a. community controls (1 point)
  b. hospital controls
  c. no description
4. Definition of controls
  a. no history of disease (requires clinical diagnostic criteria to determine this) (1 point)
  b. no description of source
5. Comparability of cases and controls on the basis of the design or analysis: exposure to sunlight
  a. study controls for exposure to sunlight at baseline and in possible changes during “intervening period” (1 point)
  b. study fails to control for this confounding influence
6. Comparability of cases and controls on the basis of the design or analysis: smoking history
  a. study controls for smoking history at baseline and in possible changes during “intervening period” (1 point)
  b. study fails to control for this confounding influence
7. Comparability of cases and controls on the basis of the design or analysis: omega-6 fatty acid intake
  a. study controls for omega-6 fatty acid intake at baseline and in possible changes during “intervening period” (1 point)
  b. study fails to control for this confounding influence
8. Ascertainment of exposure
  a. validated dietary assessment questionnaire or structured interview where blind to case/control status (1 point)
  b. interview not blinded to case/control status
  c. written self-report or medical record only
  d. no description
9. Same method of ascertainment for cases and controls
  a. yes (1 point)
  b. no
10. Non-response rate
  a. same rate for both groups (1 point)
  b. non respondents described
  c. rate different and no designation

### UNCONTROLLED STUDY DESIGNS

#### DESIGN: (QUASI-EXPERIMENTAL) NONCOMPARATIVE BEFORE-AFTER STUDY

- Description of validated method(s) to identify the target population
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
- Control for selection bias
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
- Description of withdrawals/dropouts
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
- Controlled for in the analysis: exposure to sunlight
  a. Study controls for exposure to sunlight at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
- Controlled for in the analysis: background diet (omega-6/omega-3 fatty acid intake)
  a. Study controls for background diet (omega-6/omega-3 fatty acid intake) at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
- Controlled for in the analysis: caloric/energy intake
  a. Study controls for caloric/energy intake at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
- Controlled for in the analysis: smoking history
  a. Study controls for smoking history at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
- Controlled for in the analysis: comorbid conditions (e.g., diabetes; cardiovascular disease)
  a. Study controls for comorbid conditions at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
- Description of a validated primary clinical outcome measure(s)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
- Blind assessments of outcome
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
- Description of type and amount of omega-3 fatty acid content in the intervention/exposure
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

DESIGN: SINGLE PROSPECTIVE COHORT STUDY (Modified Newcastle-Ottawa)

1. Representativeness of the exposed cohort
  a. Truly or somewhat representative of the average individual at no (or elevated) risk for eye disease/visual impairment in the community = 1
  b. Selected group of users e.g., nurses, volunteers = 0
  c. No description of the derivation of the cohort = 0
2. Ascertainment of exposure
  a. Validated dietary assessment questionnaire or structured interview = 1
  b. Written self-report = 0
  c. No description = 0
3. Demonstration that outcome of interest was not present at start of study
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Description of a validated method to quantify the amount, per type, of omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Assessment of outcome
  a. Independent blind assessment = 1
  b. Record linkage = 1
  c. Self-report = 0
  d. No description = 0
6. Was followup long enough for outcomes to occur?
  a. Yes (5 years) = 1
  b. No = 0
  c. Unable to determine = 0
7. Adequacy of followup of cohort
  a. Complete followup, all subjects accounted for = 1
  b. Subjects lost to followup unlikely to introduce bias, small number lost, at least 90% followup, or description provided of those lost = 1
  c. Followup rate of less than 90% and no description of those lost = 0
8. Analytic control for confounding: exposure to sunlight
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Analytic control for confounding: omega-6 fatty acid intake or omega-6/omega-3 fatty acid intake ratio
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
10. Analytic control for confounding: smoking history
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

#### DESIGN: SINGLE POPULATION CROSS-SECTIONAL STUDY

1. Description of appropriate sampling technique(s) to identify the sample population
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
2. Description of a validated method to identify/diagnose the target eye disease/visual impairment
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
3. Description of a validated method to identify the current intake of (foods or supplements containing) omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Description of a validated method to quantify the amount, per type, of omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Analytic control for confounding: exposure to sunlight
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
6. Analytic control for confounding: smoking history
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
7. Analytic control for confounding: severity of eye disease/visual impairment
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
8. Analytic control for confounding: intake of (foods or supplements containing) omega-6 fatty acids, or the omega-6/omega-3 fatty acid intake ratio
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Response rate (at least 75%):
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

#### DESIGN: RETROSPECTIVE SINGLE POPULATION COHORT STUDY

1. Description of appropriate sampling technique(s) to identify the sample population
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
2. Description of a validated method to identify/diagnose the target eye disease/visual impairment
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
3. Description of a validated method to identify the past/typical intake of (foods or supplements containing) omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Description of a validated method to quantify the amount, per type, of omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Analytic control for confounding: exposure to sunlight
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
6. Analytic control for confounding: smoking history
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
7. Analytic control for confounding: severity of eye disease/visual impairment
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
8. Analytic control for confounding: intake of (foods or supplements containing) omega-6 fatty acids, or the omega-6/omega-3 fatty acid intake ratio
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Response rate (at least 75%):
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

## Applicability Indices

For studies involving at least one target population identified with an eye disease/visual impairment: ^1^

1 Note that a control group (e.g., within a case control design) might have been composed of individuals without an identified psychiatric diagnosis or condition.

Assign ‘I’ to a target study population of otherwise “healthy” North American (or similar) individuals identified with an eye disease/visual impairment diagnosed using a “typical” North American methodology/nomenclature, with or without comorbid conditions, potentially receiving “typical” North American types of treatment (e.g., medication types and doses) for the primary diagnosis, representing a somewhat broad socio-demographic spectrum (i.e., gender, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15).

Assign ‘II’ to a target study population of otherwise ‘healthy’ North American (or similar) individuals identified with an eye disease/visual impairment, likely diagnosed using a ‘typical’ North American methodology/nomenclature, with or without comorbid conditions, likely receiving ‘typical’ North American types of treatment (e.g., medication types and doses) for the primary diagnosis, yet representing a more circumscribed socio-demographic picture (e.g., Asian-American/Canadian), and likely eating a diet “somewhat different” from that of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio notably less than 15, yet likely not reaching a value of 4, such as observed in Japan).

Assign ‘III’ to a target study population identified with an eye disease/visual impairment, with or without comorbid conditions, potentially diagnosed using a methodology/nomenclature other than a “typical” North American one, receiving treatment (e.g., medication types and doses) for the primary diagnosis that is potentially “atypical” of North America, representing a population whose socio-demographic characteristics are notably “atypical” of a broad spectrum North American population, and eating a diet that is “notably different” from that of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio perhaps reaching a value of 4, such as observed in Japan, or 38–50, as observed in urban India).

Assign ‘X’ when applicability cannot be ascertained due to incomplete or conflicting reporting of the details concerning the target study population, particularly relating to the primary diagnosis/condition and/or the background diet.

For studies involving a target population with or without a known elevated risk for an eye disease/visual impairment:

Assign ‘I’ to a target study population of otherwise “healthy” North American (or similar) individuals, with or without a known elevated risk for onset of an eye disease/visual impairment, representing a somewhat broad socio-demographic spectrum (i.e., gender, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio of at least 15).

Assign ‘II’ to a target study population of otherwise “healthy” North American (or similar) individuals, with or without a known elevated risk for onset of an eye disease/visual impairment, yet representing a more circumscribed socio-demographic picture (e.g., Asian-American/Canadian), and likely eating a diet “somewhat different” from that of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio notably less than 15, yet likely not reaching a value of 4, as observed in Japan).

Assign ‘III’ to a target study population of otherwise “healthy” individuals, with or without a known elevated risk for onset of an eye disease/visual impairment, yet representing a very circumscribed population whose socio-demographic characteristics are “notably atypical” of a broad spectrum North American population, and eating a diet that is “notably different” from that of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio perhaps reaching a value of 4, such as observed in Japan, or 38–50, as observed in urban India).

Assign ‘X’ when applicability cannot be ascertained due to incomplete or conflicting reporting of the details concerning the target study population, particularly relating to the background diet.