# Appendix A. Search Strategies

## Search Strategy 1

Medline, Pre-medline, Embase, Cochrane Library on Ovid

1. exp Retinal Vessels/
2. Retinal Degeneration/
3. exp Macular Degeneration/
4. Retinal Drusen/
5. exp Neovascularization, Pathologic/
6. exp Diabetic Retinopathy/
7. Retinal Vasculitis/
8. Retinal Vein Occlusion/
9. Retinal Artery Occlusion/
10. exp Retinitis/
11. Fluorescein Angiography/
12. Macular Edema, Cystoid/
13. (retinal adj5 thrombosis).tw.
14. sub?retinal neovascular$.tw.
15. (fluorescence adj5 angiography).tw.
16. (fundus adj5 fluorescence adj photography).tw.
17. ((central or branch) adj5 retinal adj5 occlus$).tw.
18. ((retinal or choroidal) adj5 neovascularization).tw.
19. ((vein or artery) adj5 retinal).tw.
20. ((macul$ or retina$ or choroid$) adj5 (degener$ or neovasc$)).tw.
21. ((wet or dry or nonexudative) adj5 macular adj5 degeneration$).tw.
22. ((age-related or senile) adj5 macular adj5 degeneration$).tw.
23. (ARMD or AMD).tw.
24. (cystoid adj5 macular adj5 edema).tw.
25. (geograph$ adj3 atrophy).tw.
26. (clinically significant adj5 macular adj5 edema).tw.
27. CSME.tw.
28. Cataract/
29. exp Cataract Extraction/
30. lens opacit$.tw.
31. angiogenesis.mp.
32. ((aspiration$ or operation$ or removal or surger$) adj5 cataract).tw.
33. (maculopath$ adj5 age$).tw.
34. exp Retinitis Pigmentosa/
35. (pigment$ adj5 retinopath$).tw.
36. ((rod cone or rod-cone) adj5 dystroph$).tw.
37. (tapetoretina$ adj5 degeneration).tw.
38. (proliferative adj5 retinopathy).tw.
39. ((age related or age-related) adj5 cataract).tw.
40. ((nuclear sclero$ or posterior subcapsular or cortic$) adj5 cataract).tw.
41. or/1–40
42. exp fatty acids, omega-3/
43. fatty acids, essential/
44. Dietary Fats, Unsaturated/
45. linolenic acids/
46. exp fish oils/
47. (n 3 fatty acid$ or omega 3).tw.
48. docosahexa?noic.tw,hw,rw.
49. eicosapenta?noic.tw,hw,rw.
50. alpha linolenic.tw,hw,rw.
51. (linolenate or cervonic or timnodonic).tw,hw,rw.
52. menhaden oil$.tw,hw,rw.
53. (mediterranean adj diet$).tw.
54. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
55. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
56. (fish adj2 oil$).tw.
57. (cod liver oil$ or marine oil$ or marine fat$).tw.
58. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
59. (fish consumption or fish intake or (fish adj2 diet$)).tw.
60. diet$ fatty acid$.tw.
61. or/42–60
62. dietary fats/
63. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
64. random$.tw.
65. exp clinical trials/ or evaluation studies/
66. follow-up studies/ or prospective studies/
67. or/63–66
68. 62 and 67
69. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
70. (omega 3 or n 3).mp.
71. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
72. 70 and 71
73. 61 or 68 or 69 or 72
74. 41 and 73

## Search Strategy 2

CAB Health on Silverplatter

#1 “retina-” in SU(527 records)

#2 explode “eye-diseases” in SU(4645 records)

#3 explode “retinitis-” in SU(515 records)

#4 (macular near degener*) in ti,ab,id(115 records)

#5 age-related-macular-degeneration in ID(15 records)

#6 ((central or branch) near5 retinal near5 occlus*) in ti,ab,id(23 records)

#7 ((vein or artery) near5 retinal) in ti,ab,id(41 records)

#8 ((macul* or retina* or choroid*) near5 (degener* or neovasc*)) in ti,ab,id(225 records)

#9 ((wet or dry or nonexudative) near5 macular) in ti,ab,id(1 records)

#10 ((age-related or senile) near5 macular near5 degeneration*) in ti,ab,id(86 records)

#11 (ARMD or AMD or AMD) in ti,ab,id(185 records)

#12 (cystoid near5 macular near5 edema) in ti,ab,id(3 records)

#13 (geograph* near atrophy) in ti,ab,id(3 records)

#14 (clinically significant near5 macular near5 edema) in ti,ab,id(1 records)

#15 (Diabet* near5 Retinopath*) in ti,ab,id(183 records)

#16 (retina* near5 thrombosis) in ti,ab,id(4 records)

#17 lens opacit* in ti,ab,id(35 records)

#18 ((aspiration* or operation* or removal or surger*) near5 cataract) in ti,ab,id(135 records)

#19 (maculopath* near5 age*) in ti,ab,id(33 records)

#20 (fluoresce* near5 angiography) in ti,ab,id(65 records)

#21 angiogen* in ti,ab,id(317 records)

#22 (sub?retinal neovascular*) in ti,ab,id(27 records)

#23 ((sub?retinal neovascular*) in ti,ab,id) or (angiogen* in ti,ab,id) or (((age-related or senile) near5 macular near5 degeneration*) in ti,ab,id) or (((wet or dry or nonexudative) near5 macular) in ti,ab,id) or (((macul* or retina* or choroid*) near5 (degener* or neovasc*)) in ti,ab,id) or (((vein or artery) near5 retinal) in ti,ab,id) or (((central or branch) near5 retinal near5 occlus*) in ti,ab,id) or (age-related-macular-degeneration in ID) or ((macular near degener*) in ti,ab,id) or (explode “retinitis-” in SU) or (explode “eye-diseases” in SU) or “retina-” in SU) or ((fluoresce* near5 angiography) in ti,ab,id) or ((maculopath* near5 age*) in ti,ab,id) or (((aspiration* or operation* or removal or surger*) near5 cataract) in ti,ab,id) or (lens opacit* in ti,ab,id) or ((retina* near5 thrombosis) in ti,ab,id) or ((Diabet* near5 Retinopath*) in ti,ab,id) or ((clinically significant near5 macular near5 edema) in ti,ab,id) or ((geograph* near atrophy) in ti,ab,id) or ((cystoid near5 macular near5 edema) in ti,ab,id) or ((ARMD or AMD or AMD) in ti,ab,id)(5769 records)

#24 omega 3(1102 records)

#25 (“essential-fatty-acids” in SU) or (“linolenic-acid” in SU)(1944 records)

#26 (“docosahexaenoic-acid” in SU) or (“eicosapentaenoic-acid” in SU)(1541 records)

#27 explode “plant-oils” in SU(5613 records)

#28 explode “fish-oils” in SU(2061 records)

#29 “fish-consumption” in SU(269 records)

#30 “polyenoic-fatty-acids” in SU(4159 records)

#31 “polyunsaturated-fats” in SU(336 records)

#32 “dietary-fat” in SU(1480 records)

#33 (n 3 fatty acid* or omega 3) in ti,ab,id(3126 records)

#34 (docosahexanoic or docosahexaenoic) in ti,ab,id(2049 records)

#35 (eicosapentanoic or eicosapentaenoic) in ti,ab,id(1710 records)

#36 (alpha linolenic)in ti,ab,id(865 records)

#37 (linolenate or cervonic or timnodonic) in ti,ab,id(179 records)

#38 (mediterranean diet) in ti,ab,id(305 records)

#39 ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or menhaden) and oil*) in ti,ab,id(2004 records)

#40 (walnut* or butternut* or soybean* or pumpkin seed*) in ti,ab,id(1922 records)

#41 (fish oil* or cod liver oil* or marine oil* or marine fat*) in ti,ab,id(2766 records)

#42 (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov*) in ti,ab,id(2069 records)

#43 (fish consumption or fish intake) in ti,ab,id(478 records)

#44 (diet* fatty acid*) in ti,ab,id(1499 records)

#45 (ropufa or maxepa or omacor or efamed or resq or epagis or almarin or coromega) in ti,ab,id(92 records)

#46 ((omega 3 or n 3) and (polyunsaturated fat* or pufa or dha or epa or long chain or longchain or lc*)) in ti,ab,id(2404 records)

#47 “long-chain-fatty-acids” in SU(588 records)

#48 (fish and diet) in ti,ab,id(3113 records)

#49 (explode “essential-oils” in SU) or (explode “olive-oil” in SU) or (explode “palm-oils” in SU) or (explode “plant-oils” in SU) or (explode “seed-oils” in SU)(7977 records)

#50 explode “fish-liver-oils” in SU(210 records)

#51 “long-chain-fatty-acids” in SU) or (((omega 3 or n 3) and (polyunsaturated fat* or pufa or dha or epa or long chain or longchain or lc*)) in ti,ab,id) or ((ropufa or maxepa or omacor or efamed or resq or epagis or almarin or coromega) in ti,ab,id) or ((diet* fatty acid*) in ti,ab,id) or ((n 3 fatty acid* or omega 3) in ti,ab,id) or “dietary-fat” in SU) or “polyunsaturated-fats” in SU) or “polyenoic-fatty-acids” in SU) or “fish-consumption” in SU) or (explode “fish-oils” in SU) or (explode “plant-oils” in SU) or (“docosahexaenoic-acid” in SU) or “eicosapentaenoic-acid” in SU)) or (“essential-fatty-acids” in SU) or “linolenic-acid” in SU)) or (omega 3) or ((fish consumption or fish intake) in ti,ab,id) or ((salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov*) in ti,ab,id) or ((fish oil* or cod liver oil* or marine oil* or marine fat*) in ti,ab,id) or ((walnut* or butternut* or soybean* or pumpkin seed*) in ti,ab,id) or (((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or menhaden) and oil*) in ti,ab,id) or ((mediterranean diet) in ti,ab,id) or ((linolenate or cervonic or timnodonic) in ti,ab,id) or ((alpha linolenic)in ti,ab,id) or ((eicosapentanoic or eicosapentaenoic) in ti,ab,id) or ((docosahexanoic or docosahexaenoic) in ti,ab,id) or (explode “fish-liver-oils” in SU) or ((explode “essential-oils” in SU) or (explode “olive-oil” in SU) or (explode “palm-oils” in SU) or (explode “plant-oils” in SU) or (explode “seed-oils” in SU)) or ((fish and diet) in ti,ab,id)(23294 records)

#52 ((explode “almond-oil” in SU) or (explode “castor-oil” in SU) or (explode “coconut-oil” in SU) or (explode “cottonseed-oil” in SU) or (explode “groundnut-oil” in SU) or (explode “jojoba-oil” in SU) or (explode “linseed-oil” in SU) or (explode “maize-oil” in SU) or (explode “melon-seed-oil” in SU) or (explode “mustard-oil” in SU) or (explode “palm-kernel-oil” in SU) or (explode “rapeseed-oil” in SU) or (explode “rice-oil” in SU) or (explode “safflower-oil” in SU) or (explode “sesame-oil” in SU) or (explode “soyabean-oil” in SU) or (explode “sunflower-oil” in SU) or (explode “tung-oil” in SU) or (explode “wheat-germ-oil” in SU)) or (“cod-liver-oil” in SU) or “menhaden-oil” in SU))(3270 records)

#53 #51 or #52(23294 records)

#54 #23 and #53(147 records)