# Appendixes

Appendix A. Search Strategies

Appendix B. Letter to Industry Representatives

Appendix C. Data Assessment and Data Abstraction Forms

Appendix D. Modified QUOROM Flow Chart

Appendix E. Evidence Tables

Appendix F. Additional Acknowledgements