# Summary Tables

Summary Table 1: Omega-3 fatty acids as primary treatment for depression

Summary Table 1: Omega-3 fatty acids as primary treatment for depression

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,3^ | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Marangell, 2003, US: 6 wk parallel RCT^95^ | 2g/d DHA (n=18) | pb (source undefined) (n=18) | NS MADRS response rate; NS after adjusting for baseline HDRS score | ↑ absolute RBC DHA only in DHA grp;^++++^ RBC DHA (% wt of total FAs) ↑ only in DHA grp | Jadad total: 2 [Grade: C]; Schulz: Unclear | X

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

MADRS = Montgomery-Asberg Depression Rating Scale;

HDRS = Hamilton Depression Rating Scale;

RBC = red blood cells;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 2: Omega-3 fatty acids as supplemental treatment for depression

Summary Table 2: Omega-3 fatty acids as supplemental treatment for depression

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,3^ | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Peet, 2002, England & Scotland: 12 wk parallel RCT^53^ | 4g/d E-EPA (n=17)/liquid paraffin pb (n=18) | 2g/d E-EPA (n=18)/1g/d E-EPA (n=17) | All ITT & PP analyses of HDRS, MADRS & BDI showed ↑ ↓'s only for 1g/d grp at 12 wk^+ - +++^ | n/a | Jadad total: 4 [Grade: A]; Schulz: Adequate | II
Nemets, 2002, Israel: 4 wk parallel RCT^97^ | 2g/d E-EPA (n=10) | pb (source undefined) (n=10) | 2g/d E-EPA showed ↑ HDRS ↓'s at 2,^+++^ 3^+++^ & 4 wk^+++^ | n/a | Jadad total: 4 [Grade: A]; Schulz: Unclear | III
Su, 2003, China: 8 wk parallel RCT^96^ | 4.4g/d EPA + 2.2g/d DHA (n=14) | olive oil ethyl ester pb (n=14) | 6.6g/d showed ↑ HDRS ↓'s at 4,^+++^ 6,^+++^ & 8 wk;^+++^ rate of ↓ in HDRS ↑ in EPA grp^++^ | ↑ RBC DHA for EPA grp only;^+^ NS ↑ in RBC EPA for both grps | Jadad total: 3 [Grade: B]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

MADRS = Montgomery-Asberg Depression Rating Scale;

HDRS = Hamilton Depression Rating Scale;

BDI = Beck Depression Inventory;

RBC = red blood cells;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 3: Association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (RCTs)

Summary Table 3: Association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (RCTs)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,3^ | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Llorente, 2003, US: 4 mo parallel RCT^98^ | ~200mg/d DHA (n=44 completers) | pb (undefined) (n=45 completers) | NS bet-group BDI difference at any time; NS bet-grp differences in EPDS & SCID-CV scores | 8%↑ in plasma PL DHA in DHA grp vs 31%↓ in pb grp;^+^ DHA content of DHA grp 50% higher than pb grp^+++^ | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Wardle, 2000, England: 12 wk parallel RCT^99^ | Mediterranean diet (with oily fish) (n=61) | low fat diet (n=59)/waiting list control (n=56) | ↓ BDI & anger reactions in both diets;^+^ ↓ stress & anxiety only in Mediterranean diet;^+^ NS bet-grp differences in outcomes | n/a | Jadad total: 2 [Grade: C]; Schulz: Adequate | II
Ness, 2003, Wales: 6 mo parallel RCT (one factor in factorial RCT)^100^ | advice to eat fish (n=229) | no advice to eat fish (n=223) | NS Δ in depression & anxiety for fish advice grp; NS bet-grp differences for depression & anxiety | n/a | Jadad total: 2 [Grade C]; Schulz: Unclear | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALAa = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

BDI = Beck Depression Inventory;

EPDS = Edinburgh Postnatal Depression Scale;

SCID-CV = Structured Clinical Interview, DSM-IV, Axis I Disorders, Clinical Version;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 4: Association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (observational studies)

Summary Table 4: Association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (observational studies)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Hakkarainen, 2004, Finland: 9 y single prospective cohort from RCT^111^ | males 50–69 y (n=29,133) from RCT's intervention & placebo grps | | NS (adjusted) association of fish or n-3 intake (from fish, vegetables, or total) &: self-reported depressed mood or hospital treatment required due to major depressive disorder | Total quality: 5 [Grade: B] | III
Tanskanen, 2001, Finland: single population cross-sectional survey^81^ | adult males & females (n=3,204) | | Mild-severe symptoms more prevalent in infrequent female consumers than frequent fish eaters;^++^ NS similar trend for males; infrequent consumption independently associated with symptoms (multiple regression);^++^ likelihood of mild-severe symptoms 31% higher in infrequent consumers than frequent ones;^++^ symptoms significantly associated with infrequent consumption for females only^++^ | Total quality: 3 [Grade: C] | III
Tanskanen, 2001, Finland: single population cross-sectional survey ^80^ | adult males & females (n=1,767) | | Adjusted depression & suicidal ideation risks ↓ in frequent fish consumers^+^ | Total quality: 4 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 5: Association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (observational studies)

Summary Table 5: Association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (observational studies)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Woo, 2002, China: 36 mo single prospective cohort study^110^ | elderly adults (n=2,032) | | NS association bet depressive symptoms & fish consumption | Total quality: 4 [Grade: B] | III
Suzuki, 2004, Japan: single population cross-sectional survey^107^ | newly diagnosed primary lung cancer patients (n=902) | | Adjusted difference for depression bet upper & lower quartiles of ALA & total n-3 intake, indicating inverse associations;^+^ NS adjusted difference for depression bet upper & lower quartiles of EPA, DHA & EPA+DHA intake; NS adjusted association bet depression & fish/seafood intake | Total quality: 7 [Grade: A] | III
Edwards, 1998, England: multiple-group cross-sectional study^48^ | depressed patients (n=10) | matched healthy controls (n=14) | NS between-grp differences for n-3 or total energy intake; for depressed pts, negative correlations bet depressive symptoms & dietary intake of total n-3^+++^ and ALA;^++^ &, data from all pts revealed no dietary n-3 or n-6 variables predicted severity of depressive symptoms | Total quality: 6 [Grade: B] | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 6: Association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (cross-national ecological analyses)

Summary Table 6: Association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (cross-national ecological analyses)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Hibbeln, 1998, 9 countries: cross-national ecological analysis^47^ | n=9 countries | | Negative correlation of apparent fish consumption & annual prevalence of major depression both with^++^ & without data from Japan^+^ | Total quality: 2 [Grade: C] | III
Hibbeln, 2002, 23 countries: cross-national ecological analysis^108^ | DHA, EPA, AA content (n=16 countries; n=14,532 pts); Seafood consumption (n=22 countries) | | Via simple regression & logarithmic model, ↑ national seafood consumption predicted ↓ prevalence rates of postpartum depression;^++++^ ↑ DHA in mother's milk predicted ↓ prevalence rates^++++^ | Total quality: 7 [Grade: A] | III
Peet, 2004, 8 countries: cross-national ecological analysis^109^ | n=8 countries | | Association bet high consumption of fish/seafood & a reduced prevalence of depression^++^ | Total quality: 3 [Grade: C] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 7: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Summary Table 7: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Ellis, 1977, England: multiple-group cross-sectional study^105^ | endogenous depression (n=6) | non-depressive psychiatric disorders (n=4)/age- & sex-matched healthy controls (n=6) | Proportions of plasma CPG EPA^++^ & DHA^++^ ↑ in endogenous depression grp vs matched controls; NS bet-grp difference for AA; results less pronounced for RBC EPG data; NS bet non-depressed pts & healthy controls | Total quality: 2 [Grade: C] | II
Fehily, 1981, England: multiple-group cross-sectional study^106^ | endogenous depression (n=26)/age- & sex-matched controls (n=NR ) | reactive depression (n=23)/other psychiatric disorders (n=11) | Concentrations of DHA^+++^ & EPA^+^ in plasma CPG ↑, but LA ↓,^+++^ in endogenous depression grp than controls; NS bet-grp difference for AA; NS plasma CPG in reactive depression or other disorders vs controls; DHA concentrations correlated with BDI severity in endogenously depressed,^++^ but not with reactive depression; smaller bet-grp differences for RBCs in endogenous depression vs controls (i.e., ↑ DHA in EPGs;^+^ ↑ EPA in serine phosphoglycerides^+^) | Total quality: 3 [Grade: C] | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

BDI = Beck Depression Inventory;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 8: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Summary Table 8: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Maes, 1996, Belgium: multiple-group cross-sectional study^103^ | inpatients with major depression (with [n=11] or without melancholia [n=25]) (n=36) | minor depression (i.e., adjustment disorder with depressed mood & dysthymia) (n=14)/healthy volunteers (staff or their family members) (n=24) | Age & sex as covariates, major depressed pts ↑ AA/EPA in serum cholesteryl esters^+^ & PLs^++^ & ↑ total n-6/n-3 in cholesteryl ester fractions;^++^ NS in total n-3, total n-6, or n-6/n-3, in PLs; correlations of HDRS & AA/EPA^+^ or total n-6/n-3^+^ in PLs; major depressed pts ↓ ALA in cholesteryl esters^++^ than controls; major depressed pts had ↓ total n-3 in cholesteryl esters^++^ & ↓ EPA in serum cholesteryl esters^++++^ & PLs; ALA, EPA & DHA cholesteryl ester fractions discriminated 3 grps.^++++^ ALA, EPA & DHA cholesteryl ester fractions as dependent variables showed differences for 3 grps;^++++^ negative relationship bet EPA in cholesteryl esters & HDRS^+^ | Total quality: 6 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

HDRS = Hamilton Depression Rating Scale;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 9: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Summary Table 9: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Peet, 1998, England: multiple-group cross-sectional study^102^ | major depressive disorder (n=15) | healthy controls (n=15) | ↓ RBC total n-3^+^ & DHA^+++^ in depressive pts; ↓ LA,^+++^ DGLA^+^ & total n-6;^+^ NS for AA/EPA, AA/DHA or total n-6/n-3 | Total quality: 4 [Grade: B] | II
Edwards, 1998, England: multiple-group cross-sectional study^48^ | depressed patients (n=10) | matched healthy controls (n=14) | RBC EPA,^+^ DHA^+^ & total n-3^+^ ↓ in depressed pts; NS for n-6; negative correlations for n-3 & BDI severity for ALA,^+++^ DHA^++^ & total n-3;^+^ only RBC ALA predicted BDI severity;^++^ when dietary & RBC data entered, only DHA^++++^ & LA^+^ predicted BDI severity | Total quality: 6 [Grade: B] | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

HDRS = Hamilton Depression Rating Scale;

BDI = Beck Depression Inventory;

RBC = red blood cells;

PL = phospholipid;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 10: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Summary Table 10: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Maes, 1999, Belgium: multiple-group cross-sectional study^101^ | major depressed inpatients (n=34) | healthy volunteers (n=14) | Serum PLs= major depression had ↓ EPA,^+^ ↑ AA/EPA ratio fractions; ↓ LA,^++^ ↓ AA,^+++^ ↓ total n-6,^+++^ ↓ ALA,^+^ ↓ EPA,^+^ ↓ DHA,^+^ & ↓ total n-3^++^ concentrations; Serum cholesteryl esters= major depression ↓ ALA,^+++^ EPA,^++^ total n-3,^++^ ↑ total n-6/n-3,^++^ & ↑ AA/EPA^++^ fractions; ↓ LA,^++^ ↓ total n-6,^++^ ↓ ALA,^+++^ ↓ EPA,^++^ & ↓ total n-3^++^ concentrations; NS correlations bet HDRS & FAs | Total quality: 6 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 11: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Summary Table 11: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Tiemeier, 2003, Holland: multiple-group cross-sectional study^104^ | depressive disorders in elderly (n=106) | subclinical depressive symptoms (n=115)/ screened negative for depression (n=461) | AA^+^ & DHA^+^ ↑ & ↓ in depressed pts; ↑ in depressed vs controls: total n-6/n-3^+^ & AA/DHA.^+^ difference in n-6/n-3 for depressed vs controls ↑ with ↓ concentrations of C-reactive protein;^+^ only for those below median, depressed pts had ↓ %'s of certain n-3's than controls; depressives had ↓ EPA,^+^ DHA^+^ & total n-3;^++^ depressives had ↑ n-6/n-3,^++^ AA/EPA^++^ & AA/DHA.^+^ | Total quality: 5 [Grade: B] | III
Llorente, 2003, US: 4 mo parallel RCT^98^ | ~200mg/d DHA (n=44 completers) | pb (undefined) (n= 45 completers) | NS correlations bet plasma PL DHA content, either at baseline or 4 mo, &: BDI, EPDS or SCID-CV | Jadad total: 5 [Grade: A] Schulz: Adequate | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

BDI = Beck Depression Inventory;

EPDS = Edinburgh Postnatal Depression Scale;

SCID-CV = Structured Clinical Interview, DSM-IV, Axis I Disorders, Clinical Version;

RBC = red blood cells;

PL = phospholipid;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 12: Association between omega-3 fatty acid intake and onset, continuation or recurrence of suicidal ideation or behavior

Summary Table 12: Association between omega-3 fatty acid intake and onset, continuation or recurrence of suicidal ideation or behavior

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Hakkarainen, 2004, Finland: 9 y single prospective cohort from RCT^111^ | males 50–69 y from RCT's intervention & placebo grps (n=29,133) | | NS association (no data reported) | Total quality: 5 [Grade: B] | III
Tanskanen, 2001, Finland: single population cross-sectional survey^80^ | adult males & females (n=1,767) | | Adjusted depression & suicidal ideation risks ↓ in frequent fish consumers^+^ | Total quality: 4 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 13: Omega-3 fatty acids as supplemental treatment for bipolar disorder

Summary Table 13: Omega-3 fatty acids as supplemental treatment for bipolar disorder

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Stoll, 1999, US: 4 mo parallel RCT^112^ | 9.6g/d EPA+DHA (6.2g/d EPA, 3.4g/d DHA) (n=~22) | olive oil ethyl ester pb (n=~22) | n-3 grp had longer remission;^++^ same result for pts without medication;^+^ bet-grp differences on CGI,^++^ GAS,^+^ & HDRS;^++^ sex, rapid cycling status or disorder type did not predict response | Jadad total: 4 [Grade: A] Schulz: Adequate | I
Akkerhuis, 2003, NR: 4 wk “controlled study”^93^ | maximum 6g/d EPA ethyl ester (n=NR) | pb (source undefined) (n=NR) | NR | Could not evaluate | X

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

HDRS = Hamilton Depression Rating Scale;

CGI = Clinical Global Impression scale;

GAS = Global Assessment Scale;

YMRS = Young Mania Rating Scale;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 14: Association between omega-3 fatty acid intake and onset, continuation or recurrence of bipolar disorder

Summary Table 14: Association between omega-3 fatty acid intake and onset, continuation or recurrence of bipolar disorder

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Noaghiul, 2003, 11 countries: cross-national ecological analysis^90^ | 11 countries | | Logarithmic regression = greater seafood consumption predicted lower prevalence rates of bipolar I disorder,^+^ bipolar II disorder^+++^ & bipolar spectrum disorder;^+++^ when subcategories combined, linear regression^+++^ & exponential decay regression^+++^ | Total quality: 4 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 15: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of bipolar disorder

Summary Table 15: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of bipolar disorder

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Mahadik, 1996, US: multiple-group cross-sectional study^114^ | bipolar pts (n=6) | drug-free schizophrenic pts (n=12)/ normal controls (n=8) | NS differences for AA & DHA bet bipolar pts & normal controls | Total quality: 5 [Grade: B] | I
Chiu 2003, Taiwan: multiple-group cross-sectional study^113^ | bipolar patients, acute manic episode (n=20) | healthy volunteers (n=20) | ↓ AA+ & DHA+ RBC in bipolar manic pts vs controls; NS total n-3 or total n-6; NS AA/EPA or total n-6/n-3; NS impacts of medication, age, age of onset, smoker status, number of episodes or illness duration on FAs | Total quality: 5 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

RBC = red blood cells;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 16: Association between omega-3 fatty acid intake and onset, continuation or recurrence of anxiety

Summary Table 16: Association between omega-3 fatty acid intake and onset, continuation or recurrence of anxiety

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Wardle, 2000, England: 12 wk parallel RCT^99^ | Mediterranean diet (with oily fish) (n=61) | low fat diet (n=59)/ waiting list control (n=56) | ↓ anxiety only in Mediterranean diet;^+^ NS bet-grp difference in anxiety | Jadad total: 2 [Grade: C] Schulz: Adequate | II
Ness, 2003, Wales: 6 mo RCT (one factor in factorial RCT)^100^ | advice to eat fish (n=229) | no advice to eat fish (n=223) | NS Δ in anxiety for fish advice group; NS bet-grp differences for anxiety | Jadad total: 2 (Grade: C] Schulz: Unclear | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

BDI = Beck Depression Inventory;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 17: Omega-3 fatty acids as supplemental treatment for obsessive-compulsive disorder

Summary Table 17: Omega-3 fatty acids as supplemental treatment for obsessive-compulsive disorder

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Fux, 2004, Israel: 6 wk crossover RCT ^115^ | 2g/d E-EPA phase (n=11) | 2g/d liquid paraffin pb phase (n=11) | NS effects of treatment order on HDRS or HAM-A; main effect for time on YBOCS, with significant ↓ by wk 6 for pb & E-EPA;^++^ NS treatment effect for clinical outcomes; NS drug-by-time interaction | Jadad total: 3 [Grade: B]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

HDRS = Hamilton Depression Rating Scale;

HAM-A: Hamilton Anxiety Rating Scake;

YBOCS = Yale-Brown Obsessive-Compulsive Scale;

HAM-A = Hamilton Anxiety Rating Scale;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 18: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of anorexia nervosa

Summary Table 18: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of anorexia nervosa

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Langan, 1985, US: multiple-group cross-sectional study ^117^ | anorexic females (n=17) | healthy female controls (n=11) | NS bet-grp difference in FA in total plasma lipids; ↓ plasma PL LA^++^ & ALA^+^ in anorexics; ↑ plasma PL DHA in anorexics;^+^ ↓ total n-6 in anorexics;^+^ ↑ AA/LA in anorexics^++^ | Total quality: 2 [Grade: C] | I
Holman, 1995, US: multiple-group cross-sectional study ^116^ | young anorexic females (n=8) | young healthy controls (n=19) | ↓ PL total n-6, EPA, DHA, ALA & total n-3 in anorexics;^+++^ NS bet-grp difference in plasma cholesterol esters n-3; ↓ DGLA in anorexics; ^+^ ↓ total n-3 in plasma triglycerides in anorexics;^+^ ↓ (n-6-)DPA & GLA in plasma triglycerides in anorexics^+^ | Total quality: 1 [Grade: C] | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 19: Omega-3 fatty acids as primary treatment forattention deficit/hyperactivity disorder

Summary Table 19: Omega-3 fatty acids as primary treatment forattention deficit/hyperactivity disorder

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Richardson, 2002, UK: 12 wk parallel RCT ^119^ | 186mg/d EPA, 480mg/d DHA, 96mg/d GLA, 864mg/d cis-linolenic acid, 42mg/d AA & 8mg/d thyme (n=22) | olive oil pb (n=19) | All PP analyses: ↓ DSM Inattention,^+^ Conners ADHD Index^+^ & psychosomatic symptoms^+^ in treatment grp | Jadad total: 5 [Grade: A]; Schulz: Adequate | II
Hirayama, 2004, Japan: 2 mo parallel RCT ^120^ | 3.6g/wk DHA & 700mg/wk EPA (n=20) | olive oil pb (n=20) | No improvement of AD/HD symptoms; ↓ errors of commission^++^ & ↑ shortterm memory in controls^+^ | Jadad total: 3 [Grade: B]; Schulz: Unclear | III
Brue, 2001, US: 12 wk parallel RCT ^118^ | [underlined: No Ritalin]: 2g/d flaxseed + dietary supplements (n=15)/ [underlined: No Ritalin]: dietary supplements + slippery elm pb (n=15) | [underlined: Ritalin]: 2g/d flaxseed + dietary supplements (n =15)/ [underlined: Ritalin]: dietary supplements + slippery elm pb (n = 15) | [underlined: No Ritalin pts]: NS effect for parent & teacher rated inattentiveness; ↓ teacher-rated hyperactivity/impulsivity^+^ in flaxseed+supplement grp whereas opposite observed for parent ratings^+^ | Jadad total: 2 [Grade: C]; Schulz: Unclear | I
Harding, 2003, US: 4 wk comparative before-after study ^121^ | 180 mg/d EPA + 120 mg/d DHA (n=10) | Ritalin (n=10) | for both grps: ↑ FSRCQ^++^ & ↑ FSACQ;^+++^ NS bet-grp differences on FSRCQ & FSACQ; NS bet-grp differences yet both groups' ↑ for ARCQ,^++^ VRCQ,^+^ AAQ^++^ & VAQ^++^ | Total quality: 4 [Grade: C] | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

FSRCQ = Full Scale Response Control Quotient;

FSACQ = Full Scale Attention Control Quotient;

ARCQ = Auditory Response Control Quotient;

VRCQ = Visual Response Control Quotient;

AAQ = Auditory Attention Quotient;

VAQ = Visual Attention Quotient;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 20: Omega-3 fatty acids as supplemental treatment for attention deficit/hyperactivity disorder

Summary Table 20: Omega-3 fatty acids as supplemental treatment for attention deficit/hyperactivity disorder

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,3^ | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Brue, 2001, US: 12 wk parallel RCT ^118^ | [underlined: No Ritalin]: 2g/d flaxseed + dietary supplements (n=15)/ [underlined: No Ritalin]: dietary supplements + slippery elm pb (n=15) | [underlined: Ritalin]: 2g/d flaxseed + dietary supplements (n =15)/ [underlined: Ritalin]: dietary supplements + slippery elm pb (n = 15) | Flaxseed + supplement: fewer attention problems (teacher only);^+^ NS difference: hyperactivity/ impulsivity | n/a | n/a | Jadad total: 2 [Grade: C]; Schulz: Unclear | I
Voigt, 2001, US: 4 mo parallel RCT ^122^ | 345mg/d DHA (n=32) | pb (undefined) (n=31) | NS bet-grp differences on TOVA, Color Trails tests, CBCL or Conners | NS Δ DHA in pb; ↑ DHA^++^ & ↓ (n-3-) DPA^++^ in DHA grp | NS correlations for plasma PL DHA & TOVA or Color Trails | Jadad total: 4 [Grade: A]; Schulz: Adequate | I
Stevens, 2003, US: 4 mo parallel RCT ^123^ | 480mg/d DHA, 80mg/d EPA, 40mg/d AA, 96mg/d GLA & 24mg/d vitamin E (n=25) | 6.4g/d olive oil pb (n= 25) | 2/16 improved outcomes: conduct problems^+^ & attention symptom;^+^ more oppositional/defiant disorders improved in PUFA grp^+^ | NS bet-grp differences for Δ in plasma FAs; size of ↓ RBC AA greater in PUFA group^+^ | % in Δ in parent ASQ negatively correlated with % Δ in RBC EPA^+^ & positively with RBC AA;^+^% Δ in teacher attention negatively correlated with RBC DHA^+^ | Jadad total: 3 [Grade: B]; Schulz: Adequate | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

ASQ = Abbreviated Symptom Questionnaire;

CBCL = Child Behavior Checklist;

DBD = Disruptive Behavior Disorders;

RBC = red blood cells;

PL = phospholipid;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 21: Association between omega-3 fatty acid intake and onset, continuation or recurrence of attention deficit/hyperactivity disorder

Summary Table 21: Association between omega-3 fatty acid intake and onset, continuation or recurrence of attention deficit/hyperactivity disorder

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Yang, 1999, Taiwan: multiple-group cross-sectional study ^94^ | AD/HD children (n=20) | healthy controls (n=32) | via 24-hour dietary recall, the hyperactive grp had lower intake of LA^+^ & ALA;^+^ only ALA^+^ ↓ in AD/HD via 3-day dietary record | Total quality: 5 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 22: Association between omega-3 or omega-6/omega-3 content of biomarkers and onset, continuation or recurrence of AD/HD

Summary Table 22: Association between omega-3 or omega-6/omega-3 content of biomarkers and onset, continuation or recurrence of AD/HD

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Mitchell, 1983, New Zealand: multiple-group cross-sectional study ^126^ | maladjusted (hyperactive) children (n=23) | normal children (n=20) | NS bet-grp differences in RBC FA content | Total quality: 1 [Grade: C] | III
Mitchell, 1987, New Zealand: multiple-group cross-sectional study ^125^ | hyperactive children (n=48) | age- & sex-matched normal children (n=49) | ↓ DHA,^+^ DGLA^++^ & AA^+^ in hyperactive children | Total quality: 4 [Grade: B] | III
Stevens, 1995, US: multiple-group cross-sectional study ^124^ | hyperactive boys (n=53) | normal boys (n=43) | ↑ PUFA intake in AD/HD;^+^ ↓ plasma AA,^+^ EPA,^+^ DHA^+^ & total n-3^+++^ in AD/HD; ↑ n-6/n-3 in AD/HD;^++^ ↓ RBC AA & DPA in AD/HD^+^ | Total quality: 3 [Grade: C] | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction

Summary Table 23: Association between omega-3 fatty acid intake and onset, continuation or recurrence of mental health difficulties

Summary Table 23: Association between omega-3 fatty acid intake and onset, continuation or recurrence of mental health difficulties

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Silvers, 2002, New Zealand: single population cross-sectional survey ^127^ | householders (n=4,644) | | Univariate analysis: NS correlation between fish consumption & mental health status; hierarchical regression, with age & income adjustments, association observed;^+++^ adjusting for age & household income, mental health status ↓ in fish consumers;^+++^ adjusting for age, household income, smoking, alcohol consumption, & eating patterns an association^++^ | Total quality: 5 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 24: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (RCTs)

Summary Table 24: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (RCTs)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Hamazaki, 1996, Japan: 3 mo parallel RCT ^130^ | 1.5–1.8g/d DHA & some EPA (n=27) | oil capsules (97% soybean oil + 3% fish oil) (n=26) | extraggression ↑ in controls;^++^NS Δ for DHA grp; bet-grp difference^+^ | NS bet-grp differences in Δ for AA, EPA or DHA | Jadad total: 3 [Grade: B]; Schulz: Unclear | III
Hamazaki, 1998, Japan: 3 mo parallel RCT ^129^ | 1.5 g/d DHA capsules (n=29) | control capsules with some ALA & DHA (n=30) | extraggression ↓ in controls;^+^NS Δ for DHA grp; bet-grp difference;^+^NS Δ hostility in either study group | ↑ RBC DHA^+++^ & EPA^+++^ in DHA grp; ↑ LA^++^ in controls | Jadad total: 3 [Grade: B]; Schulz: Unclear | III
Hamazaki, 2002, Thailand: 2 mo parallel RCT ^128^ | 1.5g/d DHA + 0.2g/d EPA from 3g/d fish oil capsules (n=20) | 3g/d mixed plant oil control (n=21) | NS Δ for extraggression for university controls; ↓ for DHA grp;^+^ bet-grp difference in extraggression;^+^NS bet-grp difference for villagers; university= NS Δ for controls; ↓ for DHA grp;^+^ villagers= NS bet-grp difference for extraggression | NS changes in FA in controls; In DHA group EPA & DHA ↑;^+++^ AA ↑^++^ | Jadad total: 3 [Grade: B]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↑ = decrease(d)/reduction/lower

Summary Table 25: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (RCT)

Summary Table 25: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (RCT)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,^ ^3^ | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Wardle, 2000, England: 12 wk parallel RCT^99^ | Mediterranean diet (with oily fish) (n=61) | low fat diet (n=59)/ waiting list control (n=56) | All grps had within-grp improvement for STAI's anger reactions;^+^ NS bet-grp differences for anger/hostility, stress, or general psychological well-being | n/a | Jadad total: 2 [Grade: C]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

STAI = State-Trait Anger Inventory;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 26: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (cross-sectional study)

Summary Table 26: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (cross-sectional study)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Iribarren, 2004, US: single population cross-sectional survey^132^ | urban white & black young adults (n=3,581): black females (n=967) & males (n=672), white females (n=1,017) & males (n=925) | | Adjusted multivariate odds ratios of scoring in the upper quartile of hostility scores associated with one standard deviation increase in DHA intake;^+^ consumption of fish rich in omega-3 fatty acids, when compared to no consumption, was associated with lower odds of high hostility.^+^ | Total quality: 5 [Grade: B] | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 27: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (RCT)

Summary Table 27: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (RCT)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Gesch, 2002, UK: ~142-day (mean) RCT^131^ | 0.08g/d EPA, 0.044g/d DHA, 1.26g/d LA & 0.16g/d GLA) capsules & vitamin/ mineral capsules (n=57 completers) | identical vegetable oil placebo capsules for fatty acids & identical vegetable oil placebo capsules for vitamins/ minerals (n=55 completers) | Bet-grp difference in favor of fewer offences for those receiving active treatment;^+^ using data from those who received at least two weeks of supplementation, only for those receiving supplementation did the number of incidents ↓;^+^ greatest ↓ was observed for most serious incidents;^++^ minor reports exhibited the same bet-grp difference | Jadad total: 5 [Grade: A]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

ITT = intention-to-treat analysis;

PP = per-protocol analysis (e.g., completers);

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 28: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (cross-national ecological analysis)

Summary Table 28: Association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies or behavior with the potential to harm others (cross-national ecological analysis)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Hibbeln, 2001, 26 countries: cross-national ecological analysis ^133^ | n=26 countries | | Simple^++^ & logarithmic regressions:^+++^ countries with ↓ apparent seafood consumption had ↑ rates of homicide mortality; excluding Asian data maintained the association^++^ | Total quality: 4 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 29: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of tendencies or behaviors with the potential to harm others

Summary Table 29: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of tendencies or behaviors with the potential to harm others

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Virkkunen, 1987, Finland: multiple-group cross-sectional study^135^ | violent antisocial personality (n=15) | intermittent explosive disorder (n=19)/ healthy controls (n=16) | ↓ LA in intermittent explosive disorder vs controls;^+++^ ↑ DGLA in both patient grps vs controls;^++^ ↓ DHA in violent antisocial personality disorder vs controls^++^ | Total quality: 4 [Grade: B] | III
Hibbeln, 1998, US: multiple-group cross-sectional study^134^ | violent group (n=27) | nonviolent control group (n=31) | NS bet grps for n-3 & n-6 FA; ↓ CSF 5-HIAA in violent pts^+^ | Total quality: 2 [Grade: C] | I
Buydens-Branchey, 2003, US: multiple-group cross-sectional study^136^ | aggressive cocaine addict males (n=6) | non-aggressive cocaine addict males (n=18) | NS total FA, PUFA & total n-6 FA bet grps; ↓ DPA,^+^ total n-3 FA^+^ & DHA^++^ in aggressive pts | Total quality: 4 [Grade: B] | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

5-HIAA = 5-hydroxindolacetic acid;

HVA = homovanillic acid;

Summary Table 30: Association between omega-3 and omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of alcoholism

Summary Table 30: Association between omega-3 and omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of alcoholism

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Alling, 1984, Sweden: multiple-group cross-sectional study^138^ | chronic alcoholic males (n=13) | healthy control males (n=21) | ↓ EPG RBC LA,^+++^ DGLA, AA & DHA^++^ in pts vs controls; ↓ LA^++^ & AA^+++^ in CPG RBCs & plasma in patients vs controls | Total quality: 2 [Grade: C] | III
Hibbeln, 1998, US: multiple-group cross-sectional study^137^ | abstinent early-onset (<25 y age) alcoholics (n=88) | abstinent late-onset alcoholics (n=39)/ healthy controls (n=49) | ↑ plasma DHA, LA, DGLA & AA in pts vs. controls;^++++^ NS bet early & late-onset alcoholics | Total quality: 3 [Grade: C] | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 31: Omega-3 fatty acids as primary treatment for borderline personality disorder

Summary Table 31: Omega-3 fatty acids as primary treatment for borderline personality disorder

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Zanarini, 2003, US: 8 wk parallel RCT^139^ | 1g/d E-EPA (n=20) | mineral oil pb (n=10) | E-EPA grp had ↓ MADRS^++++^ & MOAS^++++^ at study end | Jadad total: 3 [Grade: B]; Schulz: Unclear | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

MADRS = Montgomery-Asberg Depression Rating Scale;

MOAS = Modified Overt Aggression Scale;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 32: Omega-3 fatty acids as primary treatment for schizophrenia

Summary Table 32: Omega-3 fatty acids as primary treatment for schizophrenia

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Peet, 2001, India: 3 mo parallel RCT^58^ | 2g/d EPA (n=15) | corn oil placebo (n=15) | 12/12 pb & 6/14 EPA required antipsychotic medication by study's end;^+^ EPA pts spent fewer days on medication;^+^ EPA pts had ↓ total PANSS^+^ & PANSS positive;^+^ responder analysis 2/12 placebo & 8/14 EPA pts were responders^+^ | Jadad total: 3 [Grade: B]; Schulz: Adequate | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

PANSS = Positive and Negative Syndrome Scale;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

Summary Table 33: Omega-3 fatty acids as supplemental treatment for schizophrenia

Summary Table 33: Omega-3 fatty acids as supplemental treatment for schizophrenia

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,3^ | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Peet, 2001, England: 3 mo parallel RCT^58^ | 2g/d EPA enriched fish oil (n=15 completers) | 2g/d DHA enriched oil (source undefined) (n=16 completers)/ corn oil pb (n=14 completers) | EPA's total PANSS ↓ than pb;^+^ treatment effect for EPA over DHA ((+) PANSS^+^ ); ↑ ↓ in EPA than DHA;^+^ NS for (-) symptoms; EPA pts had ↑ ↓ for EPA than DHA^+^ or pb^+^ grps | Largest ↑ in EPA & DHA in EPA^+++^ & DHA grps;^+++^ Smaller ↑ in EPA & DHA in DHA^+^ & EPA grps;^+^ NS Δ for AA | EPA grp = greatest ↓ in total PANSS had highest baseline EPA^+^ & AA;^+^ baseline EPA predicts clinical ↓;^+^ NS correlations in all other grps | Jadad total: 4 [Grade: A]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

PANSS = Positive and Negative Syndrome Scale;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

(+) = positive;

(-) = negative;

Summary Table 34: Omega-3 fatty acids as supplemental treatment for schizophrenia

Summary Table 34: Omega-3 fatty acids as supplemental treatment for schizophrenia

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,3^ | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Fenton, 2001, US: 16 wk parallel RCT^89^ | 3g/d E-EPA (n=45) | mineral oil pb (n=45) | Time effect on total PANSS,^+++^ MADRS^+++^ & CGI;^+++^ NS time-by-grp interaction; NS effects for time or time-by-grp for cognitive impairment, EXP or TD; NS effects on (+) or (-) PANSS; improvement in pb in 1st 2 wk | EPA grp had higher % EPA^+++^ & ↓ % AA;^+++^ EPA ↑ in pb grp;^+^ AA/EPA ↓ greater for EPA;^+++^ DHA % ↓ in smokers^++^ vs nonsmokers, & males had ↓ DHA^+^ & EPA %'s^+^ vs females | Δ in AA/EPA not linked to efficacy; DHA Δ negatively correlated with Δ in (+) sysmptoms;^++^ sex & current smoking status related to FA compositions ^+ - ++^ | Jadad total: 4 [Grade: A]; Schulz: Unclear | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

MADRS = Montgomery-Asberg Depression Rating Scale;

PANSS = Positive and Negative Syndrome Scale;

CGI = Clinical Global Improvement Scale;

Jadad total = Jadad total qualility score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

TD = tardive dyskinesia;

EXP = extrapyramidal symptoms;

(+) = positive;

(-) = negative

Summary Table 35: Omega-3 fatty acids as supplemental treatment for schizophrenia

Summary Table 35: Omega-3 fatty acids as supplemental treatment for schizophrenia

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Emsley, 2002, South Africa: 12 wk parallel RCT^140^ | 3g/d E-EPA (n=20) | liquid paraffin pb (n=20) | With^+^ or without^+^ controls, total PANSS ↓'s greater in E-EPA grp; difference favored E-EPA patients in % Δ of general psychopathology (PANSS);^+^ dyskinesia ↓ greater for E-EPA pts at 12 wk^++^ | Jadad total: 3 [Grade: B]; Schulz: Unclear | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

PANSS = Positive and Negative Syndrome Scale;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporrting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 36: Omega-3 fatty acids as supplemental treatment for schizophrenia

Summary Table 36: Omega-3 fatty acids as supplemental treatment for schizophrenia

Author, Year, Location: Length & Design | Study groups^1^ | | Notable clinical effects | Notable biomarker effects^2,3^ | Notable clinical-biomarker correlations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Peet, 2002, England: 12 wk parallel RCT^87^ | 4g/d E-EPA (n=27)/liquid paraffin pb (n=31) | 2g/d E-EPA (n=32)/1g/d E-EPA (n=32) | [underlined: typical neuroleptics]: all doses improved total PANSS (size of Δ covaries with dose);^+ - ++^ large pb effects;^+ - ++^ NS differences vs pb; [underlined: atypical neuroleptics]: improvement for 1g/d^+ - +++^ & 2g/d^+ - +++^ (total & subscale); NS effect for 4g/d; pb effects;^+++^ NS differences vs pb; [underlined: clozapine]: all doses had effects;^+ - +++^ 2g/d had greatest % Δ; 2g/d E-EPA effect on total PANSS^+^ & general psychopathology^+^ | Δ in pb grp: ↑ in AA in pts on atypical antipsychotics;^+^ [underlined: clozapine]: ↑ in AA^+^ in 2g/d grp; ↓ for DHA^+^ & AA^+^ in 4g/d grp on atypical antipsychotics | Δ in AA positively related to Δ in all clinical outcomes; ^+ - +++^ Δ in DHA or EPA unrelated to Δ in clinical outcomes | Jadad total: 4 [Grade: A]; Schulz: Adequate | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

PANSS = Positive and Negative Syndrome Scale;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 37: Association between omega-3 fatty acid intake and onset, continuation or recurrence of schizophrenia (observational studies)

Summary Table 37: Association between omega-3 fatty acid intake and onset, continuation or recurrence of schizophrenia (observational studies)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Peet, 1997, UK: case-control study^92^ | schizophrenic pts (n=55) | matched nonpsychiatric controls (n=55) | Schizophrenic pts less likely to have been breastfed;^+^ breastfeeders of >4 wk less frequent in schizophrenic pt grp^+^ | Total quality: 3 [Grade: C] | II
McCreadie, 1997, UK: case-control study^143^ | schizophrenic pts (n=45) | siblings (n=92)/national survey data from Scotland (n=1,648 & n=1,718) & Great Britain (n=13,687) | NS lesser breastfeeding in schizophrenic pts than siblings; most pts born in 1940s & 1950s, with breastfeeding incidence in these decades < Scottish national surveys in 1946^+++^ & 1958;^+^ non-breastfed pts had more schizoid & schizoptypal traits^+++^ in childhood than siblings, including poorer social adjustment;^++++^ NS correlations bet breastfeeding length & adjustment | Total quality: 4 [Grade: B] | II
Leask, 2000, UK: case-control study^142^ | those developing schizophrenia in 2 national birth cohorts (1946: n=5,362; 1958: n=18,856) | those who do not develop schizophrenia in these 2 national birth cohorts | In both birth cohorts: NS feeding histories of schizophrenic pts & controls, with or without adjustment for offspring's sex & father's social class | Total quality: 5 [Grade: B] | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 38: Association between omega-3 fatty acid intake and onset, continuation or recurrence of schizophrenia (observational studies)

Summary Table 38: Association between omega-3 fatty acid intake and onset, continuation or recurrence of schizophrenia (observational studies)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Sasaki, 2000, Japan: case-control study^144^ | schizophrenic inpts & outpts (n=100) | healthy siblings (n=37)/matched healthy controls (n=200) | no evidence for lesser likelihood of breastfeeding in infancy of patients at 1 or 3 mo | Total quality: 5 [Grade: B] | III
Amore, 2003, Italy: case-control study^141^ | hospital admitted schizophrenic pts (n=113) | siblings (n=140)/normal controls (n=113) | adjusting for age, sex, birth weight, disease severity & birth order, NS breastfeeding incidence; NS age of onset for exclusively breastfed vs others; breastfeeding duration positively correlated with age of onset^+^ | Total quality: 6 [Grade: B] | III
Mellor, 1996, England: 1 wk single prospective cohort study as baseline for a noncomparative before-after study^91^ | schizophrenic pts (n=20) | | EPA intake negatively associated with total psychopathology;^+^ negative correlations for positive symptoms & ALA intake^+^ & total n-3 fatty intake.^+^ Multiple regression: EPA intake inversely related to total PANSS;^+^ total n-3 intake negatively related to positive symptoms^+^ | Total quality: 4 [Grade: B] | II

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

PANSS = Positive and Negative Symptoms Scale;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 39: Association between omega-3 fatty acid intake and onset, continuation or recurrence of schizophrenia (cross-national ecological analyses)

Summary Table 39: Association between omega-3 fatty acid intake and onset, continuation or recurrence of schizophrenia (cross-national ecological analyses)

Author, Year, Location: Length & Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Christensen, 1988, 8 countries: cross-national ecological analysis^145^ | n=8 countries | | high intake of saturated fat associated with unfavorable schizophrenia course and outcome^+- +++^ NS relationship bet intake of unsaturated fat, including PUFAs, & schizophrenia course or outcome | Total quality: 3 [Grade: C] | III
Noaghiul, 2003, 14 countries: cross-national ecological analysis^90^ | n=14 countries | | seafood consumption did not predict lifetime prevalence rates | Total quality: 4 [Grade: B] | III
Peet, 2004, 12 countries: cross-national ecological analysis^109^ | n=12 countries | | fish consumption not associated with specific schizophrenia course or outcome variables | Total quality: 3 [Grade: C] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

wt = weight;

Δ = change;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 40: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Summary Table 40: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Obi, 1979, Nigeria: multiple-group cross-sectional study^153^ | schizophrenic pts (n=6) | healthy controls (n=6) | ↑ % of LA in schizophrenic pts^+^ | Total quality: 1 [Grade: C] | III
Horrobin, 1989, England, Scotland, Ireland: multiple-group cross-sectional study^152^ | adult male & female schizophrenic pts (n=84) | adult male & female controls (n=119) | ↓ total n-6 levels in pts;^+^ ↑ n-3 levels in pts;^+^ ↓ n-6/n-3 in pts;^+^ ↓ LA & AA in pts;^+^ ↑ DHA in pts (England & Ireland);^++^ NS EPA bet grps | Total quality: 2 [Grade: C] | II
Kaiya, 1991, Japan: multiple-group cross-sectional study^151^ | adult male & female schizophrenic pts (n=59) | adult male & female affective or paranoid disorders (n=24)/adult male & female controls (n=24) | NS total n-3 FA; ↑ DGLA in schizophrenic pts;^+^↓ LA in schizophrenic pts;^+^ ↑ EPA in schizophrenic male pts vs female pts;++ in cholesterol fraction, NS bet schizophrenic pts >40 & <40 y; ↑ AA in inpts vs outpts^+^ | Total quality: 3 [Grade: C] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower

Summary Table 41: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Summary Table 41: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/Group 4 (n) | Group 2 (n)/Group 3 (n)
Fischer, 1992, Germany: multiple-group cross-sectional study^150^ | “high dose” inpts (n=9)/control males (n=6) | “low dose” outpts (n=7)/untreated pts (n=2) | ↓ LA, AA & DHA “high-dose” vs “low dose” & controls;^++^; ↓ LA, AA & DHA in ”low dose” vs untreated;^+^ ↑ ratio of SFA/PUFA in “high dose” vs “low dose” & controls^+^ | Total quality: 1 [Grade: C] | III
Peet, 1995, UK: multiple-group cross-sectional study^149^ | medicated inpts (n=23) | age & sex-matched healthy controls (n=16) | ↓ EPA & DHA in pts;^+++^ ↓ LA & AA in pts;^+++^ NS correlation bet neuroleptic dosage & FA levels | Total quality: 3 [Grade: C] | III
Vaddadi, 1996, Australia: multiple-group cross-sectional study at baseline of multiple prospective cohort study^157^ | adult male & female schizophrenic pts with tardive dyskinesia (n=32) | adult male & female schizophrenic pts without tardive dyskinesia (n=40)/normal controls (n=39) | ↓ LA pts severe TD vs pts without TD;^++^ ↓ LA pts without TD vs control group;^++^ ↑ (n-3-)DPA pts vs controls;^+^ followup at 4.5 y: ↑ RBC (n-6-)DGLA in both pt grps vs controls^++^ | Total quality: 1 [Grade: C] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

SFA = saturated fatty acids;

TD = tardive dyskinesia

Summary Table 42: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Summary Table 42: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Mahadik, 1996, US: multiple-group cross-sectional study ^114^ | male & female schizophrenic pts (n=12) | male & female bipolar pts (n=6)/ controls (n=8) | ↓ DHA in cell lines of schizophrenic pts vs bipolar pts & controls;^+^ NS DHA bet bipolar & controls; ↓ AA in schizophrenia vs bipolar pts^+^ | Total quality: 5 [Grade: B] | I
Assies, 2001, Holland: multiple-group cross-sectional study ^148^ | schizophrenia & other diagnoses in young adults (n=19) | matched controls (n=14) | ↓ DHA & (n-3-)DPA in pts;^++^ ↓ total n-3 in schizophrenic pts;^+++^ NS n-6 bet grps; ↓ DHA/AA ratio in pts;^+^ NS AA/EPA, DPA/DHA & n-6/n-3; positive correlation bet CPZ equivalents & AA/EPA;^+^ negative correlation for EPA & CPZ dosage;^+^ ↓ n-6/n-3 in cannabis users vs nonusers; no consistent pattern of correlations of FA content & symptomatology | Total quality: 2 [Grade: C] | III
Yao, 2002, US: multiple-group cross-sectional study ^154^ | drug-naïve, first episode schizophrenic pts (n=11) | normal controls (n=11) | ↓ AA in pts;^+^ NS bet-grp differences for rest of FA; positive correlation bet peripheral biomarkers & PLs only in prefrontal brain^++^ | Total quality: 3 [Grade: C] | I

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+ DHA;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

SFA = saturated fatty acids;

CPZ = chlorpromazine

Summary Table 43: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Summary Table 43: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Khan, 2002, US: multiple-group cross-sectional study ^147^ | drug-naïve, first episode schizophrenic pts (n=22) | chronic medicated schizophrenic pts (n=30)/ healthy controls (n=16) | ↓ LA, AA & DHA were lower in FE vs chronic pts;^+++^ ↓ LA, AA & DHA in FE & chronic pts vs controls;^+++^ Larger ↓ PUFA levels associated with greater severity of psychosis, indicated by ↑ clinical scores in FE pts vs chronic pts; Δ did not seem to be related to age or smoking | Total quality: 3 [Grade: C] | I
Arvindakshan, 2003, India: multiple-group cross-sectional study at baseline of before-after study ^155^ | medicated schizophrenic pts (n=28) | healthy controls (n=45) | ↓ EPA & DHA in pts (at baseline);^+++^ NS in LA or AA content (at baseline) | Total quality: 4 [Grade: B] | III
Arvindakshan, 2003, India: multiple-group cross-sectional study ^146^ | drug-naïve, first episode schizophrenic pts (n=20) | medicated schizophrenic pts (n=32)/ healthy controls (n=45) | ↓AA, DHA, total n-6 & n-3 FA in FE & MS vs controls;^+++^ NS AA & DHA bet MS vs controls; ↓ AA, DHA, total n-6 & n-3 in FE vs MS;^+++^ negative correlation bet AA & BPRS;^+^ negative correlation bet DHA & PANSS negative symptoms^+++^ | Total quality: 2 [Grade: C] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

FE = first episode;

MS = medicated schizophrenics;

SFA = saturated fatty acids;

BPRS = Brief Psychiatric Rating Scale;

PANSS = Positive and Negative Symptom Scale

Summary Table 44: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Summary Table 44: Association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Evans, 2003, US: multiple-group cross-sectional study at baseline of single prospective cohort study ^158^ | first episode schizophrenic pts (n=16) | healthy controls (n=25) | ↓ (n-3-)DPA & DHA in FE vs controls;^+^ NS AA & LA levels bet grps | Total quality: 1 [Grade: C] | I
Ranjekar, 2003, India: multiple-group cross-sectional study ^156^ | adult male schizophrenic pts (n=31) | bipolar adult males (n=10)/ healthy controls (n=31) | ↓ SOD, CAT & GPx in schizophrenic pts vs controls;^++^ ↓ ALA, DHA & EPA in pts vs controls;^+^ ↓ SOD, CAT in bipolar pts vs controls;^+^ | Total quality: 4 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

bet = between;

grp = group;

wk = week(s);

mo = month;

Δ = change;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase(d)/higher;

↓ = decrease(d)/reduction/lower;

SOD = superoxide dismutase;

CAT = catalase;

GPx = glutathione peroxidase;

PE = phosphatidylethanolamine

Summary Table 45: Association between omega-3 and omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of autism

Summary Table 45: Association between omega-3 and omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of autism

Author, Year, Location: Design | Study groups^1^ | | Notable associations | Internal validity | Applicability
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
Vancassel, 2001, France: multiple-group cross-sectional study ^159^ | autistic children (n=15) | mentally retarded children (n=18) | NS plama LA, AA bet grps; NS plasma DHA, ALA; ↓ total n-3 in autism; ↑ n-6/n-3 in autism | Total quality: 4 [Grade: B] | III

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

n-3 = omega-3 fatty acids;

n-6 = omega-6 fatty acids;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

N/A = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month;

RBC = red blood cells;

PL = phospholipid;

CPG = choline phosphoglycerides;

EPG = ethanolamine phosphoglycerides;

Jadad total = Jadad total quality score: reporting of randomization, blinding, withdrawals/dropouts (/5);

Schulz = reporting of adequacy of allocation concealment (adequate, inadequate, unclear);

+ p<.05 or significant with 95% confidence interval;

++ p<.01;

+++ p<.001;

++++ p<.0001;

↑ = increase;

↓ = decrease/reduction

Summary Table 46: Studies reporting adverse events (e.g., side effects) or contraindications

Summary Table 46: Studies reporting adverse events (e.g., side effects) or contraindications

Author, Year, Location: Length & Design | Study groups^1^ | | Safety data
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
DEPRESSION
Marangell, 2003, US: 6 wk parallel RCT ^95^ | 2g/d DHA (n=18) | pb (source undefined) (n=18) | [underlined: 2g/d DHA (source undefined]): fishy aftertaste (n=14 events), belching (n=3), lightheadedness or dizziness (n=3), loose stools (n=2), headache (n=2), insomnia (n=1), continued (n=18/18); [underlined: pb (source undefined]): fatigue (n=3 events), insomnia (n=1), loose stools (n=1), continued (n=18/18)
Peet, 2002, England & Scotland: 12 wk parallel RCT ^53^ | 4g/d E-EPA (n=17)/ liquid paraffin pb (n=18) | 2g/d E-EPA (n=18)/ 1g/d E-EPA (n=17) | [underlined: Musculoskeletal system]: 4g/d E-EPA (source undefined) (n=1); 2g/d E-EPA (n=2); [underlined: central & peripheral nervous system]: 4g/d E-EPA (n=1); 1g/d E-EPA (n=1); pb (liquid paraffin) (n=3); [underlined: visual system]: pb (n=1); [underlined: psychiatric event]: 2g/d E-EPA (n=2); 1g/d E-EPA (n=4); pb (n=2); [underlined: gastrointestinal]: 4g/d E-EPA (n=5); 2g/d E-EPA (n=8); 1g/d E-EPA (n=7); pb (n=4); [underlined: metabolic]: 1g/d E-EPA (n=2); pb (n=2); [underlined: endocrine]: 4g/d E-EPA (n=1); [underlined: respiratory system]: 4g/d E-EPA (n=1); 2g/d E-EPA (n=2); 1g/d E-EPA (n=1); pb (n=2); [underlined: white blood cells]: pb (n=1); [underlined: reproductive system]: 2g/d E-EPA (n=1); pb (n=2); [underlined: whole body]: 4g/d E-EPA (n=3); 2g/d E-EPA (n=6); 1g/d E-EPA (n=1); pb (n=4); [underlined: infections]: 4g/d E-EPA (n=3); 2g/d E-EPA (n=3); 1g/d E-EPA (n=2); pb (n=2); [underlined: diarrhea]: 1g/d E-EPA (n=1)
Su, 2003, China: 8 wk parallel RCT^96^ | 4.4g EPA + 2.2g/d DHA (n=14) | olive oil ethyl ester pb (n=14) | [underlined: 4.4g EPA + 2.2g/d DHA (fish oil)]: mild excitement (n=1), continued (n=1/1); mild diarrhea (n=1), continued (n=1/1); [underlined: pb (olive oil ethyl esters]): insomnia (n=1), continued (n=1/1)
BIPOLAR DISORDER
Stoll, 1999, US: 4 mo parallel RCT ^112^ | 9.6g/d EPA+DHA (6.2g/d EPA, 3.4g/d DHA) (n=˜22) | olive oil ethyl ester pb (n=˜22) | [underlined: Gastrointestinal (mild)]: 9.6g/d EPA+DHA (fish oil) (n=8), continued (n=8/8); pb (olive oil ethyl ester) (n=8), continued (n=8/8)

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

* No explicit description that adverse events specifically linked to exposure, only that associated with participants in a specific study group;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month

Summary Table 47: Studies reporting adverse events (e.g., side effects) or contraindications

Summary Table 47: Studies reporting adverse events (e.g., side effects) or contraindications

Author, Year, Location: Length & Design | Study groups^1^ | | Safety data
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
SCHIZOPHRENIA
Peet, 2001, England: 3 mo parallel RCT ^58^ | 2g/d EPA enriched fish oil (n=15 completers) | 2g/d DHA enriched oil (source undefined) (n=16 completers)/ corn oil pb (n=14 completers) | [underlined: Study 1]: (full sample, n=55) felt ill and forgetful (n=1), dropped out (n=1/1); nausea, irritable bowel, indigestion (n=3), dropped out (n=3/3)
Fenton, 2001, US: 16 wk parallel RCT ^89^ | 3g/d E-EPA (n=45) | mineral oil pb (n=45) | [underlined: 3g/d E-EPA (source undefined)]: upper respiratory infection (n=8), continued (n=8/8); diarrhea (n=8), continued (n=8/8)
Peet, 2002, England: 12 wk parallel RCT ^87^ | 4g/d E-EPA (n=27)/ liquid paraffin pb (n=31) | 2g/d E-EPA (n=32)/ 1g/d E-EPA (n=32) | [underlined: Body as a whole]: 4g/d E-EPA (source undefined) (n=2); 2g/d E-EPA (n=1); 1g/d E-EPA (n=2); placebo (liquid paraffin) (n=6); [underlined: cardiovascular/heart]: 4g/d E-EPA (n=1); 1g/d E-EPA (n=1); pb (n=1); [underlined: central & peripheral nervous system]: 4g/d E-EPA (n=2); 2g/d E-EPA (n=3); pb (n=3); [underlined: diarrhea]: 4g/d E-EPA (n=3); 2g/d E-EPA (n=1); 1g/d E-EPA (n=7); pb (n=7); [underlined: nausea]: 4g/d E-EPA (n=2); 2g/d E-EPA (n=3); 1g/d E-EPA (n=1); [underlined: liver & biliary tract]: 1g/d E-EPA (n=1); [underlined: metabolic]: 4g/d E-EPA (n=3); 2g/d E-EPA (n=1); 1g/d E-EPA (n=1); pb (n=1); [underlined: musculoskeletal]: pb (n=1); [underlined: psychiatric]: 4g/d E-EPA (n=6); 2g/d E-EPA (n=2); 1g/d E-EPA (n=4); [underlined: reproductive]: 4g/d E-EPA (n=2); pb (n=1); [underlined: infections & respiratory system]: 4g/d E-EPA (n=3); 2g/d E-EPA (n=1); 1g/d E-EPA (n=5); pb (n=5); [underlined: skin]: 4g/d E-EPA (n=1); 2g/d E-EPA (n=1); 1g/d E-EPA (n=2); [underlined: urinary]: 1g/d E-EPA (n=2); pb (n=1); [underlined: vision]: 1g/d E-EPA (n=1); pb (n=1); [underlined: white cells]: 4g/d E-EPA (n=1); pb (n=1); [underlined: other]: 4g/d E-EPA (n=3); 2g/d E-EPA (n=1); 1g/d E-EPA (n=2)

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

* No explicit description that adverse events specifically linked to exposure, only that associated with participants in a specific study group;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month

Summary Table 48: Studies reporting adverse events (e.g., side effects) or contraindications

Summary Table 48: Studies reporting adverse events (e.g., side effects) or contraindications

Author, Year, Location: Length & Design | Study groups^1^ | | Safety data
| Group 1 (n)/ Group 4 (n) | Group 2 (n)/ Group 3 (n)
TENDENCIES OR BEHAVIOR WITH THE POTENTIAL TO HARM OTHERS
Hamazaki, 1996, Japan: 3 mo parallel RCT ^130^ | 1.5–1.8g/d DHA (+ some EPA) (n=27) | oil capsules (97% soybean oil + 3% fish oil) pb (n=26) | [underlined: 1.5–1.8g/d DHA (fish oil)]: trend toward obesity (n=1), continued (n=1/1); [underlined: pb (97% soybean oil + 3% fish oil)]: acne (n=2), continued (n=2/2); itching (n=1), continued (n=1/1)
Hamazaki, 1998, Japan: 13 wk parallel RCT ^129^ | 1.5g/d DHA (n=29) | oil capsules (97% soybean oil + 3% fish oil) pb (n=30) | [underlined: Pb (97% soybean oil + 3% fish oil)]: gastrointestinal disorder (n=1), dropped out (n=1/1)
ATTENTION DEFICIT/HYPERACTIVITY DISORDER
Richardson, 2002, UK: 12 wk parallel RCT ^119^ | 186 mg/d EPA, 480mg/d DHA, 96mg/d GLA, 864 mg/d cis-linolenic acid, 42 mg/d AA & 8mg/d thyme (n=22) | olive oil pb (n=19) | [underlined: 186mg/d EPA & 480mg/d DHA (source undefined)]: digestive upset (n=1), dropped out (n=1/1); swallowing problems (n=1), dropped out (n=1/1); [underlined: pb (olive oil)]: digestive upset (n=1), dropped out (n=1/1)

1 Proceeding from highest omega-3, or lowest omega-6/omega-3, fatty acid content of intervention/exposure;

2 biomarker source;

3 biomarkers = EPA, DHA, AA, AA/EPA, AA/DHA, AA/EPA+DHA;

* No explicit description that adverse events specifically linked to exposure, only that associated with participants in a specific study group;

FA = fatty acids;

n-3 = omega-3 FAs;

n-6 = omega-6 FAs;

ALA = alpha linolenic acid;

DHA = docosahexaenoic acid;

EPA = eicosapentaenoic acid;

AA = arachidonic acid;

E-EPA = ethyl eicosapentaenoate;

Length = intervention length;

Design = research design;

n = sample size;

pts = study participants;

NR = not reported;

NS = nonsignificant statistical difference;

n/a = not applicable;

pb = placebo;

grp = group;

wk = week(s);

mo = month