# Listing of Reports of Included Studies

Akkerhuis G W, Nolen W A. Lithium-associated psoriasis and omega-3 fatty acids. Am J Psychiatry. 2003;160(7):1355. [pmid: 12832259].
Alling C, Gustavsson L, Kristensson-Aas A, Wallerstedt S. Changes in fatty acid composition of major glycerophospholipids in erythrocyte membranes from chronic alcoholics during withdrawal. Scand J Clin Lab Invest. 1984;44(4):283-289. [pmid: 6463560].
Amore M, Balista C, McCreadie R G, Cimmino C, Pisani F, Bevilacqua G, et al. Can breast-feeding protect against schizophrenia? Case-control Study. Biol Neonate. 2003;83(2):97-101. [pmid: 12576752].
Arvindakshan M, Sitasawad S, Debsikdar V, Ghate M, Evans D, Horrobin D F, et al. Essential polyunsaturated fatty acid and lipid peroxide levels in never-medicated and medicated schizophrenia patients. Biol Psychiatry. 2003;53(1):56-64. [pmid: 12513945].
Arvindakshan M, Ghate M, Ranjekar P K, Evans D R, Mahadik S P. Supplementation with a combination of omega-3 fatty acids and antioxidants (vitamins E and C) improves the outcome of schizophrenia. Schizophr Res. 2003;62(3):195-204. [pmid: 12837515].
Assies J, Lieverse R, Vreken P, Wanders R J, Dingemans P M, Linszen D H. Significantly reduced docosahexaenoic and docosapentaenoic acid concentrations in erythrocyte membranes from schizophrenic patients compared with a carefully matched control group. Biol Psychiatry. 2001;49(6):510-522. [pmid: 11257236].
Brue A W, Oakland T D, Evans R A. The use of a dietary supplement combination and an essential fatty acid as an alternative and complementary treatment for children with attention-deficit/hyperactivity disorder. Sci Rev Altern Med. 2001;5(4):187-194.
Buydens-Branchley L, Branchey M, McMakin D L, Hibbeln J R. Polyunsaturated fatty acid status and aggression in cocaine addicts. Drug Alcohol Depend. 2003;71(3):319-323. [pmid: 12957349].
Chiu C C, Huang S Y, Su K P, Lu M L, Huang M C, Chen C C, et al. Polyunsaturated fatty acid deficit in patients with bipolar mania. Eur Neuropsychopharmacol. 2003;13(2):99-103. [pmid: 12650953].
Christensen O, Christensen E. Fat consumption and schizophrenia. Acta Psychiatr Scand. 1988;78(5):587-591. [pmid: 3232536].
Dickerson F B, Boronow J J, Stallings C R, Lee B A, Agarwal R, Fenton W S, et al. Placebo response in a double-blind therapeutic supplementation trial in stabilized outpatients with schizophrenia. Schizophr Res. 2003;59(1):97-98. [pmid: 12413650].
Edwards R, Peet M, Shay J, Horrobin D. Depletion of docosahexaenoic acid in red blood cell membranes of depressive patients. Biochem Soc Trans. 1998;26(2):S142. [pmid: 9649817].
Edwards R, Peet M, Shay J, Horrobin D. Omega-3 polyunsaturated fatty acid levels in the diet and in red blood cell membranes of depressed patients. J Affect Disord. 1998;48(23):149-155. [pmid: 9543204].
Ellis F R, Sanders T A B. Long chain polyunsaturated fatty acids in endogenous depression. J Neurol Neurosurg Psychiatry. 1977;40(2):168-169. [pmid: 864481].
Emsley R, Myburgh C, Oosthuizen P, van Rensburg S J. Randomized, placebo-controlled study of ethyl-eicosapentaenoic acid as supplemental treatment in schizophrenia. Am J Psychiatry. 2002;159(9):1596-1598. [pmid: 12202284].
Evans D R, Parikh V V, Khan M M, Coussons C, Buckley P F, Mahadik S P. Red blood cell membrane essential fatty acid metabolism in early psychotic patients following antipsychotic drug treatment. Prostaglandins Leukot Essent Fatty Acids. 2003;69(6):393-399. [pmid: 14623492].
Fehily A M A, Bowey O A M, Ellis F R, Meade B W. Plasma and erythrocyte membrane long chain polyunsaturated fatty acids in endogenous depression. Neurochem Int. 1981;3(1):37-42. [pmid: 20487806].
Fenton W S, Dickerson F, Boronow J, Hibbeln J R, Knable M. A placebo-controlled trial of omega-3 fatty acid (ethyl eicosapentaenoic acid) supplementation for residual symptoms and cognitive impairment in schizophrenia.[comment]. Am J Psychiatry. 2001;158(12):2071-2074. [pmid: 11729030].
Fischer S, Kissling W, Kuss H J. Schizophrenic patients treated with high dose phenothiazine or thioxanthene become deficient in polyunsaturated fatty acids in their thrombocytes. Biochem Pharmacol. 1992;44(2):317-323. [pmid: 1642646].
Fux M, Benjamin J, Nemets B. A placebo-controlled cross-over trial of adjunctive EPA in OCD. J Psychiatr Res. 2004;38(3):323-325. [pmid: 15003438].
Gesch C B, Hammond S M, Hampson S E, Eves A, Crowder M J. Influence of supplementary vitamins, minerals and essential fatty acids on the antisocial behaviour of young adult prisoners. Randomised, placebo-controlled trial. Br J Psychiatry. 2002;181:22-28. [pmid: 12091259].
Hakkarainen R, Partonen T, Haukka J, Virtamo J, Albanes D, Lonnqvist J. Is low dietary intake of omega-3 fatty acids associated with depression?. Am J Psychiatry. 2004;161(3):567-569. [pmid: 14992986].
Hamazaki T, Sawazaki S, Itomura M, Asaoka E, Nagao Y, Nishimura N, et al. The effect of docosahexaenoic acid on aggression in young adults. A placebo-controlled double-blind study. J Clin Invest. 1996;97(4):1129-1133. [pmid: 8613538]. [pmcid: 507162].
Hamazaki T, Sawazaki S, Nagao Y, Kuwamori T, Yazawa K, Mizushima Y, et al. Docosahexaenoic acid does not affect aggression of normal volunteers under nonstressful conditions. A randomized, placebo-controlled, double-blind study. Lipids. 1998;33(7):663-667. [pmid: 9688168].
Hamazaki T, Thienprasert A, Kheovichai K, Samuhaseneetoo S, Nagasawa T, Watanabe S. The effect of docosahexaenoic acid on aggression in elderly Thai subjects--a placebo-controlled double-blind study. Nutr Neurosci. 2002;5(1):37-41. [pmid: 11929196].
Harding K L, Judah R D, Gant C E. Outcome-based comparison of Ritalin versus food-supplement treated children with AD/HD. Altern Med Rev. 2003;8(3):319-330. [pmid: 12946241].
Hibbeln J R, Linnoila M, Umhau J C, Rawlings R, George D T, Salem N Jr. Essential fatty acids predict metabolites of serotonin and dopamine in cerebrospinal fluid among healthy control subjects, and early- and late-onset alcoholics. Biol Psychiatry. 1998;44(4):235-242. [pmid: 9715354].
Hibbeln J R, Umhau J C, Linnoila M, George D T, Ragan P W, Shoaf S E, et al. A replication study of violent and nonviolent subjects: cerebrospinal fluid metabolites of serotonin and dopamine are predicted by plasma essential fatty acids. Biol Psychiatry. 1998;44(4):243-249. [pmid: 9715355].
Hibbeln J R. Fish consumption and major depression.[comment]. Lancet. 1998;351(9110):1213. [pmid: 9643729].
Hibbeln J R. Seafood consumption and homicide mortality: A cross-national ecological analysis. 4th Congress of the International Society for the Study of Fatty Acids and Lipids (ISSFAL 2000). World Rev Nutr Diet. 2001;88:41-46. [pmid: 11935968].
Hibbeln J R. Seafood consumption, the DHA content of mothers' milk and prevalence rates of postpartum depression: a cross-national, ecological analysis. J Affect Disord. 2002;69(13):15-29. [pmid: 12103448].
Hibbeln J R, Makino K K, Martin C E, Dickerson F, Boronow J, Fenton W S. Smoking, gender, and dietary influences on erythrocyte essential fatty acid composition among patients with schizophrenia or schizoaffective disorder. Biol Psychiatry. 2003;53(5):431-441. [pmid: 12614996].
Hirayama S, Hamazaki T, Terasawa K. Effect of docosahexaenoic acid-containing food administration on symptoms of attention-deficit/hyperactivity disorder - A placebo-controlled double-blind study. Eur J Clin Nutr. 2004;58(3):467-473. [pmid: 14985685].
Holman R T, Adams C E, Nelson R A, Grater S J, Jaskiewicz J A, Johnson S B, et al. Patients with anorexia nervosa demonstrate deficiencies of selected essential fatty acids, compensatory changes in nonessential fatty acids and decreased fluidity of plasma lipids. J Nutr. 1995;125(4):901-907. [pmid: 7722693].
Horrobin D F, Bennett C N, Peet M. Correlation between clinical improvement and red cell fatty acid changes when treating schizophrenia with eicosapentaenoic acid. Schizophr Res. 2001;49:232.
Horrobin D F, Manku M S, Morse-Fisher N, Vaddadi K S, Courtney P, Glen A I, et al. Essential fatty acids in plasma phospholipids in schizophrenics. Biol Psychiatry. 1989;25(5):562-568. [pmid: 2920191].
Iribarren C, Markovitz J H, Jacobs D R Jr, Schreiner P J, Daviglus M, Hibbeln J R. Dietary intake of n-3, n-6 fatty acids and fish: Relationship with hostility in young adults - The CARDIA study. Eur J Clin Nutr. 2004;58(1):24-31. [pmid: 14679363].
Kaiya H, Horrobin D F, Manku M S, Fisher N M. Essential and other fatty acids in plasma in schizophrenics and normal individuals from Japan. Biol Psychiatry. 1991;30(4):357-362. [pmid: 1912126].
Khan M M, Evans D R, Gunna V, Scheffer R E, Parikh V V, Mahadik S P. Reduced erythrocyte membrane essential fatty acids and increased lipid peroxides in schizophrenia at the never-medicated first-episode of psychosis and after years of treatment with antipsychotics. Schizophr Res. 2002;58(1):1-10. [pmid: 12363384].
Langan S M, Farrell P M. Vitamin E, vitamin A and essential fatty acid status of patients hospitalized for anorexia nervosa. Am J Clin Nutr. 1985;41(5):1054-1060. [pmid: 3993608].
Leask S J, Done D J, Crow T J, Richards M, Jones P B. No association between breast-feeding and adult psychosis in two national birth cohorts. Br J Psychiatry. 2000;177:218-221. [pmid: 11040881].
Llorente A M, Jensen C L, Voigt R G, Fraley J K, Berretta M C, Heird W C. Effect of maternal docosahexaenoic acid supplementation on postpartum depression and information processing. Am J Obstet Gynecol. 2003;188(5):1348-1353. [pmid: 12748510].
Maes M, Smith R, Christophe A, Cosyns P, Desnyder R, Meltzer H. Fatty acid composition in major depression: decreased omega 3 fractions in cholesteryl esters and increased C20: 4 omega 6/C20:5 omega 3 ratio in cholesteryl esters and phospholipids. J Affect Disord. 1996;38(1):35-46. [pmid: 8735157].
Maes M, Christophe A, Delanghe J, Altamura C, Neels H, Meltzer H Y. Lowered omega3 polyunsaturated fatty acids in serum phospholipids and cholesteryl esters of depressed patients. Psychiatry Res. 1999;85(3):275-291. [pmid: 10333380].
Mahadik S P, Mukherjee S, Horrobin D F, Jenkins K, Correnti E E, Scheffer R E. Plasma membrane phospholipid fatty acid composition of cultured skin fibroblasts from schizophrenic patients: comparison with bipolar patients and normal subjects. Psychiatry Res. 1996;63(23):133-142. [pmid: 8878309].
Marangell L B, Martinez J M, Zboyan H A, Kertz B, Kim H F, Puryear L J. A double-blind, placebo-controlled study of the omega-3 fatty acid docosahexaenoic acid in the treatment of major depression. Am J Psychiatry. 2003;160(5):996-998. [pmid: 12727707].
McCreadie R G. The Nithsdale Schizophrenia Surveys. 16. Breast-feeding and schizophrenia: preliminary results and hypotheses. Br J Psychiatry. 1997;170:334-337. [pmid: 9246251].
Mellor J E, Laugharne J D E, Peet M. Omega-3 fatty acid supplementation in schizophrenic patients. Hum psychopharm. 1996;11(1):39-46.
Mitchell E A, Lewis S, Cutler D R. Essential fatty acids and maladjusted behaviour in children. Prostaglandins Leukot Med. 1983;12(3):281-287. [pmid: 6581484].
Mitchell E A, Aman M G, Turbott S H, Manku M. Clinical characteristics and serum essential fatty acid levels in hyperactive children. Clin Pediatr (Phila). 1987;26(8):406-411. [pmid: 2439249].
Nemets B, Stahl Z, Belmaker R H. Addition of omega-3 fatty acid to maintenance medication treatment for recurrent unipolar depressive disorder. Am J Psychiatry. 2002;159(3):477-479. [pmid: 11870016].
Ness A R, Gallacher J E J, Bennett P D, Gunnell D J, Rogers P J, Kessler D, et al. Advice to eat fish and mood: A randomised controlled trial in men with angina. Nutr Neurosci. 2003;6(1):63-65. [pmid: 12608739].
Noaghiul S, Hibbeln J R. Cross-national comparisons of seafood consumption and rates of bipolar disorders. Am J Psychiatry. 2003;160(12):2222-2227. [pmid: 14638594].
Obi F O, Nwanze E A. Fatty acid profiles in mental disease. Part 1. Linolenate variations in schizophrenia. J Neurol Sci. 1979;43(3):447-454. [pmid: 521838].
Peet M, Poole J, Laugharne J. Infant feeding and the development of schizophrenia. Schizophr Res. 1997;24:255-256.
Peet M, Laugharne J, Rangarajan N, Horrobin D, Reynolds G. Depleted red cell membrane essential fatty acids in drug-treated schizophrenic patients. J Psychiatr Res. 1995;29(3):227-232. [pmid: 7473298].
Peet M, Murphy B, Shay J, Horrobin D. Depletion of omega-3 fatty acid levels in red blood cell membranes of depressive patients. Biol Psychiatry. 1998;43(5):315-319. [pmid: 9513745].
Peet M, Mellor J. Double-blind, placebo controlled trial of N3 polysaturated fatty acids as an adjunct to neuroleptics. Schizophr Res. 1998;29:160-161.
Peet M. Eicosapentaenoic acid (EPA) is effective in relieving schizophrenic symptoms in patients on clozapine. Schizophrenia Research. April 28 - May 2, 2001.
Peet M, Brind J, Ramchand C N, Shah S, Vankar G K. Two double-blind placebo-controlled pilot studies of eicosapentaenoic acid in the treatment of schizophrenia. Schizophr Res. 2001;49(3):243-251. [pmid: 11356585].
Peet M, Horrobin D F. A dose-ranging study of the effects of ethyl-eicosapentaenoate in patients with ongoing depression despite apparently adequate treatment with standard drugs. Arch Gen Psychiatry. 2002;59(10):913-919. [pmid: 12365878].
Peet M, Horrobin D F. Study Group E-EM. A dose-ranging exploratory study of the effects of ethyl-eicosapentaenoate in patients with persistent schizophrenic symptoms. J Psychiatr Res. 2002;36(1):7-18. [pmid: 11755456].
Peet M. International variations in the outcome of schizophrenia and the prevalence of depression in relation to national dietary practices: an ecological analysis. Br J Psychiatry. 2004;184:404-408. [pmid: 15123503].
Ranjekar P K, Hinge A, Hegde M V, Ghate M, Kale A, Sitasawad S, et al. Decreased antioxidant enzymes and membrane essential polyunsaturated fatty acids in schizophrenic and bipolar mood disorder patients. Psychiatry Res. 2003;121(2):109-122. [pmid: 14656446].
Richardson A J, Puri B K. A randomized double-blind, placebo-controlled study of the effects of supplementation with highly unsaturated fatty acids on ADHD-related symptoms in children with specific learning difficulties. Prog Neuropsychopharmacol Biol Psychiatry. 2002;26(2):233-239. [pmid: 11817499].
Sasaki T, Okazaki Y, Akaho R, Masui K, Harada S, Lee I, et al. Type of feeding during infancy and later development of schizophrenia. Schizophr Res. 2000;42(1):79-82. [pmid: 10706988].
Shah S, Ramchand C N, Peet M. Double-blind pilot study of eicosapentaenoic acid (EPC) as the sole treatment for schizophrenia. Schizophr Res. 2000;41(1):27.
Silvers K M, Scott K M. Fish consumption and self-reported physical and mental health status. Public Health Nutr. 2002;5(3):427-431. [pmid: 12003654].
Stevens L, Zhang W, Peck L, Kuczek T, Grevstad N, Mahon A, et al. EFA supplementation in children with inattention, hyperactivity, and other disruptive behaviors. Lipids. 2003;38(10):1007-1021. [pmid: 14669965].
Stevens L J, Zentall S S, Deck J L, Abate M L, Watkins B A, Lipp S R, et al. Essential fatty acid metabolism in boys with attention-deficit hyperactivity disorder. Am J Clin Nutr. 1995;62(4):761-768. [pmid: 7572706].
Stoll A L, Severus W E, Freeman M P, Rueter S, Zboyan H A, Diamond E, et al. Omega 3 fatty acids in bipolar disorder: a preliminary double-blind, placebo-controlled trial.[comment]. Arch Gen Psychiatry. 1999;56(5):407-412. [pmid: 10232294].
Su K P, Huang S Y, Chiu C C, Shen W W. Omega-3 fatty acids in major depressive disorder. A preliminary double-blind, placebo-controlled trial. Eur Neuropsychopharmacol. 2003;13(4):267-271. [pmid: 12888186].
Suzuki S, Akechi T, Kobayashi M, Taniguchi K, Goto K, Sasaki S, et al. Daily omega-3 fatty acid intake and depression in Japanese patients with newly diagnosed lung cancer. Br J Cancer. 2004;90(4):787-793. [pmid: 14970854].
Tanskanen A, Hibbeln J R, Hintikka J, Haatainen K, Honkalampi K, Viinamaki H. Fish consumption, depression, and suicidality in a general population.[comment]. Arch Gen Psychiatry. 2001;58(5):512-513. [pmid: 11343534].
Tanskanen A, Hibbeln J R, Tuomilehto J, Uutela A, Haukkala A, Viinamaki H, et al. Fish consumption and depressive symptoms in the general population in Finland. Psychiatr Serv. 2001;52(4):529-531. [pmid: 11274502].
Tiemeier H, van Tuijl H R, Hofman A, Kiliaan A J, Breteler M M B. Plasma fatty acid composition and depression are associated in the elderly: the Rotterdam Study. Am J Clin Nutr. 2003;78(1):40-46. [pmid: 12816769].
Vaddadi K S, Gilleard C J, Soosai E, Polonowita A K, Gibson R A, Burrows G D. Schizophrenia, tardive dyskinesia and essential fatty acids. Schizophr Res. 1996;20(3):287-294. [pmid: 8827855].
Vancassel S, Durand G, Barthelemy C, Lejeune B, Martineau J, Guilloteau D, et al. Plasma fatty acid levels in autistic children. Prostaglandins Leukot Essent Fatty Acids. 2001;65(1):1-7. [pmid: 11487301].
Virkkunen M E, Horrobin D F, Jenkins D K, Manku M S. Plasma phospholipid essential fatty acids and prostaglandins in alcoholic, habitually violent, and impulsive offenders. Biol Psychiatry. 1987;22(9):1087-1096. [pmid: 2958095].
Voigt R G, Llorente A M, Jensen C L, Fraley J K, Berretta M C, Heird W C. A randomized, double-blind, placebo-controlled trial of docosahexaenoic acid supplementation in children with attention-deficit/hyperactivity disorder.[comment]. J Pediatr. 2001;139(2):189-196. [pmid: 11487742].
Wardle J, Rogers P, Judd P, Taylor M A, Rapoport L, Green M, et al. Randomized trial of the effects of cholesterol-lowering dietary treatment on psychological function. Am J Med. 2000;108(7):547-553. [pmid: 10806283].
Weissman M M, Bland R C, Canino G J, Faravelli C, Greenwald S, Hwu H G, et al. Cross-national epidemiology of major depression and bipolar disorder. JAMA. 1996;276(4):293-299. [pmid: 8656541].
Woo J, Ho S C, Yu A L M. Lifestyle factors and health outcomes in elderly Hong Kong Chinese aged 70 years and over. Gerontology. 2002;48(4):234-240. [pmid: 12053113].
Yang S C, Chiu W C, Chen J R, Lee J C, Shieh M J. Dietary intakes of 4–8 years old children with attention-deficit hyperactivity disorder. Nutr Sci J. 1999;24(2):153-165.
Yao J, Stanley J A, Reddy R D, Keshavan M S, Pettegrew J W. Correlations between peripheral polyunsaturated fatty acid content and in vivo membrane phospholipid metabolites. Biol Psychiatry. 2002;52(8):823-830. [pmid: 12372654].
Zanarini M C, Frankenburg F R. omega-3 Fatty acid treatment of women with borderline personality disorder: a double-blind, placebo-controlled pilot study. Am J Psychiatry. 2003;160(1):167-169. [pmid: 12505817].