# Listing of Excluded Studies at Level 3 Screening

Adams P B, Lawson S, Sanigorski A et al. Arachidonic acid to eicosapentaenoic acid ratio in blood correlates positively with clinical symptoms of depression. Lipids 1996;31 Suppl(S157):-S161. Uncontrolled study.
Alling C, Aspenstrom G, Dencker S J, et al. Essential fatty acids in chronic alcoholism. Acta Medica Scandinavica - Supplementum. 1979;631(1):38. Uncontrolled study.
Assies J, Lok A, Bockting C L, et al. Fatty acids and homocysteine levels in patients with recurrent depression: An explorative pilot study. Prostaglandins Leukotrienes & Essential Fatty Acids. 2004;70(4):349-356. Uncontrolled study.
Bell J G, Sargent J R, Tocher D R, et al. Red blood cell fatty acid compositions in a patient with autistic spectrum disorder: A characteristic abnormality in neurodevelopmental disorders?. Prostaglandins Leukotrienes & Essential Fatty Acids. 2000;63(12):21-25. Uncontrolled study.
Buydens-Branchey M, McMakin D L, Hibbeln J R. Polyunsaturated fatty acid status and relapse vulnerability in cocaine addicts. Psychiatry Res. 2003;120(1):29-35. Uncontrolled study. [pmid: 14500111].
Chiu C C, Huang S Y, Shen W W, et al. Omega-3 fatty acids for depression in pregnancy.[erratum appears in Am J Psychiatry. 2003 Apr;160(4):810]. Am J Psychiatry. 2003;160(2):385. Uncontrolled study. [pmid: 12562593].
De Vriese S R, Christophe A B, Maes M. Lowered serum n-3 polyunsaturated fatty acid (PUFA) levels predict the occurrence of postpartum depression: Further evidence that lowered n-PUFAs are related to major depression. Life Sci. 2003;73(25):3181-3187. Uncontrolled study. [pmid: 14561523].
Holman R T, Johnson S. Changes in essential fatty acid profile of serum phospholipids in human disease. Prog Lipid Res. 1981;20(67):73. Uncontrolled study.
Hummel B, Dittmann S, Forsthoff A, et al. Clozapine as add-on medication in the maintenance treatment of bipolar and schizoaffective disorders. Neuropsychobiology. 2002;45(suppl 1):37-42. Uncontrolled study. [pmid: 11893876].
Johnson S M, Hollander E. Evidence that eicosapentaenoic acid is effective in treating autism. Hillside J Clin Psychiatry. 2003;64(7):848-849. Uncontrolled study.
Kinrys G. Hypomania associated with omega3 fatty acids.[comment]. Arch Gen Psychiatry. 2000;57(7):715-716. Uncontrolled study. [pmid: 10891045].
Mamalakis G, Tornaritis M, Kafatos A. Depression and adipose essential polyunsaturated fatty acids. Prostaglandins, Leukotrienes and Essential Fatty Acids. 2002;67(5):311-318. Uncontrolled study.
Mellor J E, Laugharne J D, Peet M. Schizophrenic symptoms and dietary intake of n-3 fatty acids. Schizophr Res. 1995;18(1):85-86. Uncontrolled study. [pmid: 8929766].
Osborne R H, Sinclair A J. Red blood cell polyunsaturated fatty acid n-6 to n-3 ratios correlate with anxiety and depression in women with breast cancer. Proceedings of the Nutrition Society of Australia 1995;19(53; 8 ref.). Uncontrolled study.
Puri B K, Richardson A J. Sustained remission of positive and negative symptoms of schizophrenia following treatment with eicosapentaenoic acid. Arch Gen Psychiatry. 1998;55(2):188-189. Uncontrolled study. [pmid: 9477938].
Puri B K, Counsell S J, Hamilton G, et al. Eicosapentaenoic acid in treatment-resistant depression associated with symptom remission, structural brain changes and reduced neuronal phospholipid turnover. Int J Clin Pract. 2001;55(8):560-563. Uncontrolled study. [pmid: 11695079].
Puri B K, Counsell S J, Richardson A J, et al. Eicosapentaenoic acid in treatment-resistant depression. Arch Gen Psychiatry. 2002;59(1):91-92. Uncontrolled study. [pmid: 11779290].
Puri B K, Richardson A J, Horrobin D F, et al. Eicosapentaenoic acid treatment in schizophrenia associated with symptom remission, normalisation of blood fatty acids, reduced neuronal membrane phospholipid turnover and structural brain changes. Int J Clin Pract. 2000;54(1):57-63. Uncontrolled study. [pmid: 10750263].
Richardson A J, Cyhlarova E, Ross M A. Omega-3 and omega-6 fatty acid concentrations in red blood cell membranes relate to schizotypal traits in healthy adults. Prostaglandins Leukotrienes & Essential Fatty Acids. 2003;69(6):461-466. Uncontrolled study.
Richardson A J, Easton T, Puri B K. Red cell and plasma fatty acid changes accompanying symptom remission in a patient with schizophrenia treated with eicosapentaenoic acid. Eur Neuropsychopharmacol. 2000;10(3):189-193. Uncontrolled study. [pmid: 10793321].
Richardson A J, Easton T, Gruzelier J H, et al. Laterality changes accompanying symptom remission in schizophrenia following treatment with eicosapentaenoic acid. Int J Psychophysiol. 1999;34(3):333-339. Uncontrolled study. [pmid: 10610057].
Shah S, Vankar G, Telang S D, Ramchand C N, et al. Eicosapentaenoic acid (EPA) as an adjunct in the treatment of schizophrenia. Schizophr Res. 1998;29(158):158. Uncontrolled study.
Snyder Dollie C. Orthomolecular, nutritional and EPA therapy: A winning combination in the treatment of schizophrenia: A parent's testimonial. Journal of Orthomolecular Medicine. 2003;18(1):33-40. Uncontrolled study.
Stevens L J, Zentall S S, Abate M L, et al. Omega-3 fatty acids in boys with behavior, learning, and health problems. Physiol Behav. 1996;59(45):915-920. Uncontrolled study. [pmid: 8778886].
Su K P, Shen W W, Huang S Y. Omega-3 fatty acids as a psychotherapeutic agent for a pregnant schizophrenic patient. Eur Neuropsychopharmacol. 2001;11(4):295-299. Uncontrolled study. [pmid: 11532384].
Woodbury M M, Woodbury M A. Neuropsychiatric development: two case reports about the use of dietary fish oils and/or choline supplementation in children. J Am Coll Nutr. 1993;12(3):239-245. Uncontrolled study. [pmid: 7691914].
Wright Jonathan. Treatment of chronic anxiety and associated physical complaints with niacinamide and essential fatty acids: Two cases. Journal of Orthomolecular Medicine. 1992;7(3):182-186. Uncontrolled study.