# Listing of Excluded Studies at Level 2 Screening

Adachi J, Hojo K, Ueno Y, et al. Identification of cholesta-3,5-dien-7-one by gas chromatography-mass spectrometry in the erythrocyte membrane of alcoholic patients. Alcoholism: Clinical & Experimental Research. 1996;20(Suppl 1):51A-55A. Not related to predefined mental health outcomes.
Aman M G, Mitchell E A, Turbott S H. The effects of essential fatty acid supplementation by Efamol in hyperactive children. J Abnorm Child Psychol. 1987;15(1):75-90. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 3553274].
Angus F. Functional foods. Chemistry and Industry 2002;No.6, 14–16; 5 ref.(14):-16. Not a first publication of empirical evidence.
Arnold L E, Pinkham S M, Votolato N. Does zinc moderate essential fatty acid and amphetamine treatment of attention-deficit/hyperactivity disorder?. Journal of Child & Adolescent Psychopharmacology. 2000;10(2):111-117. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 10933121].
Baonville H. A case of post-operative tetany with grave mental disorder. [NonEnglish]. Ann Med Psychol (Paris). 1934;92:26-40. Editions Elsevier, France(26):-40. Not related to predefined mental health outcomes.
Barak Y, Kimhi R, Bodner E, et al. Treatment of depression in patients with multiple sclerosis. Proc Aust Assoc Neurol. 1998;4(2):99-104. Not a first publication of empirical evidence.
Bates C E. Racially determined abnormal essential fatty acid and prostaglandin metabolism and food allergies linked to autoimmune, inflammatory, and psychiatric disorders among Coastal British Columbia Indians. Med Hypotheses. 1988;25(2):103-109. Not a first publication of empirical evidence. [pmid: 3357452].
Bentzen A J, Jacobsen P A, Munch-Petersen S. An investigation of the platelet adhesiveness by Hellem's method in elderly patients under longterm psychiatric care, on a controlled diet with an unsaturated fatty acid load. An evaluation of the accuracy and clinical reproductibility of the method. Gerontol Clin (Basel). 1972;14(4):217-234. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 4564276].
Blondel-Hill E, Shafran S D. Treatment of the chronic fatigue syndrome: A review and practical guide. Drugs. 1993;46(4):639-651. Not a first publication of empirical evidence. [pmid: 7506650].
Bosch X. Fish consumption and depression [12]. Lancet. 1998;352(9121):71-72. Not a first publication of empirical evidence. [pmid: 9800785].
Bowen D J, Kestin M, McTiernan A, et al. Effects of dietary fat intervention on mental health in women. Cancer Epidemiol Biomarkers Prev. 1995;4(5):555-559. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 7549814].
Brown Richard P. Herbs and nutrients in the treatment of depression, anxiety, insomnia, migraine, and obesity. Journal of Psychiatric Practice. 2001;7(2):75-91. Not a first publication of empirical evidence. [pmid: 15990509].
Calabrese J R, Rapport D J, Shelton M D. Fish oils and bipolar disorder: a promising but untested treatment.[comment]. Arch Gen Psychiatry. 1999;56(5):413-414. Not a first publication of empirical evidence. [pmid: 10232295].
Chajès V, Bougnoux P. Omega-6/Omega-3 Polyunsaturated Fatty Acid Ratio and Cancer. World Rev Nutr Diet 2003;(9):133–151. Not a first publication of empirical evidence.
Chiu C C, Huang S Y, Su K P. Omega-3 polyunsaturated fatty acids for postpartum depression.[comment]. American Journal of Obstetrics & Gynecology. 2004;190(2):582-583. Not a first publication of empirical evidence. [pmid: 15002412].
Cho W K, Stollerman G H. Chronic fatigue syndrome. [Review][10 refs]. Hospital Practice (Office Edition) 227;27(9):221–224. Not a first publication of empirical evidence.
Cleland L G, James M J, Proudman S M. Omega-6/Omega-3 Fatty Acids and Arthritis. World Rev Nutr Diet 2003;(10):152–168. Not a first publication of empirical evidence.
Clough J D. Fish oil is no snake oil. Cleve Clin J Med. 2004;71(3):174. Not a first publication of empirical evidence. [pmid: 15055241].
Cohen J H, Kristal A R, Neumark Sztainer D, et al. Psychological distress is associated with unhealthful dietary practices. J Am Diet Assoc. 2002;102(5):699-703. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12008997].
Corrigan F M. Suicide, depression and immunological resignation [ 5]. Ir J Psychol Med. 1998;15(2):78-79. Not a first publication of empirical evidence.
Cosby N, Haak-Frendscho M. Fourth Annual Promega Neurosciences Symposium: Genetic and Environmental Interactions in Neurodegeneration Los Angeles, CA, USA, November 7, 1998. CNS Drug Rev. 1999;5(1):83-90. Not a first publication of empirical evidence.
Cott J, Hibbeln J R. Lack of seasonal mood change in Icelanders.[comment]. Am J Psychiatry. 2001;158(2):328. Not a first publication of empirical evidence. [pmid: 11156835].
Das U N. Long-chain polyunsaturated fatty acids in the growth and development of the brain and memory. Adv Nutr Res. 2003;19(1):62-65. Not a first publication of empirical evidence.
de Lorgeril M, Salen P. Dietary Prevention of Coronary Heart Disease: Focus on Omega-6/Omega-3 Essential Fatty Acid Balance. World Rev Nutr Diet. 2003;(4):57-73. Not a first publication of empirical evidence. [pmid: 14579683].
do Nascimento C M, Oyama L M. Long-chain polyunsaturated fatty acids essential for brain growth and development.[comment]. Adv Nutr Res. 2003;19(1):66. Not a first publication of empirical evidence.
Dubnov G, Berry E M. Omega-6/Omega-3 Fatty Acid Ratio. The Israeli Paradox. 2003;(6):81-91. Not a first publication of empirical evidence.
Eriksen S A. [Do fish fats and vitamins have any effect in psychoses?]. [Norwegian]. Tidsskr Nor Laegeforen 3-6-2003;123(5):674. Not a first publication of empirical evidence.
Eugene Arnold L, Kleykamp D, Votolato N, et al. Potential link between dietary intake of fatty acids and behavior: Pilot exploration of serum lipids in attention-deficit hyperactivity disorder. Journal of Child & Adolescent Psychopharmacology. 1994;4(3):171-182. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Falciglia G A, Couch S C, Gribble L S, et al. Food neophobia in childhood affects dietary variety. J Am Diet Assoc. 2000;100(12):1474-1481. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 11138439].
Fava Maurizio. Docosahexanoic acid in the prevention and treatment of depression. Mischoulon, David (Ed); Rosenbaum, Jerrold F 2002; EdA, US-PsycInfo/alternative medicine/Fatty Acids/major depression/psychopharmacology. Not a first publication of empirical evidence.
Fish oil. Altern Med Rev 2000;5(6):576–580. Not a first publication of empirical evidence.
Glen I, Skinner F, Glen E, et al. The role of essential fatty acids in alcohol dependence and tissue damage. [Review] [29 refs]. Alcoholism: Clinical & Experimental Research. 1987;11(1):37-41. Not a first publication of empirical evidence.
Gnanadesikan M, Freeman M P, Gelenberg A J. Alternatives to lithium and divalproex in the maintenance treatment of bipolar disorder. [Review] [132 refs]. Bipolar Disord. 2003;5(3):203-216. Not a first publication of empirical evidence. [pmid: 12780874].
Greatrex J C, Drasdo N, Dresser K. Scotopic sensitivity in dyslexia and requirements for DHA supplementation. Lancet. 2000;355(9213):1429-1430. Not related to predefined mental health outcomes. [pmid: 10791530].
Hamazaki T, Okuyama H. The Japan Society for Lipid Nutrition Recommends to Reduce the Intake of Linoleic Acid. 2003;(8):109–132. Not a first publication of empirical evidence.
Hamazaki T, Itomura M, Sawazaki S, et al. Anti-stress effects of DHA. Biofactors. 2000;13(14):41-45. Not a first publication of empirical evidence. [pmid: 11237197].
Hamazaki T, Sawazaki S, Itomura M et al. Effect of docosahexaenoic acid on hostility. 4th Congress of the International Society for the Study of Fatty Acids and Lipids (ISSFAL 2000) 6-4-2000;2000, Tsukuba, Japan. Fatty-acids-and-lipids(-new-findings. 2001):47–52. Not a first publication of empirical evidence.
Hamazaki T, Sawazaki S, Nagasawa T et al. Administration of docosahexaenoic acid influences behavior and plasma catecholamine levels at times of psychological stress. Lipids 1999;34 Suppl(S33):-S37. Not a first publication of empirical evidence.
Hernell O, Holmgren G, Jagell S F, et al. Suspected faulty essential fatty acid metabolism in Sjogren-Larsson syndrome. Pediatr Res. 1982;16(1):45-49. Not related to predefined mental health outcomes. [pmid: 7070875].
Hibbeln J R, Salem N. Risks of cholesterol-lowering therapies. Biol Psychiatry. 1996;40(7):686-687. Not a first publication of empirical evidence. [pmid: 8886308].
Hills H C. Good food: grain-free, milk-free. undated, 123pp 123ppp. Not a first publication of empirical evidence.
Horrobin D F. Food, micronutrients, and psychiatry. Int Psychogeriatr. 2002;14(4):331-334. Not a first publication of empirical evidence. [pmid: 12670055].
Horrobin D F. The possible roles of prostaglandin E1 and of essential fatty acids in mania, depression and alcoholism. Prog Lipid Res. 1981;20(539):541. Not a first publication of empirical evidence.
Horrobin D F, Manku M S, Hillman H, et al. Fatty acid levels in the brains of schizophrenics and normal controls. Biol Psychiatry. 1991;30(8):795-805. Not involving human participants. [pmid: 1751622].
Hoyt W D, Hamilton S B, Rickard K M. The effects of dietary fat and caloric content on the body-size estimates of Anorexic Profile and normal college students. J Clin Psychol. 2003;59(1):85-91. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12508333].
Joy C B, Mumby-Croft R, Joy L A. Polyunsaturated fatty acid (fish or evening primrose oil) for schizophrenia. Schweiz Rundsch Med Prax. 2001;90(12):512-513. Not a first publication of empirical evidence.
Kendler B S. International Conference on Human Functioning, Wichita, Kansas, 22–24 September 2000. Adv Nutr Res. 2001;17(6):508-511. Not a first publication of empirical evidence.
Kidd P M. An approach to the nutritional management of autism. Alternative Therapies in Health & Medicine 2003;9(5). Not a first publication of empirical evidence.
Kiriakova N, Kiriakov A, Schneider E, et al. Therapeutic effect of essential phospholipids on functional sexual disorders in males. Journal of the European Academy of Dermatology & Venereology. 1998;11(2):191-193. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 9784056].
Laugharne J D, Mellor J E, Peet M. Fatty acids and schizophrenia. Lipids 1996;31 Suppl(S163):-S165. Not a first publication of empirical evidence.
Leonard B E. Possible relationships between thiamine, carnitine, polyunsaturated fatty acids and the neurotoxicity of alcohol. Alcohol & Alcoholism. 1984;19(2):97-99. Not a first publication of empirical evidence. [pmid: 6093831].
Lesperance F, Frasure-Smith N. Depression and coronary artery disease: Time to move from observation to trials. CMAJ: Canadian Medical Association Journal. 2003;168(5):570-571. Not a first publication of empirical evidence.
Lopez-Alarcon M, Villalpando S, Garza C. Illness-induced anorexia in the breast-fed infants. Role of IL-1beta and TNF-alpha. Advances in Experimental Medicine & Biology. 2000;478(421):422. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Mahadik S P, Khan M M, Evans D R, et al. Elevated plasma level of apolipoprotein D in schizophrenia and its treatment and outcome. Schizophr Res. 2002;58(1):55-62. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12363390].
Mahadik S P, Shendarkar N S, Scheffer R E, et al. Utilization of precursor essential fatty acids in culture by skin fibroblasts from schizophrenic patients and normal controls. Prostaglandins Leukotrienes & Essential Fatty Acids. 1996;55(12):65-70. Not related to predefined mental health outcomes.
Martinez M, Vazquez E, Garcia-Silva Ma T, et al. Treatment of generalized peroxisomal disorders with docosahexaenoic acid ethyl ester. Rev Neurol. 1999;28(suppl 1):S59-S64. Not related to predefined mental health outcomes. [pmid: 10778491].
Mason P. Could food supplements help children with common learning difficulties?. Can Pharm J. 2002;268(7199):713-714. Not a first publication of empirical evidence.
McGrath-Hanna N K, Greene D M, Tavernier R J, et al. Diet and mental health in the Arctic: is diet an important risk factor for mental health in circumpolar peoples?--a review. [Review] [169 refs]. Int J Circumpolar Health. 2003;62(3):228-241. Not a first publication of empirical evidence. [pmid: 14594198].
McIntosh A, Lawrie S. Cross-national differences in diet, the outcome of schizophrenia and the prevalence of depression: you are (associated with) what you eat. Br J Psychiatry 2004;184381–382. Not a first publication of empirical evidence.
Mehta V R. ‘Side effects of eicosapentaenoic acid and docosahexaenoic acid (maxepa)’. J Assoc Physicians India. 1992;40(7):486. Not related to predefined mental health outcomes. [pmid: 1484043].
Meletis C D, Bramwell B. Attention-deficit/hyperactivity disorder in children: Nutritional perspectives. Alternative & Complementary Therapies. 2000;6(6):315-320. Not a first publication of empirical evidence.
Minerva. Br Med J. 1996;312(7026):322. Not a first publication of empirical evidence.
Mischoulon D, Rosenbaum J F. The use of natural remedies in psychiatry: A commentary. Harv Rev Psychiatry. 1999;6(5):279-283. Not a first publication of empirical evidence. [pmid: 10372293].
Morrow J D, Tapper A R, Zackert W E, et al. Formation of novel isoprostane-like compounds from docosahexaenoic acid. Advances in Experimental Medicine & Biology. 1999;469(343):347. Not involving human participants.
Noetzel M, Moser H, Salem N, et al. Brain uptake and utilization of fatty acids: Applications to peroxisomal biogenesis disorders (An International Workshop): Roundtable discussion of session 4: The roles of DHA in Zellweger syndrome, a representative peroxisomal biogenesis disorder. J Mol Neurosci. 2001;16(23):317-321. Not a first publication of empirical evidence.
Omega-3 fatty acids and bipolar disorder. Neuroscientist 1999;5(6):349. Not a first publication of empirical evidence.
Omega-3 mania. Healthnews 2004;10(4):5 Not a first publication of empirical evidence.
Psychoses, neuroses and omega-3 essential fatty acids - case studies and an hypothesis. International Clinical Nutrition Review 1984;4(2):87–89. Not a first publication of empirical evidence.
Nova E, Varela P, Lopez-Vidriero I, et al. A one-year follow-up study in anorexia nervosa. Dietary pattern and anthropometrical evolution. Eur J Clin Nutr. 2001;55(7):547-554. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 11464228].
Oken R J. Obsessive-compulsive disorder: a neuronal membrane phospholipid hypothesis and concomitant therapeutic strategy. Med Hypotheses. 2001;56(4):413-415. Not a first publication of empirical evidence. [pmid: 11339839].
Overgaauw P. [Symposium: fish (fish oils) for head and heart]. [Dutch]. Tijdschr Diergeneeskd. 2003;128(6):191-192. Not a first publication of empirical evidence. [pmid: 12674797].
Ozgocmen S, Catal S A, Ardicoglu O, et al. Effect of omega-3 fatty acids in the management of fibromyalgia syndrome. International Journal of Clinical Pharmacology & Therapeutics. 2000;38(7):362. Not related to predefined mental health outcomes. [pmid: 10919346].
Peet M, Laugharne J, Mellor J. Double-blind trial of N3 fatty acid supplementation in the treatment of schizophrenia.. Schizophr Res 1997;24209 Not a first publication of empirical evidence.
Peet M. Diet, diabetes and schizophrenia: review and hypothesis. British Journal of Psychiatry - Supplementum 2004;47S102–S105. Not a first publication of empirical evidence.
Peet M, Laugharne J D, Mellor J, et al. Essential fatty acid deficiency in erythrocyte membranes from chronic schizophrenic patients, and the clinical effects of dietary supplementation. [Review] [33 refs]. Prostaglandins Leukotrienes & Essential Fatty Acids. 1996;55(12):71-75. Not a first publication of empirical evidence.
Pella D, Dubnov G, Singh R B, et al. Effects of an Indo-Mediterranean Diet on the Omega-6/Omega-3 Ratio in Patients at High Risk of Coronary Artery Disease: The Indian Paradox. World Rev Nutr Diet. 2003;(5):74-80. Not a first publication of empirical evidence.
Pfeiffer C C. Extra nutrients and mental illness. Biol Psychiatry. 1981;16(9):797-799. Not a first publication of empirical evidence. [pmid: 7295841].
Pridmore S, De Leo D, Ravi Shankar B, et al. Preventing suicide (multiple letters) [4]. Br J Psychiatry Suppl. 2003;182(APR.):364-366. Not a first publication of empirical evidence.
Probsting L. [Lack of appetite in childhood and its treatment with Jecorol]. [German]. Z Allgemeinmed. 1969;45(32):1542-1543. Not related to predefined mental health outcomes. [pmid: 5263684].
Puri B K, Richardson A D. The effects of olive oil on omega3 fatty acids and mood disorders.[comment]. Arch Gen Psychiatry. 2000;57(7):715. Not a first publication of empirical evidence.
Rapoport S I, Bosetti F. Do lithium and anticonvulsants target the brain arachidonic acid cascade in bipolar disorder?. [Review] [87 refs]. Arch Gen Psychiatry. 2002;59(7):592-596. Not involving human participants. [pmid: 12090811].
Raymond N C, Neumeyer B, Warren C S, et al. Energy intake patterns in obese women with binge eating disorder. Obes Res. 2003;11(7):869-879. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 12855757].
Richardson B. Salmon in a psychiatric hospital group. 4. The Salmon unit in subnormality. Nursing Mirror & Midwives Journal. 1970;131(24):23-24. Not a first publication of empirical evidence. [pmid: 5203990].
Riles S. New research on the treatment of schizophrenia. Nurs Times 93(52):47-1998. Not a first publication of empirical evidence.
Rimland B. Secretin: real therapeutic potential (response)[comment]. Journal of Pediatric Gastroenterology & Nutrition. 2000;30(2):113-114. Not a first publication of empirical evidence. [pmid: 10697127].
Ringskog S. [Omega-3 fatty acids against schizophrenia?!]. [Swedish]. Lakartidningen. 1998;95(13):1384. -Medline/Fatty Acids/Omega-3/ad [Administration & Dosage]/Human/Schizophrenia/dt [Drug Therapy]. Not a first publication of empirical evidence. [pmid: 9560963].
Robertson H L. Nutrition symposium, ‘Biochemical and molecular basis of disease’. South African Journal of Clinical Nutrition. 2002;15(3):101-102. Not a first publication of empirical evidence.
Robinson F. Freedom foods. Food Nutr Bull. 2002;27(4):225-226. Not a first publication of empirical evidence.
Ross B M, McKenzie I, Glen I, et al. Increased levels of ethane, a non-invasive marker of n-3 fatty acid oxidation, in breath of children with attention deficit hyperactivity disorder. Nutr Neurosci. 2003;6(5):277-281. Not related to predefined mental health outcomes. [pmid: 14609313].
Rudin D O. The major psychoses and neuroses as omega-3 essential fatty acid deficiency syndrome: substrate pellagra. Biol Psychiatry. 1981;16(9):837-848. Not related to predefined mental health outcomes. [pmid: 7028146].
Saito H. SHRSP: A novel field of study. Biogenic Amines. 2003;17(46):221-230. Not a first publication of empirical evidence.
Salem N, Moriguchi T, Greiner R S, et al. Alterations in brain function after loss of docosahexaenoate due to dietary restriction of n-3 fatty acids. J Mol Neurosci. 2001;16(23):299-307. Not involving human participants. [pmid: 11478385].
Saugstad L F. Suicide and resilience: The role of mental illness, psychotropic medication and abuse. Med Sci Monit. 2000;7(3):169-179. Not a first publication of empirical evidence.
Saugstad L F. Our neglect of the normal variation is linked to a reluctance to accept multifactorial inheritance and the role of environment. Med Hypotheses. 2003;60(2):181-187. Not a first publication of empirical evidence. [pmid: 12606232].
Saugstad L F. Marine fat and brain function in manic-depressive psychosis and schizophrenia: circumstantial evidence for a 2nd aquatic period. Nutrition & Health. 2002;16(1):11-12. Not a first publication of empirical evidence. [pmid: 12083403].
Saugstad L F. Human nature is unique in the mismatch between the usual diet and the need for “food for the brain” (marine fat, DHA). Adding marine fat is beneficial in schizophrenia and manic-depressive psychosis. This underlines brain dysfunction in these neurological disorders is associated with deficient intake of marine fat(DHA). Nutrition & Health. 2002;16(1):41-44. Not a first publication of empirical evidence. [pmid: 12083411].
Sawazaki S, Hamazaki T, Yazawa K, et al. The effect of docosahexaenoic acid on plasma catecholamine concentrations and glucose tolerance during long-lasting psychological stress: a double-blind placebo-controlled study. J Nutr Sci Vitaminol (Tokyo). 1999;45(5):655-665. Not related to predefined mental health outcomes. [pmid: 10683816].
Segarnick D J, Cordasco D M, Rotrosen J. Prostanoid modulation (mediation?) of certain behavioral effects of ethanol. Pharmacology, Biochemistry & Behavior. 1985;23(1):71-75. Not involving human participants.
Seung Kim H F, Weeber E J, Sweatt J D, et al. Inhibitory effects of omega-3 fatty acids on protein kinase C activity in vitro. Mol Psychiatry. 2001;6(2):246-248. Not involving human participants. [pmid: 11317232].
Severus W E, Ahrens B, Stoll A L. Omega-3 fatty acids--the missing link?[comment]. Arch Gen Psychiatry. 1999;56(4):380-381. Not a first publication of empirical evidence. [pmid: 10197836].
Shaldubina A, Nemets B, Bersudsky Y. Lack of effect of eicosapentaenoic acid in the Porsolt forced swimming test model of depression. Acta Neuropsychiatrica. 2002;14(5):203-206. Not involving human participants.
Sidhu K S. Health benefits and potential risks related to consumption of fish or fish oil. Regulatory Toxicology & Pharmacology. 2003;38(3):336-344. Not a first publication of empirical evidence. [pmid: 14623484].
Simopoulos AP. Importance of the Ratio of Omega-6/Omega-3 Essential Fatty Acids: Evolutionary Aspects. 2003;1:1–22. Not a first publication of empirical evidence.
Simopoulos AP, Kang J X. The Importance of Omega-6/Omega-3 Fatty Acid Ratio in Cell Function : The Gene Transfer of Omega-3 Fatty Acid Desaturase. 2003;2:23–36. Not a first publication of empirical evidence.
Sinclair A - J, Murphy K - J, Li D. Marine lipids: Overview ‘News insights and lipid composition of Lyprinol(TM)’. Allerg Immunol (Paris). 2000;32(7):261-271. Not a first publication of empirical evidence. [pmid: 11094639].
Sobczak S, Honig A, Christophe A, et al. Lower high-density lipoprotein cholesterol and increased omega-6 polyunsaturated fatty acids in first-degree relatives of bipolar patients. Psychol Med. 2004;34(1):103-112. Not related to predefined mental health outcomes. [pmid: 14971631].
Stoll A L, Damico K E, Daly B P, et al. Methodological considerations in clinical studies of omega 3 fatty acids in major depression and bipolar disorder. [Review] [32 refs]. World Review of Nutrition & Dietetics. 2001;88(58):67. Not a first publication of empirical evidence.
Stoll Andrew L. The effects of Olive Oil on w3 fatty acids and mood disorders. Arch Gen Psychiatry. 2000;57(7):716-717. Not a first publication of empirical evidence. [pmid: 10891047].
Stoll Andrew L. Omega-3 fatty acids in mood disorders: A review of neurobiologic and clinical actions. Mischoulon, David (Ed); Rosenbaum, Jerrold F 2002; EdA, US-PsycInfo/alternative medicine/bipolar disorder/Fatty Acids/major depression/psychopharmacology. Not a first publication of empirical evidence.
Stordy B J. Dark adaptation, motor skills, docosahexaenoic acid, and dyslexia. Am J Clin Nutr. 2000;71(Suppl 1):323S-326S. Not a first publication of empirical evidence. [pmid: 10617990].
Stordy B J. Benefit of docosahexaenoic acid supplements to dark adaptation in dyslexics.[comment]. Lancet. 1995;346(8971):385. -Medline/Dark Adaptation/de [Drug Effects]/Docosahexaenoic Acids/pd [Pharmacology]/Dyslexia/pp [Physiopathology]/Human. Not related to predefined mental health outcomes. [pmid: 7623560].
Strassnig M, Brar J S, Ganguli R. Nutritional assessment of patients with schizophrenia: a preliminary study. Schizophr. Bull. 2003;29(2):393-397. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Su K P, Shen W W, Huang S Y. Effects of polyunsaturated fatty acids on psychiatric disorders.[comment]. Am J Clin Nutr. 2000;72(5):1241. Not a first publication of empirical evidence. [pmid: 11063464].
Su K P, Shen W W, Huang S Y. Are omega3 fatty acids beneficial in depression but not mania?[comment]. Arch Gen Psychiatry. 2000;57(7):716-717. Not a first publication of empirical evidence. [pmid: 10891047].
Sullivan E A, Shulman K I. Diet and monoamine oxidase inhibitors: a re-examination. [Review] [33 refs]. Canadian Journal of Psychiatry - Revue Canadienne de Psychiatrie 1984;29(8):707–711. No omega-3 fatty acid focus (intervention/exposure or biomarkers).Sullivan P F, Gendall K A, Bulik C M, et al. Elevated total cholesterol in bulimia nervosa. Int J Eat Disord. 1998;23(4):425-432. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 9561433].
Terao T, Soya A, Brunner J, et al. Letter to the editor: Cholesterol, essential fatty acids, and suicide (multiple letters). Pharmacopsychiatry. 2003;36(2):86-88. Not a first publication of empirical evidence. [pmid: 12734769].
Tohen M. Introduction to special issue on treatment of bipolar disorder. Bipolar Disord. 2003;5(3):153-155. Not a first publication of empirical evidence.
Turpeinen O, Miettinen M, Karvonen M J, et al. Dietary prevention of coronary heart disease: long-term experiment. I. Observations on male subjects. Am J Clin Nutr. 1968;21(4):255-276. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 5652949].
Underwood A. Nourishing your brain. Newsweek. 2001;137(17):60-61. Not a first publication of empirical evidence. [pmid: 11338629].
Vaddadi K S. Penicillin and essential fatty acid supplementation in schizophrenia. Prostaglandins & Medicine. 1979;2(1):77-80. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 121601].
Vaddadi K S, Courtney P, Gilleard C J, et al. A double-blind trial of essential fatty acid supplementation in patients with tardive dyskinesia. Psychiatry Res. 1989;27(3):313-323. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 2565585].
Vaddadi K S, Gilleard C J, Mindham R H S, et al. A controlled trial of prostaglandin E1 precursor in chronic neuroleptic resistant schizophrenic patients. Psychopharmacology (Berl). 1986;88(3):362-367. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 2870533].
Vaille-Perret E, Motta C, Jalenques I. Clinical development and evolution of the membrane fluidity in schizophrenic patients treated by neuroleptics. Ann Med Psychol (Paris). 2002;160(1):58-66. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
van der, Merwe C F. Allergy in children with learning disabilities and hyperactivity [3]. S Afr Med J. 2002;92(9):663-664. Not a first publication of empirical evidence.
Wainwright P E. Dietary essential fatty acids and brain function: A developmental perspective on mechanisms. Proc Nutr Soc. 2002;61(1):61-69. Not a first publication of empirical evidence. [pmid: 12002796].
Warner R, Laugharne J, Peet M, et al. Retinal function as a marker for cell membrane omega-3 fatty acid depletion in schizophrenia: a pilot study. Biol Psychiatry. 1999;45(9):1138-1142. Not related to predefined mental health outcomes. [pmid: 10331105].
Wasielewski S. The preventive significance of omega 3 fatty acids. Deutsche Apotheker Zeitung. 1993;133(28):40-42. Not a first publication of empirical evidence.
Weidner G. Improvements in hostility and depression in relation to dietary change and cholesterol lowering. The Family Heart Study. Ann Intern Med. 1992;117(10):820-823. No omega-3 fatty acid focus (intervention/exposure or biomarkers). [pmid: 1416556].
Weston S N. Depression, heart disease and n-3 fatty acids - A fishy tale. British Journal of Cardiology. 2003;10(1):26. Not a first publication of empirical evidence.
Wolkin A, Jordan B, Peselow E, et al. Essential fatty acid supplementation in tardive dyskinesia. Am J Psychiatry. 1986;143(7):912-914. Not a first publication of empirical evidence. [pmid: 3013033].
Wolkin A, Segarnick D, Sierkierski J, et al. Essential fatty acid supplementation during early alcohol abstinence. Alcoholism: Clinical & Experimental Research. 1987;11(1):87-92. No omega-3 fatty acid focus (intervention/exposure or biomarkers).
Woodhouse R J. Report from Great Britain. Pharm Ind. 2003;65(3):242-247. Not a first publication of empirical evidence.
Yao J K, Sistilli C G, Van Kammen D P. Membrane polyunsaturated fatty acids and CSF cytokines in patients with schizophrenia. Prostaglandins Leukotrienes & Essential Fatty Acids. 2003;69(6):429-436. Not related to predefined mental health outcomes.
Yehuda S. Omega-6/Omega-3 Ratio and Brain-Related Functions. 2003;(3):37–56. Not a first publication of empirical evidence.
Young S N. Lifestyle drugs, mood, behaviour and cognition. J Psychiatry Neurosci. 2003;28(2):87-89. Not a first publication of empirical evidence. [pmid: 12670125]. [pmcid: 161729].
Zampelas A, Paschos G, Rallidis L, et al. Linoleic Acid to Alpha-Linolenic Acid Ratio: From Clinical Trials to Inflammatory Markers of Coronary Artery Disease. World Rev Nutr Diet. 2003;(7):92-108. Not a first publication of empirical evidence. [pmid: 14579686].