# References and Included Studies

(1) USDA. Individual fatty acid intakes: Results from the 1995 Continuing Survey of Food Intakes by Individuals (data table set 4). 1995.
(2) Institute of Medicine. Dietary Reference Intakes: Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids (Macronutrition). The National Academies Press, 2002.
(3) Simopoulos A P, Leaf A, Salem N Jr. Essentiality of and recommended dietary intakes for omega-6 and omega-3 fatty acids. Ann Nutr Metab. 1999;43(2):127-130. [pmid: 10436312].
(4) Fallon S Enig MG. “Tripping Lightly Down the Prostaglandin Pathways”. 2001. Price-Pottenger Nutrition Foundation.
(5) Nair J, Vaca C E, Velic I, et al. High dietary omega-6 polyunsaturated fatty acids drastically increase the formation of etheno-DNA base adducts in white blood cells of female subjects. Cancer Epidemiol Biomarkers Prev. 1997;6(8):597-601. [pmid: 9264272].
(6) James MJ, Gibson RA, Cleland LG. Dietary polyunsaturated fatty acids and inflammatory mediator production. [Review][33 refs]. Am J Clin Nutr 2000; 71(1:Suppl):Suppl-8S.
(7) Krummel D. Nutrition in cardiovascular disease. In: Mahan LK, Escot-Sump S, editors. Krause's food, nutrition, and diet therapy. W.B. Saunder Company, 1966.
(8) Omega-3 long-chain polyunsaturated fatty acids and health benefits. Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (Nutriscience), 2003.
(9) Consensus workshop on dietary assessment: nutrition monitoring and tracking the year 2000 objectives. Hyattsville, MD: National Center for Health Statistics, 1994.
(10) USDA National Nutrient Database for Standard Reference. [Release 16] Available at: [underlined: http://www.nal.usda.gov/fnic/foodcomp; Accessed November 3, 2003] 2003. US Department of Agriculture Agricultural Research Service.
(11) National Institute of Mental Health. The numbers count: mental disorders in America. A summary of statistics describing the prevalence of mental disorders in America. Bethesda, MD: National Institute of Mental Health, 2001. NIH Publication No. 01-4584.
(12) The global burden of disease. Geneva: World Health Organization, 1996.
(13) Schachter H M, Pham B, King J, et al. How efficacious and safe is short-acting methylphenidate for the treatment of attention-deficit disorder in children and adolescents? A meta-analysis. CMAJ. 2001;165(11):1475-1488. [pmid: 11762571]. [pmcid: 81663].
(14) Murray C J, Lopez A D. Alternative projections of mortality and disability by cause 1990-2020: Global Burden of Disease Study. Lancet. 1997;349(9064):1498-1504. [pmid: 9167458].
(15) Bruinsma K A, Taren D L. Dieting, essential fatty acid intake, and depression. Nutr Rev. 2000;58(4):98-108. [pmid: 10835899].
(16) Stoll A L, Locke C A, Marangell L B, et al. Omega-3 fatty acids and bipolar disorder: a review. Prostaglandins Leukot Essent Fatty Acids. 1999;60(56):329-337. [pmid: 10471117].
(17) Synopsis of psychiatry. Baltimore: Williams & Wilkins, 1998.
(18) Fava M. Augmentation and combination strategies in treatment-resistant depression. [Review] [101 refs]. J Clin Psychiatry. 2001;62(Suppl 18):4-11. [pmid: 11575733].
(19) Logan A C. Neurobehavioral aspects of omega-3 fatty acids: possible mechanisms and therapeutic value in major depression. [Review] [117 refs]. Altern Med Rev. 2003;8(4):410-425. [pmid: 14653768].
(20) Karno M, Golding J M, Sorenson S B, et al. The epidemiology of obsessive-compulsive disorder in five US communities. Arch Gen Psychiatry. 1988;45(12):1094-1099. [pmid: 3264144].
(21) Practice guideline for the treatment of patients with eating disorders (revision). American Psychiatric Association Work Group on Eating Disorders. Am J Psychiatry 2000; 157(1 Suppl): 1–39.
(22) Sullivan P F. Mortality in anorexia nervosa. Am J Psychiatry. 1995;152(7):1073-1074. [pmid: 7793446].
(23) Clinical practice guideline: treatment of the school-aged child with attention-deficit/hyperactivity disorder. Pediatrics 2001;108(4):1033–1044.
(24) Flannery R B Jr. Repetitively assaultive psychiatric patients: review of published findings, 1978-2001. Psychiatr Q. 2002;73(3):229-237. [pmid: 12143084].
(25) Soloff P, Lis J A, Kelly T, et al. Self-mutilation and suicidal behavior in borderline personality disorder. J Personal Disord. 1994;8(4):257-267.
(26) Koerner K, Linehan M M. Research on dialectical behavior therapy for patients with borderline personality disorder. Psychiatr Clin North Am. 2000;23(1):151-167. [pmid: 10729937].
(27) Haag M. Essential fatty acids and the brain. Can J Psychiatry. 2003;48(3):195-203. [pmid: 12728744].
(28) Martin R E, Bazan N G. Changing fatty acid content of growth cone lipids prior to synaptogenesis. J Neurochem. 1992;59(1):318-325. [pmid: 1613507].
(29) Green P, Glozman S, Kamensky B, et al. Developmental changes in rat brain membrane lipids and fatty acids. The preferential prenatal accumulation of docosahexaenoic acid. J Lipid Res. 1999;40(5):960-966. [pmid: 10224166].
(30) Birch E E, Garfield S, Hoffman D R, et al. A randomized controlled trial of early dietary supply of long-chain polyunsaturated fatty acids and mental development in term infants. Dev Med Child Neurol. 2000;42(3):174-181. [pmid: 10755457].
(31) Birch E E, Hoffman D R, Uauy R, et al. Visual acuity and the essentiality of docosahexaenoic acid and arachidonic acid in the diet of term infants. Pediatr Res. 1998;44(2):201-209. [pmid: 9702915].
(32) Jamieson E C, Farquharson J, Logan R W, et al. Infant cerebellar gray and white matter fatty acids in relation to age and diet. Lipids. 1999;34(10):1065-1071. [pmid: 10580334].
(33) Simopoulos AP. Importance of the ratio of Omega-6/Omega-3 essential fatty acids: Evolutionary aspects. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 1–22.
(34) Kang JX. The importance of Omega-6/Omega-3 fatty acid ratio in cell function : The gene transfer of Omega-3 fatty acid desaturase. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 23–36.
(35) Yehuda S. Omega-6/Omega-3 ratio and brain-related functions. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 37–56.
(36) de Lorgeril M, Salen P. Dietary prevention of coronary heart disease: Focus on Omega-6/Omega-3 essential fatty acid balance. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 57–73.
(37) Pella D, Dubnov G, Singh RB et al. Effects of an Indo-Mediterranean diet on the Omega-6/Omega-3 ratio in patients at high risk of coronary artery disease: The Indian paradox. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 74–80.
(38) Dubnov G, Berry EM. Omega-6/Omega-3 fatty acid ratio: The Israeli paradox. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 81–91.
(39) Zampelas A, Paschos G, Rallidis L et al. Linoleic acid to alpha-linolenic acid ratio: From clinical trials to inflammatory markers of coronary artery disease. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 92–108.
(40) Hamazaki T, Okuyama H. The Japan Society for Lipid Nutrition recommends to reduce the intake of linoleic acid: A review and critique of the scientific evidence. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 109–132.
(41) Chajès V, Bournoux P. Omega-6/Omega-3 polyunsaturated fatty acid ratio and cancer. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 133–151.
(42) Cleland LG, James MJ, Proudman SM. Omega-6/Omega-3 fatty acids and arthritis. Omega-6/Omega-3 essential fatty acid ratio: The scientific evidence. World Rev Nutr Diet. Basel: Karger, 2003: 152–168.
(43) Simopoulos A P. Essential fatty acids in health and chronic disease. Am J Clin Nutr. 1999;70(3 Suppl):560S-569S. [pmid: 10479232].
(44) Kris-Etherton P M, Taylor D S, Yu-Poth S, et al. Polyunsaturated fatty acids in the food chain in the United States. Am J Clin Nutr. 2000;71(1 Suppl):179S-188S. [pmid: 10617969].
(45) Sugano M, Hirahara F. Polyunsaturated fatty acids in the food chain in Japan. Am J Clin Nutr. 2000;71(1 Suppl):189S-196S. [pmid: 10617970].
(46) Weissman M M, Bland R C, Canino G J, et al. Cross-national epidemiology of major depression and bipolar disorder. JAMA. 1996;276(4):293-299. [pmid: 8656541].
(47) Hibbeln J R. Fish consumption and major depression.[comment]. Lancet. 1998;351(9110):1213. [pmid: 9643729].
(48) Edwards R, Peet M, Shay J, et al. Omega-3 polyunsaturated fatty acid levels in the diet and in red blood cell membranes of depressed patients. J Affect Disord. 1998;48(23):149-155. [pmid: 9543204].
(49) Smith R S. The macrophage theory of depression.[erratum appears in Med Hypotheses 1991 Oct;36(2):178]. [Review] [77 refs]. Med Hypotheses. 1991;35(4):298-306. [pmid: 1943879].
(50) Booth-Kewley S, Friedman H S. Psychological predictors of heart disease: a quantitative review. Psychol Bull. 1987;101(3):343-362. [pmid: 3602244].
(51) Pratt L A, Ford D E, Crum R M, et al. Depression, psychotropic medication, and risk of myocardial infarction. Prospective data from the Baltimore ECA follow-up. Circulation. 1996;94(12):3123-3129. [pmid: 8989119].
(52) Peet M, Edwards R W. Lipids, depression and physical diseases. Current Opinion in Psychiatry. 1997;10(6):477-480.
(53) Peet M, Horrobin D F. A dose-ranging study of the effects of ethyl-eicosapentaenoate in patients with ongoing depression despite apparently adequate treatment with standard drugs. Arch Gen Psychiatry. 2002;59(10):913-919. [pmid: 12365878].
(54) Horrobin D F, Bennett C N. Depression and bipolar disorder: relationships to impaired fatty acid and phospholipid metabolism and to diabetes, cardiovascular disease, immunological abnormalities, cancer, ageing and osteoporosis. Possible candidate genes. Prostaglandins Leukot Essent Fatty Acids. 1999;60(4):217-234. [pmid: 10397403].
(55) Horrobin D F. The membrane phospholipid hypothesis as a biochemical basis for the neurodevelopmental concept of schizophrenia. Schizophr Res. 1998;30(3):193-208. [pmid: 9589514].
(56) Mahadik S P, Mukherjee S, Correnti E E, et al. Plasma membrane phospholipid and cholesterol distribution of skin fibroblasts from drug-naive patients at the onset of psychosis. Schizophr Res. 1994;13(3):239-247. [pmid: 7841137].
(57) Fukuzako H, Fukuzako T, Hashiguchi T, et al. Changes in levels of phosphorus metabolites in temporal lobes of drug-naive schizophrenic patients. Am J Psychiatry. 1999;156(8):1205-1208. [pmid: 10450261].
(58) Peet M, Brind J, Ramchand C N, et al. Two double-blind placebo-controlled pilot studies of eicosapentaenoic acid in the treatment of schizophrenia. Schizophr Res. 2001;49(3):243-251. [pmid: 11356585].
(59) Abedin L, Lien E L, Vingrys A J, et al. The effects of dietary alpha-linolenic acid compared with docosahexaenoic acid on brain, retina, liver, and heart in the guinea pig. Lipids. 1999;34(5):475-482. [pmid: 10380119].
(60) Hibbeln J R, Makino K K, Martin C E, et al. Smoking, gender, and dietary influences on erythrocyte essential fatty acid composition among patients with schizophrenia or schizoaffective disorder. Biol Psychiatry. 2003;53(5):431-441. [pmid: 12614996].
(61) Joy CB, Mumby-Croft R, Joy LA. Polyunsaturated fatty acid supplementation for schizophrenia.[update of Cochrane Database Syst Rev. 2000;(2):CD001257; PMID: 10796622]. [Review][47 refs]. Cochrane Database Syst Rev 2003;(2):CD001257.
(62) McAuley L, Pham B, Tugwell P, et al. Does the inclusion of grey literature influence estimates of intervention effectiveness reported in meta-analyses?. Lancet. 2000;356(9237):1228-1231. [pmid: 11072941].
(63) Moher D, Pham B, Lawson M L, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
(64) Jadad AR. Randomised controlled trials. London: BMJ Publishing Group, 1998.
(65) Moher D, Cook D J, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
(66) Berlin J A. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-186. [pmid: 9250191].
(67) Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
(68) Schulz K F, Chalmers I, Hayes R J, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-412. [pmid: 7823387].
(69) Deeks J J, Dinnes J, D'Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess 2003. 7(27):iii-173.
(70) Downs S H, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-384. [pmid: 9764259].
(71) Wells GA Shea B O'Connell D Peterson J Welch V Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 3rd Symposium on Systematic Reviews: Beyond the Basics, July 2000 in Oxford. 2000.
(72) Schachter, H., Reisman, J., Tran, K., Dale, B., Kourad, K., Barnes, D., Sampson, M., Morrison, A., Gaboury, I., and Blackman, J. Health Effects of Omega-3 Fatty Acids on Asthma. Evidence Report/Technology Assessment No. 91 (Prepared by University of Ottawa Evidence-based Practice Center under Contract No. 290-02-0021). Rockville MD: Agency for Healthcare Research and Quality, 2004. AHRQ Publication No. 04-E013-2.
(73) Fehily AMA. Long chain polyunsaturated fatty acids and depressive illness. 1980.
(74) Tur J A, Cortes C, Puig M S, et al. Food consumption patterns among drug abusers involved in a methadone treatment program in the Balearic Islands. Rev Esp Nutr Comunitaria. 2003;9(1):20-29.
(75) Rapisarda V, Petralia A, De Pasquale C, et al. Assessment of immune system function in schizophrenic and depressed patients treated with omega-3 fatty acids. Ital J Psychiatry Behav Sci. 2000;10(1):22-25.
(76) Anonymous. Lipids. Fortschr Med 1993; 111(14):1–4.
(77) Peet M, Horrobin DF. The role of phospholipids in schizophrenia (Abstract). Society of Biological Psychiatry Annual Meeting 2001 7th world congress 2001.
(78) Hirayama T. Life-style and Mortality: A large Census-based Cohort Study in Japan. Basel, Switzerland: Karger, 1990.
(79) Peet M. Nutrition and schizophrenia: an epidemiological and clinical perspective. Nutr Health. 2003;17(3):211-219. [pmid: 14703154].
(80) Tanskanen A, Hibbeln J R, Hintikka J, et al. Fish consumption, depression, and suicidality in a general population.[comment]. Arch Gen Psychiatry. 2001;58(5):512-513. [pmid: 11343534].
(81) Tanskanen A, Hibbeln J R, Tuomilehto J, et al. Fish consumption and depressive symptoms in the general population in Finland. Psychiatr Serv. 2001;52(4):529-531. [pmid: 11274502].
(82) Edwards R, Peet M, Shay J, et al. Depletion of docosahexaenoic acid in red blood cell membranes of depressive patients. Biochem Soc Trans. 1998;26(2):S142. [pmid: 9649817].
(83) Shah S, Ramchand C N, Peet M. Double-blind pilot study of eicosapentaenoic acid (EPC) as the sole treatment for schizophrenia. Schizophr Res. 2000;41(1):27.
(84) Peet M, Mellor J. Double-blind, placebo controlled trial of N3 polysaturated fatty acids as an adjunct to neuroleptics. Schizophr Res. 1998;29:160-161.
(85) Eicosapentaenoic acid (EPA) is effective in relieving schizophrenic symptoms in patients on clozapine. Schizophrenia Research. April 28 - May 2.: 2001.
(86) Horrobin D F, Bennett C N, Peet M. Correlation between clinical improvement and red cell fatty acid changes when treating schizophrenia with eicosapentaenoic acid. Schizophr Res. 2001;49:232.
(87) Peet M, Horrobin D F, Study Group E E M. A dose-ranging exploratory study of the effects of ethyl-eicosapentaenoate in patients with persistent schizophrenic symptoms. J Psychiatr Res. 2002;36(1):7-18. [pmid: 11755456].
(88) Dickerson F B, Boronow J J, Stallings C R, et al. Placebo response in a double-blind therapeutic supplementation trial in stabilized outpatients with schizophrenia. Schizophr Res. 2003;59(1):97-98. [pmid: 12413650].
(89) Fenton W S, Dickerson F, Boronow J, et al. A placebo-controlled trial of omega-3 fatty acid (ethyl eicosapentaenoic acid) supplementation for residual symptoms and cognitive impairment in schizophrenia.[comment]. Am J Psychiatry. 2001;158(12):2071-2074. [pmid: 11729030].
(90) Noaghiul S, Hibbeln J R. Cross-national comparisons of seafood consumption and rates of bipolar disorders. Am J Psychiatry. 2003;160(12):2222-2227. [pmid: 14638594].
(91) Mellor J E, Laugharne J D E, Peet M. Omega-3 fatty acid supplementation in schizophrenic patients. HUM. 1996;11(1):39-46.
(92) Peet M, Poole J, Laugharne J. Infant feeding and the development of schizophrenia. Schizophr Res. 1997;24:255-256.
(93) Akkerhuis G W, Nolen W A. Lithium-associated psoriasis and omega-3 fatty acids. Am J Psychiatry. 2003;160(7):1355. [pmid: 12832259].
(94) Yang S C, Chiu W C, Chen J R, et al. Dietary intakes of 4–8 years old children with attention-deficit hyperactivity disorder. Nutr Sci J. 1999;24(2):153-165.
(95) Marangell L B, Martinez J M, Zboyan H A, et al. A double-blind, placebo-controlled study of the omega-3 fatty acid docosahexaenoic acid in the treatment of major depression. Am J Psychiatry. 2003;160(5):996-998. [pmid: 12727707].
(96) Su K P, Huang S Y, Chiu C C, et al. Omega-3 fatty acids in major depressive disorder. A preliminary double-blind, placebo-controlled trial. Eur Neuropsychopharmacol. 2003;13(4):267-271. [pmid: 12888186].
(97) Nemets B, Stahl Z, Belmaker R H. Addition of omega-3 fatty acid to maintenance medication treatment for recurrent unipolar depressive disorder. Am J Psychiatry. 2002;159(3):477-479. [pmid: 11870016].
(98) Llorente A M, Jensen C L, Voigt R G, et al. Effect of maternal docosahexaenoic acid supplementation on postpartum depression and information processing. Am J Obstet Gynecol. 2003;188(5):1348-1353. [pmid: 12748510].
(99) Wardle J, Rogers P, Judd P, et al. Randomized trial of the effects of cholesterol-lowering dietary treatment on psychological function. Am J Med. 2000;108(7):547-553. [pmid: 10806283].
(100) Ness A R, Gallacher J E J, Bennett P D, et al. Advice to eat fish and mood: A randomised controlled trial in men with angina. Nutr Neurosci. 2003;6(1):63-65. [pmid: 12608739].
(101) Maes M, Christophe A, Delanghe J, et al. Lowered omega3 polyunsaturated fatty acids in serum phospholipids and cholesteryl esters of depressed patients. Psychiatry Res. 1999;85(3):275-291. [pmid: 10333380].
(102) Peet M, Murphy B, Shay J, et al. Depletion of omega-3 fatty acid levels in red blood cell membranes of depressive patients. Biol Psychiatry. 1998;43(5):315-319. [pmid: 9513745].
(103) Maes M, Smith R, Christophe A, et al. Fatty acid composition in major depression: decreased omega 3 fractions in cholesteryl esters and increased C20: 4 omega 6/C20:5 omega 3 ratio in cholesteryl esters and phospholipids. J Affect Disord. 1996;38(1):35-46. [pmid: 8735157].
(104) Tiemeier H, van Tuijl H R, Hofman A, et al. Plasma fatty acid composition and depression are associated in the elderly: the Rotterdam Study. Am J Clin Nutr. 2003;78(1):40-46. [pmid: 12816769].
(105) Ellis F R, Sanders T A B. Long chain polyunsaturated fatty acids in endogenous depression. J Neurol Neurosurg Psychiatry. 1977;40(2):168-169. [pmid: 864481].
(106) Fehily A M A, Bowey O A M, Ellis F R, et al. Plasma and erythrocyte membrane long chain polyunsaturated fatty acids in endogenous depression. Neurochem Int. 1981;3(1):37-42. [pmid: 20487806].
(107) Suzuki S, Akechi T, Kobayashi M, et al. Daily omega-3 fatty acid intake and depression in Japanese patients with newly diagnosed lung cancer. Br J Cancer. 2004;90(4):787-793. [pmid: 14970854].
(108) Hibbeln J R. Seafood consumption, the DHA content of mothers' milk and prevalence rates of postpartum depression: a cross-national, ecological analysis. J Affect Disord. 2002;69(13):15-29. [pmid: 12103448].
(109) Peet M. International variations in the outcome of schizophrenia and the prevalence of depression in relation to national dietary practices: an ecological analysis. Br J Psychiatry. 2004;184:404-408. [pmid: 15123503].
(110) Woo J, Ho S C, Yu A L M. Lifestyle factors and health outcomes in elderly Hong Kong Chinese aged 70 years and over. Gerontology. 2002;48(4):234-240. [pmid: 12053113].
(111) Hakkarainen R, Partonen T, Haukka J, et al. Is low dietary intake of omega-3 fatty acids associated with depression?. Am J Psychiatry. 2004;161(3):567-569. [pmid: 14992986].
(112) Stoll A L, Severus W E, Freeman M P, et al. Omega 3 fatty acids in bipolar disorder: a preliminary double-blind, placebo-controlled trial.[comment]. Arch Gen Psychiatry. 1999;56(5):407-412. [pmid: 10232294].
(113) Chiu C C, Huang S Y, Su K P, et al. Polyunsaturated fatty acid deficit in patients with bipolar mania. Eur Neuropsychopharmacol. 2003;13(2):99-103. [pmid: 12650953].
(114) Mahadik S P, Mukherjee S, Horrobin D F, et al. Plasma membrane phospholipid fatty acid composition of cultured skin fibroblasts from schizophrenic patients: comparison with bipolar patients and normal subjects. Psychiatry Res. 1996;63(23):133-142. [pmid: 8878309].
(115) Fux M, Benjamin J, Nemets B. A placebo-controlled cross-over trial of adjunctive EPA in OCD. J Psychiatr Res. 2004;38(3):323-325. [pmid: 15003438].
(116) Holman R T, Adams C E, Nelson R A, et al. Patients with anorexia nervosa demonstrate deficiencies of selected essential fatty acids, compensatory changes in nonessential fatty acids and decreased fluidity of plasma lipids. J Nutr. 1995;125(4):901-907. [pmid: 7722693].
(117) Langan S M, Farrell P M. Vitamin E, vitamin A and essential fatty acid status of patients hospitalized for anorexia nervosa. Am J Clin Nutr. 1985;41(5):1054-1060. [pmid: 3993608].
(118) Brue A W, Oakland T D, Evans R A. The use of a dietary supplement combination and an essential fatty acid as an alternative and complementary treatment for children with attention-deficit/hyperactivity disorder. Sci Rev Altern Med. 2001;5(4):187-194.
(119) Richardson A J, Puri B K. A randomized double-blind, placebo-controlled study of the effects of supplementation with highly unsaturated fatty acids on ADHD-related symptoms in children with specific learning difficulties. Prog Neuropsychopharmacol Biol Psychiatry. 2002;26(2):233-239. [pmid: 11817499].
(120) Hirayama S, Hamazaki T, Terasawa K. Effect of docosahexaenoic acid-containing food administration on symptoms of attention-deficit/hyperactivity disorder - A placebo-controlled double-blind study. Eur J Clin Nutr. 2004;58(3):467-473. [pmid: 14985685].
(121) Harding K L, Judah R D, Gant C E. Outcome-based comparison of Ritalin versus food-supplement treated children with AD/HD. Altern Med Rev. 2003;8(3):319-330. [pmid: 12946241].
(122) Voigt R G, Llorente A M, Jensen C L, et al. A randomized, double-blind, placebo-controlled trial of docosahexaenoic acid supplementation in children with attention-deficit/hyperactivity disorder.[comment]. J Pediatr. 2001;139(2):189-196. [pmid: 11487742].
(123) Stevens L, Zhang W, Peck L, et al. EFA supplementation in children with inattention, hyperactivity, and other disruptive behaviors. Lipids. 2003;38(10):1007-1021. [pmid: 14669965].
(124) Stevens L J, Zentall S S, Deck J L, et al. Essential fatty acid metabolism in boys with attention-deficit hyperactivity disorder. Am J Clin Nutr. 1995;62(4):761-768. [pmid: 7572706].
(125) Mitchell E A, Aman M G, Turbott S H, et al. Clinical characteristics and serum essential fatty acid levels in hyperactive children. Clin Pediatr (Phila). 1987;26(8):406-411. [pmid: 2439249].
(126) Mitchell E A, Lewis S, Cutler D R. Essential fatty acids and maladjusted behaviour in children. Prostaglandins Leukot Med. 1983;12(3):281-287. [pmid: 6581484].
(127) Silvers K M, Scott K M. Fish consumption and self-reported physical and mental health status. Public Health Nutr. 2002;5(3):427-431. [pmid: 12003654].
(128) Hamazak T, Thienprasert A, Kheovichai K, et al. The effect of docosahexaenoic acid on aggression in elderly Thai subjects--a placebo-controlled double-blind study. Nutr Neurosci. 2002;5(1):37-41. [pmid: 11929196].
(129) Hamazaki T, Sawazaki S, Nagao Y, et al. Docosahexaenoic acid does not affect aggression of normal volunteers under nonstressful conditions. A randomized, placebo-controlled, double-blind study. Lipids. 1998;33(7):663-667. [pmid: 9688168].
(130) Hamazaki T, Sawazaki S, Itomura M, et al. The effect of docosahexaenoic acid on aggression in young adults. A placebo-controlled double-blind study. J Clin Invest. 1996;97(4):1129-1133. [pmid: 8613538]. [pmcid: 507162].
(131) Gesch C B, Hammond S M, Hampson S E, et al. Influence of supplementary vitamins, minerals and essential fatty acids on the antisocial behaviour of young adult prisoners. Randomised, placebo-controlled trial. Br J Psychiatry. 2002;181:22-28. [pmid: 12091259].
(132) Iribarren C, Markovitz J H, Jacobs D R Jr, et al. Dietary intake of n-3, n-6 fatty acids and fish: Relationship with hostility in young adults - The CARDIA study. Eur J Clin Nutr. 2004;58(1):24-31. [pmid: 14679363].
(133) Hibbeln J R. Seafood consumption and homicide mortality: A cross-national ecological analysis. 4th Congress of the International Society for the Study of Fatty Acids and Lipids (ISSFAL 2000). World Rev Nutr Diet. 2000;88:41-46. [pmid: 11935968].
(134) Hibbeln J R, Umhau J C, Linnoila M, et al. A replication study of violent and nonviolent subjects: cerebrospinal fluid metabolites of serotonin and dopamine are predicted by plasma essential fatty acids. Biol Psychiatry. 1998;44(4):243-249. [pmid: 9715355].
(135) Virkkunen M E, Horrobin D F, Jenkins D K, et al. Plasma phospholipid essential fatty acids and prostaglandins in alcoholic, habitually violent, and impulsive offenders. Biol Psychiatry. 1987;22(9):1087-1096. [pmid: 2958095].
(136) Buydens-Branchley L, Branchey M, McMakin D L, et al. Polyunsaturated fatty acid status and aggression in cocaine addicts. Drug Alcohol Depend. 2003;71(3):319-323. [pmid: 12957349].
(137) Hibbeln J R, Linnoila M, Umhau J C, et al. Essential fatty acids predict metabolites of serotonin and dopamine in cerebrospinal fluid among healthy control subjects, and early- and late-onset alcoholics. Biol Psychiatry. 1998;44(4):235-242. [pmid: 9715354].
(138) Alling C, Gustavsson L, Kristensson-Aas A, et al. Changes in fatty acid composition of major glycerophospholipids in erythrocyte membranes from chronic alcoholics during withdrawal. Scand J Clin Lab Invest. 1984;44(4):283-289. [pmid: 6463560].
(139) Zanarini M C, Frankenburg F R. omega-3 Fatty acid treatment of women with borderline personality disorder: a double-blind, placebo-controlled pilot study. Am J Psychiatry. 2003;160(1):167-169. [pmid: 12505817].
(140) Emsley R, Myburgh C, Oosthuizen P, et al. Randomized, placebo-controlled study of ethyl-eicosapentaenoic acid as supplemental treatment in schizophrenia. Am J Psychiatry. 2002;159(9):1596-1598. [pmid: 12202284].
(141) Amore M, Balista C, McCreadie R G, et al. Can breast-feeding protect against schizophrenia? Case-control Study. Biol Neonate. 2003;83(2):97-101. [pmid: 12576752].
(142) Leask S J, Done D J, Crow T J, et al. No association between breast-feeding and adult psychosis in two national birth cohorts. Br J Psychiatry. 2000;177:218-221. [pmid: 11040881].
(143) McCreadie R G. The Nithsdale Schizophrenia Surveys. 16. Breast-feeding and schizophrenia: preliminary results and hypotheses. Br J Psychiatry. 1997;170:334-337. [pmid: 9246251].
(144) Sasaki T, Okazaki Y, Akaho R, et al. Type of feeding during infancy and later development of schizophrenia. Schizophr Res. 2000;42(1):79-82. [pmid: 10706988].
(145) Christensen O, Christensen E. Fat consumption and schizophrenia. Acta Psychiatr Scand. 1988;78(5):587-591. [pmid: 3232536].
(146) Arvindakshan M, Sitasawad S, Debsikdar V, et al. Essential polyunsaturated fatty acid and lipid peroxide levels in never-medicated and medicated schizophrenia patients. Biol Psychiatry. 2003;53(1):56-64. [pmid: 12513945].
(147) Khan M M, Evans D R, Gunna V, et al. Reduced erythrocyte membrane essential fatty acids and increased lipid peroxides in schizophrenia at the never-medicated first-episode of psychosis and after years of treatment with antipsychotics. Schizophr Res. 2002;58(1):1-10. [pmid: 12363384].
(148) Assies J, Lieverse R, Vreken P, et al. Significantly reduced docosahexaenoic and docosapentaenoic acid concentrations in erythrocyte membranes from schizophrenic patients compared with a carefully matched control group. Biol Psychiatry. 2001;49(6):510-522. [pmid: 11257236].
(149) Peet M, Laugharne J, Rangarajan N, et al. Depleted red cell membrane essential fatty acids in drug-treated schizophrenic patients. J Psychiatr Res. 1995;29(3):227-232. [pmid: 7473298].
(150) Fischer S, Kissling W, Kuss H J. Schizophrenic patients treated with high dose phenothiazine or thioxanthene become deficient in polyunsaturated fatty acids in their thrombocytes. Biochem Pharmacol. 1992;44(2):317-323. [pmid: 1642646].
(151) Kaiya H, Horrobin D F, Manku M S, et al. Essential and other fatty acids in plasma in schizophrenics and normal individuals from Japan. Biol Psychiatry. 1991;30(4):357-362. [pmid: 1912126].
(152) Horrobin D F, Manku M S, Morse-Fisher N, et al. Essential fatty acids in plasma phospholipids in schizophrenics. Biol Psychiatry. 1989;25(5):562-568. [pmid: 2920191].
(153) Obi F O, Nwanze E A. Fatty acid profiles in mental disease. Part 1. Linolenate variations in schizophrenia. J Neurol Sci. 1979;43(3):447-454. [pmid: 521838].
(154) Yao J, Stanley J A, Reddy R D, et al. Correlations between peripheral polyunsaturated fatty acid content and in vivo membrane phospholipid metabolites. Biol Psychiatry. 2002;52(8):823-830. [pmid: 12372654].
(155) Arvindakshan M, Ghate M, Ranjekar P K, et al. Supplementation with a combination of omega-3 fatty acids and antioxidants (vitamins E and C) improves the outcome of schizophrenia. Schizophr Res. 2003;62(3):195-204. [pmid: 12837515].
(156) Ranjekar P K, Hinge A, Hegde M V, et al. Decreased antioxidant enzymes and membrane essential polyunsaturated fatty acids in schizophrenic and bipolar mood disorder patients. Psychiatry Res. 2003;121(2):109-122. [pmid: 14656446].
(157) Vaddadi K S, Gilleard C J, Soosai E, et al. Schizophrenia, tardive dyskinesia and essential fatty acids. Schizophr Res. 1996;20(3):287-294. [pmid: 8827855].
(158) Evans D R, Parikh V V, Khan M M, et al. Red blood cell membrane essential fatty acid metabolism in early psychotic patients following antipsychotic drug treatment. Prostaglandins Leukot Essent Fatty Acids. 2003;69(6):393-399. [pmid: 14623492].
(159) Vancassel S, Durand G, Barthelemy C, et al. Plasma fatty acid levels in autistic children. Prostaglandins Leukot Essent Fatty Acids. 2001;65(1):1-7. [pmid: 11487301].
(160) Food and Drug Administration. FDA Code of Federal Regulations documents 21 CFR 172.860 and 21 CFR 184.1472. 2004.
(161) Holman R T, Johnson S B, Ogburn P L. Deficiency of essential fatty acids and membrane fluidity during pregnancy and lactation. Proc Natl Acad Sci U S A. 1991;88(11):4835-4839. [pmid: 2052562]. [pmcid: 51761].
(162) Hibbeln J R, Salem N Jr. Dietary polyunsaturated fatty acids and depression: when cholesterol does not satisfy. [Review] [146 refs]. Am J Clin Nutr. 1995;62(1):1-9. [pmid: 7598049].
(163) Food and Agriculture Organization. Food and Agriculture Organization of the United Nations Statistical Database. 2004.
(164) World Health Organization. Schizophrenia: an International Followup Study. New York: John Wiley, 1979.
(165) Jablensky A, Sartorius N, Ernberg G, et al. Schizophrenia: manifestations, incidence and course in different cultures. A World Health Organization ten-country study. Psychol Med Monogr Suppl. 1992;20:1-97. [pmid: 1565705].
(166) Jain M, Howe G R, Rohan T. Dietary assessment in epidemiology: comparison on food frequency and a diet history questionnaire with a 7-day food record. Am J Epidemiol. 1996;143(9):953-960. [pmid: 8610709].
(167) Science and Technology Agency of Japan. Fatty Acids, Cholesterol, Vitamin E Composition Tables of Japanese Foods. 1990. Tokyo, Ishiyaku Shuppan Publishers.
(168) Ma J, Folsom A R, Shahar E, et al. Plasma fatty acid composition as an indicator of habitual dietary fat intake in middle-aged adults. The Atherosclerosis Risk in Communities (ARIC) Study Investigators. Am J Clin Nutr. 1995;62(3):564-571. [pmid: 7661118].
(169) Bates E J, Ferrante A, Harvey D P, et al. Docosahexanoic acid (22:6, n-3) but not eicosapentaenoic acid (20:5, n-3) can induce neutrophil-mediated injury of cultured endothelial cells: involvement of neutrophil elastase. J Leukoc Biol. 1993;54(6):590-598. [pmid: 8245712].
(170) Simon J A, Fong J, Bernert J T Jr, et al. Relation of smoking and alcohol consumption to serum fatty acids. Am J Epidemiol. 1996;144(4):325-334. [pmid: 8712189].
(171) Diwan A, Castine M, Pomerleau C S, et al. Differential prevalence of cigarette smoking in patients with schizophrenic vs mood disorders. Schizophr Res. 1998;33(12):113-118. [pmid: 9783351].
(172) Pawlosky R J, Salem N Jr. Alcohol consumption in rhesus monkeys depletes tissues of polyunsaturated fatty acids and alters essential fatty acid metabolism. Alcohol Clin Exp Res. 1999;23(2):311-317. [pmid: 10069561].
(173) Vickers A J. The use of percentage change from baseline as an outcome in a controlled trial is statistically inefficient: a simulation study. BMC Med Res Methodol. 2001;1(1):6. [pmid: 11459516]. [pmcid: 34605].
(174) Section 8 of Cochrane Reviewers' Handbook 4.2.2 [updated March 2004]. In: Clarke M, Oxman A, editors. The Cochrane Library, Issue 2, 2003. Oxford: Update Software, 2004.
(175) DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
(176) Uauy R, Peirano P. Breast is best: human milk is the optimal food for brain development. Am J Clin Nutr. 1999;70(4):433-434. [pmid: 10500009].
(177) Marteinsdottir I, Horrobin D F, Stenfors C, et al. Changes in dietary fatty acids alter phospholipid fatty acid composition in selected regions of rat brain. Prog Neuropsychopharmacol Biol Psychiatry. 1998;22(6):1007-1021. [pmid: 9789884].
(178) Mahadik S P, Shendarkar N S, Scheffer R E, et al. Utilization of precursor essential fatty acids in culture by skin fibroblasts from schizophrenic patients and normal controls. Prostaglandins Leukot Essent Fatty Acids. 1996;55(12):65-70. [pmid: 8888125].
(179) Horrobin D F, Glen A I, Cantril R C. Clozapine: elevation of membrane unsaturated lipid levels: a new mechanism of action. Biol Psychiatry. 1997;42:S161.
(180) Peet M. Nutrition and schizophrenia: Beyond omega-3 fatty acids. Prostaglandins Leukot Essent Fatty Acids. 2004;70(4):417-422. [pmid: 15041037].
(181) Chang M C J, Contreras M A, Rosenberger T A, et al. Chronic valproate treatment decreases the in vivo turnover of arachidonic acid in brain phospholipids: A possible common effect of mood stabilizers. J Neurochem. 2001;77(3):796-803. [pmid: 11331408].
(182) Pawlosky R, Hibbeln J, Wegher B, et al. The effects of cigarette smoking on the metabolism of essential fatty acids. Lipids. 1999;34 Suppl:S287. [pmid: 10419179].
(183) Brown A S, van Os J, Driessens C, et al. Further evidence of relation between prenatal famine and major affective disorder. Am J Psychiatry. 2000;157(2):190-195. [pmid: 10671386].
(184) Rudin D O. The major psychoses and neuroses as omega-3 essential fatty acid deficiency syndrome: substrate pellagra. Biol Psychiatry. 1981;16(9):837-850. [pmid: 7028146].
(185) Tomeo C A, Rich-Edwards J W, Michels K B, et al. Reproducibility and validity of maternal recall of pregnancy-related events. Epidemiology. 1999;10(6):774-777. [pmid: 10535796].
(186) Huttly S R, Barros F C, Victora C G, et al. Do mothers overestimate breast feeding duration? An example of recall bias from a study in southern Brazil. Am J Epidemiol. 1990;132(3):572-575. [pmid: 2389760].
(187) Eaton-Evans J, Dugdale A E. Recall by mothers of the birth weights and feeding of their children. Hum Nutr Appl Nutr. 1986;40(3):171-175. [pmid: 3771280].
(188) Peet M. Essential fatty acids: Theoretical aspects and treatment implications for schizophrenia and depression. Advances in Psychiatric Treatment. 2002;8(3):223-229.
(189) Peet M. Eicosapentaenoic acid in the treatment of schizophrenia and depression: Rationale and preliminary double-blind clinical trial results. Prostaglandins Leukot Essent Fatty Acids. 2003;69(6):477-485. [pmid: 14623502].
(190) Stoll AL, Locke CA. Omega-3 fatty acids in mood disorders: A review of neurobiologic and clinical actions. In: Mischoulon D, Rosenbaum JF, editors. Natural medications for psychiatric disorders: Considering the alternatives. Philadelphia, PA, US: Lippincott Williams & Wilkins Publishers, 2002: 13–34.
(191) Stoll A L, Damico K E, Daly B P, et al. Methodological considerations in clinical studies of omega 3 fatty acids in major depression and bipolar disorder. [Review] [32 refs]. World Rev Nutr Diet. 2001;88:58-67. [pmid: 11935971].
(192) Su K P, Shen W W, Huang S Y. Are omega3 fatty acids beneficial in depression but not mania?[comment]. Arch Gen Psychiatry. 2000;57(7):716-717. [pmid: 10891047].
(193) Sugiura T, Kondo S, Kodaka T, et al. Enzymatic synthesis of oleamide (cis-9, 10-octadecenoamide), an endogenous sleep-inducing lipid, by rat brain microsomes. Biochem Mol Biol Int. 1996;40(5):931-938. [pmid: 8955882].
(194) Thomas E A, Carson M J, Sutcliffe J G. Oleamide-induced modulation of 5-hydroxytryptamine receptor-mediated signaling. Ann N Y Acad Sci. 1998;861:183-189. [pmid: 9928256].
(195) Puri B K, Richardson A D. The effects of olive oil on omega3 fatty acids and mood disorders.[comment]. Arch Gen Psychiatry. 2000;57(7):715.