# Acknowledgments

The authors would like to thank numerous individuals for their support of the present project: Isabella Steffensen and Christine Murray for their ability to clarify the meaning of our words, figures and tables; Pieter Oosthuizen and Robin Emsley for responding affirmatively to our request for data; Malcolm Peet for trying to facilitate the sharing of data he collected yet which are now held by one of his studies' funding sources; Bill Hodge for arranging timely help with assessors of study quality; Samantha Fulton for helping check some of our work; Vladimir Fox for arranging the expert and timely translation of non-English language articles; Herb Woolf for responding with substance to our request of industry for evidence; Peter O'Blenis for assuring that the Internet-based software we used for all aspects of the review process was adapted to our needs; our collaborators at SC-RAND and Tufts-NEMC EPCs; Beth Collins-Sharp, Rosaly Correa-de-Araujo and Jacqueline Besteman who, as our Task Order Officers, provided steady support and guidance on behalf of AHRQ; and, Anne Thurn of the Office of Dietary Supplements for her thoughtful direction on behalf of the Federal Partners. Sections of Chapter 1 were developed in collaboration with Tufts-NEMC EPC, and with contributions from SC-RAND EPC.