# Results

## Results of Literature Search

Regardless of its source, the progress of each bibliographic record through the stages of the systematic review is illustrated in the modified QUOROM flow chart (Appendix D††). Ideally, a record included an abstract and key words, in addition to a citation. When a citation was discovered, for example through a manual search of a reference list, its complete bibliographic record was sought (e.g., Pubmed) and then entered into the first level of relevance screening.

Of 1,212 records entered into the initial screening for relevance, 955 were excluded. Reflecting the specific eligibility criteria, the reasons for exclusion were: a. not a first publication of empirical evidence (e.g., a review; n = 500); b. not involving human participants (n = 216); c. no omega-3 fatty acid focus (i.e., intervention/exposure or biomarkers) (n = 167); and, d. not related to predefined mental health outcomes (n = 72). All but 7^73–79^ of the remaining 257 reports were then retrieved and subjected to a more detailed relevance assessment. Of those 7 reports which were not retrieved, one was an abstract^77^ whose study results may have been published subsequently as a journal article included in the review.

A second relevance screening then excluded 137 reports for the following reasons: a. not a first publication of empirical evidence (e.g., a review; n = 91); b. not involving human participants (n = 7); c. no omega-3 fatty acid focus (i.e., intervention/exposure or biomarkers) (n = 23); and, d. not related to predefined mental health outcomes (n = 16). Finally, a third relevance screening level excluded 27 uncontrolled studies failing to meet eligibility criteria regarding the questions of the efficacious nature of omega-3 fatty acid interventions or the possible assocation of the fatty acid content of biomarkers with the onset, continuation or recurrence of psychiatric disorders or conditions.

In total, 86 reports, describing 79 unique studies, were deemed relevant for the systematic review, with 6 studies each described by more than one report. The specific relationships between studies and reports are identified in the next paragraph. As stated earlier, the two listings of studies excluded as a result of appraisals of full reports are presented at the end of this document.

When the lead author of the Tanskanen et al. studies was contacted because their two studies appeared to be similar,^80,^ ^81^ he clarified that the studies, and their study populations, were non-overlapping. As introduced above, on occasion multiple reports published or presented in different places did describe the same study. To afford transparency for those considering replicating or updating our work, we identify these relationships at this time. Hibbeln^47^ included Weissman et al.'s^46^ data as part of their cross-national ecological analysis. Edwards et al.'s data^48^ were first disseminated in an abstract.^82^ Likewise, Peet et al.'s publication, describing their study of the primary treatment of schizophrenia,^58^ was preceded by an abstract.^83^ Peet and Mellor's abstract^84^ became available before their data, concerning the supplemental treatment of schizophrenia, were published.^58^ Two abstracts^85,^ ^86^ also reported Peet and Horrobin's data regarding the supplemental treatment of schizophrenia.^87^ Two additional analyses^60,^ ^88^ extended Fenton et al.'s initial work.^89^ To avoid confusion in the text, evidence tables, summary tables and figures, only one report is used to refer to a given study and its data. It is typically the first, or “parent,” publication. Peet et al.'s report, describing two relevant studies (primary vs supplemental treatment of schizophrenia),^58^ is represented twice in Evidence Table 1 (see Appendices‡‡).

Some studies provided data addressing more than one research question. For example, Noaghiul and Hibbeln's cross-national ecological analysis evaluated the possible association of seafood consumption with bipolar disorder and with schizophrenia.^90^ Mellor et al.'s study investigated the possible associations of schizophrenia outcomes with the dietary intake of omega-3 fatty acids as well as with the omega-3 and omega-6/omega-3 fatty acid content of biomarkers.^91^ However, Mellor et al.'s subsequent intervention study, described in the same report, was not eligible for the present review because it employed an uncontrolled design.

To help guide the reader, a table appears at the end of this report, which lists the studies addressing each question. The questions are organized by the order in which they are addressed in the text. Only the first, or “parent,” report is represented in the table.

## Report and Study Design Characteristics of Included Studies

Of the included studies, only one failed to be described by at least one published report.^92^ It was reported in abstract form. Another included report was a published letter to the editor, which while reporting the use of omega-3 fatty acids for a problem outside the scope of the present review (i.e., lithium-induced psoriasis), it referred to the source of these data as being a placebo-controlled trial investigating the supplemental treatment of bipolar disorder.^93^ Of the 16 relevant studies identified by manual search, only one was disseminated in a format other than a journal publication.^92^ All but one of the included reports (all published), which required translation from Chinese,^94^ were written in English.

As an overview, the number of included studies investigating each of the three basic questions are described, distinguished by psychiatric disorder, or condition, and by research design. A given study may have addressed more than one basic question.

Twenty-two unique studies investigated the first three basic questions concerning depression. Of these, seven were RCTs,^53,^ ^95–100^ seven were multiple-group cross-sectional studies,^48,^ ^101–106^ three were single population cross-sectional surveys,^80,^ ^81,^ ^107^ three were cross-national ecological analyses^47,^ ^108,^ ^109^ and two were single prospective cohorts.^110,^ ^111^ Four RCTs examined omega-3 fatty acids as either a primary^95^ or supplemental treatment.^53,^ ^96,^ ^97^ Three RCTs,^98–100^ three cross-national ecological analyses,^47,^ ^108,^ ^109^ three single population cross-sectional surveys,^80,^ ^81,^ ^107^ one multiple-group cross-sectional study^48^ and two single prospective cohorts^110,^ ^111^ comprised the twelve studies investigating the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of depression. One RCT^98^ and seven multiple-group cross-sectional studies^48,^ ^101–106^ looked at the possible association of the onset, continuation or recurrence of depression with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers.

Two studies, one a single prospective cohort^111^ and the other a single population cross-sectional survey,^80^ investigated the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of suicidal ideation or behavior. Five unique studies investigated three basic questions concerning bipolar disorder. Two studies, one RCT^112^ and one defined merely as “controlled,”^93^ evaluated the supplemental treatment of bipolar disorder. One cross-national ecological analysis^90^ examined the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of bipolar disorder. Two multiple-group cross-sectional studies looked at the possible association of the onset, continuation or recurrence of bipolar disorder with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers.^113,^ ^114^

Two RCTs investigated the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of anxiety.^99,^ ^100^ One crossover RCT studied the supplemental treatment of obsessive-compulsive disorder.^115^ Two multiple-group cross-sectional studies examined the possible association of the onset, continuation or recurrence of anorexia nervosa with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers.^116,^ ^117^

Ten unique studies assessed the first three basic questions pertaining to AD/HD. These studies were the only ones in the review that investigated children. Three RCTs,^118–120^ with one facet of one of them^118^ centered on children not receiving medication, and one comparative before-after study,^121^ investigated the primary treatment of AD/HD. One of the same RCTs,^118^ this time looking exclusively at children receiving medication, and two other RCTs,^122,^ ^123^ evaluated the supplemental treatment of AD/HD. One multiple-group cross-sectional study investigated the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of AD/HD.^94^ Three multiple-group cross-sectional studies examined the possible association of the onset, continuation or recurrence of AD/HD with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers.^124–126^ One single population cross-sectional survey assessed the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of mental health difficulties.^127^

Ten unique studies investigated two of the three basic questions regarding tendencies or behavior with the potential to harm others. Five RCTs,^99,^ ^128–131^ one single population cross-sectional survey^132^ and one cross-national ecological analysis,^133^ studied the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of these tendencies or behavior. Three multiple-group cross-sectional studies examined the possible association of the onset, continuation or recurrence of these tendencies or behavior with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers.^134–136^ Two multiple-group cross-sectional studies investigated the possible association of the onset, continuation or recurrence of alcoholism with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers.^137,^ ^138^ One RCT studied the primary treatment of borderline personality disorder.^139^

Twenty-eight unique studies investigated the first three basic questions concerning schizophrenia. One RCT^58^ studied the primary treatment of schizophrenia and four RCTs^58,^ ^87,^ ^89,^ ^140^ investigated the supplemental treatment of schizophrenia. Five case-control designs,^92,^ ^141–144^ one single prospective cohort^91^ and three cross-national ecological analyses^90,^ ^109,^ ^145^ assessed the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of schizophrenia. Twelve multiple-group cross-sectional studies^114,^ ^146–156^ and two single prospective cohort studies^157,^ ^158^ investigated the possible association of the onset, continuation or recurrence of schizophrenia with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers.

One multiple-group cross-sectional study^159^ examined the possible association of the onset, continuation or recurrence of autism with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers. Ten RCTs described adverse event (e.g., side effects) data associated with an omega-3 fatty acid intervention/exposure (Question 4),^53,^ ^58,^ ^87,^ ^89,^ ^95,^ ^96,^ ^112,^ ^119,^ ^129,^ ^130^ with two of these trials involving healthy volunteers.^129,^ ^130^

The remainder of this chapter is organized by disorder or condition, with the evidence addressing each of its first three basic questions presented in turn. If a question is not represented in the report, there was no evidence that met eligibility criteria. Safety data are presented last. We begin with mood disorders.

## Are Omega-3 Fatty Acids Efficacious as Primary Treatment for Depression?

As observed in Summary Table 1 (below), derived from Evidence Table 1 (Appendix E§§), only one controlled study (2003) employing an RCT design met eligibility criteria in investigating the question of omega-3 fatty acids' possible efficaciousness as a primary treatment for depression.

### Overview of Relevant Study's Characteristics and Results

Likely at one US site, Marangell et al. randomized 36 adult outpatients (18–65 years; racial/ethnic background unreported) meeting DSM-IV criteria for major depressive disorder (duration unreported), without psychotic features, to receive either 2 grams per day (2 g/d) DHA or placebo (source undefined) in a 6-week parallel design (followups at 2 and 6 weeks).^95^ Inclusion criteria were a score of at least 12 on the Montgomery-Asberg Depression Rating Scale (MADRS), a score of at least 17 on the Hamilton Depression Rating Scale (HDRS), no psychotropic medication for at least 2 weeks, and dietary intake of no more than one fish serving per week. Exclusion criteria included any significant comorbid psychiatric or medical conditions, and a lifetime failure of at least two adequate antidepressant trials. Clinical response was the primary outcome, and was defined as a mimimum 50% reduction, from baseline to 6 weeks, on the MADRS. Funding was provided by way of an investigator-initiated grant from Martek Biosciences Corporation.

Response rates were 27.8% and 23.5% in the DHA (n=18 with at least one followup) and placebo groups (n=17), respectively, with the difference failing to reach statistical significance in an intention-to-treat analysis (ITT). This null finding held after an adjustment for baseline HDRS score. The two groups did not vary in terms of age, percent male participants, alcohol intake, or education. The placebo group comprised a significantly greater number of smokers and a lower weight. Both at baseline and at study endpoint the placebo group exhibited a significantly higher HDRS score. Only in the DHA group did the absolute level of RBC DHA content increase in statistically significant fashion from baseline to endpoint, whereas a report of a similar difference in the change in DHA's percent weight of total fatty acids was not accompanied by results of a statistical test of significance. No information was provided regarding the reason one participant in the placebo group did not reach final followup.

A summary matrix is not required for a single study. Study quality assessed via the Jadad total score was low, with insufficient clear information preventing us from concluding that the allocation to study groups had likely been adequately concealed. There were insufficient details reported by Marengell et al. to permit the determination of a level of applicability even though the trial appeared to have been conducted in the US.

This was a single study with a limited sample size and a limited complexity to its design (e.g., no stratification for covariates). Thus, other than the observation that the possible confounding impacts of certain factors (e.g., between-group differences or on-study changes in psychotropic medication type or dose; alcohol intake; education, age, sex) were likely controlled in this primary treatment study, little can be said about the possible impact of additional factors with the potential to influence mental health outcomes. Yet, one factor with the potential to influence these outcomes, current smoker status, was not distributed equally across study groups although the observation that more placebo group members were smokers makes it difficult to see how this may have contributed to a null between-group difference in the primary clinical outcome. This between-group difference could have influenced the observations of a between-group difference in changes in RBC DHA content, however, given the effects of smoking on EFA status.^60^ The restriction on weekly fish intake likely made study groups somewhat more comparable. Meta-analysis was considered unnecessary.

## Are Omega-3 Fatty Acids Efficacious as Supplemental Treatment for Depression?

As observed in Summary Table 2 (below), derived from Evidence Table 1 (Appendix E***), three RCTs met eligibility criteria in investigating omega-3 fatty acids' possible efficaciousness as supplemental treatment for depression. Studies were published in 2002 or 2003.

### Overview of Relevant Studies

Peet and Horrobin conducted a dose-ranging study of the effects of ethyl eicosapentaenoate (E-EPA: i.e., a pure ethyl ester derivative of EPA) in adult outpatients (n=70; 18–70 years) identified with persistent depressive symptomatology despite ongoing treatment with an adequate dose (undefined) of a standard antidepressant (Summary Table 2).^53^ Recruited by family physicians, study participants were randomized into a 12-week parallel RCT (followups at 4, 8 and 12 weeks) on a double-blind basis to receive either placebo (liquid paraffin) or total doses of 1 g/d, 2 g/d or 4 g/d E-EPA via 500 mg soft gelatin capsules (taken morning and evening). The primary outcome was HDRS score, with the MADRS and the patient-completed Beck Depression Inventory (BDI) serving as secondary outcome measures.

Nemets et al. randomized 20 Israeli outpatients (mean age: 53.4 [28–73] years), meeting DSM-IV criteria for a current diagnosis of major depressive disorder, to receive either 2 g/d E-EPA derived from 96% pure fish oil (stabilized with 0.2% vitamin E) or matching placebo (undefined) given in 1 g doses twice daily (via 50 0mg soft gelatin capsules) for 4 weeks.^97^ Only one patient did not continue receiving the antidepressant treatment they had been taking for at least 3 months, making this male's trial an evaluation of the impact of E-EPA as a primary treatment. He was exhibiting a 4-month severe depressive disorder that had been resistant to treatment with two different SSRIs. All other study participants had, in the past, suffered relapses when antidepressant doses were reduced or discontinued altogether. The primary outcome measure was the HDRS, with ratings conducted at baseline and weekly thereafter in this double-blind trial.

Su et al. conducted an eight-week, double-blind, placebo-controlled parallel RCT.^96^ They compared the impact, on HDRS scores, of 6.6 g/d of omega-3 fatty acids (i.e., 4.4 g/d EPA and 2.2 g/d DHA from menhaden fish) against placebo (i.e., olive oil ethyl ester) in 28 physically healthy outpatients diagnosed with DSM-IV major depressive disorder. Five identical gelatin capsules containing 440 mg EPA and 220 mg DHA were taken twice daily. Inclusion criteria were an HDRS score of at least 18, and no change in medication or psychotherapy 4 weeks prior to enrolment. Participants could not exhibit comorbid Axis I or Axis II psychiatric disorders, or be receiving antipsychotics or mood stabilizers. Placebo responders (i.e., mimimum 20% decrease in HDRS score) during a pre-randomization, one-week run-in were excluded. One participant in each group was free of medication, indicating that their trials assessed the primary treatment of depression. Followups using the HDRS occurred every 2 weeks. Dietary frequency ratings, recorded food diary data, and blood samples to assess the fatty acid content of RBC membranes were assessed during the run-in and at 8 weeks.

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. Three parallel RCTs involving adults addressed the question (Summary Table 2; Evidence Table 1: Appendix E).^53,^ ^96,^ ^97^ Only Su et al.^96^ and Nemets et al.^97^ provided detailed descriptions of both inclusion and exclusion criteria. Only Peet and Horrobin^53^ employed a design having more than two study groups (i.e., 4). A total of 118 adult outpatients were randomized. The mean sample size for the three studies was 39.3 (range: 20–70) participants, with the Peet and Horrobin trial being much larger than either of the other two. The studies' participants received the intervention for an average of eight (range: 4–12) weeks, with Peet and Horrobin's intervention period lasting the longest. The RCTs were conducted in three countries outside North America: the UK,^53^ Israel,^97^ and China.^96^ The UK RCT was funded by industry (Laxdale Research Ltd),^53^ the study from China was funded by government (National Science Council) and industry (China Chemical & Pharmaceutical Company),^96^ and the Israeli trial's funding source was not reported.^97^

Population characteristics. The mean age of study participants across the three trials was impossible to determine given that full sample means were not given for two trials.^53,^ ^96^ Participants' ages ranged from 18–73 years when two studies' data were combined.^53,^ ^97^ Participants in the Su et al. study tended to be younger (mean for omega-3 group=35.2 years; placebo group: 42.3 years), on average, than participants in the Peet et al. (means of four groups: 43–48 years)^53^ or Nemets et al. studies (omega-3 group mean: 54.2 years; placebo mean: 52.1).^97^ Females were consistently more strongly represented in the three trials (82–85%). Racial/ethnic backgrounds included Asian^96^ and Middle Eastern,^97^ yet no data were provided for a potentially diverse UK population.^53^

Only the Peet and Horrobin RCT^53^ did not report having employed any formal diagnostic criteria. The other two studies used DSM-IV to identify populations with major depressive disorder. Rather, the UK study required a score of at least 15 on the HDRS, and thus likely identified their participants as merely experiencing persistent depressive symptomatology. Nemets et al.'s participants had had relapses in the past when medication dosages were reduced or discontinued.^97^ All three studies employed the HDRS score to establish the severity of the psychiatric condition. While Peet and Horrobin required a score over 15, Su et al. required a score above 18.^96^ Nemets et al. only reported mean actual HDRS scores of 22.3 (placebo group) and 24.0 (EPA group).^97^ Based only on completer data subjected to a statistical test, Su et al. noted that HDRS-defined severity was equivalent for study groups.^96^ Peet and Horrobin did not present baseline HDRS severity data for study groups.

Peet and Horrobin^53^ did not identify or exclude any comorbidity while Nemets et al. required that there be no unstable medical disease, no alcohol or drug abuse, no psychotic features, no history of hypomania or mania, and no comorbid psychiatric diagnosis other than panic disorder (n=2, one per study group), dysthymic disorder (n=2, one per study group), and obsessive compulsive disorder (n=1, E-EPA group).^97^ Su et al. asserted that no one in their sample received any other Axis I or any Axis II psychiatric diagnosis.^96^

Likely because their study participants did not receive a formal diagnosis, Peet and Horrobin did not report data concerning the duration of the current depressive episode, age of onset, the number of previous episodes, or the time since diagnosis.^53^ Su et al. reported the study groups' mean current episode duration (omega-3 group: 21.5 weeks; placebo group: 22.8 weeks), age of onset (omega-3 group: 30.6 years; placebo group: 35.1 years), number of previous episodes (omega-3 group: 2.5; placebo group: 2.3), but not the time since diagnosis.^96^ Statistical tests of the possible significance of between-group baseline differences exclusively for completers revealed that study groups were comparable on these bases as well as with respect to age, percentage of males, body mass index, HDRS score, and both EPA and DHA levels in RBCs. Nemets et al. reported their sample's mean current episode duration (EPA group: 44.6 days; placebo group: 43.1 days), time since diagnosis (EPA group: 7.6 years; placebo group: 8.0 years), number of previous episodes (EPA group: 2.1; placebo group: 1.9), but not their age of onset.^97^ While statistical tests of significance were not employed, notable between-group differences at baseline were not observed for these variables.

Only Nemets et al. controlled for two of these potential confounding influences by excluding participants if they had had substance abuse or unstable medical problems.^97^ Only Su et al. reported data reflecting the omega-3 fatty acid content of biomarkers at baseline, which by statistical analysis, were comparable between study groups. They did not, however, report the units of measurement for biomarker data (e.g., absolute level; percent of total fatty acids).^96^

Intervention/exposure characteristics. Both Su et al.^96^ and Nemets et al.^97^ identified the source of their intervention as fish oil whereas Peet and Horrobin^53^ reported no details. Only Su et al. identified the exact type of source: menhaden fish.^96^ Nemets et al. compared 2 g/d E-EPA derived from 96% pure fish oil (stabilized with 0.2% vitamin E) and a matching, albeit undefined placebo.^97^ Peet and Horrobin employed 1 g/d, 2 g/d, 4 g/d or placebo (liquid paraffin) as their intervention.^53^ Su et al.'s participants received 6.6 g/d of omega-3 fatty acids (i.e., 4.4 g/d EPA and 2.2 g/d DHA) or placebo (i.e., olive oil ethyl ester).^96^ Only Su et al. used DHA in addition to EPA. Each RCT employed a placebo control and used the appropriate numbers of capsule and amounts of placebo content to equalize the total daily “intervention” across their study groups.

Omega-3 fatty acid contents were delivered by capsule in each study. However, there are few clear data to suggest that all three studies were equally able to eliminate the possible confounding influence of having unequal amounts of calories, as energy, provided for their different study groups. Nemets et al.'s placebo was not defined, making it impossible to know whether participants in each study group received the same number of calories. Although it is possible, ultimately it is unclear whether a unit of Peet and Horrobin's liquid paraffin, an inert lubricant laxative, provided the same caloric/energy content as that received from purified EPA. Given that the typical laxative dose is 15–30 g/d, and that Peet and Horrobin's study, as well as others described in this review, have consistently used much smaller daily doses, it is unlikely that its laxative effect would be any worse than that produced by a similar food oil.^87^ Su et al., on the other hand, used olive oil ethyl ester to match their groups for energy/caloric intake.

If, as it was decided in consultation with the TEP working with us on our review of the evidence regarding the effects of omega-3 fatty acids on asthma,^72^ and recognizing the FDA view that a 3 g/d dose of EPA and DHA is safe,^160^ then two of the standardized doses in the three studies met our criterion that 3 g/d is a high dose of omega-3 fatty acid supplementation: Su et al's 6.6 g/d EPA plus DHA,^96^ and Peet and Horrobin's 4 g/d E-EPA.^53^

None of the RCTs provided omega-6 fatty acids or any other supplement as cointervention, and none attempted to implement a specific on-study ratio of omega-6/omega-3 fatty acid intake through diet and/or supplementation. Nemets et al.^97^ and Peet and Horrobin^53^ did not report whether their study participants were told to maintain their background diet, to alter their background diet in some uniform fashion (e.g., modify omega-6 fatty acid intake and thereby change their omega-6/omega-3 fatty acid intake), or whether participants routinely complied with any such mandates. Only Su et al. established, for example, that study groups did not differ in terms of their on-study dietary frequency of fish intake as reported via 24-hour recall and three-day dietary records.^96^ Few compliance data, in general, were provided. Peet and Horrobin used capsule counts to report that at least 90% of the dose had been consumed in each of the four study groups.^53^ Even then, this method for determining compliance may not be overly accurate. Moreover, fatty acid content in biomarkers is likely not a perfect methodology either, given that EFA status can be influenced by various factors in addition to intake (e.g., oxidative degradation). Without hard data it is thus difficult to rule out the possibility in at least two studies that notable changes did not occur in the on-study background diet (i.e., Nemets et al., Peet et al.) or that protocol violations with respect to the number of capsules ingested did not occur, leaving unknown the extent of possible confounding with regards to clinical outcomes (i.e., from unplanned changes in the study groups' equivalence of energy/caloric intake from the “exposure” or related to unplanned changes in the between-group difference in the amount of omega-3 fatty acid received from supplementation).

Of the three trials, only Peet and Horrobin^53^ failed to report having stabilized their omega-3 fatty acid doses with some form of anti-oxidant. Su et al. attempted to maintain blinding by having all capsules vacuumed to deodorize any odour, and having their contents blended with an orange flavor.^96^ Anti-oxidant tertiary butylhydroquinone (0.2 mg/g) and tocopherols (2 mg/g) were added to all capsules both to maintain blinding, by preventing oxidation and rancidity, and to avoid possible confounding that could occur if these were added only to active treatment capsules and actually produced psychotropic effects,. In spite of no effort to deodorize their intervention, Nemets et al.'s participants were unable to reliably guess which capsules they had taken.^97^

For all three RCTs, the manufacturer of the omega-3 intervention was reported. Purity data were provided for two of the trials' exposures.^53,^ ^97^ In the one study that evaluated the fatty acid content of biomarkers, no notable inappropriate methods to extract, prepare, store or analyze lipids were described.^96^ No study report included details as to whether, or how, the presence of methylmercury was tested or eliminated from the omega-3 fatty acid exposure.

Cointervention characteristics. Given the focus of the present question is supplemental treatment, it could be argued that the omega-3 fatty acids are the cointervention. Nevertheless, to simplify matters, “cointervention” is defined as those other treatments or interventions that are provided concurrently, even if their initiation predated the omega-3 fatty acids intervention.

Peet and Horrobin reported similar distributions of background treatment by type of antidepressant (i.e., tricyclics, serotonin selective reuptake inhibitors [SSRIs], and others) in each study group.^53^ They did not present data regarding whether or not this antidepressant use remained constant, by type or dose, over the study for any of their study groups. Nemets et al. described their participants as having received their antidepressants for at least three weeks at the current dose.^97^ However, antidepressant medication was not distributed equally by type or dose across study groups. There was similar fluoxetine and mirtazapine use and doses, but five placebo and one E-EPA participant received paroxetine, usually at 20 mg/d. As well, the E-EPA study group included the only three users of fluvoxamine and the only recipient of citalopram. Moclobernide was given to a single participant in the placebo group. Participants on prestudy medication in Su et al.'s trial maintained their dosages on-study, with only oral sedatives/hypnotics (loazepam or zolpidem) permitted as additional therapy for possible anxiety or insomnia.^96^ They did report statistically-tested between-group baseline comparability for completers' duration of antidepressant use prior to enrollment or their (fluoxetine equivalent) dose of antidepressants while being enrolled.

Certain population characteristics have the potential to influence mental health outcomes if, in controlled investigations, study groups diverge significantly at baseline on these bases, or if unplanned on-study changes unrelated to the exposure occur in their status that vary notably across study groups (or within a single study group). Some cointerventional factors may exhibit a similar potential to confound clinical outcomes (e.g., psychological interventions, other licit drug use, use of complementary/alternative medicine/products, other supplement use with psychotropic potential). Not reported in the three included RCTs were data regarding the between-group comparability at baseline, or data regarding the on-study change in the status of these factors, making it difficult to rule out the possibility that these variables influenced clinical outcomes.

Outcome characteristics. All three RCTs employed the validated HDRS as the primary outcome.^53,^ ^96,^ ^97^ While Peet used the validated MADRS and BDI as well, Su et al. assessed the omega-3 fatty acid content of biomarkers.

Study quality and applicability. The three RCTs received a mean Jadad total quality score of 3.6, indicating sound internal validity (Summary Matrix 1). The trials conducted by Peet and Horrobin^53^ and Nemets et al.^97^ each received a score of 4, while Su et al.'s score was 3.^96^ The latter two studies^96,^ ^97^ each received an applicability rating of III, and a II was assigned to Peet and Horrobin's UK trial.^53^ Overall, these studies' individual or collective results were not readily generalizable to a North American population.

Summary Matrix 1: Study quality and applicability of evidence regarding the supplemental treatment of depression

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Peet^A^ | 2002 | 70
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Nemets^U^ | 2002 | 20 | Su^U^ | 2003 | 28

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

### Qualitative Synthesis of Individual Study Results

Peet and Horrobin's trial conducted both ITT (last observation carried forward) and per-protocol (PP) analyses, the latter assessing study completer data.^53^ Analyses of variance (ANOVA) compared data reflecting change from baseline to study endpoint for each active treatment group with comparable data from participants receiving placebo. All of the ITT and PP analyses involving each of the 3 scales showed that participants in the 1 g/d group improved significantly more than did those in the placebo group. For the 2 g/d and 4 g/d groups no comparison reached a level of statistical significance, with only the 4 g/d results for the PP population approaching statistical significance. For the 1 g/d versus placebo contrast, the HDRS and MADRS differences were already statistically significant at 4 weeks; only the BDI scores failed to show statistically significant changes at 4 weeks. Eight-week data regarding 1g/d supplementation was only provided for the BDI, and changes in these scores at 8 weeks only approached statistical significance. Analyses of specific items from the rating scales (i.e., the three main components of the HDRS [items 1–3: depression; 4–6: sleep; 9–11: anxiety] and the ten MADRS items) demonstrated that, for the comparison involving the PP population, there were no significantly greater improvements in the 1 g/d group compared with the placebo group. Statistically significant differences in favor of the 1 g/d dose were observed on the BDI-defined items pertaining to sadness, pessimism, inability to work, sleep disturbance and libido. These results suggest improvements defined by both patient and clinician assessments. While results of tests of statistical significance were not reported, the number of participants exhibiting a 50% improvement was always higher, when compared with placebo rates, in the 1 g/d and 4 g/d groups for all three scale scores assessed in both the ITT and PP populations. Yet, response rates for placebo participants consistently exceeded those from participants receiving the 2 g/d dose.

Analyses of covariance (ANCOVA) of Peet and Horrobin's data for each of the rating scales at each of the followups assessed overall differences between study groups.^53^ They revealed that center (exact number unreported) and background medication, by class (i.e., tricyclic, selective serotonin reuptake inhibitor [SSRI], or either norepinephrine or mixed reuptake inhibitors), had no significant effects on any rating scale scores in the ITT and PP populations. Baseline HDRS score had no effect on the HDRS and MADRS outcomes in either of the ITT or PP populations yet had a significant effect on BDI outcome only in the ITT population. Treatment had a significant overall effect on all three rating scale scores for both the ITT and PP populations yet the p-value for the HDRS comparison in the ITT population barely missed indicating statistical significance.

Nemets et al.'s multivariate analysis of covariance (MANCOVA), with baseline HDRS score as covariate, described a statistically significant treatment-by-time interaction in the ITT population (i.e., last value at week three carried forward, n=1).^97^ This observation was maintained after the week three HDRS score from the sole placebo dropout was excluded. Compared to placebo, E-EPA yielded significantly improved HDRS scores at each of weeks 2, 3 and 4. The mean reduction in HDRS score in the E-EPA group (12.4 points) was greater than that in the placebo group (1.6), and was considered clinically meaningful. Only one of ten patients in the placebo group and six of 10 in the E-EPA group achieved a 50% reduction in HDRS score. Item analysis showed that E-EPA influenced core symptoms such as depressed mood, feelings of guilt, feelings of worthlessness and insomnia. The investigators did not remove from any analyses the one study patient who was receiving E-EPA as monotherapy.

Su et al. observed, by week 4, and likewise for weeks 6 and 8, a statistically greater HDRS-defined improvement in the active treatment group.^96^ By repeated measures ANOVA it was found that the rate of reduction in HDRS scores was also significantly greater in the omega-3 fatty acids group. Pre- and post-intervention RBC fatty acid status data were limited, with a significantly increased level of DHA seen at post-treatment for the EPA group (n=7) but not the placebo group (n=6). No statistically significant increases in EPA levels were observed for either study group.

Nemets et al. reported a single study dropout, from the placebo group, by week 3 because of worsening depressive symptoms.^97^ Six of 28 participants dropped out prior to week 8 in Su et al.'s trial; two had been receiving active treatment (one lost to followup, and one lost due to noncompliance), and four were in the placebo group (three lost to followup, one lost due to noncompliance).^96^ Ten participants left Peet and Horrobin's trial,^53^ with four from the placebo group (one lost to followup, one withdrew consent during study, one violated protocol, one had an adverse event presumed to be unrelated to treatment) and two from each of the E-EPA groups (no data by group: three withdrew consent, one left due to lack of efficacy, one violated protocol, one had gastrointestinal adverse event).

### Quantitative Synthesis

We decided it was reasonable to explore the possibility of conducting meta-analysis for this question. HDRS was chosen as the primary outcome measure. We aimed to extract the mean change from baseline in HDRS, together with the standard deviation of this change, for each study group. The goal was to focus on the ITT population. We requested data to afford this analysis from the lead investigators of the Peet and Horrobin^53^ and the Su et al. trials.^96^ Only the former replied, passing on our request to the company now holding their data. A representative of the company stated they would consider the request yet no further reply was received.

In order to help decide on the possibility and appropriateness of meta-analysis, we created a forest plot of all possible combinable results. Length of follow-up varied notably between studies, so from each study we considered the longest followup data reported in addition to 4 week and 8 week results where they were provided. Su et al.'s study^96^ used capsules containing EPA together with DHA to yield a very high total dose (6.6 g/d). The other two studies^53,^ ^97^ employed capsules exclusively containing E-EPA. The study by Peet et al.^53^ reported change in HDRS after 12 weeks of treatment for four different study groups (placebo, 1 g/d, 2 g/d, and 4 g/d). Although the standard deviation of change from baseline was not reported, p-values for change from baseline relative to placebo were reported for each dose so that the standard error for each contrast could be inferred. Su et al.^96^ reported mean HDRS scores at baseline and post-treatment, but not the standard deviation in the change from baseline. We were nevertheless able to extract estimates from one of their graphs.

The Peet et al.^53^ and Nemets et al.^97^ studies reported ITT analyses (using a last observation carried forward strategy). Yet, it was unclear whether Su et al.^96^had also employed an ITT approach. In addition, their data concerning loss to followup at 4 weeks and 8 weeks were unclear.

After a careful appraisal of the estimates and key study parameters, however, it was decided not to conduct meta-analysis. No pooled estimate was derived because of the variations in dose both within and among studies, and in view of variations in the length of followup. It should also be noted that, in the Peet and Horrobin study^53^ the estimates for the different doses involving placebo shared the same placebo group. As well, Su et al.'s intervention was the only one including DHA in addition to EPA,^96^ as the other trials employed purified forms of E-EPA.^53,^ ^97^ All three RCTs employed different types of placebo. Finally, unlike the other two studies wherein patients had been formally (DSM-IV) diagnosed with major depression, Peet and Horrobin's use of a HDRS cut-off score to identify study participants yielded, at worst, a population with persistent depressive symptomatology.^53^

### Impact of Covariates and Confounders

Overall, the Su et al. study was the one exhibiting the best control of extra-interventional factors with the potential to influence, and thus confound, study results.^96^ Without repeating all of the details presented in the qualitative synthesis, these investigators indicated that study groups were balanced for key population (e.g., severity of depression, age of onset, absence of other Axis I or Axis II disorders) and cointervention parameters (e.g., patients asked to maintain constant on-study medication, although they did not demonstrate between-group baseline comparability for types and doses; established a maximum weekly frequency of background fish intake). Although Peet et al. provided few population data, their undiagnosed sample did not exhibit comorbid conditions and their study groups' patterns of medication use were similar.^53^ Nemets et al., on the other hand, did not evaluate whether study groups of depressed patients were similar at baseline in terms of the severity of their depressive symptomatology. They also reported that study groups varied in terms of their antidepressants. Still, their groups did not contain any individuals with unstable medical disease or substance abuse, and few comorbid conditions were observed. None of the studies reported data concerning prestudy/baseline omega-3 or omega-6/omega-3 fatty acid intake via diet or supplementation. Only Su et al. reported data regarding study groups' baseline comparability in their baseline omega-3 fatty acid content of biomarkers.^96^ They did not, however, report the units of measurement for these data (e.g., absolute level; percent of total fatty acids).

Dose, omega-3 fatty acid type, and whether the exposure was purified all failed to reliably predict clinical effects. For example, significant effects were associated with the largest (6.6 g/d EPA+DHA)^96^ and smallest doses (1 g/d E-EPA),^53^ various types of omega-3 fatty acid (EPA+DHA^96^ vs E-EPA^53,^ ^97^) and both EPA+DHA^96^ and E-EPA.^53,^ ^97^ Employed as a possible surrogate measure of background diet, or possibly even the background diet's omega-6/omega-3 intake ratio, the country in which a study was conducted did not predict study results. The lowest dose (1 g/d E-EPA), given to a UK population,^53^ and the highest dose (6.6 g/d EPA+DHA), given to a Chinese population,^96^ each yielded a significant clinical effect. The majority of study participants were female. Overall, though, there were too few studies with which to properly evaluate the impact of extra-interventional variables with the potential to influence study results.

## Is Omega-3 Fatty Acid Intake, Including Diet and/or Supplementation, Associated With the Onset, Continuation or Recurrence of Depression?

As observed in Summary Tables 3 through 6 (below), derived from Evidence Tables 1 through 3 (Appendix E†††), three types of evidence met eligibility criteria addressing this question. The qualitative synthesis distinguishes evidence from these types of study published between 1998 and 2004.

### Overview of Relevant Studies

Three RCTs,^98–100^ six observational studies^48,^ ^80,^ ^81,^ ^107,^ ^110,^ ^111^ and three cross-national ecological analyses^47,^ ^108,^ ^109^ were found to address this question.

Plasma DHA gradually decreases during the last trimester of pregnancy and remains low for some time during the postpartum period, and particularly in lactating women.^161^ It has been postulated that brain DHA levels may be low during late pregnancy and the early postpartum period, and that these levels may contribute to the development of postpartum depression.^162^ Postpartum depression is defined in DSM-IV as a major depressive, manic, or mixed episode in major depressive disorder, bipolar I or bipolar II disorder, or brief psychotic disorder. Llorente et al. thus attempted to determine the effect of DHA supplementation on the onset of postpartum depression as well as on plasma phospholipid DHA content in breastfeeding women (Summary Table 3).^98^ Mothers who planned to breastfeed their children (n=138; 18–42 years) were randomly assigned, in double-blind fashion, to receive either ~200 mg/d DHA or placebo (undefined) for the first four months after delivery. Clinical outcome was determined via the BDI, and was collected at baseline, 3 weeks, 2 months, and 4 months post-delivery. Depression-related data were obtained through the Structured Clinical Interview, DSM-IV, Axis I Disorders, Clinical Version (SCID-CV). As well, scores on the Edinburgh Postnatal Depression Scale (EPDS) of postpartum depression symptoms were obtained from subgroups of the sample. Plasma phospholipid data were collected just before delivery and at 4 months.

Wardle et al.'s RCT investigated whether cholesterol-lowering diets influence mood, including depression, anxiety, anger/hostility, stress, and general psychological well-being.^99^ Adult volunteers (n=176) with elevated serum cholesterol levels (>5.2 mM [198 mg/dL]) were allocated to a low-fat diet (n=59), a Mediterranean diet (n=61) or a waiting-list control (n=56). Dietary treatments were given in eight sessions over the 12-week period. Waiting-list controls were offered treatment at the end of their waiting period. Participants were exhibiting at least mild hypercholesterolemia by UK standards. Participants completed a 7-day dietary intake diary before the first assessment. Outcomes were assessed at baseline, 6 weeks and 12 weeks. These included the BDI, personal history of depression established through interview, and the following validated instruments: State-Trait Anger Inventory (STAI), the anxiety and anger subscales of the Profile of Mood States (POMS), the General Health Questionnaire (GHQ) to assess general psychological well-being, and the Perceived Stress Scale (PSS). Dietary diaries were filled out at baseline and 12 weeks.

Reflecting one factor of a factorial RCT investigating interventions to reduce mortality in angina (including: advice [not] to eat fruits and vegetables; [no] stress management), 452 males were allocated to receive advice to eat more fatty fish (i.e., mackerel, herring, kipper, pilchard, sardine, salmon, trout) or to receive no such advice. Study participants were supplied with MaxEPA® fish oil capsules if they did not like the taste of fish.^100^ Fish intake and mood (depression, anxiety) were assessed at baseline and at 6 months, the latter using the validated Derogatis Stress Profile (DSP).

In a recently published observational study, Hakkarainen et al. investigated the relationship between the dietary intake of omega-3 fatty acids and low mood, major depression, and suicide in males 50 to 69 years of age living in southwestern Finland in 1985 (Summary Table 4).^111^ The study identified a cohort (n=29,133) from a primary prevention RCT (ATBC Cancer Prevention Study). Followup lasted 9 years. The intake of fatty acids and fish consumption were derived from a validated food use questionnaire focused on the “last 12 months.” Self-reported depressed mood, suicides and hospital-based treatments for major depressive disorder were evaluated.

Tanskanen and colleagues undertook two non-overlapping cross-sectional surveys in Finland.^80,^ ^81^ Both were published in 2001. In a random sample of 3,204 Finnish adults (25–64 years), depressive symptomatology was measured using the BDI.^81^ A single food-frequency question assessed fish consumption (fish type unspecified) regarding the previous 6 months. For this study, the sample was drawn from two coastal and two lakeside areas in 1992 (n=8,000). After health questionnaires were returned, and medical examinations completed, a random sample of participants was selected based on birthdays between the twelfth and the last day of each month (n=5,105). Following other clinical measurements, this group was given a questionnaire, which included psychosocial variables. The response rate was 67% (n=3,403), while another 199 individuals did not provide complete data sets. In all, 3,204 subjects became the study sample.

In Tanskanen et al.'s other study a sample was selected, in 1999, based on a random population sample (National Population Register) of both sexes (n=3,004; 25–64 years).^80^ The number of respondents was 1,767 (59%), and they resided in Kuopio in the central-eastern part of Finland (lakeside area). Data were gathered on fish consumption, depression (BDI) and suicidality. The latter was measured using a single BDI item.

Three additional studies involved more specific definitions of population in evaluating the possible relationship between omega-3 fatty acid intake and the risk of geriatric depression (Summary Table 5). In 1991-1992, Woo et al. conducted a single cohort, 3-year prospective study examining the possible relationship of physical activity, dietary habits (e.g., fish consumption), smoking and alcohol consumption with three-year mortality as well as other health outcomes.^110^ Participants included 2,032 elderly Chinese subjects (mean age: 80 years) recruited by stratified (by age: e.g., 80–84 vs 85–89 vs >90 years) proportional random sampling.

In a cross-sectional study examining the possible association of omega-3 fatty acid intake and the prevalence of depression in 902 Japanese individuals newly diagnosed with primary lung cancer, Suzuki et al. employed a food frequency questionnaire and the depression subscale from the validated Hospital Anxiety and Depression Scale (HADS).^107^ Data from 771 patients were analyzed after excluding those failing to complete the HADS (n=73) or the food frequency questionnaire (n=62), or those having incorrectly completed the latter (n=24).

Edwards et al. measured the dietary PUFA intake as well as the fatty acid content of RBCs in a cross-sectional study of ten depressed patients and fourteen matched healthy control subjects.^48^ Biomarker results are described in a later section although the key study parameters are presented in relation to the current research question concerning the possible association of omega-3 fatty acid intake and depression. Analyses controlled for stress and smoking status.

Cross-national, ecological analyses can highlight evidence concerning the possible relationship between intake of omega-3 fatty acids and risk of depression in spite of certain inherent limitations of these data (see Discussion). Hibbeln ^47^ utilized cross-national epidemiology data from eight (of the ten) countries in Weissman et al.'s study regarding major depression (and bipolar disorder),^46^ to which they added prevalence data from Japan (Summary Table 6).^47^ Weissman et al.'s study had evaluated 35,000 participants using a random prospective design, repeat sampling techniques, multiple community sampling, and a structured interview process with accepted diagnostic criteria.^46^ Apparent fish consumption was estimated; it is an economic measure of disappearance of seafood from the economy.^108^

In a second ecological analysis, Hibbeln assessed the interrelationships among seafood consumption, the DHA content of mothers' milk, and prevalence rates of postpartum depression (n=14,532 subjects in 41 studies).^108^ To maximize comparability the investigator identified only published prevalence data for postpartum depression that had used the EPDS, and correlated these data with those indicating the EPA, DHA and AA content in mother's milk as well as published seafood consumption rates from 23 countries.

Peet's cross-national ecological analysis focused on international variations in the prevalence of depression and the outcome of schizophrenia, and their possible prediction by patterns of omega-3 fatty acid intake.^109^ Data on food use were taken from the FAOSTAT database, and reflected apparent national food consumption.^163^ Data on depression prevalence were again borrowed from Weissman et al.^46^ and the same Japanese source used by Hibbeln.^47^ Two-year outcome data relating to schizophrenia were drawn from the WHO's International Pilot Study of Schizophrenia (IPSS).^164^ A second source of schizophrenia outcome data was the Determinants of Outcome of Severe Mental Disorders (DOSMED) study.^165^ Schizophrenia results are presented later in this report.

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. One RCT employed a parallel design with two study arms,^98^ a second included three study groups,^99^ and the data from the third study came from one factor of a factorial RCT design (Summary Table 3; Evidence Table 1: Appendix E†††).^100^ In one study, the focus was on the possible utility of omega-3 fatty acids to affect the likelihood or intensity of mood changes in a population at risk for postpartum depression.^98^ In the other two studies, the intervention given for a medical disorder conveniently allowed the investigators to examine the possible relationship between omega-3 fatty acid intake and mood.^99,^ ^100^ These two studies' inclusion and exclusion criteria therefore pertained to the primary reasons these narrowly defined populations were studied in the first place: adults with elevated serum cholesterol levels, and for whom one of their cholesterol-lowering treatments was thought to have the potential to influence mood;^99^ and, males with angina, whose “fish advice” intervention was also thought to have the potential to affect mood.^100^

The populations from the latter two studies did not include individuals with formal diagnoses of depression.^99,^ ^100^ Given the heterogeneous nature of the populations, it made little sense to synthesize many of the study characteristics (e.g., mean sample size). The interventions lasted an average of 18.4 (range: 12–26) weeks. Two of the studies were conducted in the UK^99,^ ^100^ and a third in the US.^98^ Llorente et al.'s study was supported by industry (Martek Biosciences Corporation),^98^ Ness et al.'s by the UK Medical Research Council,^100^ and Wardle et al.'s by government as well (Biotechnology and Biosciences Research Council).^99^

Three of the included observational studies were conducted in Finland.^80,^ ^81,^ ^111^ Inclusion/exclusion criteria were published elsewhere for Hakkarainen et al.'s study,^111^ while eligibility criteria were delineated in each of Tanskanen et al.'s reports.^80,^ ^81^ None of the study reports made reference to a funding source.

Woo et al.'s single prospective cohort was well-defined.^110^ Clearly delineated eligibility criteria regarding the cancer diagnosis were included in Suzuki et al.'s report.^107^ Their survey was filled out both prior to and during hospital admission. Edwards et al. reported well-defined exclusion criteria.^48^ Neither Woo et al.^110^ nor Edwards et al.^48^ identified their funding source(s). Funding for Suzuki et al.'s study was received as a Grant-in-Aid for Cancer Research and Second-Term Comprehensive Ten-Year Strategy for Cancer Control and Research of the Japanese Ministry of Health, Labour, and Welfare.^107^

Eligibility criteria were sparse in Hibbeln's first report of a cross-national ecological analysis^47^ and were explicitly stated in their second one.^108^ Peet's descriptions of eligibility criteria were clear.^109^ Neither Hibbeln^47^ nor Peet^109^ reported their funding source. Hibbeln's second study was funded in part by a Young Investigators Grant from the National Association for Research on Schizophrenia and Depression (NARSAD).^108^

Population characteristics. Given the heterogeneous nature of the included studies' populations, again it made little sense to synthesize some of the population characteristics from the three RCTs (e.g., mean age, mean percent males). Racial/ethnic backgrounds included a potentially diverse UK sample,^99^ a predominantly Caucasian (82%) US population,^98^ and a likely Caucasian/European one.^100^

In Llorente et al.'s trial, women intending to breast-feed were excluded if they exhibited a chronic medical condition, were current smokers, or had been pregnant more than five times.^98^ No significant differences were observed for baseline BDI scores for depression. As well, there were no mean differences between study groups for mother's age, education, racial/ethnic distibution, and several pregnancy/delivery/infant-related factors (i.e., parity, gravidity, delivery weight, prepregnancy weight, gestational ages of infants, infants' birth weight, sex distibutuion of births, Apgar scores at 1 or 5 minutes).

In Wardle et al.'s study, adults with elevated serum cholesterol levels (>5.2 mM [198 mg/dL]) were excluded from the RCT if they were pregnant, lactating or planning pregnancy.^99^ There were no significant differences among the study groups for any of the baseline mental health (i.e., BDI; depression, anxiety or anger scores on POMS; general psychological well-being; stress; state anger and anger reactions scores on STAI), background diet (i.e., g/d or percent of energy saturated fat; g/d fiber), or other characteristics (i.e., age, marital status, sex, BMI, total, HDL, LDL cholesterol and triglyceride parameters). Seven-day diary data showed that reported energy intakes were reasonable for adults this age.

No statistical differences were observed with respect to the following baseline characteristics in Ness et al.'s RCT of adult males with angina: depression score, anxiety score, eicosapentaenoic acid (mg/d: measurment undefined), social class, past history of cardiovascular disease, smoking, fish intake, and fruit and vegetable intake.^100^ Data regarding the baseline between-group comparability, or on-study change, with respect to other factors with the potential to influence mental health were not reported for the three studies (e.g., stressors, social support).^98–100^ Likewise, data regarding the baseline comparability, or on-study change, with respect to key dietary characteristics (e.g., omega-3 or omega-6/omega-3 fatty acid content of the baseline or on-study diets) were not provided by study authors. For example, whether study groups' caloric/energy intake was equivalent in any of the studies could not be determined from reports.

The focus in Hakkarainen et al.'s observational study was on the mood experienced in the 4 months prior to their previous study visit.^111^ Mood difficulties ranged from 5 to 8 years in duration (median=6). Alcohol consumption was also assessed via validated food-use questionnaire. Various covariates were entered into data analysis (see below). In each of Tanskanen et al.'s observational studies, the nature of the sampling meant that individuals varied in terms of their levels of depressive symptom, or even their thoughts of harming themselves.^80,^ ^81^ Woo et al.'s population were elderly Chinese potentially experiencing depressive symptomatology^110^ while Suzuki et al.'s population of newly diagnosed primary lung cancer patients included 436 (of 771: 56.5%) with analyzable data, and who were exhibiting depressive symptomatology.^107^ Edwards et al. identified ten individuals with a major depressive episode using DSM-IV criteria. Each was receiving antidepressant medication. Exclusion citeria included physical illness of a severity or nature suggestive of low omega-3 fatty acid levels. The 14 healthy controls showed no history of psychiatric disorder although how this was determined was not reported. Matching was based on age, sex, social class, BMI, number of children, recent life events, smoking habits, and alcohol consumption. An assessment of these data revealed the soundness of the matching strategy. All study participants were evaluated using the BDI.

Hibbeln's cross-national ecological analysis^47^ identified its populations by using Weissman et al.'s cross-national prevalence study, which included a structured clinical interview employing accepted diagnostic criteria (DSM-III).^46^ The core symptoms of major depression, and not merely symptom severity as reflected in rating scale scores, were identified. Hibbeln drew data on the annual prevalence of major depression in Japan from the Ministry of Welfare (n=130,000). However, one limitation of these Japanese data is that they were not produced using a structured diagnostic instrument or random population sampling techniques.

In his second analysis Hibbeln's populations were drawn from countries varying in terms of their background diet.^108^ A high score indicated severe depressive symptomatology rather than a major depression. Prevalence data were derived from well-defined populations. Peet's cross-national ecological analysis^109^ included data on depression prevalence once again borrowed from Weissman et al.^46^ and the same Japanese source used in Hibbeln's first analysis.^47^ Two-year data concerning the outcome of schizophrenia were drawn from the WHO's International Pilot Study of Schizophrenia (IPSS). A second source was the Determinants of Outcome of Severe Mental Disorders (DOSMED) study.

Intervention/exposure characteristics. Given the great divergence of interventions or exposures, it likely makes little sense to synthesize many of the intervention/exposure characteristics (e.g., mean dose or serving size; number of studies utilizing a “high” dose or serving size). Two of the RCTs encouraged specific dietary patterns^99,^ ^100^ while the third provided supplementation capsules.^98^ Regarding the latter investigation, Llorente et al. provided ~200mg/d DHA from algae-derived triglyceride capsules yet did not describe the number of capsules constituting a “dose” or what the placebo capsules contained.^98^ Wardle et al.'s RCT allocated adults with elevated serum cholesterol levels either to a low-fat diet (i.e., reduce energy from [saturated] fats to <20%, and ingest mostly polyunsaturates), a Mediterranean diet (i.e., increase intake of fruits and vegetables, oily fish; reduce fat to 30% of calories; use monounsaturated fats instead of saturated fats) or a waiting-list control (i.e., no advice given yet not discouraged from making dietary changes). This entailed educating participants about recommended dietary changes and included a cognitive-behavioral intervention focused on implementing changes in eating behavior. Participants were also given spreadable fat and oils consistent with their assigned diet. Finally, Ness et al. observed that, at 6 months, of the men allocated to fish advice, 78% were consuming fish weekly or taking fish oil capsules (21%), as compared to 14% of those who did not receive fish advice. These details, in addition to the observation that compliance data were not always available, raise some doubt that participants in the different study groups in each RCT actually received a constant difference in their amount of omega-3 fatty acid intake, or an equivalent intake of calories/energy over the intervention period, sufficient to control for possible confounding stemming from such protocol violations.

None of the studies specifically identified the omega-6/omega-3 fatty acid content of their planned on-study^99,^ ^100^ or background diets.^98^ Llorente et al. did not report an attempt to maintain blinding via deodorizing their omega-3 fatty acid materials and/or by preventing oxidation and inevitable rancidity. Neither general purity data, nor data concerning possible methylmercury contamination, were provided regarding their DHA supplementation.^98^ On the other hand, Llorente et al. appeared to use appropriate methods to handle blood lipid materials.

Hakkarainen et al.'s observational study assessed habitual dietary intake over the previous year (measure undefined).^111^ This included fish consumption as well as the intake of omega-3 fatty acid content from fish and vegetables, and total omega-3 fatty acid intake. Total omega-3 fatty acid intake was calculated as 2.2 g/d or 0.47 g/d from fish, a value that they asserted is considerably higher than what is observed in North American populations.^111^

Tanskanen et al's single food-frequency question assessed fish consumption over the past six months ("How often do you usually eat fish or fish meals? 1, < once a month or never; 2, once or twice a month; 3, once a week; 4, twice a week; 5, almost daily; 6, once a day or more often).^81^ Responses of 2 or less constituted infrequent consumption. In their second observational study Tanskanen et al.^80^ estimated fish consumption via a food-frequency questionnaire (undefined) purported to produce comparable results to a 7-day food record.^166^ A frequent fish consumer was defined as someone eating fish at least twice a week.

Fish intake in Woo et al.'s study was measured via a food frequency questionnaire administered at the participants' residence.^110^ Suzuki et al. utilized a validated semiquantitative food frequency questionnaire regarding 138 foods, including 18 fish and seafood items. It had in the past exhibited a significant association with dietary record data.^107^ Participants were asked to report the average frequency, and usual serving size, of consumption during the year immediately preceding the onset of cancer symptoms. From this, Suzuki et al. calculated an average daily intake of food and nutrients. They then calculated the daily intake of omega-3 fatty acid content using the Fatty Acid Composition Table of Japanese Foods.^167^ For the 771 participants whose data were analyzed, total omega-3 fatty acid intake was primarily ingested from vegetable oils and fats (37% of total intake), followed by 17 types of fish (35%), soybean products (11%), seasonings (5%), and cereals (4%). The daily intake consisted of 62% ALA, 20% DHA, and 11% EPA.^107^ Edwards et al. completed a full analysis of the current diet using a 7-day weighted intake method.^48^ Although data are reported later in this report, it should be stated here that no notable inappropriate methods to extract, prepare, store or analyze lipids were described.^48^

Hibbeln's first ecological analysis estimated apparent fish consumption as: fish catch plus imports, minus exports.^47^ This method is not as reliable as direct dietary surveys but at least this analysis included comparable data across countries. In his second analysis apparent fish consumption data were drawn by Hibbeln from the National Marine Fisheries Service and the Food and Agriculture Organization of the United Nations.^108^ Data on food use were taken from the FAOSTAT database,^163^ and captured apparent national food consumption in Peet's analysis.^109^ Food use was estimated from the total domestic production of food plus imports, minus exports, while taking into account changes in stocks (e.g., stored grain), and subtracted food lost to waste during processing. Fish and seafood data were included, and were expressed as supply in kilograms per capita per year. Annual food consumption was approximated closest to the years in which the clinical studies were conducted (i.e., IPSS=1970; DOSMED=1980; depression=1990).^109^

The manufacturer of Llorente et al.'s intervention was Martek Biosciences Corporation.^98^ Purity data concerning its contents were not provided. No study report included details as to whether, or how, the presence of methylmercury was tested or eliminated from their omega-3 fatty acid exposure.

Cointervention characteristics. In Llorente et al.'s study, breast-feeding women were excluded if they used dietary supplements other than vitamins.^98^ Wardle et al. excluded participants if they were currently using, or had used within the last 3 months, lipid-lowering medication.^99^ In Ness et al.'s study, male adults were receiving anti-anginal medication, details of which were not provided in their report.^100^ The possible use of other products with psychotropic properties was not reported for these studies.

Of the six observational studies,^48,^ ^80,^ ^81,^ ^107,^ ^110,^ ^111^ only the study by Edwards et al. reported on the status of possible cointerventions. Each individual diagnosed as depressed was receiving antidepressant medication.^48^ Similar data were not reported in any of the cross-national ecological analyses.^47,^ ^108,^ ^109^

Outcome characteristics. Llorente et al. employed the BDI, EPDS and the SCID-CV, with the latter supporting DSM-IV diagnostic criteria.^98^ Wardle et al. used the BDI, along with the STAI, anxiety and anger subscales of the POMS, GHQ to assess general psychological well-being, and the PSS. Dietary diaries were filled out at baseline and 12 weeks. Ness et al. used the DSP to measure depression and anxiety.

Hakkarainen et al.'s study evaluated depressed mood via self-report (no measure identified).^111^ Assessments were recorded three times annually. Data on hospital-based treatments for major depressive disorder were drawn from the National Hospital Discharge Register, and suicides were identified from death certificates. Cox's proportional hazards regression models estimated the relationships between baseline dietary intake of omega-3 fatty acids (from fish, vegetables, and total intake), calculated from the food-use questionnaire and categorized in tertiles (with the lowest tertile as reference category), and measures of mood level and hospital-based treatments for major depressive disorder. The following potential risk factors for major depressive disorder and suicide were entered, as covariates, into the regression models: age, BMI, energy intake, serum total cholesterol, HDL cholesterol level, alcohol consumption, education, marriage, self-reported depression, self-reported anxiety, and smoking. Dietary factors were adjusted for energy intake.

The following BDI-defined distinctions were made in Tanskanen et al.'s first study: scores below 10 indicated no or minimal depressive symptoms; scores from 10–18 indicated mild symptoms; 19–29, moderate symptoms; and 30–63, severe symptoms.^81^ For bivariate analyses, the categories were normal mood, 0–9, and mild to severe symptoms, 10–63.^81^ Multiple logistic regression analysis assessed the relationship between BDI-indexed depressive symptomatology and fish consumption. Adjustments were made for these potential confounders: age, marital status, unemployment, current smoker status, irregular physical activity, female, BMI, more than 120g per week of pure alcohol, at least seven cups per day of coffee, low education level, and serum cholesterol level. The other Tanskanen et al. study also employed the BDI, while analyzing separately data for the single item pertaining to suicide ideation.^80^ Analyses adjusted for the following potential confounders: sex, age, marital status, education, employment status, work ability, area of residence, financial status, general health smoker status, alcohol intake, coffee intake, and physical activity.

Woo et al. utilized the GDS while adusting for age and baseline health status at the start of their 3-year study.^110^ From previous validational work it was reported that a score of at least 8 on the 15-point GDS provides a sensitivity and a specificity of 96.3% and 87.5%, respectively, for a psychiatric diagnosis of depression in the local Chinese population. The HADS depression subscale was employed by Suzuki et al.^107^ A cutpoint of 4 out of 5 has previously been observed to reflect good sensitivity and specificity (91.5% and 58%, respectively) for screening depression (e.g., major depression). Analyses adjusted for age, sex, performance status, clinical stage, histology, pain, breathlessness, employment status, smoker status, alcohol consumption, and BMI. Edwards et al.'s analyses controlled for stress and smoking status.^48^

Given the limitation of the Japanese data, in that they were not produced using a structured diagnostic instrument or via random population sampling techniques, data analysis in Hibbeln's first cross-national assessment was completed both including and excluding data from Japan.^47^ Since adverse personal, social and economic conditions can increase the risk of depressive symptomatology in the postpartum period, the following variables were controlled for in Hibbeln's second cross-national ecological analysis: study time postpartum, low socioeconomic status, percentage of young mothers, percentage of mothers without partners, percentage of mothers with secondary education, and the influence of Asian cultures.^108^ Data on depression prevalence in Peet's cross-national ecological analysis^109^ were captured from Weissman et al.^46^ and the same Japanese source used by Hibbeln.^47^ From the IPSS study, data on mean days out of hospital and percentage of patients with schizophrenia and severe social impairment were used as outcomes.^109^ In addition, a total outcome score was derived.^145^ It is a composite score taking into account all IPSS outcomes. From the DOSMED study, outcomes selected were percentage of patients never hospitalized and the percentage of patients with little social impairment. Urban data were used exclusively, where available. A “total best outcome” score was derived by adding data from various “best possible” DOSMED outcomes (e.g., remitting course with full remissions; on no antipsychotic medication during followup).

Study quality and applicability. The mean total Jadad quality score was 3,^98–100^ with two of the three RCTs adequately concealing their allocation of participants to study groups.^98,^ ^99^ The third RCT received an Unclear allocation concealment rating.^100^ The mean quality score for the two single prospective cohort studies was 4.5, with both studies attaining a III applicability rating.^110,^ ^111^ All three cross-sectional surveys received an applicability rating of III, and together they achieved a mean quality score of 4.7.^80,^ ^81,^ ^107^ The single cross-sectional study received a quality score of 6 and an applicability rating of II.^48^ The three cross-national ecological analyses received a mean quality score of 4, with all achieving an applicability rating of III.^47,^ ^108,^ ^109^ Of all the studies, only the Edwards et al. one received an applicability rating other than III (i.e., II),^48^ and only three investigations achieved a study quality grade of A.^98,^ ^107,^ ^108^

Summary Matrix 2: Study quality and applicability of evidence regarding the association between omega-3 fatty acid intake and onset, continuation or recurrence of depression (all designs)

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Llorente^A^ | 2003 | >89 | Edwards | 1998 | 24 | Ness^U^ | 2003 | 452
| | | | | | | | Wardle^A^ | 2000 | 176
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | Suzuki | 2004 | 902 | Hakkarainen | 2004 | >29k | Tanskanen | 2001 | >3k
| | Hibbeln | 2002 | 16C | Tanskanen | 2001 | >1k | Hibbeln | 1998 | 9C
| | | | | Woo | 2002 | >2k | Peet | 2004 | 8C

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment;

C = Countries;

k = 1,000's

### Qualitative Synthesis of Individual Study Results

Llorente et al. reported data only for completers for whom they had baseline and 4-month data.^98^ After 4 months of supplementation, plasma phospholipid DHA content in the DHA group had increased by 8% while the DHA content in the placebo group had decreased by 31%, the former observation indicating a reversal in the typical decline in DHA levels. The DHA content of the DHA group was 50% higher than that of the placebo group 4 months post-delivery. However, there were nonsignificant statistical differences between study groups after 4 months for the BDI, EPDS and the SCID-CV (diagnostic counts). Yet, according to BDI scores, only nine women in the placebo group and 11 women in the DHA group achieved a score of at least 10 at one of their followups, indicating minimal symptoms of depression (>9 may indicate mild symptoms). Two and four women in the placebo and DHA groups, respectively, had a BDI score of at least 20, indicating moderate symptoms. SCID-CV observations confirmed these results. Only seven women (DHA group=4; placebo group=3) met DSM-IV diagnostic criteria for a “current depressive episode” during the 4-month postpartum period.

All three of Wardle et al.'s study groups showed significant within-group improvement on many of the mental health outcomes after 12 weeks (i.e., BDI score and anger reactions in both diet groups; stress and anxiety only in Mediterranean diet group).^99^ Yet, there were no significant between-group differences observed for any of the following clinical outcomes: depression, anxiety, anger/hostility, stress, and general psychological well-being. Thus, no reliable associations between intake of omega-3 fatty acids and any of the examined indices of mental health were observed.

Ness et al. observed that self-reported fish intake was higher in the fish advice group at study's end.^100^ No statistical difference was observed in the fish advice group either for depression or anxiety; and, controlling for baseline mood, the between-group difference for each outcome was not statistically different. This last observation did not change following an additional adjustment made for one's status as having been randomized to the stress management arm, nor was there any statistical evidence of interaction between these factors in their effects on mood. Looking exclusively at the upper quartile of baseline depression or anxiety score did not contradict these observations.

In Llorente et al.'s study no subject withdrew due to adverse effects related to the supplement.^98^ However, 37 of 138 women either withdrew or were dropped. Thirteen withdrew because of maternal illness, 14 were dropped due to lactation failure or excessive formula intake by the child (>20% of total intake), one mother moved away, five were dropped due to infant illness, and four discontinued participation. Wardle et al. reported that similar numbers of patient withdrew before 12 weeks in each study group (low-fat=7; Mediterranean=8; control=6), and typically due to attendance problems.^99^ Seven men died within 7 months of randomization into Ness et al.'s trial (fish advice group=3), and for reasons other than the intervention.^100^

Hakkarainen et al.'s attempt, in their observational study, to assess the possible relationship between low dietary intake of omega-3 fatty acids and depression revealed that, accounting for the above-noted covariates, there was no significant association of fish consumption or calculated intake of omega-3 fatty acids and self-reported depressed mood, hospital treatment required due to major depressive disorder, or suicide (data not reported).^111^

Tanskanen et al. showed that, using BDI scores, 20% of their sample experienced mild depressive symptoms (n=647), 6.3% had moderate symptoms (n=201), and 1.5% reported severe symptoms (n=48).^81^ Sixty-four percent reported eating fish or fish meals once or twice a week (n=2,053), 6.3% ate fish daily (n=201), and 30% ate fish once or twice a month, or less often (n=950). From bivariate analysis, mild to severe depressive symptoms were more prevalent among women who infrequently consumed fish (less than once a week) than those who were frequent fish eaters (more than once per week). A similar trend was observed among men, yet the results were not statistically significant. Compared with frequent fish consumers (bivariate analysis), infrequent consumers were younger, less physically active, less obese, less likely to have a lower serum cholesterol level, unmarried, smoked, and drank a lot of coffee. Yet, higher age, being unmarried, unemployment, smoking, lower levels of physical activity, greater degree of obesity, low level of education, and higher serum cholesterol level were associated with depressive symptoms. Multiple logistic regression analysis, including confounders, revealed that infrequent fish consumption was independently associated with depressive symptoms. The likelihood of exhibiting mild to severe depressive symptoms was 31% higher among infrequent fish consumers than frequent consumers. Depressive symptoms were significantly associated with infrequent fish consumption for females only.

In their second cross-sectional study Tanskanen et al. observed that the risk of being depressed and the risk of suicidal ideation were significantly lower among those who frequently ate lake fish, compared with infrequent fish consumers.^80^ These relationships held after adjusting for the above-noted factors.

Woo et al. found nonsignificant adjusted and unadjusted estimates of association involving fish intake and depressive symptoms in a Chinese elderly population although data were not reported per se.^110^ They also observed that increasing levels of physical activity and occasional intake of alcohol were associated with a reduced risk of depressive symptoms. After 36 months, 341 participants (17%) had been lost to followup and 519 had died.

For newly diagnosed lung cancer patients Suzuki et al. reported a statistically significant adjusted odds ratio for depression between upper and lower quartiles of ALA and total omega-3 fatty acid intake, indicating a significant inverse association.^107^ They also found a statistically nonsignificant adjusted difference for depression between upper and lower quartiles of intake of EPA, DHA and EPA+DHA.^107^ Results of tests for trend paralleled these findings. But, no association was observed for depression and intake of fish or seafood, also following adjustments for potential confounders.

There were no significant between-group differences for current intake of omega-3 fatty acids or total energy intake assessed by 7-day dietary intake in Edwards et al.'s study.^48^ Within the depressed patient group there was a significant negative correlation between the BDI-defined severity of depressive symptomatology and dietary intake of total omega-3 fatty acids as well as ALA. When data were pooled from patients and controls and entered into multiple regression, none of the dietary omega-3 or omega-6 fatty acid variables were significant predictors of depression. Data pertaining to smoker status and stress were entered only into analyses involving biomarker data.

In their first cross-national ecological analysis Hibbeln found a significant, inverse correlation between apparent fish consumption (fish pounds per person; 1 pound = 0.4536 kg) and major depression.^47^ When data were excluded from Japan for the above-noted reason, a significant correlation was maintained. Data regarding potential confounders were not consistently available for each of the countries in Hibbeln's second cross-national ecological analysis.^108^. Nevertheless, simple regression and a logarithmic equation revealed that higher national seafood consumption predicted lower prevalence rates of postpartum depression, that higher DHA content in mother's milk predicted lower prevalence rates, and that the AA and EPA content of mother's milk were unrelated to prevalence rates of postpartum depression. Only low socioeconomic status, young maternal age, the percentage of women without partners, and percentage of mothers with a secondary education predicted prevalence rates. These relationships appeared to be influenced by data from Brazil and South Africa, suggesting that these results may have confounded the findings in the primary analyses. However, first excluding Asian countries' data because of their stronger intake of omega-3 fatty acids in the background diet, and then data from Brazil or South Africa, yielded findings paralleling those from the primary analyses. This indicated the robustness of the main findings.

Peet's schizophrenia results are presented below.^109^ He observed a significant association between high consumption of fish and seafood and a reduced prevalence of depression.^109^

### Quantitative Synthesis

Very few of the studies that met the eligibility criteria for this question actually demonstrated the inherent capacity to afford the drawing of causal inferences regarding the possible relationship between the intake of omega-3 fatty acids and the onset of depression as disorder or symptom. Only three of 12 studies were eligible for quantitative synthesis in that they were both controlled and prospective by design.^98–100^ The observation that these three RCTs employed highly different target populations, interventions, controls and outcomes made it inappropriate to consider conducting meta-analysis. Moreover, only one trial investigated the potential of specific amounts of omega-3 fatty acid content, via DHA supplementation, to protect its population (i.e., breastfeeding women) from developing (postpartum) depression.^98^

### Impact of Covariates and Confounders

With such diverse designs, populations, exposures, controls and outcomes it is difficult to cull patterns of notable finding regarding the influence of extra-exposure variables on outcomes pertinent to this review. The designs with the greatest inherent potential to control for confounding influences (i.e., RCTs)^98–100^ did not yield a single significant result, although the primary goal in two of them did not entail demonstrating the potential of omega-3 fatty acids as protection against depression.^99,^ ^100^ At the same time, the three RCTs likely confirmed, in part, the success of their randomizations by showing that study groups were equivalent at baseline on certain important bases (e.g., mental health variables).

Likewise, the multiple-group cross-sectional study did not reveal a significant association between omega-3 fatty acid intake and depression while also reporting that study groups were equivalent in their intake of omega-3 fatty acids, for example.^48^ And, while most of the uncontrolled observational studies did a reasonable job of adjusting for confounders in their analyses (e.g., age, smoker status, alcohol consumption),^80,^ ^81,^ ^107,^ ^111^ their results did not consistently show a significant association between the intake of omega-3 fatty acids and the risk of depression. Even the two surveys conducted in Finland, where fish intake is considerably higher than in North America, for example, failed to produce a consistent result for both sexes.^80,^ ^81^

The ability to control for confounders in the three cross-national ecological analyses depended on the initial data collection strategies, which produced the databases from which the three studies' data were obtained. Without all of the details, many of which were not published in the included reports, it is difficult to draw conclusions about these three analyses' successes or failures in controlling for key influences on outcomes.

## Is the Onset, Continuation or Recurrence of Depression Associated With Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Biomarkers?

As observed in Summary Tables 7 through 11 (below), derived from Evidence Tables 1 and 2 (Appendix E§§§), one RCT and various observational studies met eligibility criteria for this question. Studies were published between 1977 and 2003.

### Overview of Relevant Studies

Seven multiple-group cross-sectional studies^48,^ ^101–106^ and one RCT^98^ provided data pertaining to this question. Two studies have already had their key study parameters introduced with respect to the question of the possible association of omega-3 fatty acid intake and the onset, continuation or recurrence of depression. Yet, the Llorente et al. RCT^98^ and Edwards et al.'s multiple-group cross-sectional study^48^ data were nevertheless placed in summary tables.

Ellis and Sanders assessed the fatty acid content of plasma choline phosphoglycerides (CPG) and RBC ethanolamine phosphoglycerides (EPG) in patients diagnosed with endogenous depression (n=6), patients on the same ward yet with non-depressive psychiatric disorders (n=4; types undefined), and age- and sex-matched controls drawn from hospital staff (n=6) (Summary Table 7).^105^ Fehily et al. compared the fatty acid content of plasma CPG and RBC phospholipids in patients with: endogenous depression (n=26; mean age: 52 [21–74] years; 7 bipolar and 16 unipolar diagnoses; 54% drug-free for at least 2 weeks before study), those with reactive depression (n=23; mean age: 38 [22–65] years; 65% drug-free for at least 2 weeks), other psychiatric disorders (n=11; mean age=35 [19–59] years; 6 schizophrenia and 5 personality disorder diagnoses; 46% drug-free for at least 2 weeks) and age- and sex-matched healthy controls (n=undefined; age undefined).^106^

Maes et al. examined the fatty acid composition of serum cholesterol esters and phospholipids in 36 patients with major depressive disorder (with [n=11] or without melancholia [n=25]), 14 with minor depression (i.e., adjustment disorder with depressed mood and dysthymia) and 24 healthy volunteer subjects (staff or their family members) (Summary Table 8).^103^

Peet et al. investigated fatty acid composition in the RBC membranes of 15 drug-free patients with major depressive disorder, unipolar variety, and 15 age- and sex-matched healthy controls (Summary Table 9).^102^ All medication was stopped for 8 to 91 days prior to blood sampling.

Edwards et al. measured the dietary PUFA intake as well as the fatty acid content of RBCs in a cross-sectional study of ten depressed patients diagnosed with major depression using DSM-IV criteria, and 14 matched healthy control subjects.^48^ Each depressed patient was receiving antidepressant medication. Analyses controlled for stress and smoking status. Additional details regarding exclusion criteria or matching requirements were presented in relation to the question concerning the possible association between omega-3 fatty acid intake and the onset, continuation or recurrence of depression.

Maes et al.'s second study investigated 34 major depressed inpatients and 14 healthy volunteers in an attempt to establish whether major depression was associated with a decrease in omega-3 fatty acids or an increase in omega-6 fatty acids in serum phospholipids and cholesteryl esters (Summary Table 10).^101^ They also assessed the relationship between these PUFAs and levels of serum zinc (with a low level being a marker of the inflammatory response system's activation), as well as the effects of 5 weeks of subchronic treatment with antidepressants (i.e., fluoxetine 20 mg/d alone or with trazodone 100 mg/d or pindolol 7.5 mg/d) on fatty acid levels in 20 patients. Patients underwent a 10-day drug-free period upon hospital admission.

Tiemeier and colleagues investigated whether community-dwelling elderly with depression have a fatty acid composition different from those who are not depressed (Summary Table 11).^104^ As part of the Rotterdam population-based cohort study (n=7,983), 3,884 adults of at least 60 years of age were screened for depressive symptoms. Those that screened positive had a psychiatric interview to diagnose depressive disorders. After excluding individuals with other disorders (n=29), and following the loss of 14 subjects, study groups became: those with depressive disorder (n=106; 61–97 years), those with subclinical depressive symptoms (n=115; 61–93 years) and randomly selected controls who had screened negative for depression in the Rotterdam study (n=461; 61–101 years). The analysis included an assessment of the possible roles played by atherosclerosis and the inflammatory response, the latter measured by C-reactive protein. Given that certain factors such as chronic diseases, smoking and cholesterol concentrations have been related in community-dwelling populations to depression and fatty acid composition,^168^ they were investigated for their possible roles as confounders. Other confounders included: age, sex, level of education, history of stroke, cognitive function (Mini Mental State examination), functional status, and blood pressure.

Llorente et al. assessed the effect of DHA supplementation on the onset of postpartum depression as well as on plasma phospholipid DHA content in women who breast-feed.^98^ Mothers who planned to breast-feed their children (n=138; 18–42 years) were randomly assigned, in double-blind fashion, to receive either ~200 mg/d DHA or placebo (undefined) for the first 4 months after delivery. Plasma phospholipid data were collected just before delivery and at 4 months. Additional data regarding study, population and intervention parameters are presented with reference to evidence concerning the possible association of omega-3 fatty acid intake and the onset, continuation or recurrence of depression.

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. With the exception of Llorente et al.'s RCT,^98^ studies were cross-sectional studies involving at least two groups.^48,^ ^101–106^ Some study reports provided very detailed inclusion/exclusion criteria establishing strong experimental controls,^101,^ ^103^ whereas others provided very little information.^105^ Other reports provided sufficient detail to allow for an appreciation of the rigor associated with these studies.^48,^ ^98,^ ^102,^ ^104,^ ^106^ Study sizes varied between 16^105^ and 682 participants.^104^ Countries where the studies were conducted included England,^48,^ ^102,^ ^105,^ ^106^ Belgium,^101,^ ^103^ Holland^104^ and the US.^98^ Fehily et al's study was supported by a grant from the South Thames Regional Health Authority.^106^ The first Maes et al. study was funded by numerous sources, including the National Funds for Scientific Research (Belgium), the IUAP program (Belgium), as well as grants from the US Preventive Health Services (USPHS) and the Elisabeth Severance Prentiss and John Pascal Sawyer Foundations.^103^ One author was the receipient of a USPHS Research Center Career Scientist Award. The second Maes and colleagues study was funded in part by the National Funds for Scientific Research (Belgium), the Clinical Research Center for Mental Health (Belgium), in addition to an Staglin Investigator Award given to the lead investigator.^101^ Tiemeier et al.'s work was supported by the Research Institute for Diseases in the Elderly, which is funded by the Ministry of Education and Science, and the Ministry of Health, Welfare, and Sports through the Netherlands Organization for Scientific Research, and a grant from Numico Research.^104^ Llorente et al.'s study was supported by industry (Martek Biosciences Corporation).^98^ Three groups did not report a funding source.^48,^ ^102,^ ^105^

Population characteristics. Complete population age data were not reported for both the full sample and/or the different study groups in some studies, this despite the avowal of the authors that study groups were matched by age and sex.^48,^ ^102,^ ^105^ In the study by Fehily et al., the group of subjects with endogenous depression was older than the control group.^106^ The pregnant women examined in Llorente et al.'s study were between 18 and 42 years of age; there was no significant difference in ages of the participants between study groups.^98^ In each of Maes et al.'s studies, neither the between-group age of participants nor the between-group female/male ratio were significantly different.^101,^ ^103^ Neither age nor sex significantly predicted any omega-3 fatty acid fractions or any omega-6/omega-3 ratios in these two studies.^101,^ ^103^ Yet, both variables were entered as covariates in subsequent analyses due to their possible relationship with fatty acid levels.^101,^ ^103^ Peet et al.'s study population was between 18 and 65 years of age, and the authors confirmed successful matching for this possible confounder.^102^ Tiemeier et al.'s study groups were age-matched, with ages ranging from 61 to 101 years of age; subjects with depressive disorder were more likely to be female.^104^ Six of the study populations were not described in terms of ethnic/racial background, while Maes et al.'s participants were explicitly identified as Caucasian of Flemish origin.^101,^ ^103^

The studies conducted by Ellis and Sanders^105^ and Fehily et al.^106^ each included heterogeneous subtypes of endogenous depression, with subtypes undefined in the former^105^ and with neither report presenting outcome data broken down by any of these subtypes. The remaining studies identified reasonably well-defined groups for which to compare biomarkers data. The Maes et al. studies likely serve as the best examples of a well-conceived and operationalized separation of study groups.^101,^ ^103^ In this regard, their depressed patients were identified using DSM-III-R diagnostic criteria applied via the SCID, patient version.^101,^ ^103^ Peet et al. employed DSM-IV criteria to identify depressed patients.^102^ Neither Ellis and Sanders nor Fehily et al. described their diagnostic criteria.^105,^ ^106^ Depressive disorders were identified by Tiemeier et al. via a score of at least 16 (i.e., clinically significant depressive symptoms) on the validated Dutch version of the Center for Epidemiologic Studies Depression scale (CES-D) during a home interview, followed by a psychiatric workup using the Dutch version of the Present State Examination (i.e., a semistructured interview from the validated Schedules for Clinical Assessment in Neuropsychiatry). DSM-IV criteria were used to guide the diagnosis, with categories including major depression and dsythymia in addition to minor depression.^104^

Few studies adequately ruled out the presence of possible psychopathology, or risks thereto, in subjects typically identified as “healthy volunteers” or “healthy controls.”^102,^ ^105^ Maes et al.'s investigations carefully provided the basis for separating their study groups to achieve control of this confounder. Healthy volunteers were excluded for present, past and family (first degree) history of Axis I or Axis II disorders using the SCID, Lifetime version.^101,^ ^103^ All participants had low scores on the Zung Depression and Anxiety Scales (<32) and the BDI (<9).^103^ Controls were medication-free for at least 1 month prior to blood sampling.^101,^ ^103^ None had ever taken psychotropic drugs^103^ or was a regular drinker.^101,^ ^103^

A few studies established the baseline severity of symptomatology. For example, Fehily et al. used the BDI,^106^ Maes et al. employed the HDRS, and Peet et al. used the MADRS (no data reported).^102,^ ^103^ In their first study Maes et al. observed that those with major depression had significantly higher baseline HDRS severity scores than did those with minor depression.^103^ Ellis and Sanders, for example, did not measure severity.^105^ Baseline data concerning the duration of the current episode, age of onset, number of previous episodes, and time since diagnosis were rare.

In attempts to control for possible confounding from variability due to comorbid conditions, some studies applied strict exclusion criteria. For example, in both of the studies by Maes et al., patients were excluded if they had Axis I diagnoses other than unipolar depression, including psychotic disorders, organic mental disorders, impulse control disorders, substance use disorder or substance abuse (within the last 6 months), or borderline and antisocial personality (Axis II) disorders.^101,^ ^103^ Also excluded were individuals with abnormal X-rays of heart and lungs, electrocardiogram or electroencephalogram.^101,^ ^103^ All study participants had normal chemical and hematologic tests relating to, for example, liver function and renal function,^101,^ ^103^ as well as electrolyte, thyroid hormone and thyroid stimulating hormone levels.^101^ All were free of medical illness (e.g., immune and endocrine disorders such as diabetes, inflammatory bowel syndrome, autoimmune disorders, essential hypertension and arteriosclerosis).^101,^ ^103^ None exhibited evidence of allergic, inflammatory or immune responses for at least 2 weeks prior to blood sampling.^101,^ ^103^ BMI was within normal limits.^101,^ ^103^ Heavy smokers (>15 cigarettes per day) were excluded.^101^

Peet et al. excluded those individuals with a physical illness of a severity or nature associating it with abnormal levels of omega-3 fatty acid levels.^102^ Controls were medication-free, and without a history of psychiatric illness, personality disorder, substance abuse or medical illness (method undefined). Yet, Tiemeier et al. noted differences in their study groups, with elderly individuals with depressive disorders more likely to have had a stroke and to exhibit significantly lower activities of daily living scores and cognitive scores compared with those without depressive symptoms.^104^ Some studies did not identify possible psychiatric comorbidity or control for it via the application of clearly stated exclusion criteria.^105,^ ^106^ Yet, Peet et al. did note the absence of significant between-group differences regarding smoker status or in the relationship between smoker status and PUFA content.^102^

Six of eight studies did not involve an intervention or exposure. Only Llorente et al. employed supplementation,^98^ as possible prophylaxis, and Edwards et al. assessed dietary intake of omega-3 fatty acids.^48^ In both Maes et al. studies all participants were consuming a normal Belgian diet (PS ratio=0.54±0.43); and, those on a low fat diet were excluded.^101,^ ^103^ No other studies controlled statistically for background diet in their analyses. No study reported inappropriate methods by which lipids were extracted, prepared, stored or analyzed.

Ellis and Sanders did not describe the medication status of their participants (i.e., medication-naïve, medication-free or medicated, with type and dose).^105^ Fehily et al. reported that different percentages of individual within study groups were drug-free, indicating heterogeneity within diagnostic groups.^106^ This situation could confound the results. Those receiving medication were receiving a hypnotic and/or a tranquillizer. Two schizophrenic patients that had been admitted to the study, yet whose data were not analyzed separately, were taking a neuroleptic. The investigators reported that the fatty acid content of those taking these drugs and those who were medication-free was not different (no data or p-value reported).^106^ Peet et al.'s patients were drug-free at first assessment.^102^ Seven patients then received dothiepin, three took paroxetine, and one each received trazodone and lofepramine.^102^

Maes et al. excluded those individuals receiving treatment with MAOIs, antipsychotic doses of neuroleptic, anticonvulsants, lithium or ECT in the previous year.^101,^ ^103^ Maes et al. also specified fluoxetine and trazadone in their second study.^101^ No cholesterol-lowering drugs were permitted.^101^ Use of any medication known to influence fatty acid metabolism or endocrine and immune function was prohibited as well.^101^ No significant between-group differences were observed for the prestudy use of antidepressants, benzodiazepines or antipsychotics in Maes et al.'s first study.^103^ Prestudy use of the different drug classes did not significantly predict any of the omega-3 fatty acid fractions or any omega-6/omega-3 ratios.^103^ All antidepressant, benzodiazepine or low dose antipyschotics were discontinued the month prior to an 8–10 day washout period.^103^ The second Maes et al. study mandated the discontinuation of antidepressants upon hospital admission.^101^ Twenty-six depressed patients had been treated with antidepressants during the depressive episode.^101^

Twenty-seven patients with depression in Maes et al.'s first study,^103^ and 18 patients in their second study,^101^ used a low dose of benzodiazepines for severe agitation, anxiety sleep disorders or suicidal ideation during the study period. There was no significant between-group difference in the use of these on-study medications.^101,^ ^103^ As well, there were no significant differences in EFA status data for those depressed patients who did or did not use on-study benzodiazepines.^101^

Outcome characteristics. Outcomes included all types of fatty acid, from various sources, and were expressed either as percentages, or fractions (i.e., composition), or concentrations.

Study quality and applicability. The seven cross-sectional studies received a mean quality score of 4.6, with four achieving an applicability rating of II,^48,^ ^102,^ ^105,^ ^106^ and three attaining an applicability rating of III.^101,^ ^103,^ ^104^ The single RCT was assigned an Jadad total quality score of 5, an Adequate allocation concealment rating, and an applicability score of I.^98^

Summary Matrix 3: Study quality and applicability of evidence regarding the association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of depression (all designs)

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Llorente^A^ | 2003 | >89 | Peet | 1998 | 30 | Ellis | 1977 | 16
| | | | | Edwards | 1998 | 24 | Fehily | 1981 | >60
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Maes | 1996 | 74
| | | | | Maes | 1999 | 48
| | | | | Tiemeier | 2003 | 682

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

### Qualitative Synthesis of Individual Study Results

The proportions of plasma CPG EPA and DHA were each significantly greater in the endogenous depression group as compared to healthy controls in the Ellis and Sanders study.^105^ On the other hand, AA did not differ between these two groups. These differences were less pronounced for RBC EPG data (no data or p-values reported). There were no significant differences in fatty acid status between non-depressed patients and healthy controls.

Concentrations of DHA and EPA in plasma CPG were each significantly higher, but LA was significantly lower, in Fehily et al.'s endogenous depression group compared with matched controls.^106^ There was no significant difference between these two groups in terms of AA levels. The plasma CPG status of patients with reactive depression or other psychiatric disorders did not differ from the controls. Eighty percent of those with endogenous depression had DHA levels of more than 54 mg/g total fatty acid esters detected, as compared to 19% of matched controls. DHA concentrations were correlated with BDI severity score for those identified as endogenously depressed, but not for those with reactive depression. Similar, but smaller, between-group differences were observed for the fatty acid content of RBCs of patients with endogenous depression compared with matched controls (i.e., higher DHA in EPGs; higher EPA in serine phosphoglycerides).

By ANCOVA, with age and sex as covariates, major depressed patients exhibited a significantly higher AA/EPA ratio in both serum cholesteryl esters and phospholipids in addition to a significantly increased total omega-6/omega-3 ratio in cholesteryl ester fractions than did healthy volunteers or minor depressed subjects in Maes et al.'s first study.^103^ Significant between-group differences were not observed for total omega-3 or total omega-6 fatty acid content, or their ratio, in phospholipids. The only significant correlations involved the HDRS score with the AA/EPA or total omega-6/omega-3 fatty acid ratios in phospholipids. Major depressed patients had significantly lower ALA in cholesteryl esters compared with healthy controls. Major depressed patients showed significantly lower total omega-3 fatty acids in cholesteryl esters and significantly lower EPA in serum cholesteryl esters and phospholipids compared with minor depressed subjects or healthy controls. ALA, EPA and DHA cholesteryl ester fractions successfully discriminated the three study groups. MANOVA using ALA, EPA and DHA cholesteryl ester fractions as dependent variables showed highly significant differences among the three study groups. There was a significant negative relationship between EPA in cholesteryl esters and HDRS scores.

Peet et al. observed a significant reduction in RBC membrane total omega-3 fatty acids and DHA content in drug-free depressive patients.^102^ They also observed a significant reduction in LA, DGLA and total omega-6 fatty acids. No significant between-group differences were found for AA/EPA, AA/DHA or total omega-6/omega-3 fatty acid ratios. Subsequent intervention with anti-depressants failed to have a significant effect on the RBC omega-3 fatty acid status. Yet, this study failed to fully control for possible confounding influences such as stress, smoking or diet.

Edwards et al. reported that RBC membrane EPA, DHA and total omega-3 fatty acid levels were significantly lower in the depressed patient group.^48^ There were no significant differences for any omega-6 fatty acid levels. There were no significant between-group differences for current dietary intake of omega-3 fatty acids or total energy intake (via 7-day weighted intake). The only significant, and negative, correlations involved omega-3 fatty acids and BDI-defined severity score: for ALA, DHA and total omega-3 fatty acid content. Multiple regression revealed that only RBC membrane ALA significantly predicted BDI score. When dietary and RBC membrane data were entered in stepwise fashion, DHA and LA emerged as the only predictors of BDI severity score. Neither current smoker status nor recent stress had an effect on RBC membrane values.

Maes et al. found in serum phospholipids that major depression was associated with (all significant): higher MUFA fractions, lower adrenic acid (omega-6) yet higher (omega-6-)DPA, lower EPA, lower (omega-3-)DPA, higher AA/EPA ratio, higher (omega-6-)DPA/DHA fractions (i.e., composition: weight as percent of total).^101^ In addition, lower concentrations (mg/dL) of SFAs, MUFAs, LA, AA, adrenic acid (omega-6), total omega-6 fatty acids, ALA, EPA, (omega-3-)DPA, DHA, and total omega-3 fatty acids (all significant) were found in the serum phospholipids of patients with major depression.^101^ For serum cholesteryl esters, major depression was associated with (all significant): lower ALA, EPA, and total omega-3 fatty acids; and, higher total omega-6/omega-3 fatty acids and AA/EPA fractions. Additionally, major depression was associated with lower total saturated fatty acids, MUFAs, LA, DGLA, total omega-6 fatty acids, ALA, EPA, and total omega-3 fatty acid concentrations (all significant), in serum cholesteryl esters.^101^ All analyses included age and sex as covariates. There were no significant correlations between HDRS score for depressive patients and any of the fatty acid variables.

In the phospholipids of major depressed patients, serum zinc was significantly and positively correlated with the percentages and concentrations of EPA, DHA and total omega-3 fatty acids.^101^ Significant negative correlations were observed for percentage of total omega-6 fatty acids, AA/EPA, (omega-6-)DPA/DHA, and total omega-6/omega-3 fatty acids. In their cholesteryl esters, only the total omega-3 fatty acid percentage, and EPA, were significantly and positively correlated with major depression. There was no significant effect of antidepressant treatment on fatty acid levels. With a decrease of at least 50% in HDRS score defining a good clinical response to antidepressants after 5 weeks, depressed patients were divided into responders and non-responders.^101^ There were no significant differences in fatty acid percentages between responders and non-responders.

Tiemeier et al. found no significant differences in the percentages or ratios of plasma phospholipid fatty acids between controls and those exhibiting subclinical depressive symptoms.^104^ When the comparisons involved depressed subjects and controls, only a few, marginal differences were observed. By ANCOVA, with the above-noted covariates, percentages of AA and DHA were higher and lower, respectively, in the depressed subjects compared with controls. The ratios of total omega-6/omega-3 fatty acids and AA/DHA were higher in the depressed subject group when compared to reference subjects. Neither the inflammation marker C-reactive protein nor atherosclerosis affected these results. A test of interaction showed that the relation between the omega-6/omega-3 ratios and depressive disorders depended on the C-reactive concentration. That is, the difference in the omega-6/omega-3 ratio between depressed and reference subjects increased with lower concentrations of C-reactive protein. Stratification of the analysis at the median of C-reactive protein concentrations (1.5 mg/L), and involving subjects above this cutpoint, revealed no significant difference in fatty acid composition between the depressed and reference groups. Yet, when data were analyzed from those falling below the cutpoint, it was observed that depressed persons had significantly lower percentages of certain omega-3 fatty acids than did reference subjects. By ANCOVA, subjects with depressive disorder showed lower levels of EPA, DHA and total omega-3 fatty acids. As well, depressed subjects showed higher values for total omega-6/omega-3 fatty acids, AA/EPA and AA/DHA.

In their RCT, Llorente et al. observed no statistically significant correlations between plasma phospholipid DHA content, either at baseline or at 4 months, and self-rating (BDI, EPDS) or syndromal measures of depression (SCID-CV).^98^

### Quantitative Synthesis

Although all of the included studies were controlled, only one was prospective by design. Thus, meta-analysis was considered inappropriate. The exact nature of the inappropriateness of cross-sectional study data to address the question of onset is described in the Discussion.

### Impact of Covariates and Confounders

Numerous factors have the capacity to influence EFA levels, including dietary intake, smoking and alcohol consumption.^101–103^ Most of the studies did not control for smoking, for example, which alone could produce a picture of omega-3 fatty acid deficiency.^60^ Only a minority of studies adequately controlled for the possible influence of this or any other variable.

The study by Peet et al.,^102^ and especially the two studies by Maes et al.,^101,^ ^103^ employed strict controls, and results suggested an omega-3 fatty acid deficiency in depressed patients. Edwards et al. controlled for stress and smoker status.^48^ However, less well-controlled studies—for example, failing to formally rule out psychopathology in the controls—also produced a similar picture of an omega-3 fatty acid deficiency in depressed patients. It is possible that the between-group differences might have been more pronounced in the latter studies had the possible influence of this and other potential confounding factors been minimized.

Failure to include even minimally homogeneous groups of depressed individual may have produced the only two study results suggesting that, compared with depressed patients, healthy controls exhibited an omega-3 fatty acid deficiency.^105,^ ^106^ As well, in studies where patients were either already receiving antidepressant medication,^48^ or received medication sometime after the initial blood sampling and were subsequently retested,^101,^ ^102^ analyses revealed that antidepressant medication did not substantially modify the between-group difference in omega-3 fatty acid levels in biomarkers. The country in which the study was conducted could not readily be used as a surrogate for background diet in assessing the impact of the latter on study results since there was insufficient variability in study results.

## Is Omega-3 Fatty Acid Intake, Including Diet and/or Supplementation, Associated With the Onset, Continuation or Recurrence of Suicidal Ideation or Behavior?

As observed in Summary Table 12 (below), derived from Evidence Table 2 (Appendix E****), two observational studies met eligibility criteria. The studies were published in 2001 and 2004.

### Overview of Relevant Studies' Characteristics and Results

Each observational study has already had its key characteristics described with reference to the question of the possible association of omega-3 fatty acid intake and the onset, continuation or recurrence of depression. Hakkarainen et al. investigated the relationship between dietary intake of omega-3 fatty acids and low mood, major depression, and suicide in males 50 to 69 years of age living in southwestern Finland in 1985.^111^ The study utilized a cohort (n=29,133) from a primary prevention RCT (ATBC Cancer Prevention Study). Followup lasted nine years. The intake of fatty acids and fish consumption were derived from a validated food use questionnaire focused on the “last 12 months.” Suicides were determined from Central Population Register data.

Tanskanen et al.'s sample was selected based on a random population sample (National Population Register) of both sexes (n=3,004; 25–64 years).^80^ Data were gathered on fish consumption, depression (BDI) and suicidality. Suicidality was measured using a single BDI item. Given that the studies varied on the basis of their focus, that is, one on “successful” suicidal behavior and the other on suicidal ideation, and that the key study and population parameters have already been contrasted in an earlier part of the report, only the results are now presented. Quantitative analysis was considered inappropriate.

Adjusting for numerous factors (i.e., age, sex, marital status, education, employement status, work ability, area of residence, financial status, general health, smoking, alcohol intake, coffee drinking, and physical activity), Tanskanen et al. found that the risk of suicidal ideation was significantly lower among frequent consumers of lakefish.^80^ Adjusting for many factors as well (i.e., age, BMI, energy intake, serum cholesterol level, HDL level, alcohol use, education, marriage, self-reported depression and anxiety, and smoking), Hakkarainen et al. observed no significant association between fish consumption or intake of omega-3 fatty acids and suicide.^111^ Both Hakkarainen et al. and Tanskanen et al.'s results, while indicating good statistical control for important key confounders, are insufficient to allow us to infer the role of any covariates or confounders. Meta-analysis was not considered since outcomes were not comparable.

Study quality and applicability. Although they employed different research designs, both studies were assigned a level III for applicability, and together they received a mean quality score of 4.5.^80,^ ^111^

Summary Matrix 4: Study quality and applicability of evidence regarding the association between omega-3 fatty acid intake and onset, continuation or recurrence of suicidal ideation or behavior (all designs)

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Hakkarainen | 2004 | >29k
| | | | | Tanskanen | 2001 | >1k

n = number of allocated/selected participants;

k = 1,000's

## Are Omega-3 Fatty Acids Efficacious as Supplemental Treatment for Bipolar Disorder?

As observed in Summary Table 13 (below), derived from Evidence Table 1 (Appendix E††††), two controlled studies met eligibility criteria. While both were published, only Stoll et al. (1999) provided sufficient study-related data to permit its full review.^112^ Akkerhuis and Nolen (2003) reported some peripherally-related data in a letter to the editor in which they referred to the placebo-controlled study from which their anecdotal data were derived.^93^ A search via Pubmed did not locate a report of the full study. Thus, a comprehensive qualitative synthesis (or meta-analysis) could not be achieved (e.g., impact of covariates and confounders). A summary matrix could not be derived.

### Overview of Relevant Studies' Characteristics and Results

Stoll et al. randomized 44 patients with bipolar disorder (18–65 years) to receive either 9.6 g/d of omega-3 fatty acids (6.2 g/d EPA, 3.4 g/d DHA) from menhaden fish body oil, via seven capsules twice daily, or identical gelatin placebo capsules containing olive oil ethyl ester (Summary Table 13).^112^ Capsules were vacuum deodorized, and both tertiary butylhydroquinone (0.2 mg/g) and tocopherols (2 mg/g) were added as antioxidants. Randomization was stratified by sex (n=9/14 completers in omega-3 fatty acid group; n=11/16 completers in placebo group), concurrent lithium use (n=6/14 completers in omega-3 fatty acid group; n=6/16 completers in placebo group), and rapid cycling status (n=7/14 completers in omega-3 fatty acid group; n=5/16 completers in placebo group). Diagnosis was established using the SCID and DSM-IV criteria for Types I or II bipolar disorder (n=2/14 completers with Type II in omega-3 fatty acid group; n=3/16 completers with Type II in placebo group). Eight patients entered the study without receiving psychotropic medication, and a post hoc analysis of their data constituted an evaluation of omega-3 fatty acids as primary treatment (n=4 per study group). Mood states varied at study entry both across study groups and within each study group.

Patients were free of notable medical and psychiatric comorbidity. They were required to have experienced at least one manic or hypomanic episode within the past year.^112^ The investigators argued that this inclusion criterion would enhance the study's power to detect a difference since such episodes were likely to recur. Forty percent of participants had exhibited rapid-cycling symptoms (i.e., at least four mood episodes in the past year). While participants were permitted to continue with existing psychotherapies (data unreported), no new regimens were permitted. Those receiving psychotropic medication continued to do so on-study, at constant dosages, and irrespective of whether they were in the therapeutic range (n=4/14 and n=3/16 patients in the active and placebo arms, respectively, received no medication). However, there was considerable heterogeneity both between- and within-study groups in terms of which types of on-study medication (doses unreported) were taken. Clinical assessments took place every second week for four months. The investigators defined the followup required to observe an effect as 30 days, thereby establishing the criterion for data that could be entered into analysis.

While planned as a 9-month trial with 60 patients required based on a sample size calculation, a stoppage in the production of the fish oil material and a significant between-group difference observed via a preplanned interim analysis, conducted when 20 patients had either failed treatment or completed 4 months, together led to ending accrual and reanalyzing data from 30 patients. P-values were adjusted accordingly. While it was reported that the exposure was produced by the National Marine Fisheries Fish Oil Program (US), no data were provided regarding its purity or whether the presence of methylmercury was tested or eliminated.

There were no significant differences in the baseline characteristics of the study groups (i.e., age, sex, rapid cycling in past year, Clinical Global Impression [CGI] scale, Global Assessment Scale [GAS], Young Mania Rating Scale [YMRS], HDRS).^112^ Results of analyses involving 30 evaluable patients were reported (n=14 in active treatment group).^112^ Kaplan-Meier survival analysis revealed that the active treatment group exhibited a significantly longer period of remission (i.e., duration of time remaining in the study) than did the placebo group. When data were analyzed exclusively from those subjects who entered the study without receiving psychotropic medication, the same difference was observed. For the full sample, the time to a 50% rate of ending the trial prematurely (“nonresponse”) was 65 days for the placebo group. The investigators interpreted this result as being consistent with the study population. Significant differences in improvement on the CGI, GAS, and the HDRS were observed in favor of the active treatment group. The latter result suggests that depression was also positively affected by supplementation. Post hoc analyses showed that sex, rapid cycling status and bipolar disorder type did not predict response (no data reported).

There was some evidence that the blind had been broken. A “fishy” aftertaste was more often reported in the active treatment group, such that 86% of participants guessed that they had received fish oil capsules. Only 63% in the placebo group guessed correctly. However, debriefing revealed that clinical response, or lack thereof, also played a role in tipping-off subjects to which study group they had been allocated.

Akkerhuis and Nolen reported the spontaneous reduction of psoriasis in a double blind trial wherein patients with bipolar disorder were allocated either to a maximum of 6g/d EPA ethyl ester or placebo (undefined).^93^ Neither results relating to clinical outcomes nor other study details were provided.

Study quality and applicability. The Stoll et al. trial received an internal validity grade of A (Jadad total score=4), exhibited Adequate concealment of allocation to study groups, and was rated as being applicable to a North American population.^112^ The Akkerhuis and Nolen report did not provide sufficient data to permit an evaluation of its study's internal validity or applicability.^93^

## Is Omega-3 Fatty Acid Intake, Including Diet and/or Supplementation, Associated With the Onset, Continuation or Recurrence of Bipolar Disorder?

As observed in Summary Table 14 (below), derived from Evidence Table 3 (Appendix E‡‡‡‡), one study published in 2003 met eligibility criteria. A comprehensive qualitative synthesis (e.g., impact of covariates and confounders), summary matrix and meta-analysis were not possible.

### Overview of Relevant Study's Characteristics and Results

Noaghiul and Hibbeln conducted a cross-national ecological analysis assessing the possible association of seafood consumption and published lifetime prevalence rates (ages 18–64 years) of bipolar disorder and schizophrenia.^90^ Bipolar I disorder prevalence data from six countries (US, Canada, Puerto Rico, Taiwan, Korea and New Zealand) were obtained from the Cross-National Collaborative Group epidemiological study of 10 countries. To these were added data from Germany, Italy, Israel, Iceland and Switzerland. All studies used structured diagnostic instruments and appropriate sampling methods to obtain clearly defined community samples. For example, with the exception of Switzerland and Israel, all studies used the NIMH Diagnostic Interview Schedule (DIS). The former used the SPIKE and Schedule for Affective Disorders and Schizophrenia, respectively. A Hungarian study of bipolar II disorder met eligibility criteria, as did a study from Norway. The latter used the DIS yet did not provide data subdivided by diagnostic subcategory. Data from Norway were compared with those from other countries after data from different diagnostic subcategories were first combined. All rates were reported as cases per 100,000 persons. Prevalence rates drawn from the Cross-National Collaborative Group epidemiological study were standardized at each site, with a weight calculated per subject, and stratified for age and sex. Data from other sources could not be weighted in this manner since primary data were unavailable. Socioeconomic status and educational level were not taken into consideration. The female-to-male ratio was roughly equal at all sites, with slightly higher rates seen for Canada, Puerto Rico, Korea and New Zealand. Sources of lifetime prevalence data for schizophrenia are described later in our report.

National seafood consumption data were obtained from the National Marine Fisheries Service and the Food and Agriculture Organization of the WHO. The rates of consumption appeared to be stable across the period in which the data were collected. As a measure of the disappearance of seafood from the economy per year, apparent seafood consumption (lb/person/year) was calculated as total catch plus imports minus exports.

Results indicated variability in the rates of bipolar disorder across the countries.^90^ By simple linear regression, greater national seafood consumption predicted lower prevalence rates of bipolar spectrum disorder and bipolar II disorder, but not bipolar I disorder, for which a nonsignificant association was observed. An investigation of the residual plots of these findings suggested that nonlinear models would better express the association. By logarithmic regression, greater seafood consumption predicted lower prevalence rates of bipolar I disorder, bipolar II disorder and bipolar spectrum disorder. The best curve fitting entailed a simple exponential decay regression whereby greater seafood consumption again predicted lower rates of bipolar I disorder, bipolar II disorder and bipolar spectrum disorder. When all subcategories were combined, both linear regression and exponential decay regression remained significant. When outlier data from Iceland (by far the highest seafood consumption, very low rates of bipolar I and bipolar spectrum disorder) were excluded, the association strengthened involving bipolar II disorder but did not change the results for bipolar I or bipolar spectrum disorder.

Study quality and applicability. Given its multiple national entries of data, Noaghiul and Hibbeln's study received an applicability rating of III.^90^ Its total quality score was 4.

## Is the Onset, Continuation or Recurrence of Bipolar Disorder Associated With Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Biomarkers?

As observed in Summary Table 15 (below), derived from Evidence Table 2 (Appendix E§§§§), two studies met eligibility criteria. One was published in 1996 and the other in 2003. Since Mahadik et al.'s investigation was focused primarily on schizophrenia, with bipolar patients used as a comparator group along with normal controls, most of the details regarding this study are described with respect to the topic of schizophrenia.^114^ As a result, a full qualitative synthesis is not produced here. Nevertheless, it is clear from both study reports that the study of Chiu et al. more extensively controlled for possible confounding factors.^113^

### Overview of Relevant Studies' Characteristics and Results

Both studies employed a cross-sectional design.^113,^ ^114^ Only Chiu et al. reported their funding source: three National Science Council grants, and the China Chemical and Pharmaceutical Company.

Mahadik et al. investigated AA and DHA compositions of cultured skin fibroblasts of schizophrenic patients (n=12; eight drug-naïve and in a first episode of nonaffective psychosis, four drug-free although presently admitted for recurrence), bipolar patients (n=6; two in first manic episode) and normal controls (n=8).^114^ Bipolar patients were selected because they do not tend to manifest prominent negative symptoms. Mahadik et al. reported no significant differences between bipolar patients and normal controls for AA or DHA although schizophrenic patients exhibited significantly lower DHA compositions compared with either bipolar patients or normal controls.^114^

Chiu et al. examined whether there was a depletion of PUFAs in RBC membranes of patients admitted to hospital with DSM-IV diagnosed bipolar I disorder and whose most recent episode manic (n=20; 18–65 years), compared with healthy volunteer controls (n=20; 18–65 years).^113^ Excluded were bipolar patients with mixed symptom episodes or comorbid Axis I psychiatric disorders (i.e., due to a medical condition or induced by substance use). The mean age of onset of the bipolar patients was 26.5 (SD=9.9) years with an average duration of 11.1 (SD=9.6) years. The mean number of mood (i.e., manic or depressive) episodes was 5.2 (SD=4.5) and the mean number of hospitalizations was 3.8 (SD-3.2). The mean YMRS score was 32.1 (range: 14–42). During index hospitalization, all bipolar patients continued to receive their mood stabilizers, benzodiazepine or antipsychotic drugs. Fifteen patients were receiving mood stabilizers, including lithium (n=9), valproate (n=5), and valproate with carbamazepine (n=1). Of these, ten were taking antipsychotics. At the time of blood sampling, five patients had been free of psychotropic medication for at least one week. Healthy controls did not have a positive family history of psychiatric disorder or take psychotropic medication although no method to rule out psychiatric disturbance was described.^113^ All study participants were of Han background, were free of medical illness (e.g., immune or endocrine disorders) and were exluded if they were on a low fat or vegetarian diet. There were no significant between-group baseline differences for age, sex or BMI.

Chiu et al. found significantly reduced AA and DHA compositions in RBC membranes in bipolar manic patients relative to healthy volunteers.^113^ There were no significant differences in either total omega-3 or total omega-6 fatty acid compositions. No significant differences were observed for either the AA/EPA or total omega-6/omega-3 fatty acid ratio. An assessment of the impact of medication on PUFAs in bipolar patients revealed no significant differences for AA and DHA levels. AA and DHA levels were not significantly correlated with age, age of onset, number of episodes or length of illness. There were no significant differences in AA or DHA levels for bipolar patients varying on the basis of their smoker status. No inappropriate methods to extract, prepare, store or analyze lipids were described in either report.^113,^ ^114^

Although both included studies were controlled, neither was prospective by design. Thus, meta-analysis was not considered. That said, the studies collected fatty acid status data using two very different methodologies, and from different sources. The small numbers of study precluded any meaningful evaluation of the possible impact of covariates or confounders.

Study quality and applicability. Mahadik et al. and Chiu et al.'s studies received applicability ratings of I and III, respectively. Each study received a quality score of 5.

Summary Matrix 5: Study quality and applicability of evidence regarding the association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of bipolar disorder

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Mahadik | 1996 | 26
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Chiu | 2003 | 40

n = number of allocated/selected participants

## Is Omega-3 Fatty Acid Intake, Including Diet and/or Supplementation, Associated With the Onset, Continuation or Recurrence of Anxiety?

As observed in Summary Table 16 (below), derived from Evidence Table 1 (Appendix E*****), two studies met eligibility criteria. One was published in 2000 and the other in 2003. The key parameters describing these studies have already been presented with regards to the evidence for the possible association of intake of omega-3 fatty acids and the onset, continuation or recurrence of depression. Neither study included patients with diagnoses of anxiety disorder.

### Overview of Relevant Studies' Characteristics and Results

Wardle et al.'s RCT investigated whether cholesterol-lowering diets influence mood, including depression, anxiety, anger/hostility, stress, and general psychological well-being.^99^ Adult volunteers (n=176) with elevated serum cholesterol levels (>5.2 mM [198 mg/dL]) were allocated to a low-fat diet (n=59), a Mediterranean diet (n=61), or a waiting-list control (n=56). Dietary treatments were given in eight sessions over the 12-week period. Participants completed a seven-day dietary intake diary before the first assessment. The outcome measure was the anxiety subscale of the POMS. Dietary diaries were filled out at baseline and 12 weeks. There were no significant between-group differences observed for anxiety. There was no reliable association between intake of omega-3 fatty acids and anxiety.

Reflecting one factor within a factorial RCT investigating interventions to reduce mortality in angina (including: advice [not] to eat fruits and vegetables; [no] stress management), 452 males were allocated to receive advice to eat more fatty fish (i.e., mackerel, herring, kipper, pilchard, sardine, salmon, trout) or to receive no such advice. Ness et al. supplied MaxEPA® fish oil capsules to study participants if they did not like the taste of fish.^100^ Fish intake and mood (depression, anxiety) were assessed at baseline and at six months, the latter using the validated Derogatis Stress Profile (DSP). Ness et al. observed that self-reported fish intake was higher in the fish advice group at study's end.^100^ No statistical difference was observed in the fish advice group for anxiety; controlling for baseline mood, the between-group difference was not statistically different. This last observation did not change following an additional adjustment made for randomization to the stress management arm, nor was there any statistical evidence of interaction between these factors in their effects on mood. These observations were not contradicted when they looked exclusively at the upper quartile of baseline anxiety scores.

The very different interventions and outcomes precluded quantitative synthesis. The dearth of data concerning covariates and confounders did not permit a meaningful assessment of their possible influence. That said, neither study demonstrated a significant clinical effect.

Study quality and applicability. Both RCTs received a Jadad total quality score of 2, indicating low quality, and level II applicability ratings.^99,^ ^100^ Wardle et al.'s trial^99^ described adequate allocation concealment while Ness et al.'s report was unclear.^100^

Summary Matrix 6: Study quality and applicability of evidence regarding the association between omega-3 fatty acid intake and onset, continuation or recurrence of anxiety

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | | | | Ness^U^ | 2003 | 452
| | | | | | | | Wardle^A^ | 2000 | 176
| III | Author | Year | n | Author | Year | n | Author | Year | n

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

## Are Omega-3 Fatty Acids Efficacious as Supplemental Treatment for Obsessive-Compulsive Disorder?

As observed in Summary Table 17 (below), derived from Evidence Table 1 (Appendix E†††††), one placebo-controlled crossover RCT published in 2004 met eligibility criteria.

### Overview of Relevant Study's Characteristics and Results

At one Israeli site, Fux et al. selected eleven patients from an anxiety disorders clinic (18–75 years; racial/ethnic background unreported) meeting DSM-IV criteria for obsessive-compulsive disorder (duration: 14.1±8 years).^115^ Participants began either with 2 g/d E-EPA (96% pure semi-synthetic E-EPA; plus stabilized with 0.2% vitamin E) or matched 2 g/d placebo (liquid paraffin) gelatin capsules in a six-week, two-phase crossover RCT. Selection criteria included having been on a stable dose of SSRIs (paroxetine: n=8; fluvoxamine: n=1; fluoxetine: n=1) for at least 2 months, and having demonstrated some response to treatment yet without further improvement over the last 2 months. Exclusion criteria included no unstable medical disease, alcohol or drug abuse, or comorbid Axis II psychiatric diagnosis. Patients maintained their SSRI dose over the study. None received psychotherapy aside from basic clinical management or support. The primary outcome measures were scores on the Yale-Brown Obsessive-Compulsive Scale (YBOCS), HDRS, and the Hamilton Anxiety Rating Scale (HAM-A). The intervention was prepared by Laxdale, Ltd. No data described its purity or whether methylmercury was tested for and eliminated.

Overall, 91% of the sample completed the full 12 weeks (n=10/11); however, data were analyzed based on an ITT basis, with the last value carried forward for the participant who dropped out at week 10 of the study (i.e., moved out of city). Results indicated that there were no effects of order of treatment on HDRS or HAM-A. Time had a main effect on YBOCS scores, with significant decreases by week 6 for both placebo and E-EPA phases. There was neither a treatment effect for any clinical outcome, or a significant drug-by-time interaction. No assessment of the impact of covariates or confounders was possible. This RCT received a Jadad total quality score of 3 and an applicability rating of III.

## Is the Onset, Continuation or Recurrence of Anorexia Nervosa Associated With Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Biomarkers?

As observed in Summary Table 18 (below), derived from Evidence Table 3 (Appendix E‡‡‡‡‡‡‡), two cross-sectional studies published in 1985 and 1995 met eligibility criteria.

### Overview of Relevant Studies' Characteristics and Results

Both studies had a cross-sectional design and were conducted in the US.^116,^ ^117^ Langan and Farrell's study was funded by the NIH^117^ while Holman et al.'s work was supported by the Carle Foundation, NIH, Harmel Foundation and by Scotia Pharmaceuticals.^116^

Langan and Farrell investigated the plasma fatty acid composition in a group of females with anorexia nervosa admitted to a hospital (n=17; mean age: 16.8 years; duration of anorexia: 17.2 months) compared to healthy females serving as controls (n=11; mean age: 20.7 years).^117^ The anorexic patients were admitted because of an electrolyte imbalance, a greater than 25 percent loss of ideal body weight (mean: 28.5 pounds) and severe psychosocial problems. Patients varied in their degree of malnutrition. The control group was slightly older than the patient group. Compared with the control group, the weight-to-height ratio (lb/in) was significantly reduced in the patient group.

Holman et al. compared the plama phospholipid fatty acid composition in young females with anorexia nervosa (n=8; mean age: 18.4 [15–24] years) admitted to a treatment program in an urban clinic, with that of healthy female adults (n=19; mean age: 23.5 years).^116^ All patients had lost at least 15% of their usual body weight. No inappropriate methods to handle lipids were described in either study.

Langan and Farrell showed that there were no significant between-group differences in the fatty acid composition of total plasma lipids.^117^ Only plasma phospholipid LA and ALA were significantly reduced in the group with anorexia compared with controls, while DHA was significantly higher in the females with anorexia. The total amount of omega-6 fatty acids was significantly lower in those with anorexia compared with normal controls, yet the AA/LA ratio was significantly higher among patients with anorexia compared with controls.

Holman et al. observed that the phospholipid content of total omega-6 fatty acids was significantly reduced in the patients with anorexia compared with controls.^116^ The same observation was made with respect to EPA, DHA, ALA and total omega-3 fatty acids. When the analysis was performed on plasma cholesteryl esters, there were no significant between-group differences for the omega-3 fatty acids, while DGLA was significantly lower in patients than in controls. For the plasma triglycerides fraction, total omega-3 fatty acid content was significantly reduced in patients compared to healthy subjects. The only two omega-6 fatty acids exhibiting a significant reduction in the patient group were DPA and GLA.

Study quality and applicability. Both studies received an applicability rating of I. Their mean quality score was 1.5.

Summary Matrix 7: Study quality and applicability of evidence regarding the association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of anorexia nervosa

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | | | | Holman | 1995 | 27
| | | | | | | | Langan | 1985 | 28
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n

n = number of allocated/selected participants

Although all of the included studies were controlled, none were prospective by design. Thus, meta-analysis was not considered. Insufficient data precluded an assessment of the possible impact of covariates and confounders.

## Are Omega-3 Fatty Acids Efficacious as Primary Treatment for Attention Deficit/Hyperactivity Disorder?

As observed in Summary Table 19 (see below), derived from Evidence Table 1 (Appendix E§§§§§), three RCTs and one comparative before-after study met eligibility criteria. Studies were published between 2001 and 2004.

One RCT conducted by Brue et al. included children allocated, in part, on the basis of whether or not they were receiving methylphenidate (Ritalin®).^118^ As a result, data for those not receiving this medication reflect the primary treatment of AD/HD and are reviewed here. Other data from this RCT are presented below as evidence concerning the supplemental treatment of AD/HD. To minimize the presentation of redundant information, Brue et al.'s study is described once in detail.

### Overview of Relevant Studies

Richardson and Puri's RCT evaluated the effects of supplementation with highly unsaturated (HUFA) fatty acids in children (n=41; 8–12 years) with both AD/HD-related symptoms and specific learning difficulties (mainly dyslexia).^119^ Children were not formally assigned a diagnosis of AD/HD. Teacher-identified children were allocated to receive for 12 weeks either olive oil placebo or a “cocktail” including 186mg/d EPA, 480mg/d DHA, 96mg/d GLA, 60 IU/d vitamin E (as antioxidant), 864mg/d cis-linolenic acid, 42mg/d AA and 8mg/d thyme. Behavioral and learning problems associated with AD/HD were assessed using Conners Parent Rating Scale (CPRS). Analyses of teacher ratings were not conducted given that the children were new to their school.

Hirayama et al. investigated primarily the effects of DHA on symptoms of AD/HD.^120^ They conducted an RCT of children (6–12 years) recruited by psychiatrists. Children were assigned to receive, for 2 months, either 3.6 g/wk DHA plus 700mg/wk EPA from fish oil contained in active foods (fermented soybean milk, bread rolls and steamed bread) or these same foods without fish oil. Most of the children were not receiving medication (n=34/40). AD/HD related symptoms, aggression, visual perception, visual and auditory short-term memory, development of visual-motor integration, continuous performance and impatience were assessed in this study.

Brue et al. conducted two 12-week trials to evaluate the efficacy of a dietary supplement combination and flaxseed for the treatment of inattentiveness and hyperactivity in children with AD/HD (mean age: 8.4 years; 4–12 years).^118^ Each child was supposed to participate in both studies. However, 51 of 60 children enrolled in the first study completed the second RCT as well. To initiate the first RCT, 30 children were chosen randomly from a group not taking any stimulant medication and 30 were randomly chosen from those taking methylphenidate. Each RCT included two experimental and two control groups. Here, we are interested only in the second trial because the first one did not include an omega-3 fatty acid exposure.

The second trial consisted of unmedicated patients randomly allocated to receive either 2 g/d flaxseed plus a dietary supplement combination (40 mg/d Ginkgo biloba [proposed effect: mental clarity/alertness], 800 mg Melissa officinalis [proposed effect: relaxing effect], 120 mg Grapine [proposed effect: attention, memory], 140 mg dimethyaminoethanol [proposed effect: memory, learning], 400 mg L-glutamine [proposed effect: mental clarity/alertness]) or the dietary supplement combination paired with a slippery elm supplement as placebo (amount not reported).^118^ As will be described below, children taking methylphenidate were likewise randomized to these study groups. Participants were instructed to take their intervention twice daily, once with breakfast and then with an afternoon snack or dinner. Only the results with respect to unmedicated children are presented here. Data from children receiving the intervention supplemental to methylphenidate are described below. The CPRS and CTRS were used to measure study outcomes.

Harding et al. conducted a study in children (7–12 years) with AD/HD. They were recruited by a clinical child psychologist. They were then divided, by parental choice, into two groups. They received, for 4 weeks, either Ritalin at a dose of 5–15 mg two to three times daily (n=10), or dietary supplementation containing a mix of essential fatty acids (e.g., 180 mg/d EPA and 120 mg/d DHA from 1g salmon oil), a multiple vitamin (e.g., thiamine, niacin), multiple minerals (e.g., magnesium, calcium), phytonutrients, phospholipids (soy lecithin), probiotics (n=10) and amino acids (e.g., glutamine).

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. Three parallel RCTs^118–120^ and one comparative before-after study,^121^ each involving children, were conducted to evaluate the efficacy of omega-3 fatty acids as a primary treatment for AD/HD. Inclusion and exclusion conditions were well-defined in three studies.^118,^ ^119,^ ^121^ Hirayama et al. did not specify any exclusion criteria.^120^ Only Brue et al.^118^ employed a design having more than two groups (i.e., 4). However, only one of their study arms addressed the present question. A total of 161 children were randomized. The mean sample size for the four studies was 40.25 (range: 20–60) participants, with the Brue et al. trial being the largest (n=60) and the Harding et al. study being the smallest (n=20). Study participants received the intervention for an average of 9 weeks, with the Harding et al. intervention being the shortest (i.e., 4 weeks).^121^ The RCTs were conducted in the US,^118^ the UK ^119^ and Japan.^120^ The UK RCT was funded by the Dyslexia Research Trust Funding,^119^ and the study from Japan by Japan Fisheries Association and the Foundation for Total Health Promotion.^120^ The funding sources for the two US trials were not reported.^118,^ ^121^

Population characteristics. The mean age of study participants across the four trials was impossible to determine given that full sample means were not provided in two trials.^120,^ ^121^ The age of the participants ranged from 4 to 12 years when all studies were combined. The sex ratio was provided in three studies.^118–120^ Males were consistently more strongly represented in these studies (80%-86%). With respect to racial/ethnic backgrounds, Hirayama et al.'s study likely included an Asian population^120^ while similar data were not reported for the UK, or for the US, sample populations.^118,^ ^121,^ ^121^

All studies used DSM-IV criteria to identify AD/HD.^118–121^ Hirayama et al. reported that eight of 40 children might not have been identifiable as AD/HD according to DSM-IV criteria but this diagnosis was nevertheless “strongly suspected” by two psychiatrists.^120^ Even though there were no significant differences between the two study groups on a number of bases, it should be noted that, in the control group there were more patients taking medication/polymedication (4 vs 2) than in the DHA group. As well, there were more patients in the control group with a comorbid condition (15 vs 12), including Asperger's syndrome (7 vs 2), conduct disorder (3 vs 0) or mood disorder (5 vs 1). Conversely there were more patients with learning disorders in the DHA group than in the controls (10 vs 5).^120^ Overall, almost three-quarters (n=27/40) of the children exhibited comorbidity. At baseline, no significant between-group differences were observed on outcome measures.

In the study conducted by Richardson et al. the participants had, in addition to AD/HD-related symptoms, specific learning difficulties assessed by the Similarities and Matrices subtests from the British Ability Scales (BAS).^119^ Patients with a history of any other neurological or major psychiatric disorder or significant medical problems were excluded. No patients were receiving any medication. At baseline, the two groups did not differ significantly for age, sex, ethnicity or on any of the Conners scales.

The Brue et al. report indicated that participants taking a stimulant medication other than methylphenidate were excluded, as were those with serious and preexisting medical or psychological conditions such as asthma or depression.^118^ These authors did not report any baseline data. Harding et al. excluded patients with co-existing conduct disorder or oppositional defiant disorder, medication use, street drugs, or use of other nutritional or botanical supplements.^121^

Intervention/exposure characteristics. In the study conducted by Richardson and Puri, children in the treatment group received a supplement containing both omega-3 and omega-6 fatty acids. The sources of these agents were not identified. Vitamin E was added as an antioxidant. The placebo group received an unspecified dose of olive oil in identical capsules.^119^ In the study by Hirayama et al., the treatment group received active foods containing fish oil (fermented soybean milk; bread rolls and steamed bread) that provided 3.6 g/wk DHA and 700 mg/wk EPA.^120^ Fermented soybean milk was given three times per week and provided 600 mg DHA per 125 mL. Bread rolls and steamed milk were given twice a week, providing 300 mg DHA per 45g and 600 mg DHA per 60g, respectively. The placebo group received the same foods but containing olive oil.^120^ The authors masked the fishy taste in the milk product using special flavors (no method reported). For the other active foods, the fish oil was emulsified with fruit juices. No mention was made as to whether these same procedures were applied to placebo-containing foods. Parents were asked to maintain their child's habitual diet other than reducing bread consumption to accommodate the inclusion of breads containing the exposure.^120^ Brue et al.'s dietary supplement “cocktail” is well described above. Harding et al.'s active ingredients are too numerous to mention them all here.^121^

Not one of the trial reports described the manufacturers of the sources of their interventions, the purity of their exposures, or whether, or how, the presence of methylmercury was tested for, or eliminated from, the sources.^118–121^

Cointervention characteristics. Omega-3 fatty acids were often given concurrently with other agents, including omega-6 fatty acids, vitamins, minerals, polynutrients, probiotics and amino acids.^119,^ ^121^ Hirayama et al. stated that DHA, from fish oil, was added to foods (fermented soybean milk, bread rolls and steamed bread).^120^ However, the nutritional content of these foods was not reported. In these investigators' control group, four patients were receiving medication, including methylphenidate (n=1), methylphenidate plus risperidone (n=1), carbamazepine plus fluvoxamine (n=1) or carbamazepine plus sulpiride (n=1).^120^ Two patients in the DHA group were exclusively taking methylphenidate.

Outcome characteristics. Richardson and Puri defined changes in CPRS scores (AD/HD subscales, AD/HD global scales) as the primary outcome.^119^ Hirayama et al. powered their study to assess changes in aggression using a questionnaire developed by the authors.^120^ Other assessments included AD/HD-related symptom criteria based on DSM-IV, visual perception, visual and auditory shortterm memory, visual-motor integration, a continuous performance test and an impatience test. Brue et al. employed the DSM-IV Inattentive and Hyperactive-Impulsive subscales.^118^ The primary outcome in the Harding et al. study was the Intermediate Visual and Auditory/Continuous Performance Test (IVA/CPT) although CPRS data were obtained as well.^121^ Two major quotients are derived from the six primary IVA/CPT scales: the Full Scale Response Control Quotient (FSRCQ: prudence, consistency, stamina) and the Full Scale Attention Control Quotient (FASCQ: vigilance, focus, speed).

Study quality and applicability. The three RCTs received a mean Jadad total quality score of 3.3, indicating sound internal validity.^118–120^ Their three applicability ratings ranged from I to III. The applicability rating for the comparative before-after study was I, and it received a total quality score of 4.

Summary Matrix 8: Study quality and applicability of evidence regarding the primary treatment of attention deficit/hyperactivity disorder (all designs)

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | | | | Brue^U^ | 2001 | 60
| | | | | | | | Harding | 2003 | 20
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Richardson^A^ | 2001 | 41
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Hirayama^U^ | 2003 | 40

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

### Qualitative Synthesis of Individual Study Results

Richardson and Puri compared the changes in CPRS subscale scores after 12 weeks.^119^ From the 41 patients enrolled, 15 in the active group and 14 in the placebo group completed the study. Analyses at endpoint revealed that the active treatment group had significantly lower scores on DSM Inattention, Conners ADHD Index and psychosomatic symptoms.

Hirayama et al. reported that all subjects completed the study. Data analyses did not show any improvement in AD/HD symptoms (e.g., problems of inattention, hyperactivity/impulsivity) in the DHA group compared to the placebo group. The number of errors of commission on the continuous performance test decreased significantly in the control group. Visual short-term memory was significantly improved in the control group. Excluding data from those receiving medication (i.e., supplemental treatment patients) or from those only suspected of being AD/HD did not change these results (no data reported). Food consumption was estimated to be close to 100% (no data reported).

Brue et al.'s results indicated no significant between-group differences on parent and teacher ratings of inattentiveness. Teacher-reported hyperactivity/impulsivity was significantly lower in the flaxseed plus supplement combination group, compared with the supplement combination plus placebo group. However, the opposite was observed for parent ratings.

Significant improvements were observed on both the FSRCQ and FSACQ in each of the study groups of Harding et al.^121^ There were no significant between-group differences on either the FSRCQ or the FSACQ. No significant between-group differences were observed for the following four subquotients although both study groups' improvements were statistically significant: Auditory Response Control Quotient, Visual Response Control Quotient, Auditory Attention Quotient and the Visual Attention Quotient.

### Quantitative Synthesis

Meta-analysis was not attempted for several reasons. The two studies employing DHA and EPA as active treatment employed different research designs (i.e., Harding et al.'s noncomparative before-after study^121^ vs Hirayama et al.'s RCT^120^). More importantly, though, in the only two studies using a common comparator (i.e., olive oil pacebo), their active treatments were completely different (i.e., Richardson and Puri's “cocktail”^119^ vs Hirayama et al.'s DHA+EPA exposure^120^).

### Impact of Covariates and Confounders

A few studies attempted to control for possible confounding, including the study of Harding et al.,^121^ which excluded children with externalizing disorders commonly associated with AD/HD (i.e., conduct disorder, oppositional defiant disorder), as well as the study of Hirayama et al., where the children maintained their background diets.^120^ On the other hand, the latter study also included subjects with a wide range of comorbid conditions;^120^ and, Richardson and Puri included children with a variety of learning difficulties.^119^ Yet, the inconsistent findings, including a small number of significant clinical effects, and the variability in both the types of intervention and comparator made it impossible to begin to reliably identify key covariables affecting clinical outcomes.

## Are Omega-3 Fatty Acids Efficacious as Supplemental Treatment for Attention Deficit/Hyperactivity Disorder?

As observed in Summary Table 20 (see below), derived from Evidence Table 1 (Appendix E******), three RCTs met eligibility criteria. Studies were published in 2001 or 2003. Results for children on methylphenidate from the Brue et al. trial are described here.

### Overview of Relevant Studies

Voigt et al. conducted an RCT investigating DHA supplementation in children (n=63; 6–12 years) diagnosed with AD/HD.^122^ Children being treated successfully with stimulant medication were recruited by a pediatrician. They were randomly assigned to receive either 345mg/d DHA or placebo (undefined) for 4 months. Children with comorbid conduct disorder or oppositional defiant disorder were eligible. Measures of attention and impulsivity were assessed by changes in scores on the Test of Variables of Attention (TOVA) and the Children's Color Trails Test. Other outcomes included scores on the Child Behavior Checklist (CBCL), and the Conners Rating Scale, in addition to plasma phospholipid fatty acid concentrations.

Stevens et al. conducted an RCT to evaluate the effects of supplementation with PUFA on the behavior and blood fatty acid composition of children (n= 50; 6–13 years) with AD/HD-like symptoms, who were also reporting thirst and skin problems potentially indicative of omega-3 fatty acid deficiency.^123^ Fifty children were randomized to receive daily either the PUFA supplement Efalex® (480 mg/d DHA, 80 mg/d EPA, 40 mg/d AA, 96 mg/d GLA and 24 mg/d vitamin E as anti-oxidant preservative) or 6.4 g/d olive oil as placebo for 4 months. Only five participants in each group were not receiving medication. The primary outcome measures were the parent- and teacher-endorsed Conners Abbreviated Symptom Questionnaires (ASQ) and the Disruptive Behavior Disorders (DBD) Rating Scale. Other outcomes measures were the Conners CPT and the Woodcock-Johnson Psycho-Educational Battery-Revised (WJ-R). Brue et al. conducted the third RCT, described with respect to the primary treatment of AD/HD.^118^

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. Three RCTs examined the use of omega-3 fatty acids as supplemental treatment for AD/HD.^118,^ ^122,^ ^123^ A total of 131 children were randomized. The mean sample size for the three studies was 43.3 (range: 30–51) children. Participants received the intervention for an average of 14.6 weeks (range: 12–16 weeks). All three studies were conducted in the US. The study conducted by Voigt was funded in part by the US Department of Agriculture.^122^ The Stevens et al. study was funded by grants from the NIMH, National Fisheries Institute and Scotia Pharmaceuticals, Ltd.^123^ Brue et al.'s funding source was not reported.^118^

Population characteristics. The mean age of children enrolled in these 3 trials was approximately 9.16 years (range: 4–13 years).^118,^ ^122,^ ^123^ Those in the Brue et al. study tended be younger (mean: 8.4 years). Males were consistently better represented in the three studies (~80%). The percentage of white participants in Voigt et al.'s study was 100% in the DHA group and 85% in the placebo group.^122^ These data were not provided for the other two RCTs.^118,^ ^123^

Two studies employed DSM-IV diagnostic criteria^118,^ ^122^ while a third one did not report how AD/HD was identified.^123^ Brue et al. excluded children with serious and preexisting medical or psychological conditions such asthma or depression.^118^ Voigt et al. excluded patients who had experienced ineffective treatment with stimulant medication, treatment with other psychotropic medications, previous diagnoses of other childhood psychiatric disorders, use of dietary supplements other than vitamins, occurrence of a significant life event in the past six months, a history of head injury, receipt of special education services for mental retardation or a pervasive developmental disorder, premature birth, exposure to tobacco, drugs or alchol, or the diagnosis of a disorder of lipid metabolism or any other chronic medical condition.^122^ There were no significant between-group baseline differences for sex, methyphenidate dose, TOVA scores or Color Trails scores. All participants in the DHA group were white compared to 85% in the placebo group. While 22 of those allocated to the DHA group received a DSM-IV subtype diagnosis of combined (inattentive plus hyperactive) AD/HD and five were identified as predominantly inattentive, all children in the placebo group met criteria for combined subtype. Thirteen children in the DHA group and 15 children in the placebo group met DSM-IV criteria for oppositional defiant disorder. Six children in the DHA group and two children in the placebo group met criteria for conduct disorder. Minor between-group differences for age (i.e., slightly older in placebo group) and AD/HD subtype were controlled for in analyses.

Stevens et al. included children under the care of a clinician for AD/HD who were receiving standard therapy and were required to have a high frequency of skin/thirst symptoms evaluated by a questionnaire administered to parents.^123^ They excluded children with chronic health problems such as diabetes and kidney disease. Study groups were balanced for sex and medication status. No significant between-group differences were observed for age, height, sex, medication status, frequency of thirst/skin symptoms or nutrient intake. At baseline, few between-group differences in clinical outcomes were noted. The inattention score on the Disruptive Behavior Disorders (DBD) Rating Scale scores was higher in the placebo group. Parent-rated, Conners-related Abbreviated Symptom Questionnaire (ASQ) scores were also higher in the placebo group. Inconsistent between-group differences were seen for measures of reaction time. No significant between-group differences were seen for either plasma or RBC fatty acid levels.

Intervention/exposure characteristics. Voigt et al. identified the source of their intervention as an algae-derived triglyceride capsule providing 345mg of DHA per day. Although, it was stated that the placebo was identical in appearance and was supplied by the same company, the content was not defined.^122^ Patients in the Steven et al. study received either eight capsules a day of Efalex® or placebo.^123^ The intervention characteristics of the study conducted by Brue et al. have been described previously (see above).^118^ Voight et al. reported their exposure's manufacturer (Martek Biosciences Corporation, Columbia, MD)^122^ as did Stevens et al. (Efamol Ltd).^123^ None of the reports provided either purity data regarding their treatments or descriptions about whether, and how, the presence of methylmercury was tested or eliminated from the omega-3 fatty acid exposure. In the two studies that evaluated the fatty acid content of biomarkers, no notable inappropriate methods to extract, prepare, store or analyze lipids were described.^122,^ ^123^

Cointervention characteristics. In each study, omega-3 fatty acids were supplied as supplemental treatment. The patients enrolled in Voigt et al.'s trial received either methyphenidate at a dose of 29.2±30.1 mg/d in the DHA group (n=25) or 29.3±17.6 mg/d in the placebo group (n=22), dextroamphetamine at a dose of 15.0 mg/d (n=1) in the DHA group or 16.3±8.8 mg/d in the placebo group (n=2) or amphetamine/dextroamphetamine at a dose of 10 mg/d (n=1) in the DHA group or 15.0+/-8.7 in the placebo group (n=3).^122^ The treatment duration was 26.3 months in the DHA group compared to 29.5 months in the placebo group. In the Stevens et al. trial, children received methylphenidate, methylphenidate plus an antidepressant, or other medication such as pemoline or dextroamphetamine salts. Both study groups in the Brue et al. RCT were receiving methylphenidate.^118^

Outcome characteristics. Voigt et al. employed as primary outcome the changes in scores on the TOVA.^122^ They also evaluated the impact of supplementation on the omega-3 fatty acid content of plasma phospholipid fractions. In Stevens et al.'s trial, the parent- and teacher-rated ASQ and the DBD were the primary outcomes.^123^ Brue et al. employed the DSM-IV's Inattentive and Hyperactive-Impulsive subscales as outcomes.^118^

Study quality and applicability. The mean Jadad total quality score was 3, with each RCT receiving an applicability rating of I.^118,^ ^122,^ ^123^

Summary Matrix 9: Study quality and applicability of evidence regarding the supplemental treatment of attention deficit/hyperactivity disorder

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | Voigt^A^ | 2001 | 63 | Stevens^A^ | 2003 | 50 | Brue^U^ | 2001 | 60
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

### Qualitative Synthesis of Individual Study Results

Voigt et al. only conducted statistical analyses on complete TOVA and Color Trails test data available at baseline and at the end of the 4-month study.^122^ This amounted to data from only 49 (DHA=25, placebo=24) of the 63 randomized children. Capsule counts indicated high levels of compliance. After 4 months, there were no statistically significant between-group differences in scores on any component of the TOVA, for scores from either of the Color Trails tests, on the parent-endorsed CBCL or Conners Rating Scales. The plasma phospholipid DHA content in the placebo group remained unchanged, whereas that of the DHA group increased significantly. This increase was accompanied by a nonsignificant decline in AA, and a significant decrease in (omega-3-)DPA. No significant correlations were seen between initial plasma phospholipid DHA content and initial TOVA scores, final plasma phospholipid DHA content and final TOVA scores, or between changes in these two variables. The same patterns held for Color Trails data.

In the Stevens et al. study, the analyses of primary endpoints ASQ and DBD were conducted on those subjects who completed the 4-month intervention and had a minimum compliance of 75%.^123^ The total number of subjects evaluated for clinical outcomes at the end of the study were 18 in the PUFA group and 15 in the placebo group. Secondary analyses were performed on an ITT basis, with the last observation carried forward for all subjects who were randomized and who had received the first dose of the supplement.

A clear benefit of PUFA supplementation on behavioral characteristics of AD/HD was not observed. A significant improvement in the PUFA compared to placebo was observed in only two of sixteen outcome measures: conduct problems rated by parents and attention symptoms rated by the teacher. Only one of eight DBD rating scales showed a treatment effect, with a significantly greater proportion of children's oppositional defiant disorder improving clinically in the PUFA group. Supplementation did not produce a significant benefit in decreasing the frequency of thirst/skin symptoms. No significant between-group differences were found related to changes in plasma fatty acid levels. The magnitude of the decrease in RBC AA was significantly greater in the PUFA group. The percentage change in parent-rated ASQ scores was significantly and negatively correlated with the percentage change in RBC EPA and positively correlated with RBC AA. Percentage change in teacher-endorsed Attention scores on the DBD was significantly and negatively correlated with RBC DHA.

Brue et al.'s teacher-endorsed data revealed that children taking the dietary supplement combination, with flaxseed in addition to methylphenidate, manifested significantly less inattentiveness. Parent data did not confirm this finding. No significant between-group differences for either parent or teacher ratings of hyperactivity/impulsivity were found.

### Quantitative Synthesis

Given the lack of comparability in the interventions, comparators, and their combinations, in addition to the variability in the three studies' populations especially related to the presence of varying types of comorbid condition, meta-analysis was not performed. Only one report explicitly identified the AD/HD subtypes included in their RCT.^122^ This is a key population source of clinical heterogeneity.

### Impact of Covariates and Confounders

Voigt et al.'s trial was the best controlled of the three studies.^122^ They identified the subtypes of DSM-IV AD/HD allocated to each study group although their baseline assessments revealed that the DHA group contained a less homogeneous distribution of subtypes than did their control group. They also controlled for other confounders (e.g., other psychiatric diagnoses, use of dietary supplements), while at the same time allowing entry into the study various types of comorbid condition with the potential to influence outcomes (e.g., oppositional defiant disorder, conduct disorder). Voigt et al. provided the simplest of the three active treatments, focusing exclusively on DHA supplementation. Yet, they found no benefits relating to their very small dose, which in and of itself may have contributed to the failure to find a significant clinical effect.

The other two trials exercised considerably less experimental control, and when viewed together, the three studies provided at best an inconsistent picture of the benefits of providing omega-3 fatty acids. Thus, as with the topic pertaining to the primary treatment of AD/HD, the inconsistent findings, including a small number of significant clinical effects, and the variability in both the types of intervention and comparator made it impossible to begin to reliably identify key covariables affecting clinical outcomes.

## Is Omega-3 Fatty Acid Intake, Including Diet and/or Supplementation, Associated With the Onset, Continuation or Recurrence of Attention Deficit/Hyperactivity Disorder?

As observed in Summary Table 21 (below), derived from Evidence Table 3 (Appendix E††††††), one cross-sectional study published in 1999 met eligibility criteria.

### Overview of Relevant Study's Characteristics and Results

Yang et al. employed a cross-sectional design to investigate whether there were any differences in dietary intake between children diagnosed with AD/HD and normal healthy children.^94^ The AD/HD group (n=20; 4–8 years) consisted of outpatients (90% male) with a mean age of 5.7 (SD=0.9) years, who met DSM-IV criteria for AD/HD (duration not reported). Inclusion criteria for this group included a score of greater than 80% on the Standard Child Activity Level Form filled out by parents and teachers. The normal control group (n=32) consisted of children (91% male) with a mean age of 5.2 (SD=1.1) years recruited from junior and senior kindergarten, as well as grades one and two from schools in Taipei, Taiwan. Inclusion criteria for controls included being ages 4 to 8 years, and verification of good health. Excluded were children with AD/HD. The male-to-female ratio in the control group approximated that of the AD/HD group.

Anthropometric measurements were taken and participants filled out a dietary survey containing four categories: dietary intake from the previous 24 hours, 3-day dietary records, frequency of food intake, and dietary history. During the initial visit participants completed all categories of the dietary survey except for the 3-day dietary record. The latter was filled out following the initial visit and returned by mail. Given the extremely shortterm followup, and the data collected regarding past and present dietary intake, the study was considered a cross-sectional design. Funding was provided by the Chun Qing Infant and Child Nutritional Research Foundation.

Response rates for the 3-day dietary record for the AD/HD and control subjects were 60% (n=12) and 87.5% (n=28), respectively. The two groups did not differ significantly in age, height, body weight, weight-for-length index, chest circumference or tricep skin thickness. There were no significant between-group differences in intake of tryptophan, cholesterol or saturated fatty acids. According to the 24-hour dietary recall, the hyperactive group had significantly lower intake of LA and ALA. Only ALA was reduced in AD/HD children, relative to controls, measured by the 3-day dietary record.

Meta-analysis was not considered, and the existence of a single study, reporting few details, made it impossible to assess the possible impact of covariates and confounders. Yang et al.'s study received an applicability rating of III and a total quality score of 5.

## Is the Onset, Continuation or Recurrence of Attention Deficit/Hyperactivity Disorder Associated With Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Biomarkers?

As observed in Summary Table 22, derived from Evidence Table 2 (Appendix E‡‡‡‡‡‡), three cross-sectional studies met eligibility criteria. Studies were published between 1983 and 1995.

### Overview of Relevant Studies' Characteristics and Results

Mitchell et al.'s study was supported by Efamol Research Ltd. and the Medical Research Council of New Zealand,^125^ Stevens et al.'s funding source was the State of Indiana,^124^ and the second Mitchell et al. study did not report this information.^126^

Mitchell et al. investigated the RBC fatty acid content in hyperactive children compared to normal control children.^126^ Inclusion and exclusion criteria were not described, and a formal diagnosis was not assigned. Enrolled were children (n=23; 91% male; 7.5–13 years) identified with “maladjusted disorder” (nomenclature not reported) from a residential school for maladjusted children. The central clinical feature was hyperactivity. The controls were children (n=20; 50% male; 10–13 years) from a regular intermediate school. No inappropriate methods to extract, prepare, store or analyze lipids were described.

Mitchell et al.'s 1987 study examined the clinical characteristics and serum phospholipid EFA levels in DSM-III diagnosed hyperactive children (n=48; mean age: 9.1 years) compared with age- and sex-matched controls (n=49; mean age: 8.7 years).^125^ Subjects were recruited from the general population of Auckland using the Revised Behaviour Problem Checklist (RBPC) and the Conners Teacher Rating Scale (CTRS). The control group was drawn from two primary schools. The study groups exhibited no statistically significant differences for age, sex, ethnicity (92% European) and socioeconomic status. Some children in the hyperactive group (n=12) were on special diets, with ten on the Feingold diet and seven on sugar reduction diets. Between-group baseline differences were statistically significant for the RBPC Inattention subscale and CTRS scores, with higher scores in the hyperactive children. There was no significant between-group difference in medication use (no data reported).

Stevens et al. evaluated the RBC and plasma fatty acid content in boys with AD/HD and sex-matched children without this disorder.^124^ The sample was drawn from the general population. The diagnosis was made using the CPRS and CTRS. Questionnaires measured food intake and health information. The AD/HD children (n=53, mean age: 9.1 years) and normal controls (n=43, mean age: 9.1 years) were well matched for age, height, weight BMI and socioeconomic status. AD/HD children were less likely to have been breastfed but more likely to have temper tantrums, problems getting to sleep and waking up, to be taking medications (e.g., Ritalin), to have stomachaches, ear infections and asthma. Baseline Conners scores were significantly higher in the AD/HD group.

By univariate analysis, Mitchell et al. showed that there were no significant between-group differences for any RBC fatty acid content.^126^ Multivariate analysis revealed that a model involving ALA and AA, among other fatty acids, distinguished maladjusted and control children. There was no significant difference for RBC PUFA content between the sexes.

In Mitchell et al.'s second study the absolute levels of DHA, DGLA and AA in serum phospholipids were significantly lower in hyperactive children compared to controls.^125^ No other omega-3 or omega-6 fatty acid compositions distinguished the two study groups. When hyperactive children were subdivided on the basis of their concentrations of DHA, DGLA and AA, high and low DHA subgroups did not differ significantly on any clinical outcomes. Higher probabilities of speech difficulties, slower development and learning difficulties were each associated with low AA levels.

Stevens et al. demonstrated that the hyperactive group had a significantly higher PUFA intake in their diet compared to controls.^124^ The plasma levels of AA, EPA, DHA and total omega-3 fatty acids were significantly lower in hyperactive children. The plasma omega-6/omega-3 fatty acid ratio was significantly higher in the hyperactive group. Patients with hyperactivity had significantly lower RBC AA and (omega-6-)DPA levels. There was a significant and negative correlation between DHA concentration and CPRS scores.

Each of the Mitchell et al. studies received an applicability rating of III while the Stevens et al. study was assigned a I. Mean study quality for these studies was 2.7.

Summary Matrix 10: Study quality and applicability of evidence regarding the association between omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of attention deficit/hyperactivity disorder

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | | | | Stevens | 1995 | 96
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Mitchell | 1987 | 97 | Mitchell | 1983 | 43

n = number of allocated/selected participants

Although all of the included studies were controlled, none were prospective by design. Thus, meta-analysis was not considered. As well, the three studies did not investigate the same biomarker sources. Given the small number of studies, and the variability in the definition of the study populations and their controls, it was impossible to meaningfully explore the possible impact of predefined covariates or confounders.

## Is Omega-3 Fatty Acid Intake, Including Diet and/or Supplementation, Associated With the Onset, Continuation or Recurrence of Mental Health Status Difficulties?

As observed in Summary Table 23 (below), derived from Evidence Table 2 (Appendix E§§§§§§), one cross-sectional study published in 2002 met eligibility criteria.

### Overview of Relevant Study's Characteristics and Results

Silvers and Scott conducted a cross-sectional survey investigating the possible association between dietary intake of fish and self-reported mental health status in adults (15–65+ years) living in New Zealand.^127^ The data collected were from a combined 1996/1997 health survey and a 1997 nutrition survey. Participants were sampled using a stratified design based on contingent geographic areas. The sample consisted of 11,921 households. The final response rate was 73.8% (n=7,862) for the health survey and 50% (n=4,644) for the nutrition survey. Analysis was conducted on data from 4,644 participants. Participants completed the SF-36 questionnaire regarding their self-reported mental health status. Adjustments were made for the following potential confounders: age (four groups: 15–24 years; 25–44 years; 45–64 years; 65+ years), annual household income (four groups: < $20,000; $20,001–30,000; $30,001–50,000; $50,000+), smoking status (smokers, ex-smokers and non-smokers), alcohol use (non-drinkers, moderate drinkers scoring 1–7 on Alcohol Use Disorders Identification Test [AUDIT], problem drinkers scoring 8+ on AUDIT), and eating patterns (meat eaters, vegetarians, vegans). Funding was provided by the New Zealand Ministry of Health.

Respondents were divided on the basis of those who did (<once a month, to at least twice a day), or did not, consume fish.^127^ Univariate analysis revealed no significant correlation between fish consumption and mental health scores. By hierarchical regression, with age and income adjusted for, there was a significant association between fish consumption and mental health status. The mental health score was significantly lower in the group which consumed no fish, compared with the fish eaters. After adjusting for age, household income, smoking, alcohol consumption, and eating patterns this difference remained significant. This study received an applicability rating of III and a total quality score of 5.

Given that only one study was identified, meta-analysis and a formal assessment of the potential influence of covariates and confounders were not undertaken. Although this study conducted their analysis by controlling for several confounders, results need to be replicated before any meaningful conclusions can be drawn.

## Is Omega-3 Fatty Acid Intake, Including Diet and/or Supplementation, Associated With the Onset, Continuation or Recurrence of Tendencies or Behaviors With the Potential to Harm Others?

As observed in Summary Tables 24 through 28 (below), derived from Evidence Tables 1 through 3 (Appendix E*******), seven studies met eligibility criteria. These studies were published between 1996 and 2004. Five studies employed an RCT design while one cross-sectional study and a cross-national ecological analysis were also included. Although each question addressed the possible association of omega-3 fatty acid intake with the onset of tendencies or behaviors with the potential to harm others, the types of population fit into three categories. This is the order in which the studies are presented.

The first three RCTs investigated the possible protective effects of omega-3 fatty acids against aggression in healthy volunteers.^128–130^ One RCT and a cross-sectional survey examined the possible protective potential of the exposure against anger and/or hostility in populations identified at risk for heart disease^132^ or identified as having cholesterol problems.^99^ The latter study, by Wardle et al., has been reviewed elsewhere with respect to depression and anxiety.^99^ One RCT assessed the possible protective effect on the antisocial behavior in young adult prisoners, making this the only study designed specifically to investigate the exposure's possible influence on the continuation of this behavior (i.e., secondary prevention).^131^ The final study assessed the possible association of seafood consumption and homicide mortality.^133^

### Overview of Relevant Studies

Hamazaki and colleagues conducted all three of the RCTs investigating the effect of omega-3 fatty acid supplementation on aggression.^128–130^ The first two studies assessed the possible benefits of the exposure on healthy college volunteers^129,^ ^130^ while the final RCT enrolled elderly volunteers.^128^

Hamazaki et al.'s first trial randomly assigned nonsmoking university students to receive 3 months of either 1.5–1.8 g/d DHA (from fish oil; n=26) or control oil capsules (n=27) containing some omega-3 fatty acid content (97% soybean oil plus 3% fish oil; exact omega-3 fatty acid content not reported). The active intervention also contained some EPA and some omega-6 fatty acid content (see intervention/exposure characteristics below). Doses varied because they were adusted according to participants' weight. The study began at the end of the students' summer vacation and was completed in the middle of final exams (i.e., the stressor). The rationale was to see if stress could be prevented from becoming frustration and aggression.

Hamazaki et al.'s second trial examined possible protective effects against aggression in normal volunteers under nonstressful conditions.^129^ Fifty-nine nonsmoking university students, with 15 males per study group, were randomized to receive 3 months of either DHA-rich fish oil capsules containing 1.5 g/d DHA (n=29) or the same control oil capsules (97% soybean oil plus 3% fish oil; n=30) used in their first study. None of the participants had been enrolled in the first RCT. The timing of the trials' initiation and completion determined that volunteers would not likely be subjected to the same stressful conditions as arranged in the first study (i.e., final exams).

The third study focused on elderly Thai subjects.^128^ Forty-one subjects (50–60 years) were randomly assigned to receive either 1.5 g/d DHA (n=20) via 3g/d fish oil capsules or 3g/d of mixed plant oil via capsules (n=21) for 2 months. Extraggression was assessed at the beginning and end of the study. Immediately prior to its assessment at study end subjects were shown a 20-minute, stress-inducing videotape of real crimes and accidents as the study's stressor. Participants were recruited from two sources: university employees and villagers.

Wardle et al.'s RCT investigated whether cholesterol-lowering diets influence mood, including depression, anxiety, anger/hostility, stress, and general psychological well-being.^99^ Adult volunteers (n=176) with elevated serum cholesterol levels (>5.2mM [198mg/dL]) were allocated to a low-fat diet (n=59), a Mediterranean diet (n=61), or a waiting-list control (n=56). Dietary treatments were given in eight sessions over the 12-week period. Participants completed a seven-day dietary intake diary before the first assessment. Outcomes included the STAI, the anger subscale of the POMS, GHQ to assess general psychological well-being, and the PSS. Dietary diaries were filled out at baseline and 12 weeks.

Iribarren et al. assessed the possible association between dietary omega-3 fatty acids, omega-6 fatty acids and fish intake with the level of hostility in a sample of 3,581 urban white and black young adults.^132^ Their cross-sectional survey was conducted as part of the ongoing CARDIA cohort study investigating heart disease risk factors and subclinical coronary disease. The dietary assessment took place in 1992-1993, while data pertaining to hostility and other covariates were collected in 1990-1991. At baseline (1985-1986; n=5,115) participants had been 18 to 30 years of age. Sampling ensured a balanced racial distribution, and included random-digit dialing (Birmingham, Alabama), door-to-door recruitment (Minneapolis, Minnesota) and random selections from files at a medical care program (Oakland, California). Reassessments took place 2, 5, 7, 10 and 15 years from baseline. Retention was high even after 15 years (73%).

Gesch et al. empirically tested whether a “cocktail” of vitamins, minerals and essential fatty acids (0.08 g/d EPA, 0.044 g/d DHA, 1.26 g/d LA and 0.16 g/d GLA) would produce a reduction of antisocial behavior in adult prisoners at least eighteen years of age when compared to placebo.^131^ It had been hypothesized that offenders suffer from a lack of essential nutrients. The main focus was on whether or not antisocial behavior leading to disciplinary incidents would decrease from baseline. Given the requirements of life in an institution (e.g., parole), the analysis allowed participation ranging from 2 weeks to 9 months. Although 231 volunteers were identified, the number randomized to each group was not reported. The average time spent on supplementation was 142.6 days for the active treatment group (n=57 completers) and 142 days for the placebo group (n=55 completers). Randomization was stratified based on the four wings of the institution in which participants resided.

Hibbeln undertook a cross-national ecological analysis investigating the possible association between seafood consumption and homicide mortality.^133^ They posited that, since rates of death due to homicide demonstrate a 20-fold variation across countries paralleling cross-national differences in mortality from cardiovascular disease, then similar dietary factors might underlie both patterns. They argued that this relationship might be important since factors like hostility, depression and anger can increase the risk of cardiovascular morbidity. They considered violent behavior to sit at the extreme of a continuum that includes hostility. Homicide rates were taken from the 1995 Annual Health Statistics report of the WHO. Data concerning apparent seafood consumption were taken from the FAOSTAT database as was achieved in numerous other cross-national ecological analyses. Planned analysis included data from 26 countries.

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. Five RCTs,^99,^ ^128–131^ one cross-sectional survey^132^ and one cross-national ecological analysis^133^ were deemed relevant for the review. Two of the RCTs were conducted in Japan,^129,^ ^130^ two in the UK^99,^ ^131^ and one in Thailand.^128^ The cross-sectional survey was undertaken in the US^132^ while the cross-national ecological analysis obtained data from many countries.^133^ Except the cross-sectional ecological analysis, eligibility criteria for each of the studies were adequately described. Hamazaki et al.'s first trial was funded by the Nissin Seifun Foundation and a grant from the Japan-US Cooperative Medical Science Program.^130^ Their second study was supported by the Shorai Foundation for Science and Technology and by the Special Coordination Funds for Promoting Science and Technology of the Science and Technology Agency of the Japanese government.^129^ Their study of elderly volunteers received funds from the Special Coordination Funds for Promoting Science and Technology of the Science and Technology Agency of the Japanese government in addition to the Goho Life Sciences International Fund and a grant from the Japan-US Cooperative Medical Science Program.^128^ Wardle et al.'s trial was supported by a grant from the Biotechnology and Biological Sciences Research Council.^99^ Iribarren and colleagues received two NIH grants from the National Heart, Lung and Blood Institute, with the lead author also awarded a Scientist Development Grant from the American Heart Association.^132^ Gesch et al.'s study was supported by a grant from the research charity Natural Justice and its various contributors.^131^ Funding support for Hibbeln's ecological analysis was not reported.^133^

Population characteristics. The “healthy” status of student volunteers in the first two Hamazaki et al. RCTs was determined by physical examination and interview,^129,^ ^130^ although one also included blood tests completed three to four months prior to study entry.^130^ In their second and third studies, Hamazaki et al.'s volunteers had to be free of chronic illness, including alcoholism and any regular medication use.^128–130^ Additional reasons for exclusion in the trial with elderly subjects were health problems such as myocardial or cerebral infarction, cancer, severe hypertension and other serious diseases.^128^ Both samples of student were asked to keep their body weight and physical activity constant during the study^129,^ ^130^ In their study involving a stressor component, Hamazaki et al. described their students as ranging in age from 19 to 30 years, with more than half being female (n=34/53).^130^ In the RCT conducted without a stressor, subjects ranged from 20 to 30 years and slightly more than half were male (n=30/59).^129^ Elderly Thai subjects were between the ages of 50 and 60 years, with more male participants (n=22/41).^128^

There were no significant differences among the study groups for any of the baseline mental health (i.e., anger scores on POMS; general psychological well-being; stress; state anger and anger reactions scores on STAI), background diet (i.e., g/d or percent of energy saturated fat; g/d fiber), or other characteristics (i.e., age, marital status, sex, BMI, total, HDL and LDL cholesterol and trigyceride parameters) in Wardle et al.'s trial.^99^ Iribarren et al.'s observational study evaluated young adult white and black males and females.^132^ Significant heterogeneity was observed when the different subgroups were compared. For example, the mean hostility score was highest in black males, followed by white males, black females and white females. White participants were older than black subjects. Total energy intake was highest in black males, followed by white males, black females and white females. Intake of LA and ALA were each highest in black females, lowest in white females, and intermediate in males. Intake of AA was highest in black males and lowest in white females. Intake of EPA and DHA were each higher in black than white subjects. Omega-6/omega-3 fatty acid intake was significantly lower in white females than any of the other subgroups. Black participants consumed more total omega-6 fatty acid and total omega-3 fatty acid content than did white subjects. Alcohol intake was higher among males than females, and higher in white females than black females. While total fish intake did not vary by sex and/or race, black subjects consumed more fish rich in omega-3 fatty acids than did white participants. In black subjects, the proportion of current smokers and the prevalence of unemployment were higher while the level of education and the likelihood of being married were lower.

There were no statistically significant between-group differences at baseline on any of the measures of intelligence, verbal ability, anger, anxiety, malaise or depression in Gesch et al.'s trial.^131^ Countries included those from Asia (e.g., Japan, Hong Kong), continental Europe (e.g., Germany, Holland), the UK, Scandinavia (e.g., Norway, Sweden), South America (e.g., Chile), the Middle East (e.g., Israel), Australia, New Zealand, Canada and the United States in Hibbeln's cross-national ecological analysis.^133^ This suggests considerable variability in the background diet in general and not merely related to fish consumption.

Intervention/exposure characteristics. The exposure was weight-adjusted only in Hamazaki et al.'s first trial.^130^ In both studies involving students, each capsule contained 300mg of oil with the antioxidant α-tocopherol (0.3%) added to stabilize the exposure.^129,^ ^130^ The fish oil received by those in the DHA group contained 49.3% (wt/wt) DHA, 6.7% EPA, 9% palmitic acid, 7.3% oleic acid, 3.2% AA, 3.2% palmitoleic acid, 2.3% stearic acid and other contents (no data reported).^129,^ ^130^ The control oil was not inactive in that it contained 3% concentrated sardine oil that had been partially deodorized, and included 54.1% LA, 22.3% oleic acid, 10.8% palmitic acid, 6.8% ALA, 3.7% stearic acid, 0.5% DHA and other contents (no data reported).^129,^ ^130^ In the study of elderly Thai subjects, the DHA group took 1.5g/d DHA in addition to 0.2g/d EPA.^128^ Controls received 3g/d of mixed plant oil (47% olive oil, 25% rapeseed oil; 25% soybean oil, 3% fish oil), indicating that these subjects received some omega-3 fatty acid content as well.^128^ Capsules were typically taken around meal time.^128–130^ In none of the Hamazaki et al. trials were descriptions provided indicating the inappropriate handling of lipids.^128–130^

On three occasions, participants in Hamazaki et al.'s first RCT were asked to complete a food frequency questionnaire, to provide data concerning their dietary intake of various lipids, and to maintain their background diet.^130^ Participants in Hamazaki et al.'s last two trials completed the food frequency questionnaire at study's start and end.^128,^ ^129^ Compliance was monitored by capsule counts in their first RCT.^130^ Only 45% of subjects in each study group in the second trial reliably guessed which exposure they had been receiving.^129^ Likely due to having placed some fish oil in the control exposure, and perhaps also because of a briefing at study initiation which outlined this plan for study participants, elderly subjects could not reliably guess which exposure they had received (although villagers did significantly better).^128^

Portion sizes were established in Iribarren et al.'s observational study using cups and spoons, and reference was made to intake during the month preceding each clinical visit.^132^ Daily nutrient intake was estimated using the validated CARDIA diet history questionnaire. The intake of omega-3 and omega-6 fatty acid content was expressed as nutrient density (kcal/1000kcal/d). Intake of total fish or fish rich in omega-3 fatty acids (i.e., salmon, mackerel, trout, herring, eel, cod) were expressed as occasions per week.

The vitamin/mineral supplement combination (Vitamins A, D, B1, B2, B6, B12, C, E, K; biotin, nicotinamide, pantothenic acid, folic acid, calcium, iron, copper, magnesium, zinc, iodine, manganese, potassium, phosphorus, selenium, chromium, molybdenum) in Gesch et al.'s trial of young adult prisoners was matched with a vegetable oil placebo given in an identical, opaque bicolored gelatin shell.^131^ To this was added an Efamol Marine® product containing both omega-3 and omega-6 fatty acids. The daily dose was 80 mg EPA, 44 mg DHA, 1260 mg LA and 160 mg GLA. A vegetable oil placebo of identical color was delivered via a clear gelatin shell. Diet was assessed via a 7-day food diary. Meal portion weights were determined as well. Compliance was 89.3% and a significant between-group difference was not observed. Participants could not reliably guess which exposure they had been receiving.^131^ Hibbeln's apparent seafood consumption was defined as catch plus imports minus exports. Wardle et al.'s dietary changes have been described twice already and these details are not repeated here.^99^

Only Gesch et al. identified the manufacturer of their omega-3 fatty acid exposure (Efamol Ltd.),^131^ with no reports of interventional studies describing purity data or details as to whether, and how, the presence of methylmercury was tested or eliminated from the omega-3 fatty acid exposure.

Cointervention characteristics. No cointervention data were described in any of the study reports.

Outcome characteristics. All three of Hamazaki et al.s' trials used the Japanese version of Rosenzweig's validated adult Picture-Frustration test at pre- and poststudy.^128–130^ First responses to cards depicting frustrating scenarios were categorized as aggression varying in terms of its direction (extraggression: toward others; intraggression: toward self; imaggression: against nobody). In the second study, the Cook and Medley hostility scale (0/low to 50/high)was also employed.^129^ Blinded ratings were highly reliable (no data reported).^130^ The fatty acid composition of serum phospholipids was assessd in their first study,^130^ with phospholipid fractions of RBCs measured in their other two trials.^128,^ ^129^

Hostility was measured using the Cook-Medley Scale in Iribarren et al.'s observational study.^132^ Two types of incident report were defined by Gesch et al.: serious (e.g., violence) and minor (i.e., failure to comply with requirements).^131^ Homicide mortality rates were collected by Hibbeln.^133^ Wardle et al.'s outcomes are described above.^99^

Study quality and applicability. The five RCTs received a mean Jadad total quality score of 3.2, indicating sound internal validity.^99,^ ^128–131^ Two studies achieved a rating indicating Adequate allocation concealment,^99,^ ^131^ and three received an Unclear rating regarding allocation concealment.^128–130^ Three RCTs attained an applicability rating of III,^128–130^ whereas two trials achieved an applicability score of II.^99,^ ^131^ The cross-sectional survey was assigned a quality score of 5 and an applicability rating of II.^132^ The cross-sectional ecological analysis achieved a quality score of 4 and an applicability rating of III.^133^

Summary Matrix 11: Study quality and applicability of evidence regarding the association between omega-3 fatty acid intake and onset, continuation or recurrence of tendencies of behavior with the potential to harm others

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Gesch^A^ | 2002 | 112 | Iribarren | 2004 | >3k | Wardle^A^ | 2000 | 176
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Hamazaki^U^ | 1996 | 53
| | | | | Hamazaki^U^ | 1998 | 59
| | | | | Hamazaki^U^ | 2002 | 41
| | | | | Hibbeln | 2001 | 26C

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment;

C = Countries;

k = 1,000's

### Qualitative Synthesis of Individual Study Results

In Hamazaki et al.'s first study, dropouts and withdrawals did not present a notable barrier to the integrity of their study or in turn the meaningful interpretation of their results. Aggression directed toward others (extraggression) at times of stress was significantly increased in the control group by study's end, while no significant change was observed in the DHA group.^130^ The between-group difference was significant. Yet, under nonstresssful conditions (second study) it was found that extraggression decreased significantly in the control group whereas no significant change was observed for the DHA group.^129^ The between-group difference was barely significant. Hostility scores did not change significantly within either study group.^129^

There were no significant differences in changes in extraggression over Hamazaki et al.'s study of elderly Thai subjects for either males and females or for those varying in terms of their smoker status.^128^ Given that villagers in the control group had their extraggression scores decrease significantly more than did university employees, their data were analyzed separately. Extraggression did not change for those university employees receiving the control exposure while it did decrease significantly for those taking the DHA capsules. There was also a significant difference in extraggression between the two study groups. There was no significant between-group difference for the villager subjects. Results relating to the university employees showed that extraggression did not change over time for the control group yet decreased significantly for participants receiving DHA. For those subjects receiving the control exposure, the fact that they had been consuming approximately 150–160 mg/d of DHA from their regular food sources was insufficient to have a positive effect on responses to the test procedure.^128^

No significant between-group differences in changes from baseline were observed for AA, EPA or DHA in Hamazaki et al.'s first study.^130^ But, in their second trial they found significant increases in RBC membrane DHA and EPA in the DHA group while LA increased in the control group.^129^ AA decreased significantly in the DHA group as well.^129^ The two studies evaluated different biomarker sources. Hamazaki et al.'s trial enrolling elderly Thai subjects found no significant differences in fatty acid compositions between those varying on the basis of their sex, smoker status or urban status.^128^ As a result, these data were combined in subsequent analyses. No significant changes in fatty acid composition were observed in the control group. In the DHA group both EPA and DHA levels increased significantly over the trial. At the same time AA decreased significantly.

Each of Wardle et al.'s three study groups showed a significant within-group improvement only for the STAI's anger reactions after 12 weeks.^99^ Yet, there were no significant between-group differences observed for any of the following clinical outcomes: anger/hostility, stress, or general psychological well-being.

Iribarren et al. reported that total energy was positively correlated with hostility for the full sample and for all sex-by-race groups.^132^. ALA was exclusively and negatively associated with hostility for black males. EPA intake for all subjects was negatively correlated with hostility. Among black males, intakes of DHA, LA, total omega-6 fatty acid content, total omega-3 fatty acid content and of fish rich in omega-3 fatty acids were each correlated negatively with hostility. Omega-6/omega-3 fatty acid intake was uncorrelated with hostility for each of the sex-by-race groups. Alcohol intake was positively associated with hostility only in black subjects. Total energy and alcohol consumption were significantly and positively correlated with high hostility (>75^th^ percentile). Adjusting for age, sex, race, center, educational level, marital status, BMI, smoking, alcohol consumption and physical activity, the multivariate odds ratios of scoring in the upper quartile of hostility scores associated with one standard deviation increase in DHA intake was statistically significant. Consumption of fish rich in omega-3 fatty acids, when compared to no consumption, was significantly associated with lower odds of high hostility. When consumption of fish rich in omega-3 fatty acids was entered into a multivariate model along with intake of DHA, the association of the former variable with hostility was no longer significant. The investigators suggested that the original significant association was accounted for by DHA content.

Gesch et al.'s ITT analysis (n=231) revealed a statistically significant between-group difference in favor of fewer offences for those receiving active treatment. Those receiving active capsules showed a reduction of 26% compared to those taking placebo. Using data exclusively from those who received at least two weeks of supplementation (n=172; study group sizes not reported), only for those receiving supplementation did the number of incidents decrease significantly. The greatest reduction was observed for the most serious incidents. Minor reports exhibited the same pattern of difference between active and placebo groups.

US data were excluded from Hibbeln's cross-national ecological analysis since their rate of mortality due to homicide was 20 per 100,000 persons, making it more than double the rate from any other country, or 10-fold greater than the mean.^133^ Simple regression and logarithmic regression respectively revealed that countries with lower apparent seafood consumption had higher rates of death due to homicide. Excluding data from logarithmic regression for Asian countries (n=21 countries), which exhibited both high rates of seafood consumption and low rates of homicide mortality, maintained the significant relationship.

### Quantitative Synthesis

Meta-analysis was not conducted because of noncomparable outcomes (i.e., aggression vs anger/hostility vs antisocial behavior vs homicide), populations (i.e., healthy vs at risk for heart disease vs cholesterol problems vs young adult prisoners vs multiple national populations) and designs (RCTs vs observational studies vs cross-national ecological analyses). As well, of the three studies investigating the possible protective influence of exposures containing omega-3 fatty acids on aggression, one included a narrowly defined population (i.e., elderly volunteers).^128^ The remaining two Hamazaki et al. studies^129,^ ^130^ varied in terms of whether they weight-adjusted their doses, and only one of them employed a stressor against whose effects the exposure was targeted. More importantly, since the latter two studies used “cocktails” from which the exact contributions of omega-3 fatty acids could not readily be teased out, any attempt to combine their results would fail to elucidate the possible protective influence of omega-3 fatty acids per se.

### Impact of Covariates and Confounders

Given the noncomparability of the studies, it is difficult to identify threads of consistency across all of them. Even looking at the most homogeneous collection of studies, what cannot be ascertained are the individual or collective impacts on study outcomes of Hamazaki et al.'s attempts to control for body weight, physical activity and background diet in all three RCTs,^128–130^ smoking in their two RCTs with university students,^129,^ ^130^ for alcohol consumption in their second and third studies,^128,^ ^129^ their stratification for age and sex in their second study^129^ or for sex and smoker status in their study of the elderly.^128^ In their first trial report, Hamazaki et al. noted that there were no significant differences in the intake of DHA, EPA, LA, total omega-6/omega3 fatty acids or total lipid intake per day.^130^ This likely eliminated several possible sources of confounding. Other sources were seen to have been similarly controlled by virtue of specific observations. For example, the on-study intake of total energy did not change significantly for either study group in Hamazaki and colleagues' second trial;^129^ and, in their third study, daily on-study intake of DHA from food sources was similar for both study groups although the result of a statistical test was not reported.^128^

In other studies, many variables with confounder potential were likewise controlled. Wardle et al. found no between-group differences for age, sex, marital status or baseline clinical outcome scores for any disorder/condition, and not just anger.^99^ Iribarren adjusted analyses for age, sex, race, center, educational level, marital status, BMI, smoking, alcohol consumption and physical activity.^132^ Gech et al. noted no clinically significant between-group differences with respect to dietary intake.^131^ On the other hand, Hibbeln failed to control for important confounding factors such as alcohol consumption and smoking.^133^ Yet, regardless of these observations it is not possible to abstract clear and consistent patterns of influence by covariates and confounders.

## Is the Onset, Continuation or Recurrence of Tendencies or Behaviors With the Potential to Harm Others Associated With Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Biomarkers?

As observed in Summary Table 29 (below), derived from Evidence Table 2 (Appendix E†††††††), three cross-sectional studies published between 1987 and 2003 met eligibility criteria.

### Overview of Relevant Studies' Characteristics and Results

Hibbeln et al.'s research was supported by the National Association for Research on Schizophrenia and Depression (NARSAD)^134^ while Buydens-Branchey et al.'s study was funded by the Veterans Administration, the National Institute of Drug Abuse (NIDA) and the National Institute of Alcohol Abuse and Alcoholism (NIAAA).^136^ Virkkunen et al. did not report their funding source.^135^

Virkkunen et al. evaluated EFA levels in plasma phospolipids in two groups of habitually violent and impulsive male offenders (n=34, mean age: 33.2 years) compared to a healthy control group (n=16; mean age: 33 years).^135^ Each participant in the former had commited at least one violent crime and had had at least two discrete episodes of loss of control of aggressive impulses. The first subgroup included males meeting DSM-III criteria for antisocial personality (n=15) and had exhibited evidence of conduct disorder since childhood. The second subgroup of patients were habitually violent and had had problems with impulsivity only in adulthood. Their behavior satisfied DSM-III criteria for intermittent explosive disorder. Exclusion criteria were patients with mental retardation, chromosome abnormalities, antisocial personality without any habitually violent tendencies or schizophrenia. All fulfilled DSM-III criteria for alcohol abuse, yet without liver disease. They had been in prison an average of 5 months, with no access to alcohol. Patients and controls were well matched by age and weight. Controls were healthy men drawn from the personnel of a Psychiatric Clinic. None exhibited problems with aggression or alcohol. The diet of controls and patients was maintained in the hospital for 3 days prior to blood sampling, and none took any medication over that period.

Hibbeln et al. assessed plasma EFA contents and their correlation with serotonin and dopamine metabolites in cerebrospinal fluids in violent and nonviolent subjects (n=31; 71% male; mean age: 39.9 years).^134^ The group of violent subjects (n=27; 78% male; mean age: 38.5 years) were included if they had a history, within the last 3 months, of more than five episodes of violent, physical aggression that could cause bodily harm. Violent and control subjects were excluded if they had a history of a major psychotic or major affective disorder, panic disorder, illicit drug dependence, seizure or other neurological disorders. The controls were also excluded if they had a history of one episode of violent physical aggression. Thirteen violent participants met DSM-III-R diagnostic criteria for current alcohol dependence. No participants were taking any medication. The diagnostic tests used to perform the multidimentional clinical assessment were the Brown-Goodwin Lifetime Aggression Rating scales and the Buss-Durkee Hostility Inventory scales. Baseline scores on both scales were significantly higher in the violent subject group. All subjects were maintained on a low-monoamine diet for at least 3 days prior to blood and cerebrospinal fluid sampling. Confounders controlled for were age, alcohol consumption and alcohol-related liver damage.

Buydens-Branchey et al. examined the plasma levels of fatty acids in cocaine addicted males with or without aggressive behavior.^136^ The enrolled subjects were hospitalized for treatment of their DSM-IV diagnosed cocaine dependence. They were physically healthy and were not receiving any medication. The diagnostic test employed to assess aggression was the Brown-Goodwin Assessment for Life History of Aggression, and subjects with a score of 8 or more were considered to have a history of aggression (n=6; mean age: 38 years). The control group (n=18; mean age: 39.6 years) included non-aggressive cocaine addicts. No significant between-group baseline differences were observed for age, weight, number of years of cocaine use and amounts of cocaine used during the preceeding month. None of the three studies provided descriptions indicating inappropriate handling of lipids.

Virkkunen et al. found that the patients with intermittent explosive disorder had a significantly lower content of LA in plasma phospholipids compared to controls.^135^ DGLA was significantly higher in both violent groups compared with controls. The content of DHA was significantly reduced in the group of patients with violent antisocial personality disorder compared to controls.

Hibbeln et al. observed no significant between-group differences for omega-3 or omega-6 fatty acid content in plasma.^134^ The violent subjects group had a significantly lower concentration of cerebrospinal 5-hydroxindolacetic acid (CSF 5-HIAA) than did controls. Age, height, weight, plasma total cholesterol, frequency and quantity of alcohol consumed, lifetime alcohol consumption, Hollingshead socioeconomic scale, Michigan Alcohol Screening Test (MAST) and CAGE scores (derived from MAST) were not significantly associated with CSF 5-HIAA, CSF homovanillic acid (HVA), cholesterol, or plasma fatty acid contents (e.g., DHA).

Buydens-Branchey et al. did not find a significant full-sample correlation between EFA levels and patients' age, weight, number of years of cocaine use or amount of cocaine used during the preceeding month.^136^ No significant between-group differences were observed for plasma total fatty acids, PUFA content or total omega-6 fatty acid composition. (Omega-6)DPA, total omega-3 fatty acids and DHA were significantly lower in the aggressive patients compared to nonaggressive addicts. The omega-6/omega-3 fatty acid ratio was higher in the aggressive patient group, and the difference was only marginally nonsignificant (p = 0.055).

Study quality and applicability. Two of the studies received an applicability rating of I^134,^ ^136^ and a third was assigned a III.^135^ Mean study quality for the studies was 3.3.

Summary Matrix 12: Study quality and applicability of evidence regarding the association between the omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of tendencies or behavior with the potential to harm others

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Buydens-Branchey | 2003 | 24 | Hibbeln | 1998 | 58
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Virkkunen | 1987 | 50

n = number of allocated/selected participants

### Quantitative Synthesis

Although all of the included studies were controlled, none were prospective by design. Thus, meta-analysis was not considered.

### Impact of Covariates and Confounders

Too few studies, reporting too few details, and involving different combinations of target and control populations, precluded even an informal assessment of the possible influence of covariates and confounders.

## Is the Onset, Continuation or Recurrence of Alcoholism Associated With Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Biomarkers?

As observed in Summary Table 30 (below), derived from Evidence Table 2 (Appendix E), two cross-sectional studies published in 1984 and 1998 met eligibility criteria.

### Overview of Relevant Studies' Characteristics and Results

Alling et al.'s study was supported by the Swedish Medical Research Council and the pharmaceutical company Merck Darmastadt.^138^ Hibbeln et al.'s investigation was funded by the National Alliance for Research on Schizophrenia and Depression (NARSAD).^137^

Alling et al. measured the RBC and plasma fatty acid compositions in males with chronic alcoholism hospitalized for detoxication after a heavy drinking period (n=13; mean age: 54 [41–68] years) compared to healthy male controls drawn from hospital ward staff (n=21; mean age: 39 [22–58] years).^138^ Data included in this review focus exclusively on the baseline period, before detoxification began. No attempts to control for confounders were reported.

Hibbeln et al. investigated the relationship between concentrations of plasma EFAs and CSF 5-HIAA in abstinent alcoholics and healthy volunteers.^137^ Patients were admitted to the National Institute on Alcohol Abuse and Alcoholism (early-onset: n=88; late-onset: n=39). The diagnosis was made using different tools, including the Research Diagnostic Critera for alcoholism, the Schedule of Affective Disorders and Schizophrenia-Lifetime (SADS), MAST scores, Hollingshead ratings of socioeconomic class, the SCID (DSM-III-R) and the HDRS. The healthy volunteers (n=49, mean age: 37 years, 77.5% male) had to have a negative alcohol breath test and urine drug test in addition to a clinical history indicating no current or lifetime psychiatric or substance abuse disorders. Subjects with a history of major psychotic illness or bipolar affective disorder were excluded. All patients were medication-free. Both patients and controls were maintained on a low-monoamine diet for at least three days prior to blood sampling. Late-onset alcoholics were significantly older than early-onset ones, but there was no difference in age between either group and healthy controls. There were no significant differences between the three groups in terms of height, weight or BMI. The alcoholic patients did have a significantly higher number of cigarettes smoked per year as well as met more criteria indicating antisocial tendencies than did controls. Controls had a significantly higher Hollinghead score than did the early-onset alcoholics.

Alling et al. found significantly reduced phosphatidylcholine RBC membrane concentrations of LA, DGLA, AA and DHA in chronic alcoholic patients compared to healthy controls.^138^ There was a significantly reduced LA and AA content in phosphatidylethanolamine RBC membrane concentrations and in plasma in patients compared with controls.

Each of Hibbeln et al.'s alcoholic patient groups had significantly higher plasma cholesterol concentrations of total PUFAs, LA, AA, (omega-6-)DPA and DHA compared with healthy controls.^137^ No significant between-group differences characterized the remaining omega-3 and omega-6 fatty acid contents. Only the plasma concentration of DHA predicted CSF neurotransmitter metabolite concentrations in all three study groups.

Study quality and applicability. The mean study quality score was 2.5. Alling et al.'s study^138^ received an applicability rating of III whereas Hibbeln et al.'s rating was I.^137^

Summary Matrix 13: Study quality and applicability of evidence regarding the association between the omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of alcoholism

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | | | | Hibbeln | 1998 | 176
| II | Author | Year | n | Author | Year | n | Author | Year | n
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | | | | Alling | 1984 | 34

n = number of allocated/selected participants

### Quantitative Synthesis

Although all of the included studies were controlled, none were prospective by design. Thus, meta-analysis was not considered.

### Impact of Covariates and Confounders

Too few studies, focusing on different biomarker sources, and involving different combinations of target and control populations, precluded even an informal assessment of the possible influence of covariates and confounders.

## Are Omega-3 Fatty Acids Efficacious as Primary Treatment for Borderline Personality Disorder?

As observed in Summary Table 31 (below), derived from Evidence Table 1 (Appendix E§§§§§§§), one RCT published in 2003 met eligibility criteria. Meta-analysis was not considered.

### Overview of Relevant Study's Characteristics and Results

Zanarini et al. randomized 30 female outpatients (76.7% Caucasian; mean age: 26.3 [SD=6.2] identified with borderline personality disorder (duration unreported).^139^ Participants received either 1 g/d (97% pure; Laxdale Ltd.) E-EPA (n=20) or placebo (mineral oil; n=10) in a parallel design for 8 weeks (followups at 2, 3, 4, 6, and 8 weeks). The 2:1 randomization ratio was selected to permit the investigators to gain experience working with E-EPA as an exposure. Participants had to meet both the Revised Diagnostic Interview for Borderlines (DIB-R) and DSM-IV criteria for borderline personality disorder. By these criteria, patients were considered moderately ill. Exclusion criteria were those patients who were currently on psychotropic medication, medically ill, taking E-EPA supplements, eating more than one to two servings of fatty fish per week, alcohol or drug abusers, acutely suicidal, meeting current or lifetime criteria for schizophrenia, schizoaffective disorder, bipolar I, bipolar II or in the midst of a major depressive episode. Scores over the course of the study on the Modified Overt Aggression Scale (MOAS) and MADRS served as the primary outcome measures. Funding was provided by NARSAD.

Ninety percent of both E-EPA (n=20 with at least two followups) and placebo participants (n=10 with at least three followups) completed the 8-week trial. The three participants who dropped out of the study did so because of life events unrelated to the study or intervention. Statistical analyses were conducted on those participants who completed the full 8-week intervention. At baseline, results showed that there were no significant between-group differences on demographic characteristics or history of treatment (i.e., n=7/30 [23.3%] had taken psychotropic medication; 25/30 [83.3%] had received psychotherapy; n=3/20 [10%] had been hospitalized for psychiatric reasons). There were also no significant differences between the groups at baseline on either the MADRS or MOAS. This study report did not provide details as to whether, or how, the presence of methylmercury was tested or eliminated from the omega-3 fatty acid exposure. It received an applicability rating of I and an Jadad total quality score of 3, indicating good internal validity. There were significant clinical effects over the course of the study, as the E-EPA group had, at study end, significantly lower mean scores on both the MADRS and MOAS compared to the placebo group.

## Are Omega-3 Fatty Acids Efficacious as Primary Treatment for Schizophrenia?

A publication by Peet et al. in 2001 reported one study examining the use of omega-3 fatty acids as a primary treatment for schizophrenia, as well as a second study describing its use as a supplemental treatment for schizophrenia.^58^ The former is described here (Summary Table 32; Evidence Table 1: Appendix E********). Meta-analysis was not considered, and a meaningful assessment of the impact of covariates and confounders was not possible.

### Overview of Relevant Study's Characteristics and Results

Peet et al.'s pilot RCT allocated 30 DSM-IV diagnosed, drug-free schizophrenic patients to receive either 3 months of 2g/d EPA of enriched oil (Kirunal®; n=15) or corn oil placebo (n=15) via identical capsules (Summary Table 32).^58^ Patients were either newly diagnosed or had relapsed. For ethical reasons, medication was permitted, as required. Clinical judgement, and not predetermined criteria, guided these decisions. No significant between-group differences were observed for age, sex, duration of the illness, baseline total Positive and Negative Syndrome Scale (PANSS) or PANSS positive symptoms scores. Nine patients were drug-naïve and the others had had no medication for at least 2 weeks. Outcomes included the need for, and duration of, conventional medication in addition to the PANSS assessed at baseline and at study's end. Some financial assistance for this project was provided by a colleague of the investigators and by Laxdale Limited, the manufacturer of the EPA product. Purity data were not reported. No attempts to test for and eliminate methylmercury from the exposure were described.

Analyses were based on sixteen completers with final PANSS scores (n=12/15 in placebo group). Three patients were lost to followup, and one died of accidental burns unrelated to the illness or study protocol. All 12 patients in the placebo group and six of fourteen in the treatment group required antipsychotic medication by study's end. Of the latter six patients, four required no medication over the 3 month period, one needed antipsychotic medication during the first week, and one received a dose of depot antipsychotic medication (25 mg flupenthixol deconoate) at study initiation. Patients receiving EPA spent significantly fewer days on medication. In spite of the positive effect on symptoms that may have accrued to placebo patients, those receiving EPA had significantly lower total PANSS and PANSS positive scores when compared with placebo patients. The small sample size did not permit a statistical comparison of scores based on patients who were and were not drug-naïve. Responder analysis (50% improvement on PANSS positive) revealed that two of 12 placebo patients and eight of 14 EPA patients achieved responder status. This trial received a Jadad total score of 3, indicating good quality, an allocation concealment rating of Adequate, and an applicability rating of III.

## Are Omega-3 Fatty Acids Efficacious as Supplemental Treatment for Schizophrenia?

Four RCTs published either in 2001 or 2002 were identified as addressing this question (Summary Tables 33 through 36; Evidence Table 1: Appendix E††††††††). The second study in Peet et al.'s report is reviewed here.^58^

### Overview of Relevant Studies

Peet et al. have pointed out that EPA and DHA exhibit different metabolic functions. DHA is primarily a membrane structural component and EPA is implicated in eicosanoid synthesis.^58^ These metabolites have also been observed to have varying physiological effects.^169^ Together, these patterns suggest the need to differentiate between the possible effects of EPA and DHA in the treatment of schizophrenia.

As a result, Peet et al. conducted an RCT (n=55 allocated) designed to examine the impact, over 3 months, of 2 g/d EPA enriched fish oil (Kirunal®; 15 completers), 2 g/d DHA enriched oil (source undefined; 16 completers) or a corn oil placebo (14 completers) on symptomatic (PANSS score of at least 40), DSM-IV diagnosed schizophrenic individuals (Summary Table 33).^58^ Delivery of the exposure involved pourable bottles of oil. Participants were to continue on-study with stable doses of antipsychotic medication, and the study protocol anticipated that no changes in dose would be required. A psychiatrist monitored on-study medication. Outcomes included the PANSS score and RBC PUFA levels.

Fenton et al. conducted an RCT evaluating the efficacy of 16 weeks of 3 g/d E-EPA (n=45) compared to placebo (n=45) in 90 outpatients diagnosed with DSM-IV schizophrenia (n=61/87) or schizoaffective disorder (n=26/87) and clinically significant residual symptoms (Summary Table 34).^89^ Residual symptoms were defined as one or more positive and/or negative symptom scores greater than 4, or total scores greater than 45 with a score of 3 or more on at least three positive or negative items on the PANSS. Blind assessments took place at baseline and then every second week. The EFA content of RBCs was assessed at baseline and at study's end. Three patients withdrew consent in the first week of the trial (n=2 in placebo group).

Emsley et al. undertook a trial including 40 (18–55 years) DSM-IV diagnosed schizophrenic patients with persistent symptoms, randomized to receive, via 500 mg capsules twice daily, either 3 g/d E-EPA or placebo (liquid paraffin) as 12 weeks of supplemental treatment (Summary Table 35).^140^ All had received stable doses of antipsychotic for 6 months and had a total PANSS score of greater than 50. Patients were assessed at baseline and every 3 weeks thereafter using the PANSS and Extrapyramidal Symptom Rating Scale.

Peet and colleagues conducted a dose-ranging study of the effects of E-EPA on outpatients (n=122; 18–70 years) with persistent schizophrenic symptoms despite treatment with adequate doses of antipsychotic drug (typical [n=36 in ITT population], new atypical [n=48 in ITT population] or clozapine [n=31 in ITT population]) (Summary Table 36).^87^ Participants across nine sites were diagnosed as schizophrenic via DSM-IV criteria and were randomized to receive twelve weeks of either 1 g/d, 2 g/d or 4 g/d E-EPA, or placebo (liquid paraffin in identical gelatin capsule). These investigators selected EPA since it can inhibit the enzyme phospholipase A_2_. This enzyme's cycle entails the release of AA, and its overactivity and the concomitant loss of AA from cell membranes have been observed in association with schizophrenia.^87^ Change from baseline on the PANSS was the primary outcome. Assessments were conducted at baseline and then every 4 weeks.

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. Two of the trials were conducted in England,^58,^ ^87^ one in the US,^89^ and one in South Africa.^140^ Peet et al.'s RCT provided, by far, the most comprehensive information concerning inclusion and exclusion criteria. All trials employed a parallel design, with the number of groups ranging from two to four. All included a placebo control. An average of 76.8 patients were randomized, with a range of 40 to 122 patients. Studies'participants received the intervention for an average of 13.3 (range: 12–16) weeks. Some financial assistance for Peet et al.'s first project was provided by the investigators' colleague and by Laxdale Limited, the manufacturer of the EPA product.^58^ Fenton et al.'s RCT was supported by a grant from the Stanley Foundation/National Alliance for the Mentally Ill Research Institute.^89^ Emsley et al.'s study was supported by a grant from the Medical Research Council of South Africa, with the study exposure supplied by Laxdale Limited (Stirling, Scotland).^140^ Peet and colleagues' second trial received funding from Laxdale Limited, the manufacturer/supplier of their exposure.^87^

Population characteristics. Mean age data across all four included studies could not be calculated given that not all studies reported full sample data while some only provided demographic data for study completers.^58^ Participants' ages ranged from approximately 18 to 65 years across the four RCTs.

Age data only from completers were reported for Peet et al.'s study.^58^ For these outpatients, mean ages by study group were similar (42–44 years) although a formal statistical test was not performed. Patients' average age in Fenton et al.'s study was 40 years (SD=10; range: 18–65 years).^89^ Emsley's et al.'s RCT involved patients between the ages of 18 and 55 years.^140^ Baseline demographic were similar for their two study groups (no statistical tests reported). For example, mean ages for the E-EPA (46.2 years; SD=10.6) and placebo groups (43.6 years; SD=13.9) were comparable.^140^ Peet and colleagues' patients ranged from 20 to 62 years of age, with study group means making their sample population the youngest of all four trials (34–39 years).^87^ In this last RCT, study group mean ages were comparable although no test of statistical significance was reported. At baseline, patients in the 2g/d E-EPA group were slightly younger than those in the other three study groups.

Peet et al. found that males exceeded females in the EPA (67% male) and DHA (75% male) groups, and to a lesser extent in the placebo group (57% male).^58^ In their second study, male composition of the study groups ranged from 63% to 71%.^87^ Fenton et al.'s study randomized mostly males (61%).^89^ Emsley et al. did not report any data regarding sex.^140^ Only one study report provided ethnicity/race data,^89^ with 84% being Caucasian. In Fenton et al.'s study, 80% were single and 70% were high school graduates.

All studies employed DSM-IV criteria to identify outpatients with schizophrenia, while one study included diagnoses of schizophrenia and schizoaffective disorder.^89^ Only three study reports explicitly stated that patients were currently experiencing persistent, residual symptoms despite antipsychotic medication.^87,^ ^89,^ ^140^ Three RCTs used PANSS scores to demonstrate the presence and extent of persistent symptomatology^87,^ ^89,^ ^140^ while a fourth likely used these scores for this purpose.^58^ Peet et al. set a criterion PANSS total score of at least 40.^58^ No significant between-group baseline differences in PANSS total scores were noted in Peet et al.'s trial, although the mean score was the lowest in the EPA group.^58^ Residual symptoms were defined by Fenton et al. as one or more positive and/or negative symptom score(s) greater than 4, or total scores greater than 45 concomitant with a score of 3 or more on at least three PANSS positive or negative items.^89^ Emsley established a score of greater than 50 while Peet and colleagues required a total PANSS score of at least 50 in addition to a score of at least 15 on the positive PANSS.^87^ In the latter study little difference between study groups was seen for baseline total PANSS or MADRS scores. Baseline scores on the Liverpool University Neuroleptic Side Effects Rating Scale (LUNSERS), AIMS, Barnes Akithisia Scale (BAS) and the Simpson-Angus Scale for abnormal movements (SAS) were low and similar across study groups.^87^

In Peet et al.'s study, patients with symptomatic schizophrenia were also selected on the basis of failing to exhibit evidence of significant physical illness or other psychiatric disorders (e.g., mood disorders, learning disability).^58^ Substance abuse and significant medical conditions were exclusion criteria in Emsley et al.'s trial.^140^ An additional inclusion criterion in the Fenton et al. trial was that there could not be any change in antipsychotic medication in the thirty days preceding the trial, and no on-study change was expected.^89^ Exclusion criteria included diagnoses of substance dependence or mental retardation, bleeding disorders, taking fish oil supplements, anticoagulants, cholestramine or clofibrate antilipemic agents. However, Fenton et al. did not describe statistical tests designed to establish the baseline comparability of patients on key study outcomes.^89^ Their ITT group involved those patients with their last observation carried forward (n=87), and to achieve “completer” status patients had to experience no increase in neuroleptics over the study and at least 12 weeks of treatment (n=75; n=37 receiving EPA). As with trial completers and noncompleters, their two study groups did not differ significantly for any patient characteristics, including prestudy/baseline consumption of omega-3 fatty acids in the daily diet, or current smoker status.^89^ Prestudy/baseline between-group comparability in terms of dietary intake of omega-3 fatty acids or of omega-6/omega-3 content was not assessed in the remaining three RCTs.^58,^ ^87,^ ^140^

Few data were reported for key characteristics such as age of onset or time since diagnosis. In Peet and colleagues' RCT, patients were required to exhibit a time since first diagnosis of no more than 20 years and the absence of other important medical conditions.^87^ Mean illness durations were similar for Emsley et al.'s two study groups (no statistical tests reported) (E-EPA: 23.1 years, SD=8.5; placebo: 22.1 years, SD=12.4).^140^ Patients in Fenton et al.'s study first became ill at a mean age of 20.8 years, were first hospitalized at (mean) age 21.8 years, and had had an average of 10.7 prior hospitalizations.

Intervention/exposure characteristics. While each of the four studies employed an exposure from the same company (Laxdale Limited), only one explicitly stated its exact source (i.e., concentrated fish oil).^58^ The other studies referred to E-EPA, a purified form of EPA, yet did not identify its source or describe the process of purification.^87,^ ^89,^ ^140^ Dose contrasts included 3 g/d E-EPA or placebo (liquid paraffin),^140^ 3g/d E-EPA or placebo (mineral oil) in addition to 4 mg of vitamin E to retard spoilage,^89^ three different doses of E-EPA (4 g/d, 2 g/d, 1 g/d) or placebo (liquid paraffin),^87^ and 2 g/d EPA enriched oil as opposed to 2g/d DHA enriched oil or placebo (corn oil).^58^ However, there were few data allowing us to conclude definitively that these studies were equally able to eliminate the possible confounding influence of having unequal amounts of calories, as energy, provided for their different study groups.

In three RCTS, the omega-3 fatty acid contents were delivered by capsule,^87,^ ^89,^ ^140^ and one study provided their exposure via identical bottles.^58^ Of those using capsules, all provided some information suggesting that the appropriate numbers of capsule and amount of placebo content were used to equalize the total daily “intervention” per study group.^87,^ ^89,^ ^140^ Two of these trial reports did not describe whether the capsules were identical^89,^ ^140^ whereas the third did.^87^ Fenton et al.'s tasteless and odourless contents likely contributed to their patients' inability to reliably guess which exposure they were receiving.^89^ They also employed capsule counts to assure compliance.

The pourable oils (from identical bottles) used in Peet et al.'s trial^58^ were described as being indistinguishable by colour, texture and taste; however, no details were provided as to how the fishy taste or odour were controlled so as to preclude breaching the blind. That the exposure was delivered through pourable bottles raises an issue that was not addressed in Peet et al.'s report;^58^ such a poorly controlled approach to delivery typically complicates the interpretation of results (see Discussion).^72^

Three of the four trials employed a high dose, that is, one including at least 3 g/d of omega-3 fatty acids.^87,^ ^89,^ ^140^ As with the three supplemental treatment trials in depression, none of the studies provided omega-6 fatty acids or any other supplement as cointervention, and none attempted to implement a specific on-study ratio of omega-6/omega-3 fatty acid intake through diet or supplementation. Patients in the four trials were not instructed to maintain their background diet although Emsley et al. had a dietitian review the dietary intake of study participants at baseline and during the study.^140^ EPA intake was derived from standard food supplementation tables (South African Medical Research Council). During their study, no between-group differences were observed for the dietary intake of omega-3 fatty acids. A balanced diet (undefined) was attributed to study participants both at baseline and during the trial.^89^ Fenton et al. employed the Willett Dietary Survey to estimate baseline fatty acid consumption. Dietary EPA intake was low, ranging from 0.56 g/wk to 1.13 g/wk.^89^ For the other RCTs, possible between-or within-group group variability data regarding dietary intake were not provided. Thus, this potential confounder was not controlled for.

Only Fenton et al. used an antioxidant to retard spoilage.^89^ None of the trials described efforts to deodorize their exposures to maintain blinding. In the three studies evaluating biomarker data, no notable inappropriate methods to extract, prepare, store or analyze lipids were described.^58,^ ^87,^ ^89^ Purity data regarding the exposure were not provided by any of the trialists. No study report included details as to whether, or how, the presence of methylmercury was tested or eliminated from the omega-3 fatty acid exposure.

Cointervention characteristics. In Peet et al.'s study, patients with symptomatic schizophrenia were receiving various types of antipsychotic medication, including both oral and depot preparations (no data reported).^58^ Some required anticholinergic medication to address side effects from the primary medications (no data reported). Fenton et al. reported that all but one patient used a neuroleptic, with 19 taking two neuroleptics, 34 using risperidone, olanzapine or quetiapine, and 24 receiving clozapine.^89^ Eight participants required an increased neuroleptic dose (four per study group) and four were terminated by week 12 for nonadherence to study medication protocol (two per study group). Peet and colleagues asked that their participants be maintained on their regular antipsychotic medication and dose for at least one month: clozapine (n=31 in ITT population), novel atypical antipsychotic drugs (i.e., olanzapine, risperidone or quetiapine; n=48 in ITT population) or typical antipsychotic medication (n=36 in ITT population).^87^ The proportions of patient on the different antipsychotic medications were similar although fewer individuals were taking standard neuroleptics in the 2 g/d E-EPA group. Antipsychotic doses, expressed as chlorpromazine equivalents in the Emsley et al trial, were slightly different (E-EPA: 1011 mg/d, SD=532; placebo=931 mg/d, SD=652), although results of a statistical test were not reported.^140^ Nine patients in each group were receiving clozapine, with the rest taking conventional medication (undefined). The types and doses of antipsychotic medication did not change during the study. No additional medication had to be prescribed during the study except for occasional analgesics for headache or lorazepam for insomnia.

Outcome characteristics. Peet et al. employed the PANSS and assessed RBC PUFA composition.^58^ In Fenton et al.'s study, outcomes included the PANSS, the Abnormal Involuntary Movement Scale (AIMS), Simpson-Angus Rating Scale, MADRS and the CGI.^89^ The Repeatable Battery for the Assessment of Neuropsychological Status was used at baseline and 16 weeks. Adverse events were solicited at each study visit using open-ended queries. The fatty acid content of RBCs was also investigated.

PANSS change scores and Extrapyramidal Symptom Rating Scale (total score and subscale scores for dyskinesia, dystonia, akathisia and parkinsonism) were evaluated by Emsley et al.^140^ Peet et al. assessed change in scores on the PANSS and its subscales.^58^ Other outcomes included the MADRS, the LUNSERS, AIMS, BAS, and SAS.^87^ Peet et al.'s ITT population included 115 patients (of 122 randomized) who had had at least one post-baseline assessment, which was then carried forward.^87^ Given that E-EPA appears to act on membrane phospholipids, and different classes of neuroleptic have been seen to act on phospholipids differently, it was argued that patients receiving different antipsychotic medications would respond differently.^87^ Data from the three groups of patient receiving different types of antipsychotic were analyzed separately by Peet and colleagues^87^ Logistic regression took into consideration center, baseline scores, illness duration and type of antipsychotic medication. Peet and colleagues also assessed the impact on RBC PUFA.

Two additional analyses were conducted with Fenton et al.'s data.^89^ The first assessed some of the details defining the strong placebo response observed in the study (see below).^88^ The second^60^ assessed the impact on RBC fatty acid compositions of current smoker status, as one pro-oxidant factor with known degrading effects on PUFAs.^170^ Schizophrenic patients have disproportionately high rates of smoking.^171^ Analyses also evaluated the possible impact of another factor with the potential to degrade PUFAs (alcohol^172^), which, for example, was not controlled for by Peet et al.^58^ Other variables whose possible impacts were assessed were antipsychotic medication, sex, dietary intake, age, psychopathology, diagnostic subclassification and illness duration. Results from this second additional analysis by Hibbeln et al.^60^ could not be used to address the present review's question about the possible association of the fatty acid content of biomarkers and disease states since only schizophrenic patients were a priori selected as study participants. This review required controlled studies to address this question.

Study quality and applicability. The four RCTs received a mean Jadad total quality score of 3.8, indicating sound internal validity. Two each received allocation concealment ratings of Adequate^58,^ ^87^ or Unclear.^89,^ ^140^ Two received applicability ratings of II,^58,^ ^87^ and two received ratings of III.^89,^ ^140^

Summary Matrix 14: Study quality and applicability of evidence regarding the supplemental treatment of schizophrenia

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | Fenton^U^ | 2001 | 90
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | Peet^A^ | 2001 | 55
| | Peet^A^ | 2002 | 122
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Emsley^U^ | 2002 | 40

n = number of allocated/selected participants;

A RCT = Adequate vs ^U^Unclear allocation concealment

### Qualitative Synthesis of Individual Study Results

Ten of Peet et al.'s schizophrenic patients discontinued treatment (never started, n=3; lost to followup, n=2; felt better, n=1; adverse events described below), leaving data from 45 participants to be entered into the analysis.^58^ At study's end, the EPA group's total PANSS score was significantly lower than that in the placebo group. Taking baseline scores into account, repeated measures ANOVA revealed a significant treatment effect in favor of EPA over DHA using positive PANSS scores. EPA produced significantly greater improvement than did DHA yet the EPA versus placebo difference only approached statistical significance for positive PANSS scores. No significant differences were found for negative symptom scores. When patients were divided on the basis of their type of response (i.e., >25% improvement vs < 25% improvement or unchanged or worse), the groups were significantly different, with EPA patients more likely to show greater than or less than 25% improvement. Additional, pairwise comparisons revealed a significant difference between EPA and either DHA or placebo.

Including data from twelve patients in each of the three groups, analyses of RBC fatty acid levels from Peet et al.'s study showed the largest increases in EPA and DHA in the EPA and DHA groups, respectively.^58^ Smaller rises in EPA and DHA were observed in the DHA and EPA groups, respectively. No significant changes were observed for AA. For EPA group participants, patients showing the greatest improvement in total PANSS also had the highest baseline levels of EPA and AA; and, multiple regression identified baseline EPA as a significant predictor of clinical improvement. No similar significant results were found for the DHA group, the placebo group or the full sample.

In Fenton et al.'s study, repeated measures ANOVA showed a small but significant time effect for patients on each of total PANSS, MADRS and CGI scores.^89^ Both EPA and placebo patients benefited from their exposures. No time-by-group interaction effect was observed. No significant effects for time or a time-by-group interaction were found for ratings of cognitive impairment, extrapyramidal symptoms or tardive dykinesia. No significant differences were observed for the positive or negative PANSS scores. Results from analyses of data from study completers (n=75) were similar. Dickerson et al.'s followup assessment of the placebo response in the 37 patients receiving placebo revealed that most of the improvement occurred during the first 2 weeks of the study, with no PANSS score (total, positive, negative, general psychopathology) exhibiting significant change from week 2 to week 16.^88^

Analyses of biomarker data were reported by Fenton et al.^89^ and Hibbeln et al.^60^ No evidence of baseline bimodal distributions of RBC EPA, DHA or AA compositions was found to characterize the schizophrenic patients. By study's end, the EPA group exhibited higher percent compositions of EPA and (omega-3-)DPA, and lower percent compositions of DGLA, AA, and (omega-6-)DPA. A decrease in DHA in the EPA group was observed yet it did not reach statistical significance. EPA increased significantly in the placebo group. The decrease in the AA/EPA ratio over the study was significantly greater for patients receiving EPA.^89^ After adjusting for multiple testing, the change in AA/EPA ratio was not significantly associated with any clinical variables. Changes in DHA composition were negatively correlated with changes in positive symptoms and positively associated with changes in involuntary movement.

Of many investigations using various factors (e.g., diagnostic subclassification), only sex and current smoking status were significantly related to fatty acid compositions.^89^ The DHA percent was reduced in smokers compared to nonsmokers, and males had lower DHA and EPA percents compared to females. For patients exclusively receiving EPA, neither sex nor smoker status predicted changes in EPA, DHA or AA. Other findings are reported briefly in the Discussion.

With or without controlling for dietary EPA intake, medication, illness duration and sex, total PANSS score decrements were significantly greater in the E-EPA group in Emsley et al.'s trial.^140^ This significant difference was observed by week 3. The reduction in E-EPA patients taking clozapine was greater yet it did not achieve statistical significance. The only subscale score that produced a significant difference favored E-EPA patients for percent change in the general psychopathology score (PANSS). The only between-group difference on the dyskinesia scores from the Extrapyramidal Symptom Rating Scale involved a significantly greater reduction in scores for E-EPA participants at 12 weeks. Yet, ANCOVA with total PANSS change as the dependent variable and change in dyskinesia entered into the analysis revealed no significant between-group differences, suggesting that reduction in total PANSS scores is related to reduction in dyskinesia scores. One participant in the E-EPA group was withdrawn after an overdose of antipsychotic medication.

Peet et al. reported that nine patients experienced an adverse event leading to withdrawal although none were associated with the intervention.^87^ Four of these participants had been in the 1 g/d E-EPA group. This active treatment group had the highest number of “failures” other than a protocol violation (n=12/32) although these data included individuals providing more than one reason (data not reported). No demographic or clinical differences were observed for those who dropped out and those who completed the trial. Peet and colleagues observed no or minor reductions in LUNSERS, AIMS, BAS and SAS scores across the study, with no significant between-group differences.^87^

Changes in the total PANSS, its subscales and the MADRS for patients on typical neuroleptic drugs indicated that all E-EPA dosing groups improved significantly from baseline on the total PANSS, with the magnitude of the change covarying with the dose size.^87^ Only the 2 g/d and 4 g/d E-EPA groups improved significantly on positive PANSS scores, with the magnitude of the change covarying with the dose size. A similar pattern was found for negative PANSS scores although the magnitude did not covary with the dose size. For the general psychopathology subscale of the PANSS, equivalent improvements were seen in the 1 g/d and 4 g/d E-EPA study groups. No significant changes were seen for MADRS scores. However, large placebo effects were found such that significant improvements from baseline were observed for each of these clinical outcomes, including the MADRS. However, when compared to placebo, no significant differences were observed for patients on typical neuroleptics.

Results from patients receiving atypical neuroleptics indicated significant within-group improvement for typical neuroleptics for the 1 g/d and 2 g/d E-EPA doses with respect to the total and subscale scores on the PANSS as well as the MADRS, yet the 4 g/d E-EPA did not yield any significant improvement on any of the clinical outcomes.^87^ Significant improvements were seen for all clinical outcomes for placebo patients, contributing to the lack of significant between-group differences.

Patients on clozapine exhibited a different pattern of results.^87^ Results indicated that patients receiving placebo showed no significant improvements from baseline for any clinical outcome. Yet, except for the MADRS and the general psychopathology score on the PANSS, which were characterized by an absence of significant change, all three E-EPA doses showed significant improvements from baseline. The 2 g/d dose exhibited the greatest magnitudes of percent change in scores. Unlike what was found when the other two types of medication were examined, patients on 2 g/d E-EPA added to clozapine improved significantly relative to placebo on the total PANSS scale and the PANSS general psychopathology subscale.

Fatty acid composition data were analyzed by antipsychotic medication.^87^ The only significant change in the placebo group was a significant mean increase from baseline in AA within the group of patients taking atypical antipsychotics. In all drug groups except for 1 g/d E-EPA given in addition to clozapine, there were significant dose-related increases in EPA levels from baseline. In patients taking clozapine, a significant increase in AA was observed in the 2 g/d E-EPA group. The increment in DHA in the 2 g/d E-EPA group did not achieve statistical significance. Significant decreases were observed for both DHA and AA levels in the 4 g/d E-EPA group of patients also taking atypical antipsychotics. No other significant differences were observed.

Mean percentage change data for the total PANSS score as well as PANSS subscale scores and the MADRS from each of the twelve groups of patient (4 treatment levels by 3 types of neuroleptic) were assessed for their possible association with mean percentage change data for each of EPA, DHA and AA RBC levels.^87^ Peet et al. found that changes in AA were significantly and positively related to changes in all clinical outcomes. Changes in DHA or EPA were unrelated to changes in clinical outcomes.

A known side effect of clozapine, elevated levels of triglycerides were either prevented (in placebo and 1g/d E-EPA groups) or baseline levels were reduced significantly (2 g/d E-EPA and 4 g/d E-EPA).^87^

### Quantitative Synthesis

Given the available data, total PANSS score was chosen as the primary outcome measure. Since each of the RCTs measured PANSS at baseline and 12 weeks post-treatment, we aimed to extract the mean change from baseline in PANSS, together with the standard deviation of this change, for each treatment group. Where possible, data for ITT populations were used. Since only one study included more than one dose level of EPA, only placebo-controlled data were analyzed.^87^ A single study included one DHA dose,^58^ which yielded no benefit when compared to placebo.

In two reports,^58,^ ^140^ summaries and statistical analyses were reported in terms of percent change. However, percent change has undesirable statistical properties.^173^ Thus, the authors of both reports were contacted and change from baseline data were requested.

Only one author provided the requested data.^140^ In the Peet et al. report,^58^ post-treatment means and standard deviations were used instead of those for change from baseline.^174^ In Fenton et al.'s publication,^89^ the mean and standard deviation of PANSS were reported at baseline and at followup, but the standard deviation of change from baseline was not provided. The author was contacted but no reply was received, and post-treatment means and standard deviations were used instead of those for change from baseline. In Peet and colleagues' report,^87^ results were reported separately by background treatment (typical neuroleptics, atypical neuroleptics, and clozapine), and for four different treatment groups (placebo and three different E-EPA doses). Although the standard deviation of change from baseline was not reported, p-values for change from baseline were provided, enabling us to infer the standard deviation. For each treatment group, the mean change was pooled across primary treatments using a weighted mean, and the standard deviation of the change was pooled across these treatments using a pooled standard deviation.

Pooling was conducted using the weighted mean difference approach and the random effects method of DerSimonian and Laird.^175^ Statistical heterogeneity was assessed using the chi-square test with a significance level of 0.10. In all but one study,^58^ results from ITT analyses were available (using a last-observation-carried-forward strategy).

No pooled estimate is shown in Figure 4 because of the variation in dose within and among studies. Additionally, it should be noted that in the Peet and colleagues study^87^ the estimates for different doses versus placebo share the same placebo group. It was thus decided to investigate separately the placebo-controlled impacts of high- and low-dose EPA supplementation (i.e. <3 g/d vs ≥3 g/d).

Figure 4. Estimates of the difference in mean total PANSS score between EPA and placebo groups, by study evaluating the supplemental treatment of schizophrenia

Given the number and sizes of the studies, a random effects model was employed. The pooled estimate (-7.5) and its 95% confidence interval (-14.5 to -0.4) are represented by the diamond at the bottom of Figure 5. While the estimate of precision was large, the model revealed significant benefit accruing to a 2 g/d EPA dose.^87^ The 1 g/d estimate from the Peet et al. study^87^ is shown as an open circle because it was not included in the pooled estimate; the estimate for the 2 g/d dose shares the same placebo group. Statistical heterogeneity was not significant between the two pooled studies (chi-square statistic 0.66 on 1 degree of freedom, p=0.42).

Figure 5. Estimates of the difference in mean total PANSS score between low dose (<3 g/day) EPA and placebo groups. Percentage weights contributed by each study to the pooled estimate are shown on the right-hand side

Looking at high doses of at least 3 g/d EPA, the pooled estimate (-1.5) and its 95% confidence interval (-8.0 to 4.9) are represented by the diamond at the bottom of Figure 6. No significant benefit was observed in association with high-dose EPA. Statistical heterogeneity between the studies was significant at the 0.10 level (chi-square statistic 4.9 on 2 degrees of freedom, p=0.09).

Figure 6. Estimates of the difference in total PANSS score between high dose (3 g/day or greater) EPA and placebo groups. Percentage weights contributed by each study to the pooled estimate are shown on the right-hand side

### Impact of Covariates and Confounders

From these preliminary analyses, only 2 g/d, or low-dose, EPA produced a significant benefit. Only one trial employed a 1 g/d dose and hence this definition of a low dose could not be subjected to quantitative synthesis. Since only data from the UK trials were combined statistically in the meta-analysis of low-dose EPA, possible confounding from differences in the background diet was minimized, or even eliminated, in a way that likely would not have occurred if data from the South African study of Emsley et al. or the American RCT of Fenton et al. had been included in this meta-analysis. It must also be recalled that, in Peet and colleagues' RCT, only those receiving clozapine as primary treatment exhibited a significant benefit associated with E-EPA supplementation.^87^

## Is Omega-3 Fatty Acid Intake, Including Diet and/or Supplementation, Associated With the Onset, Continuation or Recurrence of Schizophrenia?

As observed in Summary Tables 37 through 39 (below), derived from Evidence Tables 2 and 3 (Appendix E‡‡‡‡‡‡‡‡), six observational studies and three cross-national ecological analyses met eligibility criteria. Two of the latter have already been described in this report, and so some of their details are not repeated. Since it investigated a single group of patients, the Mellor et al. study did not qualify to address either basic question 1 (i.e., interventional focus) or 3 (i.e., fatty acid content of biomarkers).^91^ It did, however, meet eligibility criteria to address the present question. The nine studies were published between 1988 and 2004.

### Overview of Relevant Studies

Mother's milk is considered an important dietary source of omega-3 fatty acids, which are essential for the development of the brain.^176^ It is thought that schizophrenia may be linked to early brain development,^55^ and therefore it is not surprising that the relationship between the early intake of omega-3 fatty acids and the risk of developing schizophrenia has been explored.

Peet et al. conducted a case-control study comparing the infant feeding histories (breastfed vs formula-fed) of DSM-IV diagnosed schizophrenic patients (n=55) and nonpsychiatric controls (n=55) matched for age (mean: 34 years), sex (47 males) and socioeconomic status.^92^

In McCreadie et al.'s case-control study, mothers of patients with schizophrenia (n=45; 29 males) completed a questionnaire about whether, and for how long, their offspring, including all siblings (n=92), had been breastfed.^143^ A census in 1989 identified 146 schizophrenic patients, 61 of whom had living mothers. From these, 51 mothers were interviewed regarding the birth of their children and their subsequent adjustment. The current mental health status of the patients was also assessed (details published elsewhere). In 1995, a questionnaire was sent to the mothers to determine their offspring's breastfeeding history, including its duration. National survey data for Great Britain (1946: n=13,687), Scotland (1958: n=1,648) and Scotland (1980: n=1,718) were used to establish various reference standards.

Leask et al. analyzed prospective data separately from two UK national birth cohorts (1946: n=5,362; 1958: n=18,856) using a nested case-control approach.^142^ They compared the feeding histories (including duration) of those individuals who later developed schizophrenia with the rest of the population. The 1946 British National Survey of Health and Development was devised to survey all births in mainland Britain. A random sample, stratified by social class, comprised a cohort (n=5,362) who were followed up on many occasions (i.e., 20 followups by age 43). The 1958 National Child Development Study included 98% of the births in mainland Britain, and had five followups, ending when individuals were 33 years of age. Mothers provided details about perinatal feeding by interview (1946: when child was age 2; 1958: when child was age 7).

Sasaki et al. examined feeding patterns during the infancy of inpatients and outpatients with schizophrenia (n=100; 60 males; age=32±9 years), their healthy siblings (n=37; 22 males; age=34.6±8.4 years) and age-matched healthy controls (n=200; 92 males; age=31±10 years) (Summary Table 38).^144^ Mothers of controls were primarily recruited from hospital staff and a few physicians.

Amore et al. conducted a case-control study to compare the incidence and length of breastfeeding in patients with schizophrenia (n=113; n=58 inpatients), their siblings (n=140) and normal (i.e., nonschizophrenic) controls (n=113).^141^ The goal was to examine the relationship between the duration of breastfeeding and age of onset of schizophrenia. Schizophrenic patients who were either consecutively admitted to a psychiatric ward or attending an outpatient community health center were enrolled in Bologna. For each patient, a control was selected from the Bologna birth register. The latter were matched for age, sex, singleton status and residential district.

Mellor et al. examined the possible association of both dietary intake and RBC fatty acid status with schizophrenic symptoms in a cohort of schizophrenic patients (mean age: 56.1 years; 13 males) who, after providing prospective data concerning dietary intake, then went on to receive supplementation in a noncomparative before-after study.^91^ All patients were receiving neuroleptic medication.

Christensen and Christensen described the statistical association between the course and outcome of schizophrenia using data from eight national centers involved in the WHO's 2-year followup study (Denmark, India, Colombia, Nigeria, UK, the former USSR, US and the former Czechoslovakia), and data regarding the dietary intake of fats from various food sources, including fish and seafood (Summary Table 39).^145^ The latter data were obtained from the same FAOSTAT source consulted by Peet in his cross-national ecological analysis.^109^

Lifetime prevalence rates for schizophrenia, from seven countries, were obtained by Noaghiul and Hibbeln from the Cross-National Collaborative Group epidemiological study in their cross-national ecological analysis.^90^ To these were added prevalence data from seven additional countries (Spain, Israel, Iceland, Australia, UK, Greece and Hong Kong). All rates were reported as cases per 100,000 population. Prevalence rates drawn from the Cross-National Collaborative Group epidemiological study were standardized at each site, with a weight calculated per subject, and stratified for age and sex. Data from other sources could not be weighted in this manner since primary data were unavailable. Socioeconomic status and educational level were not taken into consideration. The female-to-male ratio (age=18–64 years) was roughly equal at all sites, with slightly higher rates seen for Canada, Puerto Rico, Korea and New Zealand. National seafood consumption data, measured as apparent seafood consumption (lb/person/y), were obtained from the National Marine Fisheries Service and the WHO's FAOSTAT database. As a measure of the disappearance of seafood from the economy per year, apparent seafood consumption (lb/person/y) was once again calculated as total catch plus imports minus exports.

Peet's ecological analysis focused on international variations in the prevalence of depression and the outcome of schizophrenia, and their possible prediction by patterns of omega-3 fatty acid intake.^109^ Data on food use were taken from the FAOSTAT database, and reflect apparent national food consumption. Two-year outcome data relating to schizophrenia were drawn from the WHO's International Pilot Study of Schizophrenia (IPSS). A second source of schizophrenia outcome data was the Determinants of Outcome of Severe Mental Disorders (DOSMED) study. Additional references to the sources of these data are included earlier in this report.

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. Of the five case-control studies, only Peet et al.'s abstract^92^ failed to give adequate descriptions of eligibility criteria. Mellor et al.'s description of their patient cohort was sparse.^91^ All three cross-national ecological analyses provided sufficient amounts of detail to determine their methods.^90,^ ^109,^ ^145^ While the latter each included data from multiple countries, the observational studies were conducted in Italy,^141^ Japan^144^ and the UK.^91,^ ^92,^ ^142,^ ^143^

Population characteristics. Given the heterogeneous nature of the included studies' populations it made little sense to synthesize some of the population characteristics such as age or percent male composition. On two occasions, inpatients and outpatients were described as the source of the study population.^141,^ ^144^ Mellor et al.'s schizophrenic patients had been, or were, longterm inpatients.^91^ The remaining reports did not provide similar details.^90,^ ^92,^ ^109,^ ^142,^ ^143,^ ^145^ Diagnoses of schizophrenia were assigned using DSM-IV criteria,^92,^ ^141,^ ^144^ the ICD-9^143^ or DSM-III-R for Leask et al.'s 1946 birth cohort and CATEGO criteria for their 1958 birth cohort.^142^ Mellor et al. also employed DSM-III-R criteria.^91^ Most of Sasaki et al.'s patients had been chronically ill, had had several episodes of exacerbation and had histories of admission to hospital.^144^ Other than this case-control study report, none of the other reports described a method used to rule out schizophrenia or other psychopathology from control groups. Comparison subjects and their mothers, in addition to unaffected siblings, were interviewed by Sasaki et al.'s clinicians to establish that none were experiencing major psychoses or other psychiatric disorders. The WHO's international followup study, using its own diagnostic criteria, were implicated in all three cross-national ecological analyses.^90,^ ^109,^ ^145^

Each observational study report failed to present ethnicity/racial data although Sasaki et al.'s likely involved Asian participants.^144^ The cross-national ecological analyses included, by definition, mixed ethnicities/races.^90,^ ^109,^ ^145^ Some active attempts to match controls and patients were made. Amore et al. matched their groups by age, sex, singleton status and residential district.^141^ Peet et al. matched groups based on age, sex and socioeconomic status.^92^ The social class of the father at birth, and sex of the child were taken into consideration as potential confounders in Leask et al.'s study.^142^ In Amore et al.'s study, the only significant between-group differences were that more patients than siblings were male, and more patients than controls were second-born or more.^141^ No significant differences were observed for age of offspring, age of mothers at birth, or age of fathers at birth. Amore et al. divided their patients with schizophrenia into those who had been solely breastfed for at least the first four months of life, those having exclusively received formula, or those having received a mixed feeding within the first four months of life.^141^

Intervention/exposure characteristics. Typically, interviews were employed in case-control studies to gather data concerning the feeding method,^92,^ ^142^ with some investigators also inquiring about the duration of feeding practices.^141,^ ^143^ Sasaki et al. employed a written questionnaire to collect their data.^144^ Leask et al.'s breastfeeding data were collected from the two cohorts in the same way: prospectively from UK birth registries.^142^ Data were not provided in any report on the possible intake of omega-3 fatty acids by mothers during pregnancy or breastfeeding. Mellor et al. collected meal intake data prospectively for one week using a 7-day weighed intake approach.^91^ Diet history diary data were also requested to keep track of between-meal intake. Exposure data for all three cross-national analyses were extracted from the United Nations' FAOSTAT database.^90,^ ^109,^ ^145^

Outcome characteristics. Two case-control studies assessed outcomes pertaining to the course and outcome of schizophrenia.^109,^ ^145^ Amore et al. evaluated the age of onset of schizophrenia.^141^ McCreadie assessed a number of scores based on instruments evaluating adjustment, including the PANSS.^143^ Mellor et al. employed the PANSS, AIMS and Research Diagnostic Criteria concerning tardive dyskinesia.^91^ All other studies focused on the prevalence of schizophrenia.

Study quality and applicability. The five case-control studies received a mean quality score of 4.6, with three studies assigned an applicability rating of II,^92,^ ^142,^ ^143^ and another two studies receiving an applicability rating of III.^141,^ ^144^ The single prospective cohort study attained a quality score of 4 and an applicability rating of II.^91^ The mean quality score received by the three cross-national ecological analyses was 3.3, and each attained an applicability rating of III.^90,^ ^109,^ ^145^

Summary Matrix 15: Study quality and applicability of evidence regarding the association between omega-3 fatty acid intake and onset, continuation or recurrence of schizophrenia

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | McCreadie | 1997 | >13k | Peet | 1997 | 110
| | | | | Leask | 2000 | >23k
| | | | | Mellor | 1996 | 20
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Sasaki | 2000 | 337 | Christensen | 1988 | 8C
| | | | | Amore | 2003 | 363 | Peet | 2004 | 12C
| | | | | Noaghiul | 2003 | 14C

n = number of allocated/selected participants;

C = Countries;

k = 1,000's

### Qualitative Synthesis of Individual Study Results

Peet et al. found that, compared with nonpsychiatric controls (78%), schizophrenic patients (60%) were less likely to have been breastfed.^92^ Additional analysis of those individuals who had been breastfed for more than 4 weeks indicated that there were fewer of these individuals in the schizophrenic group (44%) compared with the control group (67%).

McCreadie reported that the incidence of breastfeeding (i.e., breastfed at least once) was lower in schizophrenic patients (29%) than in their siblings (38%).^143^ This difference was not statistically significant. Neither mother's age at birth, nor birth order, distinguished between patients and their siblings. Most of the patients had been born in the 1940s and 1950s, with the incidence of breastfeeding in these decades being significantly lower than what was observed in Scottish national surveys in 1946 (33% vs 81%) and 1958 (26% vs 51%), respectively. Those patients who had not been breastfed exhibited more schizoid and schizotypal personality traits (Scale for Assessment of Premorbid Schizoid and Schizotypal Traits) in childhood than did their siblings, including poorer social adjustment (Premorbid Social Adjustment Scale). Breastfed patients did not differ in these ways from their siblings. No significant correlations were observed between length of breastfeeding and any indices of adjustment, including the negative PANSS.

Leask et al. did not find significant differences in the feeding histories of patients with schizophrenia and controls, with or without adjustment for offspring's sex and father's social class.^142^ In the 1946 birth cohort, 30 cases of schizophrenia or schizoaffective disorder (n=20 males) had manifested by age 43 years, with 24.1% of cases and 23.6% of controls having exclusively been formula-fed. In addition, 17.3% of cases and 12.3% of controls had been breastfed for less than 1 month. Corresponding data for those breastfed more than one month were 58.6% and 64.1%, respectively. In the 1958 birth cohort, 40 cases of “narrow schizophrenia” (n=14 males) had emerged by age 28 years. Of these, 24.1% of cases had been solely bottle-fed compared with 31.7% of controls. The figures for those breastfed for less than 1 month were 27.6% and 24.9%, respectively. Data for those breastfed longer than 1 month were 48.3% and 43.3%, respectively.

Sasaki et al. found no evidence for a lesser likelihood of schizophrenic patients having been breastfed, either at 1 month or 3 months post-birth (no statistics reported).^144^ Nor was there evidence that a decrease in breastfeeding had occurred during the infancy of schizophrenic patients (no statistics reported).

Amore et al. divided their schizophrenic patients into those who had been solely breastfed for at least the first 4 months of life, those who had exclusively received formula, or those having received “mixed” feeding within the first 4 months of life.^141^ Adjusting for age, sex, birth weight, disease severity and birth order, they found no significant between-group differences in the incidence of breastfeeding. As well, there were no between-group sex differences in the type of feeding. Siblings had been breastfed longer than normal controls. Age of onset was later in those exclusively breastfed (22.1±6.3 years) compared with all others (20.8±4.9 years), yet this difference was not statistically significant. However, the duration of breastfeeding was positively and significantly correlated with the age of onset of schizophrenia.^141^

Mellor et al. observed that dietary EPA intake was significantly and negatively associated with PANSS total psychopathology.^91^ Significant and negative correlations were likewise found for positive symptoms and both ALA dietary intake and total omega-3 fatty acid intake. Dietary EPA intake was also significantly and negatively associated with tardive dyskinesia scores on the AIMS. Multiple regression revealed that EPA intake was significantly and inversely related to PANSS total scores and to tardive dyskinesia ratings, and that total omega-3 fatty acid intake was significantly and negatively related to PANSS positive symptoms. While these results do not come from a controlled study, RBC total omega-3 fatty acid content was significantly and positively correlated with PANSS negative symptoms.

In their cross-national ecological analysis Christensen and Christensen found that a high total intake of saturated fat was significantly associated with ratings of an unfavorable schizophrenia course and outcome. To be exact, both the percentage energy derived from fat, including saturated fat, and the percentage energy derived predominantly from land animals and birds, containing saturated fat, were: a) significantly and positively associated with the mean percentage of followups spent in psychotic episodes, the percentage of patients with severe social impairment and total overall outcome score; and b) significantly and negatively associated with mean days spent outside hospital. The percentage of energy derived from sources with a relatively high content of unsaturated fat, including PUFAs (i.e., vegetables, fish and seafood), was not significantly associated with any of the aformentioned mental health parameters. Multiple regression revealed that only total outcome score was significantly predicted by both the percentages of intake of saturated (positive correlation) and unsaturated fats (negative correlation). Countries obtaining more of their dietary fat from land animals and fowl and less from vegetable or marine sources exhibited a worse schizophrenia outcome. This scenario accounted for 97% of the variance in outcome between countries. However, the evidence did not exhibit a significant direct relationship between intake of unsaturated fat, including PUFAs, and schizophrenia course or outcome.

Using linear and nonlinear regression models, Noaghiul and Hibbeln found that seafood consumption did not significantly predict lifetime prevalence rates (no data reported).^90^ Peet reported that fish consumption was not significantly associated with specific schizophrenia course or outcome variables, including mean days out of hospital, percentage of patients with severe social impairment, total outcome score, hospitalization status, percentage of patients with little social impairment, or total “best outcome” score.

### Quantitative Synthesis

Meta-analysis was not considered because of the variability in the study designs (case-control vs single prospective cohort study vs cross-national ecological analysis), the schizophrenia-related outcomes (incidence vs prevalence vs course vs outcome) as well as in the sampling strategies, methods assessing breastfeeding practices and the definitions of cases or controls employed in the case-control studies.

### Impact of Covariates and Confounders

The mix of study designs and study outcomes, in addition to the failure of studies to try to experimentally or statistically control for variables with the potential to influence clinical outcomes, made it impossible to assess the impact of extra-exposure factors on study outcomes. At the same time, few studies yielded results indicating a significant association between omega-3 fatty acid intake and the onset, continuation or recurrence of schizophrenia; and, no variables were noted as being potentially responsible for determining this pattern of findings.

## Is the Onset, Continuation or Recurrence of Schizophrenia Associated With Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Biomarkers?

As observed in Summary Tables 40 through 44 (below), derived from Evidence Table 2 (Appendix E§§§§§§§§), 14 cross-sectional studies published between 1979 and 2003 were included.^114,^ ^146–158^ Two of these studies were conducted at baseline in prospective cohort studies.^157,^ ^158^

### Overview of Relevant Studies

Obi and Nwanze assessed the RBC and plasma fatty acid compositions of schizophrenic patients (n=6; 30–50 years) compared to age-matched (22–45 years) healthy controls (n=6) drawn from hospital staff and students in Nigeria (Summary Table 40).^153^ Horrobin et al. evaluated the fatty acid content in plasma phospholipids in an heterogeneous population of schizophrenic patients from three different cities (n=84; mean age: 40.8 [20–71] years; 72.6 % male), compared with younger healthy controls (n=119; mean age: 35.7 [19–66] years; 51.3 % male).^152^ Kaiya et al. examined the plasma fatty acid composition in medicated Japanese schizophrenics (n=59; mean age: 35.7 years; 61% male), patients with an affective or paranoid disorder (n=24; mean age: 36.3 years; 37.5% male) and healthy volunteers recruited from hospital personnel (n=24; mean age: 36.3 years; 37.5% male).^151^

Fischer et al. analyzed the fatty acid content in platelets from: German schizophrenic patients treated with “high dose” (n=9; age: 24–42 years, inpatients) or “low dose” (n=7; age: 35–53 years, outpatients) monotherapy of neuroleptic drug (phenothiazine and thioxanthene); untreated schizophrenic patients (n=2); and, untreated healthy controls (n=6; 100% male) (Summary Table 41).^150^ Peet et al. examined the RBC fatty acid content in medicated schizophrenic inpatients (n=23; mean age: 55 years; 69.5% male) and in age- and sex-matched healthy controls (n=16).^149^ Vaddadi et al. examined the RBC fatty acid content in hospitalized and non-hospitalized medicated schizophrenic patients with or without tardive dyskinesia (n=72), in addition to patients with schizophrenia or schizoaffective disorders (n=72; mean age: 35.4 [18–64] years; 75% male) and age-matched healthy controls (n=39).^157^

Mahadik et al.'s sample of 12 schizophrenic patients (n=8 drug-naïve and first episode) and six patients with bipolar mood disorder (n=2 manic first episode) were compared to eight sex-matched control subjects with respect to their fatty acid content in cells extracted from skin biopsies (Summary Table 42).^114^ Assies et al. evaluated the RBC fatty acid content in schizophrenics (n=16), one patient with psychoaffective disorder, one with bipolar disorder and one with a brief psychotic disorder according to DSM-IV diagnostic criteria (n=19; mean age: 21.2 years; 89% male), compared with age, sex, height and weight-matched healthy controls (n=14; mean age: 20.9 years; 85.7% male).^148^ Yao et al. examined the correlation between RBC fatty acid content and in vivo membrane phospholipid metabolites in first-episode, drug-naïve schizophrenics (n=11; mean age: 26 [17–44] years; 54.5% male) compared to age-, sex- and race-matched normal controls (n=11; mean age: 26 [19–39] years; 54.5% male).^154^

Khan et al. enrolled drug-naïve, first episode schizophrenic patients (n=22) drawn from the Army Medical Center in United States, chronically medicated schizophrenic patients from an outpatient clinic (n=30) and age- and sex-matched healthy volunteers (n=16) (Summary Table 43).^147^ This study measured plasma and RBC fatty acid contents and their metabolites from peroxidation.

The first Arvindakshan et al. study examined the RBC and plasma fatty acid compositions in medicated schizophrenic patients in India (n=28; mean age: 29.6 years; 64.3% male) and in age- and sex-matched healthy volunteers (n=45; mean age: 30 years; 67% male).^155^ This was a before-after study, where only the patients received an intervention (i.e., omega-3 fatty supplementation) for 24 weeks. We assessed the cross-sectional baseline data from schizophrenics and controls. Because the intervention part of the study was uncontrolled, clinical efficacy data were not eligible for inclusion in this review. Arvindakshan et al.'s second study evaluated the RBC membrane content in drug-naïve, first episode schizophrenics (n=20; mean age: 29.4 years; 60% male), medicated patients (n=32; mean age: 31.3 years; 65.6% male) and age-, sex -and race-matched healthy controls (n=45; mean age: 29.2 years; 55.6% male).^146^

Evans et al. assessed the RBC fatty acid content in patients with first-episode schizophrenia (n=16) and healthy volunteers (n=25), although the latter group was significantly older and were more highly educated than the schizophrenic group (Summary Table 44).^158^ Ranjekar et al. measured the RBC and plasma fatty acid content, as well as the lipid oxidative products, in medicated schizophrenic patients (n=31; mean age: 37.3 years), patients with bipolar mood disorder (n=10; mean age: 40.8 years), and age-, sex- and race-matched healthy controls (n=31).^156^

### Qualitative Synthesis of Relevant Studies' Key Characteristics

Study characteristics. Fourteen included studies had cross-sectional designs involving at least two groups.^114,^ ^146–158^ Six studies did not report inclusion criteria,^147,^ ^148,^ ^150,^ ^151,^ ^153,^ ^155^ and seven did not report exclusion criteria.^147,^ ^149–153^ ^158^ Study sizes ranged from 12^153^ to 203 participants.^152^ Countries where the studies were conducted included: India,^146,^ ^155,^ ^156^ Holland,^148^ Nigeria,^153^ Japan,^151^ Germany,^150^ Australia,^157^ the US ^114,^ ^147,^ ^154,^ ^158^ and the UK.^149,^ ^152^

The Arvindakshan et al. studies were supported by the Council of Scientific and Industrial Research, M.L. Vasa, Laxmichand Dayabhai NIH/Fogarty International Center, Interactive Research School for Health Affairs and the Vasa Heart Foundation (India).^146,^ ^155^ Evans et al. and Khan et al.'s funding source was the NIH/NCCAM^147,^ ^158^ and the Stanley Foundation.^158^ Ranjekar et al.'s work was supported by Mr. M.L. Vasa, Laxmichand Dayabhai (Export) Co.^156^ and Vaddadi et al.'s study was funded by Scotia Pharmaceuticals Ltd. (UK).^157^ Yao et al.'s study was supported by the NIMH, an NARSAD Young Investigator Award, the Office of Research and Development, Department of Veteran Affairs and Highland Drive Veteran Affairs Pittsburgh Healthcare System.^154^ Seven studies did not report a funding source.^114,^ ^148–153^

Population characteristics. Studies included only adult participants. Horrobin et al.'s controls were younger than their schizophrenic participants and were not fully sex-matched, although the difference was not significant.^152^ Obi and Nwanze's schizophrenic patients were likely well-matched by age (30–50 years).^153^ Kaiya et al.'s subjects were matched by age.^151^ In Fischer et al.'s study the low-dose antipsychotic therapy group was slightly older than the other groups.^150^ Peet et al. and Assies et al.'s samples were well-matched by age and sex.^149^ Vaddadi et al.'s study groups were well-matched by age (18–64 years).^157^ Mahadik et al.'s schizophrenic and bipolar patients were well-matched by age and sex, with a preponderance of males taking part in their project.^114^ Yao et al.'s work included participants who were matched by age, sex and race.^154^ Only Khan et al.'s first-episode psychotic patients and their controls were matched by age.^147^ Their chronically medicated-schizophrenics were older. For both of Arvindakshan et al.'s studies, between-group differences were not observed for age or sex.^146,^ ^155^ Evans et al.'s controls were significantly older than their schizophrenic patients.^158^ Ranjekar et al.'s study groups were well-matched by age; and, only males with the same racial origin were included.^156^ Few studies described the ethnicity/race of their participants. Three studies included east Indian patients^146,^ ^155,^ ^156^ and one study included Japanese participants.^151^

All studies involved inpatients and/or outpatients with acute and/or chronic schizophrenia of varying degrees of severity and ages of onset. Some studies included heterogeneous subtypes of schizophrenia, namely schizoaffective disorder,^146,^ ^148,^ ^151,^ ^154,^ ^157^ severe bipolar mood disorder,^114,^ ^148,^ ^156^ schizophreniform disorder^146,^ ^154,^ ^158^ and paranoid disorder.^151^ Five studies included neuroleptic-naïve, first episode schizophrenic participants.^114,^ ^146,^ ^147,^ ^154,^ ^158^ Diagnoses were made on the basis of DSM-III-R^114,^ ^149,^ ^151,^ ^152,^ ^157^ or DSM-IV diagnostic criteria.^146–148,^ ^154–156,^ ^158^ Only two studies failed to report this information.^150,^ ^153^ Horrobin et al. also used the Research Diagnostic Criteria for schizophrenia.^152^ Assies et al. as well as Khan et al. employed the PANSS.^147,^ ^148^ Assies et al. utilized the MADRS to identify depressive symptomatology within the context of bipolar mood disorder.^148^

The control groups were composed of “healthy volunteers” who were sometimes screened for mental disorders using the nonpatient version of the SCID.^114,^ ^146,^ ^154–156^ Healthy controls were excluded from four studies if they had a personal or family history of psychiatric disorder, medication use and/or substance abuse.^154–156^ Exclusion criteria pertaining to healthy controls were not described in most study reports.

In order to control for possible confounding factors, some studies established exclusion criteria. Vaddadi et al. excluded any subject with a history of established neurological illness, developmental handicap or currently receiving nonsteroidal anti-inflammatory drugs.^157^ Mahadik et al.'s patients were excluded if they had a history of substance abuse or dependence, seizure disorder, head injury with loss of consciousness, or positive family history of Huntington's Disease, dementia, or mental retardation in first degree relatives.^114^ Assies et al. did not include subjects with a major medical illness, mental retardation, endocrine disorders, or a cholesterol-lowering diet or medication.^148^ Yao et al. excluded patients with significant drug or alcohol use within one month of the initial assessment, a history of significant medical illness, hyperlipidemia at baseline, obesity, starvation in the previous two weeks, neurologic disorders, history of psychosis longer than two years, or comorbidity involving a DSM-IV Axis I diagnosis.^154^ Both of Arvindakshan et al.'s studies, as well as that conducted by Ranjekar et al., excluded patients with WAIS-R full-scale IQ<80, high levels of dietary supplement use, severe under- or malnourishment, seizure disorder, head injury with loss of consciousness, alcohol and substance abuse or dependence, excessive smoking, type II diabetes, lipid disorders, cardiovascular disease, hypertension or obesity.^146,^ ^155,^ ^156^

Intervention/exposure characteristics. Thirteen studies did not involve an intervention or exposure. Only one of the Arvindakshan et al.'s studies employed supplementation^155^, and Assies et al. assessed dietary intake of omega-3 fatty acids using a questionnaire.^148^ Kaiya et al. described the use of a typical Japanese diet rich in rice and seafood by their inpatients residing in a Geriatric Hospital.^151^ No other studies controlled statistically for background diet in their analysis. No study reported inappropriate methods by which lipids were extracted, prepared, stored or analyzed.

Cointervention characteristics. One of the most relevant confounders is the use of medication for the treatment of schizophrenia. Obi and Nwanze did not report the medication used by their participants.^153^ Horrobin et al.'s sample from England and Scotland were using neuroleptic drugs.^152^ Kaiya et al.'s schizophrenic patients used neuroleptic drugs (i.e., haloperidol), while the participants with affective or paranoid disorders were taking antidepressants.^151^ Fischer et al.'s patients were receiving neuroleptics such as phenothiazines (i.e., perazine) or thioxanthenes (i.e., flupentixol).^150^ The reports of Peet et al. and Vaddadi et al. mentioned the use of neuroleptic medication by all their patients, but did not provide additional details.^149,^ ^157^ Assies et al.'s subjects were taking olanzapine (n=11), pimozide (n=4), risperidone (n=3) or clozapine (n=1), combined with other medications such as paroxetine, fluvoxamine, oxazepam, temazepam, alprazolam, biperideen, trihexyfenidyl, dexetimide or lithium carbonate.^148^ Some studies also described the use of atypical antipsychotics (i.e., risperidone).^146,^ ^147,^ ^155,^ ^156,^ ^158^ Ranjekar et al.'s sample took antidepressants as well.^156^ In a small number of studies, particularly those including cases of first-episode schizophrenia, the participants did not receive any type of drug prior to the study or during the study assessment period.^114,^ ^146,^ ^154^

Outcome characteristics. Outcomes included all types of fatty acid, from various sources, and were expressed either as percentages, or fractions (i.e., composition), or concentrations.

Study quality and applicability. The fourteen cross-sectional studies received a mean quality score of 2.5, with all but five studies achieving an applicability rating of III.^146,^ ^148–151^ ^153,^ ^155–157^ Four studies received an applicability rating of I,^114,^ ^147,^ ^154,^ ^158^ and one study attained a rating of II.^152^

Summary Matrix 16: Study quality and applicability of evidence regarding the association between the omega-3 or omega-6/omega-3 fatty acid content of biomarkers and onset, continuation or recurrence of schizophrenia

| | Study Quality
| | A | | | B | | | C
Applicability | I | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Mahadik | 1996 | 26 | Yao | 2002 | 22
| | | | | | | | Evans | 2003 | 41
| | | | | | | | Khan | 2002 | 68
| II | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | | | | Horrobin | 1989 | 203
| III | Author | Year | n | Author | Year | n | Author | Year | n
| | | | | Arvindakshan | 2003 | 73 | Obi | 1979 | 12
| | | | | Ranjekar | 2003 | 72 | Kaiya | 1991 | 97
| | | | | | | | Fischer | 1992 | 24
| | | | | | | | Peet | 1995 | 39
| | | | | | | | Vaddadi | 1996 | 111
| | | | | | | | Assies | 2001 | 34
| | | | | | | | Arvindakshan | 2003 | 97

n = number of allocated/selected participants

### Qualitative Synthesis of Individual Study Results

In Obi and Nwanze's study, a significantly higher proportion of LA was found in schizophrenic patients compared with controls.^153^ The difference was observed in both the neutral lipids and the phospholipids extracted from plasma and RBCs.

In Horrobin et al.'s study, a separate analysis was performed for data from each of the three countries.^152^ There were no significant differences between patients and controls in the total amount of plasma phospholipid present. At all three sites, patients had significantly reduced total omega-6 fatty acid levels compared with controls. The levels of omega-3 fatty acid were significantly increased in the schizophrenic groups. The omega-6/omega-3 fatty acid ratio was significantly reduced in all three patient groups. LA and AA were significantly reduced in all three groups of patient, and DGLA was reduced in two of them. DHA was significantly increased in the schizophrenic patients of England and Ireland compared with controls. EPA levels were not significantly different between groups.

Kaiya et al. found that, with the exception of DGLA which was significantly above normal in the schizophrenic patients, the levels of omega-3 fatty acid in plasma phospholipids were not significantly different between normal Japanese subjects and schizophrenic patients or patients with affective or paranoid disorders.^151^ From the analysis of fatty acids in plasma cholesterol esters, LA was significantly lower in schizophrenic patients compared with controls, but not in patients with affective or paranoid disorders. In plasma phospholipids, EPA was significantly higher in schizophrenic males compared with schizophrenic females. In the cholesterol fraction, there were no significant differences between schizophrenics over and under 40 years of age. When data from hospitalized schizophrenics were contrasted with that from outpatients, AA was significantly higher in the inpatients.

Fischer et al. analyzed data regarding the total fatty acid composition of platelets. LA, AA and DHA were significantly lower in schizophrenic patients using high-dose neuroleptics compared with those taking low-dose neuroleptics or with untreated healthy controls.^150^ LA, AA and DHA were significantly lower in the group of low dose patients compared to two untreated schizophrenic patients. In general, the ratio of SFAs to PUFAs was significantly higher in the high-dose group compared with the low-dose group or with healthy controls. This ratio was also significantly higher in the low dose group than in the controls.

The medicated and hospitalized schizophrenic patients included in the Peet et al. study exhibited significantly lower RBC EPA and DHA levels compared to healthy controls.^149^ LA and AA were also significantly lower than in controls. There was no significant correlation between neuroleptic dosage, expressed as chlorpromazine equivalents, and any of the measures of fatty acid level. Plasma levels of total free fatty acids did not differ between groups.

Based on Vaddadi et al.'s initial assessment, schizophrenic patients were grouped according to their tardive dyskinesia status.^157^ The RBC fatty acid compositions from four groups were compared. Patients with severe tardive dyskinesia had significantly lower LA compared to patients without tardive dyskinesia, who in turn had lower levels compared to the control group. All patients had elevated levels of omega-3 fatty acids, but only (omega-3-)DPA was significantly higher when compared to controls. Half of the patients were assessed 4.5 years later, when only RBC (omega-6-)DGLA was found to be significantly elevated, relative to controls, in schizophrenics with and without tardive dyskinesia.

Given that the cell membrane distributions of AA and DHA did not differ in cultured skin fibroblasts from patients with chronic schizophrenia and patients with first-episode schizophrenia, Mahadik et al. combined data from these two patient groups for analyses.^114^ These data were then compared to those obtained from patients with recurrent bipolar mood disorder and sex-matched controls. The DHA composition was found to be significantly lower in cell lines of schizophrenic patients compared with cell lines obtained from either bipolar patients or normal subjects. Data from the two latter groups did not differ. The percent distribution of AA in the cell lines of schizophrenic patients was significantly lower than that in bipolar patients, but the percent distribution of AA from either group did not differ significantly from that seen in normal controls.

In the study of Assies et al., no significant differences were found between schizophrenic patients and normal controls in terms of age, sex, BMI or dietary intake of lipids at baseline in Assies et al.'s study.^148^ DHA content and that of its precursor (n-3-)DPA were each significantly reduced in the RBCs of schizophrenic patients compared with controls. Between-group differences for the other omega-3 fatty acids were not observed. Total omega-3 fatty acid content was significantly reduced in the schizophrenic group. No significant between-group differences were found for any of the omega-6 fatty acids. The DHA/AA ratio was lower in schizophrenic patients than in control subjects. The study groups' AA/EPA, DPA/DHA and total omega-6/omega-3 fatty acid content ratios did not differ. There was a significant positive correlation between chlorpromazine equivalents and the AA/EPA ratio. A significant negative correlation linked EPA content and chlorpromazine dosage. By subgroup analysis, the omega-6/omega-3 fatty acid content ratio was significantly lower in cannabis users compared with nonusers. There was no consistent pattern of correlations involving fatty acid contents and measures of symptomatology.

Yao et al.'s population of first-episode, untreated schizophrenics had a significantly lower RBC AA concentration than did normal controls.^154^ The remaining fatty acid contents did not differ significantly between groups. There was a significant correlation between the levels of peripheral biomarkers and the level of free phospholipids in the prefrontal region of the brain, as assessed by ^31^P Spectroscopy.

Khan et al.'s heterogeneous sample of active army personnel consisted of drug-naïve first-episode schizophrenics, chronic medicated schizophrenics and healthy controls. The fatty acid contents of their RBC membranes were compared.^147^ The levels of LA, AA and DHA were significantly lower in first episode patients than in chronic patients. Levels were also lower in first-episode patients and in chronic patients compared with controls. The larger reductions in PUFA levels were associated with a greater severity of psychosis assessed in drug-naïve, first-episode patients, compared with chronic medicated schizophrenics, as assessed using the Brief Psychiatric Rating Scale (BPRS), negative PANSS and positive PANSS. These changes did not appear to be related to age or to smoking.

The first Arvindakshan et al. study showed that the schizophrenic patients had a significantly lower RBC membrane concentration of EPA and DHA compared to healthy controls.^155^ Significant between-group differences were not observed for LA or AA content.

In the second Arvindakshan et al. study, the RBC membrane AA, DHA, total omega-6 and total omega-3 fatty acid contents were each significantly lower in both patient groups, (medicated and never medicated) when compared to healthy controls.^146^ The differences remained significantly different when the never-medicated patients were compared to the normal controls, but neither the AA nor the DHA contents were significantly different when medicated schizophrenics and controls were compared. The AA, DHA, total omega-6 fatty acids and total omega-3 fatty acid levels in RBCs were significantly lower in never medicated patients compared to medicated schizophrenics. The psychopathologic measures in never medicated subjects were examined for their relationship to PUFA levels. Significantly negative correlations were found for AA levels and BPRS scores, and for DHA levels and PANSS negative symptoms. Never medicated patients appeared to exhibit more severe psychopathology than medicated patients.

Evans et al. showed that RBC (omega-3-)DPA and DHA levels were significantly lower in first episode, untreated schizophrenics compared with controls.^158^ Significant between-group differences were not observed for AA or LA levels. RBC antioxidant enzymes were assessed and it was found that the level of superoxide dismutase (SOD) was significantly lower in schizophrenic patients than controls, and catalase (CAT) was significantly elevated in these patients.

Ranjekar et al. evaluated the possible association of levels of RBC antioxidant enzymes (i.e., SOD, CAT, glutathione peroxidase [GPx]), as key indices of oxidative stress, with RBC fatty acid contents for schizophrenics, bipolar mood disorder patients and normal controls.^156^ These enzymes were significantly lower in schizophrenics compared with controls. ALA, DHA and EPA levels were also significantly lower in patients compared to controls. When these analyses included data from bipolar patients, only two enzymes—SOD and CAT—were reduced significantly relative to control subjects.

Four studies measured the products of membrane lipid peroxidation utilizing blood levels of thiobarbituric acid reactive substances (TBARS).^146,^ ^147,^ ^149,^ ^155^ The results were inconsistent when data from schizophrenics and healthy controls were compared. These data are not reviewed in more detail here since they lie beyond the scope of our report.

### Quantitative Synthesis

Although all of the included studies were controlled, only one had a formal followup that included controlled data. Thus, a meta-analysis was not considered.

### Impact of Covariates and Confounders

Studies were distinguishable on the basis of whether the sample of schizophrenic patients was currently, or ever had been, medicated with neuroleptics. Comparing the results obtained from studies where patients were, or were not, receiving medication could illumine one possible source controlling variation in biomarker outcomes. All comparisons presented here involve healthy controls; the use of any other types of control was too infrequent and idiosyncratic to specific studies to afford generalization.

In the five studies where at least one set of analyses involved a comparison between patients not on medication and healthy controls,^114,^ ^146,^ ^147,^ ^154,^ ^158^ all assessed RBC fatty acid content data, four revealed reductions in DHA,^114,^ ^146,^ ^147,^ ^158^ three showed reductions in AA content,^146,^ ^147,^ ^154^ one highlighted a reduction in LA,^147^ one noted a reduction in (omega-3-)DPA^158^ and one found significantly lower levels of total omega-6 fatty acids and total omega-3 fatty acids in never-medicated schizophrenic patients.^146^ In this last study, when data from patients who had never been medicated were compared with data from patients who were currently medicated, levels of AA, DHA, total omega-6 fatty acids and total omega-3 fatty acids were significantly lower in never-medicated patients.^146^

In studies where patients were medicated, and RBC data were again compared with those from healthy controls, significant reductions in DHA,^148,^ ^149,^ ^155,^ ^156^ AA,^149^ LA,^149,^ ^157^ (omega-3-)DPA,^148^ ALA,^156^ total omega-3 fatty acids,^148^ DHA/AA^148^ and EPA^149,^ ^155,^ ^156^ were observed in schizophrenic patients. While there is considerable overlap when these results are contrasted with those from studies where schizophrenic patients were not receiving medication, one notable difference is that, compared to controls, medicated patients were more likely to show reduced levels of EPA in RBCs. Thus, medication status may have an influence on between-group differences in RBC fatty acid content when the comparator is healthy controls.

As with RBC data, when plasma phospholipids were examined, Horrobin et al. reported significantly lower levels of total omega-6 fatty acid content, LA and AA in schizophrenic patients compared with controls.^152^ Kaia et al. revealed that LA was significantly reduced in plasma choleterol esters.^151^ When Fischer et al. assessed the total fatty acid content of platelets they found that significant reductions in DHA, AA and LA were associated with medicated patients compared with controls as well as with patients receiving high-dose versus low-dose neuroleptic medication.^150^ Patients on low dose medication also exhibited significantly lower levels of LA, AA and DHA compared with controls. Those taking high doses of medication also displayed a higher SFA/PUFA value compared with those receiving lower doses. These data suggest that, as with studies investigating RBC content, medication appears to have an impact on biomarker outcomes that may be independent of the disease process.

However, other biomarker data gleaned from a minority of studies provided a picture of effects that are inconsistent with what was found for RBCs. Vaddadi et al. reported that all RBC omega-3 fatty acid levels were significantly higher in schizophrenic patients compared with healthy controls.^157^ Horrobin et al. noted the same difference albeit in plasma phospholipids.^152^ One final study showed that LA content in either RBCs or plasma phospholipids was actually increased significantly in schizophrenic patients compared with controls.^153^

## Is the Onset, Continuation or Recurrence of Autism Associated With Omega-3 or Omega-6/Omega-3 Fatty Acid Content of Biomarkers?

As observed in Summary Table 45 (see below), derived from Evidence Table 2 (Appendix E*********), a single cross-sectional study published in 2001 met eligibility criteria.

### Overview of Relevant Study's Characteristics and Results

Vancassel et al.'s study was supported by INRA, INSERM U316, INSERM Network and the Fondation France Telecom.^159^ It compared the plasma phospholipid fatty acids of mentally retarded children (n=18; 72.2% male; mean age: 8.7 years) and in children having received a diagnosis of autism (n=15; 73.3% male; mean age: 8.3 years), who were attending the Child Psychiatry Day Care Unit in a hospital in France. The diagnoses of autism and mental retardation were based on DSM-III-R and DSM-IV criteria. The entire study population participated in day care and received the same diet over a 12-hour period. There were no significant between-group differences for height or weight. The aim of the study was to compare the study groups' plasma fatty acid content. No notable inappropriate methods to extract, prepare, store or analyze lipids were described.

The results showed that there were no significant between-group differences in the plasma content of omega-6 fatty acids or in ALA and DHA.^159^ Yet, autistic children had a significantly lower total omega-3 fatty acid level and a significantly higher omega-6/omega-3 fatty acid ratio compared to the mentally retarded children. This study received an applicability rating of II and a total quality score of 4.

## What is the Evidence That, in Review-Relevant Studies Concerning Mental Health, Adverse Events (e.g., Side Effects) or Contraindications are Associated With the Intake of Omega-3 Fatty Acids?

Adverse events are often underreported in study reports; therefore, failure to report any does not constitute evidence that none occurred. That said, a number of study reports explicitly stated that no exposure-related events had been observed;^97–99,^ ^115,^ ^120,^ ^122,^ ^131,^ ^139,^ ^140^ since the focus here is on exposure-related events, we had to include event data (e.g., type, consequence) in Summary Tables 46 through 48 when it was unclear as to which circumstances these events could be attributed. On one occasion, a failure of study authors to state that certain events were not directly linked to the expoure did not prevent our review team from suggesting that they were likely related to the disorder and not the exposure (i.e, self-harm [e.g., wrist scratching] in two active treatment patients and one control patient, respectively).^139^ At the same time, Peet et al. did not identify the patients or study groups from whom adverse event data were collected.^58^ Finally, multiple adverse events can be experienced concurrently or at different points in time over a study by a single patient. On occasion, included reports failed to explicitly identify these scenarios whereby a small number of study participants contributed many or most of the adverse event data.

Eight treatment RCTs provided some adverse event data.^53,^ ^58,^ ^87,^ ^89,^ ^95,^ ^96,^ ^112,^ ^119^ Two of the three intervention studies looking at the possible protective effects of omega-3 fatty acids in healthy volunteers also reported safety data.^129,^ ^130^ The treatment trials included two of the three RCTs and the only RCT investigating the supplemental and primary treatment of depression, respectively. Three of four trials investigating the supplemental treatment of schizophrenia yielded adverse event data.^58,^ ^87,^ ^89^

In Peet et al.'s supplemental treatment study of depression, no adverse events were reported by placebo group participants, whereas 20 of 52 individuals receiving E-EPA had at least one mild adverse event.^53^ One patient dropped out due to a gastrointestinal event (severity undefined). According to the authors, all events in the E-EPA groups were linked to the ingestion of an oily subtance, not the omega-3 fatty acids per se. Adverse event types were evenly distributed across the E-EPA groups. The fewest number of events occurred in the 2 g/d E-EPA group. The exact meaning of some of the events was not transparent to our review team, however. Likely using the same methodology, and again failing to adequately define some of their adverse events, Peet et al.'s study of the supplemental treatment of depression revealed that none of the nine patients withdrawn due to an adverse event (4 g/d E-EPA [n=2]; 2 g/d E-EPA [n=2]; 1 g/d E-EPA[(n=4]; placebo [n=1]) left because of the exposure per se.^87^ No between-group difference was observed for exposure-related adverse events. The most common events were mild and transient (i.e., diarrhea, nausea), and only one control patient withdrew for these reasons. It is conceivable that greater numbers of adverse event were reported in these two studies because the investigators used a more comprehensive approach to solicit these data.

Stoll et al. indicated that side effects were associated with their omega-3 fatty acid exposure.^112^ Their study delivered, by far, the largest dose of omega-3 fatty acids as an intervention (9.6 g/d). Three patients had to decrease their daily dose from seven capsules twice a day to a minumum of five capsules twice a day from seven capsules twice a day. At the same time, while there was no variability in the types of reported adverse event (i.e., gastrointestinal disorder), at least a third of study participants from each study group experienced gastrointestinal problems. This suggests that the omega-3 fatty acid dose and/or the amount of oil required to deliver it may have been too high. While Su et al.'s omega-3 fatty acid dose was high by standards established earlier, their participants described very few adverse events.^96^

Fenton et al. noted that two types of adverse event occurred among more than 5% of the EPA-treated patients.^89^ Marangell et al. identified the largest number of patients describing a fishy aftertaste or problems related to belching.^95^ However, these complaints were not associated with studies using E-EPA, a largely purified exposure with relatively minimal odour and taste.^53,^ ^87,^ ^89^

In Richardson and Puri's trial examining the primary treatment of children identified with AD/HD and learning difficulties, two active treatment group subjects and one placebo group participant left the study due to adverse events. However, the authors did not report on the seriousness of these events.^119^ It is likely not surprising that, of the ten studies that reported adverse events, only the study that included children identified problems with swallowing the capsules, which led to a discontinuation.

Ten subjects from each of the two study groups in Hamazaki et al.'s first trial with healthy volunteers complained of transient and minor adverse effects (no data reported).^130^ Of the others noted by the investigators (see Summary Table 46), none were sufficiently serious to warrant discontinuation from the study. In their second RCT, a gastrointestinal difficulty required that a single volunteer withdraw from the control group.^129^