# Methods

## Overview

The UO-EPC's evidence report on omega-3 fatty acids in mental health is based on a systematic review of the scientific-medical literature to identify, and synthesize the results from, studies addressing key questions. Together with content experts, UO-EPC staff identified specific issues integral to the review. A Technical Expert Panel (TEP) helped refine the research questions as well as highlighted key variables requiring consideration in the evidence synthesis. Evidence tables presenting key study-related characteristics were developed and are found in the Appendices. In-text summary tables were derived from the evidence tables. The methodological quality and generalizability of the included studies was appraised, and individual study results were summarized.

## Key Questions Addressed In This Report

The purpose of this evidence report was to synthesize information from relevant studies to address the following basic questions:

- Are omega-3 fatty acids efficacious as primary or supplemental treatment for (some psychiatric disorder or condition)? (Question 1)
- Is omega-3 fatty acid intake, including diet and/or supplementation, associated with the onset, continuation or recurrence of (some psychiatric disorder or condition)? (Question 2)
- Is the onset, continuation or recurrence of (some psychiatric disorder or condition) associated with omega-3 or omega-6/omega-3 fatty acid content of biomarkers? (Question 3)
- What is the evidence that, in review-relevant studies concerning mental health, adverse events (e.g., side effects) or contraindications are associated with the intake of omega-3 fatty acids? (Question 4)

The overarching goal was to identify and systematically review whatever evidence exists within the eligibility boundaries established for this review in consultation with our TEP and in light of the topics being addressed by SC-RAND and Tufts-NEMC EPCs. These boundaries are delineated in the Eligibility Criteria section (below). More details concerning the four basic questions are provided in conjunction with the description of the Analytic Framework (below). We were also guided collectively by ODS, our TEP and our UO-EPC review team content experts to examine, where data permitted, the possible influence on efficacy, association or safety evidence of the following potential effect modifiers:

- intervention/exposure length;
- type(s) of omega-3 fatty acid (e.g., ALA, EPA, DHA);
- source of the omega-3 fatty acids (e.g., marine, plant, nut), including the specific source (e.g., mackerel as an oily fish);
- delivery format (e.g., whole food servings, capsules, pourable or spreadable oils);
- dose/serving size, including the precision/control of its delivery (e.g., per-day specific, minimum, maximum or range of numbers of capsules, whole food servings or bottle-pourable litres);
- type of processing used to purify the intervention/exposure and/or to maintain the experimental blind (e.g., ethyl esterification; adding an anti-oxidant to stabilize/preserve oils; adding flavor to oils; [vacuum] deodorization);
- amount/dose of omega-6 fatty acid intake either added as a separate cointervention or identified as being present in the background diet, thereby establishing a specific, minimum, maximum or range of allowable or mandated on-study omega-6/omega-3 fatty acid intake;
- the identity of the manufacturer and/or certain characteristics of their product(s) (i.e., purity; presence of other potentially active agents that have not been added intentionally: e.g., methylmercury content);
- for questions relating to efficacy or association, the prestudy/baseline or on-study omega-3 or omega-6/omega-3 fatty acid content of blood lipid biomarkers;
- absolute or relative omega-3 fatty acid content of the prestudy/baseline diet;
- omega-6/omega-3 fatty acid content in the prestudy/baseline diet, with the study population's country of origin as a possible surrogate measure of the omega-6/omega-3 fatty acid content of the background diet; and,
- any study subpopulations (e.g., minority; ethnic; genetic, including diabetics).

Furthermore, where data permitted, the following factors with the potential to influence (i.e.., aggravate, control) mental health outcomes (e.g., intensity of symptoms/behaviors) were also investigated:

- severity of the psychiatric disorder or condition;
- psychotropic medication type and dose;
- comorbid conditions and their treatments;
- diagnostic classification system/criteria employed to identify study population;
- age and other sociodemographic factors (e.g., marital status, education, income, employment status);
- general health status;
- stressors;
- other cointerventions (e.g., licit drug use, other supplement use, psychological interventions, use of complementary/alternative [CAM] medicine/products);
- social support;
- current smoker status;
- current alcohol consumption; and,
- influences on vegetative functioning (e.g., exercise, quality of sleep).

Psychotropic medication, current smoker status, and alcohol consumption are especially important effect modifiers in that they have been observed to influence both mental health status and essential fatty acid status, with levels of the latter potentially affecting the former.^60^

## Analytic Framework

An analytic framework was developed to make explicit the review's specific links relating the populations and settings of interest (i.e., the study participants and the disorders or conditions of interest), the focal exposure or intervention (i.e., omega-3 fatty acids ingested as supplementation and/or from food sources), potential effect-modifying factors, key mental health outcomes, and the possible role played by the omega-3 or omega-6/omega-3 fatty acid content of biomarkers in mediating the intake-outcome relationship (Figure 2). The possibilities of adverse events (e.g., side effects) and contraindications are recognized. In short, the framework outlines the various lines of logic defining the review's research questions. However, not all linkages were investigated.

Figure 3. Estimates of the change in HDRS score between omega-3 fatty acid and placebo groups from studies evaluating the supplemental treatment of depression

Figure 2. Analytic Framework for omega-3 fatty acids in mental health. Populations of interest in rectangles. Exposure in oval. Outcomes in rounded rectangles. Effect modifiers in hexagons. Solid connecting arrows indicate associations and effects reviewed in this report

One criterion established in this review is that each researchable question had to be clinically relevant. That is, each question had to involve the investigation of at least one relevant clinical outcome. Likewise, to be eligible for inclusion in the review each study had to entail an investigation of at least one pertinent clinical outcome. Considering the purpose of the two-year task order is to afford a clinically-relevant research agenda, this decision was judged to be appropriate by both our TEP and our review team. Thus, excluded were studies whose sole focus was to examine the impact of omega-3 fatty acid interventions or exposures on the omega-3 or omega-6/omega-3 fatty acid content of biomarkers, even if the study populations met the other eligibility criteria set for the present review. Each of the four basic questions outlined above is now seen in light of the links identified in the framework.

The populations of interest include those:

- with a current psychiatric diagnosis (Population 1);
- at elevated risk to develop a psychiatric disorder or condition by virtue of certain past or present events (i.e., a past psychiatric diagnosis; currently experiencing a subset of symptoms/behaviors with the potential [e.g., intensity] to develop into a full-fledged disorder; having a first order relative with a psychiatric diagnosis) (Population 2);
- who are not necessarily at risk to develop a psychiatric disorder despite currently experiencing a subset of its symptoms/behaviors (Population 3);
- “healthy” individuals who, under certain circumstances (e.g., stress) may exhibit a subset of symptoms/behaviors necessary yet insufficient to indicate a psychiatric disorder (e.g., aggression) (Population 4); and,
- specific subpopulations, some of whose characteristics may predispose them to develop or avoid developing psychiatric difficulties (Population 5).

Our TEP requested that studies investigating the fourth population category be included in the review. As the four basic questions are introduced, and their important linkages are highlighted within the framework, the relevant populations are identified. The fifth category of population, or specific subpopulations, could be examined with respect to each of the four basic questions.

Questions pertaining to the efficacy of omega-3 fatty acids as primary or supplemental treatment (i.e., Question 1) entail a direct investigation of their potentially beneficial influence on clinical outcomes. Pertinent populations include the first three delineated above, that is, those individuals with a psychiatric diagnosis or a psychiatric condition at the time of the study, the latter including symptoms/behaviors insufficient to merit a formal diagnosis (e.g., dysphoric mood). Outcomes could involve changes in symptom severity, time to a treatment failure, or remission of the disorder.

The question regarding the possible association between the intake of omega-3 fatty acids and the onset, continuation or recurrence of a psychiatric disorder or condition (i.e., Question 2) examines whether intake protects individuals from developing, or perhaps predisposes them to develop, a psychiatric disorder or a subset of its symptoms/behaviors (i.e. onset). The question also examines whether omega-3 fatty acid intake influences the clinical course or outcome of a psychiatric disorder or condition insofar as it could facilitate or prevent its continuation (e.g., progression of a condition so that it becomes a disorder; progression of a disorder) or recurrence. Relevant populations for the “onset” subquestion include those in Population 4 (i.e., “healthy” individuals), those belonging to “at risk” Population 2 with a psychiatrically diagnosed first order relative, or those in either Populations 2 or 3 who might be exhibiting a psychiatric condition that could develop into a full-fledged disorder. For the “continuation” subquestion, pertinent populations include Populations 1 (i.e., a current psychiatric disorder), 2 or 3 (i.e., a current psychiatric condition). The “recurrence” focus includes Population 2 (i.e., past diagnosis). Outcomes could include prevalence and incidence, as well as indices of secondary prevention. The latter could be observed where amounts or types of fatty acid intake prevent the intensity of a psychiatric condition (e.g., dysphoric mood) from increasing and contributing to the development of a full-fledged disorder (e.g., major depression).

Results from relevant studies (see Eligibility Criteria) with respect to Questions 1 and 2, which reflect the possible influence of interventions/exposures on the omega-3 or omega-6/omega-3 fatty acid content of biomarkers (see their definition in Eligibility Criteria section), are highlighted briefly and exclusively with an exploratory intention since reliable associations between biological and clinical effects could suggest a mechanism by which omega-3 fatty acid interventions/exposures bring about improved clinical outcomes.

The question regarding the possible association between the omega-3 or omega-6/omega-3 fatty acid content of biomarkers and the onset, continuation or recurrence of a psychiatric disorder or condition (i.e., Question 3) investigates whether certain levels of fatty acid content (i.e., composition, or concentration) in blood lipid biomarkers (e.g., RBCs, plasma phospholipids) protect individuals from developing, or perhaps predispose them to develop, psychiatric disorders or subsets of their symptoms/behaviors (i.e. onset). The question also examines whether certain levels of fatty acid content in blood lipid biomarkers can influence the clinical course or outcome of a psychiatric disorder or condition by facilitating or preventing their continuation (e.g., progression of a condition so that it becomes a disorder; progression of a disorder) or recurrence. Relevant populations for the “onset” subquestion include those in Population 4 (i.e., “healthy” individuals), those belonging to “at risk” Population 2 with a diagnosed first order relative, or those in either Populations 2 or 3 who might have a psychiatric condition that could develop into a full-fledged disorder. For the “continuation” subquestion, pertinent populations are Populations 1 (i.e., a current psychiatric disorder), 2 or 3 (i.e., a current psychiatric condition). The “recurrence” focus includes Population 2 (i.e., a past diagnosis). Outcomes could include prevalence and incidence, although observing that a certain fatty acid composition in biomarkers prevents the intensity of a psychiatric condition (e.g., dysphoric mood) from increasing and contributing to the development of a full-fledged disorder (e.g., major depression) could indicate secondary prevention. Question 4 is addressed using safety data from studies meeting eligibility criteria.

The possible influence of predefined effect modifiers is evaluated in relation to each of the basic questions. Where possible, question-specific sections titled “Impact of Covariates and Confounders” elucidate a) those variables (e.g., omega-3 fatty acid type; comorbid conditions; psychotropic medication) that were consistently observed, across reviewed studies, to influence study outcomes as well as b) those variables (e.g., age, sex), which having been controlled for either experimentally or analytically in reviewed studies, were observed to consistently influence, or consistently fail to influence, study outcomes.

## Study Identification

### Search Strategy

The search strategy for this project was designed to be comprehensive and achieve the highest possible recall of relevant clinical studies. The electronic search strategy was developed by an information specialist in consultation with clinical content experts in mental health. Because of the number of conditions falling under the rubric of mental health, the mental health subject tree and index terms for suicidal, aggressive and impulsive behavior was used, rather than terms appearing in free text. For those with less robust subject indexing in the area of mental health, supplemental free text terms were added to the electronic search strategy (CDSR, CAB Health). The mental health search concept was combined with the core omega-3 fatty acids search strategy established in collaboration with the project librarians, biochemists, nutritionists, and clinicians from the three EPCs involved in the 2-year, Health Benefits of Omega-3 Fatty Acids task order. Consultation among these sources provided the biochemical names and abbreviations of omega-3 fatty acids, names of commercial omega-3 fatty acids products, and food sources of omega-3 fatty acids.

The following electronic databases were searched: Medline (1966 - November Week 2 2003 and updated to April Week 3 2004), Embase (1980 to 2003 Week 48 and updated to 2004 Week 18), the Cochrane Library including the Cochrane Central Register of Controlled Trials (3^rd^ Quarter 2003), PsycInfo (1982 to December Week 1, 2003) and CAB Health (1973-Sept 2003). All databases were searched via the Ovid interface using Search Strategy 1 (Appendix A), except CDSR where we used Search Strategy 2 (Appendix A *) and CAB Health, which was searched through SilverPlatter using Search Strategy 3 (Appendix A *). Searches were not restricted by language of publication, publication type, or study design, except with respect to the MeSH term “dietary fats,” which was limited by study design to increase its specificity. A total of 1606 bibliographic records were downloaded, with 410 duplicate records identified and removed using citation management software (Reference Manager®).

* Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gvo/clinic/tp/o3menttp.htm.

Reference lists of included studies, book chapters, and narrative or systematic reviews retrieved after having passed the first level of relevance screening, were manually searched to identify additional unique references. Through contact with content experts, attempts were made to identify both published and unpublished studies. On behalf of the three EPCs investigating the evidence concerning the health benefits of omega-3 fatty acids, a letter was written to industry representatives to obtain additional evidence (Appendix B *). Unsuccessful attempts were made to contact the lead author of a recent Cochrane Collaboration systematic review of PUFA supplementation for schizophrenia to obtain unpublished data they claimed to have received from investigators.^61^ These supplementary efforts identified an additional 16 records that were added to the collection for review. A final set of 1,212 unique references was identified.

### Eligibility Criteria

Published and unpublished studies, written in any language, were eligible for inclusion. Excluding grey literature from systematic reviews of interventions can lead to the overestimation of effect sizes.^62^ Substantial bias in the results of a systematic review pertaining to a complementary/alternative medical (CAM) intervention can ensue from the exclusion of data from reports written in languages other than English.^63^ AHRQ and ODS consider omega-3 fatty acids to be a CAM exposure.

Data from live human study populations or subpopulations (e.g., genetic, minority, ethnic: e.g., diabetic) of any age were required to maximize generalizability. Study populations in treatment studies, as well as in those investigating the possible association of the onset, continuation or recurrence of psychiatric disorders or conditions with either the intake of omega-3 fatty acids or the fatty acid content of biomarkers had to have been assessed using any formal psychiatric diagnostic criteria (e.g., DSM-IV) or established psychiatric research instruments (e.g., Hamilton Depression Rating Scale). Our TEP requested that we investigate both psychiatric disorders and psychiatric conditions (i.e., behaviors, symptoms: e.g., dysphoric mood), recognizing that while the latter are necessary to identify a psychiatric disorder, alone they are insufficient to signal the presence of one (e.g., major depression). Any and all types of comorbid condition were eligible. Studies conducted in any era of psychiatric practice were considered candidates for inclusion.

The specific types of population required to address each of the basic research questions are described with reference to the analytic framework and those details are not repeated here. As one point of clarification, our TEP asked that, within the context of assessing the possible association between omega-3 fatty acid intake and psychiatric disorders or conditions (Question 2) we should review studies examining the possible protective effects of omega-3 fatty acid intake on the development of maladaptive behavior in populations presumed to be “healthy” (e.g., college volunteers), yet who might, for example, develop evidence of disrupted well-being when subjected to stressful circumstances. Excluded populations were those with degenerative (e.g., Alzheimer's) and peroxisomal (e.g., Zellweger's) disorders since each was addressed in SC-RAND's year-2 review of the evidence concerning omega-3 fatty acids in neurology.

Treatment studies, as well as those investigating the possible association between omega-3 fatty acid intake and the onset, continuation or recurrence of specific psychiatric disorders or conditions, had to specifically investigate foods or supplements known to contain omega-3 fatty acids of any type (e.g., EPA, ALA), from any source (e.g., fish, walnuts, seed oil), any serving size or dose, delivered in any fashion (e.g., capsules, liquid, PUFA-rich diet), and for any length of time. In all studies, some method had to have been employed to suggest the presence of omega-3 fatty acid content in the exposure, if not its actual amount (e.g., g/d). Studies investigating “PUFAs” or “ LC PUFAs,” or even types of diet one might presume would contain marine or land sources of omega-3 fatty acids (e.g., “Mediterranean diet”) at minimum had to highlight at least one source of the omega-3 fatty acid content (e.g., oily fish servings). No restrictions were placed on the types or doses of pre- or on-study cointerventions (e.g., medication, omega-6 fatty acid intake, other dietary supplements).

Controlled studies were required to address questions of intervention efficacy or effectiveness, with randomized controlled trials (RCTs) being the gold standard method to investigate these questions (Question 1).^64^ Any definition of control, or comparator, was permitted. RCTs exhibit a greater inherent potential to deal with potentially serious biasing influences (e.g., selection bias) although a poorly designed or conducted RCT can produce results whose interpretability is no less complicated by the presence of confounding influences, for example, than observations derived from a well-constructed and conducted study employing a design with a lesser intrinsic capacity to control for these biases (e.g., non-RCT; prospective cohort study). For example, not all RCTs succeed, either through an explicit experimental plan or the process of randomization per se, to equally distribute known confounding influences (e.g., background diet; energy/caloric intake from the intervention; types and doses of psychotropic medication) across study arms in intervention studies. That said, our TEP asked that we identify all excluded uncontrolled studies with respect to questions of intervention efficacy/effectiveness so that future synthesis work could begin with these data. We achieved this by adding a third level of screening, which yielded a listing of citations for these excluded studies (see Study Selection Process section for details).

Any type of research design other than noncomparative case series or case studies was deemed appropriate for questions concerning the possible association between the intake of omega-3 fatty acids and the onset, continuation or recurrence of psychiatric disorders or conditions (Question 2). Often, but not exclusively, relevant data were generated by cross-sectional surveys involving a single sample. A special interpretative emphasis was placed on results from prevention RCTs and other controlled prospective designs.

Controlled studies were required to address the questions of the possible association between the fatty acid content of biomarkers and the onset, continuation or recurrence of psychiatric disorders or conditions (Question 3). Evidence of the possible role played by the fatty acid content of biomarkers in the etiology of schizophrenia, for example, requires derivation from controlled designs although not all of these designs are equal in their capacity to generate data directly pertinent to Question 3. A special interpretative emphasis was thus placed on results from prospective controlled designs, with cross-sectional studies yielding the least direct evidence.

Overall, any and all clinical outcomes were considered relevant, including symptom severity or control, response rate, incidence, prevalence or diagnostic status (e.g., case-control or cross-sectional studies). As markers of omega-3 fatty acid metabolism, the following fatty acid compositions or concentrations, from any source (e.g., red blood cell [RBC] membranes, plasma phospholipids), were considered relevant in intervention studies (i.e., exclusively as an exploratory focus on the possible covariation of clinical and biomarker effects, or correlations between these factors) or as possible predictors of the onset, continuation or recurrence of psychiatric disorders or conditions: EPA, DHA, AA/EPA, AA/DHA, AA/EPA+DHA. Studies exclusively evaluating the role of other biomarkers (e.g., cytokine production, eicosanoid levels) were not included. These decisions were made with the assistance of our TEP.

### Study Selection Process

The present review employed specific electronic functionality in the form of an internet-based software system, housed on a secure web site. It brings appreciable efficiencies to the systematic review process and the management of a systematic review team. Electronic yields of literature searches are posted to the system for review. Reviewers then submit all of their results of relevance screening, data appraisal or data abstraction directly to the system. The software system automatically conducts an internal comparison of multiple reviewers' responses to screening questions, to determine the eligibility/relevance of a bibliographic record or a full report. As well, the software captures responses to specific requests to abstract pre-specified data (e.g., mean age of study participants; the assessment of a study's internal validity) from pertinent reports. One large advantage associated with using this software is that review team members are able to complete their work from wherever they have internet access.

Following a calibration exercise, which involved screening five sample records using an electronic form developed and tested especially for this review (Appendix C ^†^), two reviewers independently screened the title, abstract, and key words from each bibliographic record for relevance by liberally applying the eligibility criteria. A record was retained if it appeared to contain pertinent study information. If the reviewers did not agree in finding at least one unequivocal reason for excluding it, it was entered into the next phase of the review. The reasons for exclusion were noted using a modified QUOROM format (Appendix D ^‡^).^65^ The screening process also aimed to identify the exact mental health question a record addressed, in addition to determining whether it might also or instead pertain to any of the other topics being systematically reviewed by the three EPCs in year 2 of the omega-3 fatty acids project.

Print or electronic copies of the full reports for those citations having passed level one screening were then retrieved. After completing a calibration exercise which involved evaluating five sample reports using the same eligibility criteria (Appendix C *), the rest of the reports were independently assessed by two reviewers. Reports were not masked given the equivocal evidence regarding the benefits of this practice.^66^ To be considered relevant at this second level of screening, all eligibility criteria had to be met. Implementing the recommendations of our TEP, a third level of dual-reviewer screening was used to exclude, yet at the same time to identify, studies addressing questions of intervention efficacy/effectiveness employing uncontrolled research designs.

Disagreements arising at either screening levels 2 or 3 were resolved by forced consensus and, if necessary, third party intervention. Excluded studies at each of these levels are noted as to the reason for their ineligibility in listings found at the end of this report.

## Data Abstraction

Following a calibration exercise involving two studies, seven reviewers independently abstracted the contents of included studies using an electronic Data Abstraction form developed especially for this review (Appendix C *). A second reviewer then verified those data. Data abstracted included the characteristics of the:

- report (e.g., publication status, language of publication, year of publication);
- study (e.g., sample size; research design; number of study arms/groups, cohorts, or phases; funding source);
- population (e.g., age; percent males; diagnosis description, including severity, duration, and comorbid conditions);
- intervention/exposure (e.g., omega-3 fatty acid types, sources, doses, and intervention/exposure length), and comparator(s);
- cointerventions (e.g., concurrent medications, omega-6 fatty acid use);
- withdrawals and dropouts, including reasons;
- clinical outcomes;
- fatty acid content of biomarkers; and,
- adverse events (e.g., side effects).

## Summarizing the Evidence

### Overview

The evidence is presented in three ways. Evidence tables in the Appendices offer a detailed description of the included studies (e.g., study design, population characteristics [e.g., diagnosis], intervention/exposure characteristics [e.g., omega-3 fatty acid types and doses], cointervention [e.g., background diet, concurrent medication]), with a study represented only once. These tables are organized by research design (Table 1: experimental studies [e.g., treatment RCTs]; Table 2: observational studies [e.g., cross-sectional studies examining the possible association of the omega-3 or omega-6/omega-3 fatty acid content of biomarkers with the onset, continuation or recurrence of a specific psychiatric disorder or condition]; Table 3: cross-national ecological analyses [e.g., studies addressing the possible association of omega-3 fatty acid intake with the onset, continuation or recurrence of a specific psychiatric disorder or condition), with studies arranged alphabetically within each of the three table/design categories.

Question-specific summary tables embedded in the text describe each study addressing a given question in abbreviated fashion, highlighting some key characteristics, including sample size (as measure of the “weight” of the evidence and possible precision of the results), dose and type of omega-3 fatty acids, and comparators' (i.e., comparison groups') specifications. This affords a comparison of all studies addressing a given question. A study can appear in more than one summary table since it can address more than one research question. Also question-specific is each summary matrix, situating each study in terms of its study quality and its applicability.

### Study Quality

Study quality refers to the internal validity, or methodological soundness, of a study. A systematic review can be faced with great variability in the quality of its included studies. Our approach is not to use a minimal level of quality as an inclusion criterion since this precludes assessing the possible impact of study quality on study results.

A study with low quality can make it difficult to clearly and meaningfully interpret its results, that is, to unequivocally attribute a significant observed benefit exclusively to an intervention/exposure (as opposed to other factors). Since definitions, or standards, of study quality can depend on the type of research design, different constructs were selected to evaluate, from study reports, the quality of RCTs and studies employing other types of research design. After a calibration exercise involving two studies with an RCT design, two assessors independently evaluated study quality. Disagreements were resolved via forced consensus. In the case of designs other than RCTs, a single experienced quality assessor performed the evaluations. Time did not permit their dual assessment.

Four fundamental quality constructs from two instruments were used to rate the internal validity of RCTs. These tools were chosen collectively by the three EPCs involved in the 2-year task order because they have been validated. The Jadad items^67^ assess the reporting of randomization, double blinding, and, withdrawals and dropouts (Appendix C ^§^). Total scores range from 0 to 5, with a score less than 3 indicating low quality. The reporting of the concealment of a trial's allocation to treatment^68^ yields three grades (A = adequate; B = unclear; C = inadequate) (Appendix C *).

The assessment of the quality of studies using designs other than RCTs is complicated by the dearth of validated instruments and the variety of such designs (e.g., non-randomized controlled trials; uncontrolled studies). Nevertheless, a recent systematic review by Deeks et al. identified a number of “best tools” for use with these designs.^69^ Among them was a published instrument developed by Downs and Black^70^ and an unpublished one derived by experts in Newcastle and Ottawa (NOS).^71^ The former validated both design-specific and design-neutral items.

Where case-control and cohort studies were included in the review, the validated NOS was employed. Items applicable to other designs such as non-RCTs, cross-sectional designs, cross-sectional surveys and others were taken from the Downs and Black instrument; or, if the required constructs were not operationalized in this instrument, they were developed as modifications of existing Downs and Black items (e.g., for multiple-group cross-sectional designs), NOS items (e.g., single prospective cohort studies), borrowed from Jadad's assessment tool (e.g., description of withdrawals/dropouts), or developed outright. For example, items needed to be created to evaluate cross-national ecological analyses (Appendix C *).

It should be noted that the items defining the case-control and cohort study assessment tools from the NOS were each used as a whole, although specific guidelines as to which design-specific total scores indicate low or sound quality are unavailable. Likewise, no guidelines exist to mark low or sound study quality based on any subset of Downs and Black's 27-item instrument. As already asserted, an Jadad total quality score of less than 3 indicates low quality. To permit the entry of these quality data into a summary matrix, cutpoints for each type of design were set somewhat arbitrarily to establish three levels of internal validity (see Summary Matrix).

It was decided by our review team that, given the limitations of space, especially in print-based study reports, and the amount of detail that would likely be required to provide all of the details we needed to fully establish that only appropriate methods had been used to extract, prepare, store and analyze lipid content, it was reasonable to appraise these methods by focusing instead on identifying extant descriptions of inappropriate methods. On occasion, the inappropriateness of methods had to be determined by reference to standard protocols.

Pilot-tested exclusively for their ease of use within the data abstraction form were questions designed to informally assess the successful control of study confounding from variables identified by content experts as potential threats to the internal validity of studies pertinent to the review. In their view, these variables required experimental or statistical control to permit an uncomplicated interpretation of study results (Appendix C *). The two major categories of threat in controlled designs came from having study groups vary in terms of key prestudy or baseline characteristics (e.g., background diet; psychotropic medication; severity of a disorder), or from having certain on-study changes (e.g., unexpected stressors; changes in medication type or dose) unrelated to the exposure or intervention, occur unequally across study groups to produce confounding. Even RCTs are not immune from being affected by these threats to internal validity.

For example, if in a placebo-controlled RCT test of the supplemental treatment efficacy of omega-3 fatty acids, only certain treatment group members' background diets changed appreciably from what was observed at baseline (e.g., decreased fish intake and thus an increased omega-6/omega-3 ratio in the background diet), at which point the two study groups' baseline diets had been deemed comparable, then this on-study inequality could influence study outcomes. Because of this change in background diet, one study group might all of a sudden be receiving a different ratio of omega-6/omega-3 fatty acid intake than what had been set in the study protocol. This would amount to a change in the planned, on-study between-group difference in omega-6/omega-3 fatty acid intake; and, it is this intake ratio which could have the greatest influence on clinical outcomes. In general, contraventions of planned on-study between-group equivalences (e.g., caloric/energy intake; background diet; medication types and doses; severity of disorder; current smoker status; alcohol consumption) or of planned, on-study between-group differences (e.g., amount of omega-3 fatty acid intake) related to events other than the intervention/exposure (e.g., stressors, which can alter the severity of the disorder in addition to the patterns of eating, smoking and alcohol consumption), that is, in variables with the potential to affect mental health outcomes (and biomarker levels), could either “mask” or incorrectly “reveal” clinical benefits of the intervention depending on the groups in which these unexpected changes occurred. Then, unless statistical adjustments are made, such a scenario will complicate the meaningful interpretation of outcomes.

These informal assessment items were modified to assess single group studies since on-study changes involving the same key variables can also complicate the interpretation of their study results. However, no quality scores were derived from the data abstractors' responses to these questions pertaining to controlled or uncontrolled studies.

### Study Applicability

As specified in the scope of work for this series of evidence reports on the health benefits of omega-3 fatty acids, the primary focus is on the US population. Given the geographical location of the UO-EPC, however, the definition of study applicability was expanded slightly to include Canada as part of a larger North American context. This study's reference point became the “typical” North American.

Also known as external validity, or generalizability, the construct of applicability refers to the degree to which a given study's sample population is sufficiently representative of the population to which one wishes to generalize its results. In the present review, two schemes operationally defined applicability (Appendix C**). One assessed studies involving at least one target population identified with a psychiatric disorder or condition, with the other evaluating studies involving a target population with or without a known elevated risk for a psychiatric disorder or condition.

With regards to the highest level of applicability (Level I) in the first scheme, the broadest definition of the population of interest is the otherwise “healthy” North American (or similar individual) identified with a psychiatric disorder or condition, diagnosed using a standard North American strategy and methodology/nomenclature (e.g., DSM-IV) or identified using at least one established psychiatric instrument, presenting with or without comorbid psychiatric conditions while possibly receiving “typical” North American medications for the primary diagnosis, is drawn from a somewhat broad socio-demographic spectrum (i.e., gender, race), and eats a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15: see below for references). For Level I applicability in the second scheme, the broadest definition of the population of interest is the otherwise “healthy” North American (or similar) individual, presenting with or without a known elevated risk for onset of a psychiatric disorder or condition, representing a somewhat broad socio-demographic spectrum (i.e., gender, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15).

Together, these level I definitions represent the respective reference points, with applicability decreasing as the definition of the sample study population narrows in terms of the factors represented in the two schemes. With respect to the scheme applied to studies with diagnosed participants, we identified what are likely the two most important variables as being the method of diagnosis and the background diet of participants leading up to the study, if not also during the study. Each defines the study population. When the second scheme is applied to studies where the participants have not yet been diagnosed with a psychiatric disorder or condition, background diet is the key variable.

The method of diagnosis is an important factor since not all countries employ the diagnostic methods or nomenclatures used most frequently in North America (e.g., DSM). Psychiatric populations identified using different approaches, even when diagnostic labels are the same, can vary in terms of what these labels refer to.^13^ At the same time, different labels (e.g., “AD/HD” in North America versus “hyperactivity” in the UK) can refer to the same clinical entity. That said, the most frequently employed approaches employed in North America are considered the reference point.

Operationalized ideally in this review as the omega-6/omega-3 fatty acid ratio, background diet is an important factor in assessing both types of study population (i.e., diagnosed vs undiagnosed participants). Given the competitive relationship between omega-3 and omega-6 fatty acids, both for enzymes to yield key metabolites with specific effects in the human biosystem (see Chapter 1) and for positions in cell membranes from which to have these and other possible influences (e.g., clinical improvement or prevention), the absolute and relative intake of omega-3 and omega-6 fatty acids from all sources, and not just from the identified exposure, likely need to be taken into account when deciding whether populations assessed in different studies are comparable. The likelihood of biological and/or clinical effects in studies may turn out to vary depending on these absolute or relative intake values. A high background dietary omega-6/omega-3 fatty acid intake ratio—potentially reflected in a corresponding differential in these contents in cell membranes—may make it harder for omega-3 fatty acid supplementation to make a clinically meaningful difference,^72^ although already having considerable omega-3 fatty acid content in the background diet and in cell membranes because of a low omega-6/omega-3 fatty acid intake ratio may make it difficult for typically small amounts of omega-3 fatty acid supplementation to make a clinically meaningful difference (see Discussion).

Irrespective of which of these hypotheses may be eventually confirmed elsewhere, the fact that national, and sometimes regional, populations can vary in terms of their diet's omega-6/omega-3 fatty acid intake ratio strongly suggests that this potential confounding influence on study outcomes needs to be represented in the applicability schemes whereby the North American value is the reference point. The typical North American diet contains an omega-6/omega-3 fatty acid intake ratio of at least 15, while urban India and Japan's corresponding values are 38–50 and 4, respectively.^33–45^

UK populations represent somewhat of a special case in that, while they often use the same diagnostic methods and research instruments to identify psychiatric disorders and conditions in populations, respectively, and while they can exhibit socio-demographic pictures similarly broad to the ones seen in North American study populations, their somewhat different lifestyle and background diet recommended an applicability value of “II.” However, if participants were drawn from a narrower UK population, then a “III” was assigned. Given their inclusion of multi-national populations, with or without representation from the U.S. or Canada, cross-national ecological analyses necessarily received a “III.” One experienced assessor evaluated study applicability.

### Summary Matrix

For a given research question, and where possible (e.g., more than one study addressing the question), a summary matrix situates the pertinent studies in terms of their respective study quality (internal validity) and applicability (external validity) values. The Jadad total quality score defined RCTs' internal validity in summary matrices. A three-level format was derived from the range of possible RCT quality scores (A = Jadad total score of 4 or 5; B = Jadad total score of 3; C = Jadad total score of 0, 1 or 2). Given that allocation concealment scores have in the past tended to vary less widely than Jadad total scores, allocation concealment values were entered as superscripts in the summary matrices.^72^ A similar approach was taken for the studies employing other research designs. The following cutpoints were established, albeit without benefit of a validational exercise:

- comparative before-after study: A = total quality score of 8–11; B = 5–7; C = 1–4;
- case-control study (NOS): A = 8–10; B = 4–7; C = 1–3;
- (multiple-group) cross-sectional study: A = 8–10; B = 4–7; C = 1–3;
- single prospective cohort study (Modified NOS): A = 8–10; B = 4–7; C = 1–3;
- cross-sectional survey: A = 8–10; B = 4–7; C = 1–3; and,
- cross-national ecological analysis: A = 7–9; B = 4–6; C = 1–3.

The three-level applicability format was established by the 3 EPCs involved in the 2-year project for practical reasons, to permit the incorporation of quality scores within a summary matrix. Studies assigned an “X” (i.e., insufficient information to establish applicability) were excluded from summary matrices.

### Qualitative Data Synthesis

An overarching qualitative synthesis describes the progress of each citation, then report, through the stages of the systematic review. It also highlights certain report and study design characteristics of included studies (e.g., distributions of research design by research question). Then, for each question, a separate qualitative synthesis is derived for included evidence, organized by broad categories of research design (i.e., experimental studies vs observational studies vs cross-national analyses). A brief study-by-study overview typically introduces the synthesis, followed by a narrative summary of the key defining features of relevant studies (e.g., inclusion/exclusion criteria), including their populations (e.g., diagnosis-related), intervention/exposures (e.g., types of omega-3 fatty acid), cointerventions (e.g., psychotropic medication), outcomes, study quality, applicability and results. Whether or not data can be organized according to these subheadings depends on the number of studies addressing a given question and the amount or variety of detail available in the study reports. For example, having identified too few studies per research question that do and do not exhibit significant effects for a given clinical outcome can preclude determining the impact of covariables with the potential to modify or confound study results (e.g., type or dose of omega-3 fatty acids).

Juxtaposing, in turn, all pertinent studies' parameters for a given research question has two key consequences. It allows us to identify the “gaps” in knowledge deemed crucial by content experts to understand the clinical phenomenon (e.g., efficacy of omega-3 fatty acids). That is, data regarding possible confounders may be lacking, making it difficult to interpret study results with unfettered confidence. These gaps point to those variables requiring measurement and experimental or statistical control in future research. Second, it affords an understanding of the definition and extent of the included studies' clinical homogeneity (i.e., population, intervention, cointervention, outcome), which can then inform decisions regarding the appropriateness of meta-analysis. Where strong clinical heterogeneity is observed, it may be important to forego meta-analysis because the “population” to which any point estimate, and measure of precision, might be extrapolated may not exist per se; it, too, is synthetic (e.g., the “average” schizophrenic). Subject to scrutiny in the evaluation of cross-study clinical homogeneity is the ability of each study to control for confounding influences and yield results that can be interpreted without serious question marks. The existence of statistical heterogeneity also plays a role in the decision to do without a quantitative synthesis. Whether or not meta-analysis is considered appropriate, an attempt is made to make sense of the possible influence of covariates and confounders within the context of the qualitative synthesis.

Where eligibility criteria permit, evidence from research designs with a lesser inherent potential to control for biasing influences are used to see whether, collectively, they confirm the picture of efficacy, or association, derived from designs with a greater inherent potential to achieve this goal (see Eligibility Criteria). For the purposes of interpreting results, greater emphasis is placed on the latter, with “greater emphasis” meaning that we assign greater interpretative, not numerical or statistical, weight to these intrinsically stronger designs. Factors other than study design also taken into account in interpreting results include study quality, the number of studies, and whether studies were sufficiently powered.

### Quantitative Data Synthesis

Given its greater potential to control for possible confounding factors, only RCT evidence regarding the question of interventions' efficaciousness was considered for inclusion in meta-analysis. All things being equal, it was also assumed that priority in meta-analysis might be given to clinical outcomes pertinent to the present day practice of psychiatry and psychology.

Providing the result would have a clearly defined population to which to generalize a synthetic result, and that sufficient numbers of prospective controlled studies exist (e.g., RCT; cohort study), meta-analysis was considered with respect to data investigating questions of the possible association of the onset, continuation or recurrence of a psychiatric disorder or condition with either the intake of omega-3 fatty acids or the PUFA content of biomarkers. Prospective controlled designs constitute the most appropriate way to establish these risk-relationships among variables. Decisions regarding statistical models are provided where results of meta-analysis are reported. Reasons to forego meta-analysis are likewise described.