# Introduction

This evidence report by the University of Ottawa's Evidence-Based Practice Center (EPC) concerning the effects of omega-3 fatty acids on mental health is one among several that address topics related to omega-3 fatty acids that were requested and funded by the Office of Dietary Supplements (ODS), National Institutes of Health (NIH), through the EPC program at the Agency for Healthcare Research and Quality (AHRQ). Three EPCs—the Tufts-New England Medical Center (Tufts-NEMC) EPC, the Southern California-RAND (SC-RAND) EPC, and the University of Ottawa EPC (UO-EPC)—each produced evidence reports. To ensure consistency of approach, the three EPCs collaborated on selected methodological elements, including literature search strategies, rating of evidence, and data table design.

The aim of these reports is to summarize the current evidence concerning the health effects of omega-3 fatty acids on the following: cardiovascular diseases, cancer, child and maternal health, eye health, gastrointestinal/renal diseases, asthma, autoimmune diseases, immune-mediated diseases, transplantation, mental health, and, neurological diseases and conditions. In addition to informing the research community and the public on the effects of omega-3 fatty acids on various health conditions, it is anticipated that the findings of the reports will also be used to help define the agenda for future research.

The focus of this report is on mental health outcomes in humans. In this chapter, the metabolism, physiological functions, and sources of omega-3 fatty acids are briefly discussed. This constitutes background material, placing in context the data presented in the evidence report. As well, the description of the U.S. population's intake of omega-3 fatty acids is provided in response to a general question posed within the task order (i.e., project). This introductory material is then complemented by a brief review of the epidemiology and descriptions of mental health disorders or conditions, in addition to some of their treatment options. The brief review is intended as an overview rather than a comprehensive description. The terms “mental health” and “psychiatric” are used interchangeably, as in “psychiatric” or “mental health” disorders or conditions. “Conditions” refer to behavior or symptoms (e.g., dysphoric feelings, suicidal ideation, anger, aggressiveness), which are necessary yet insufficient to warrant a formal diagnosis of psychiatric disorder despite their potentially serious consequences.

Chapter 2 describes the methods used to identify, review and synthesize the results from studies concerning omega-3 fatty acids in mental health. Chapter 3 presents the findings of studies meeting eligibility criteria, with discussion points, including recommendations for future research, completing the report in Chapter 4.

## Metabolism and Biological Effects of Essential Fatty Acids

Dietary fat is an important source of energy for biological activities in human beings. It encompasses saturated fatty acids (SFAs), which are usually solid at room temperature, and unsaturated fatty acids (UFAs), which are liquid at room temperature. UFAs can be further divided into monounsaturated (MUFAs) and polyunsaturated fatty acids (PUFAs). PUFAs can be classified, on the basis of their chemical structure, into two groups: omega-3 (n-3) fatty acids and omega-6 (n-6) fatty acids. The omega-3 or n-3 notation means that the first double bond in this family of PUFAs is 3 carbons from the methyl end of the molecule. The same principle applies to the omega-6 or n-6 notation. Despite their differences in structure, all fats contain the same amount of energy (i.e., 9 kcal/g or 37 kJ/g).

Of all fats found in food, two—alpha-linolenic acid (chemical abbreviation: ALA; 18:3 n-3) and linoleic acid (LA; 18:2 n-6)—cannot be synthesized in the human body, yet these are necessary for proper physiological functioning. These two fats are thus called “essential fatty acids” (EFAs). The EFAs can be converted in the liver to long-chain PUFAs (LC PUFAs), which have a higher number of carbon atoms and double bonds. These LC PUFAs retain the omega type (n-3 or n-6) of the parent essential fatty acids.

ALA and LA comprise the bulk of the total PUFAs consumed in a typical North American diet. Typically, LA comprises 89 percent of the total PUFAs consumed, while ALA comprises 9 percent. Smaller amounts of other PUFAs make up the remainder.^1^ Both ALA and LA are present in a variety of foods. For example, LA is present in high concentrations in many commonly used oils, including safflower, sunflower, soy, and corn oil. ALA, which is consumed in smaller quantities, is present in leafy green vegetables and in some commonly used oils, including canola and soybean oil. Some novelty oils, such as flaxseed oil, contain relatively high concentrations of ALA, but these oils are not commonly found in the food supply.

The Institute of Medicine (IOM) suggests that, for adults 19 and older, an adequate intake (AI) of ALA is 1.1–1.6 grams/day (g/d), and 11–17 g/d for LA.^2^ Recommendations regarding AI differ by age and gender groups, and for special conditions such as pregnancy and lactation.

As shown in Figure 1, eicosapentaenoic acid (EPA; 20:5 n-3) and docosahexaenoic acid (DHA; 22:6 n-3) can act as competitors for the same metabolic pathways as arachidonic acid (AA; 20:4 n-6). In human studies, the analyses of fatty-acid compositions in both blood phospholipids and adipose tissue have shown a similar competitive relationship between omega-3 LC PUFAs and AA. General scientific agreement supports an increased consumption of omega-3 fatty acids and reduced intake of omega-6 fatty acids to promote good health. However, for omega-3 fatty acid intake, the specific quantitative recommendations vary widely among countries not only in terms of different units — ratio, grams, total energy intake — but also in quantity.^3^ Furthermore, there remain numerous questions relating to the inherent complexities concerning omega-3 and omega-6 fatty acid metabolism, in particular the relationships between the two fatty acids. For example, it remains unclear to what extent ALA is converted to EPA and DHA in humans, and to what extent the high intake of omega-6 fatty acids compromises any benefits of omega-3 fatty acid consumption. Without the resolution of these two fundamental questions, it remains difficult to study the importance of the omega-6/omega-3 fatty acid ratio.

Figure 1. Classical omega-3 and omega-6 fatty acid synthesis pathways and the role of omega-3 fatty acids in regulating health/disease markers

## Metabolic Pathways of Omega-3 and Omega-6 Fatty Acids

Omega-3 and omega-6 fatty acids share the same pools of enzymes and go through the same oxidation pathways while being metabolized (Figure 1). Once ingested, the parent of the omega-3 fatty acids, ALA, and the parent of the omega-6 fatty acids, LA, can be elongated and desaturated into LC PUFAs. LA is converted into gamma-linolenic acid (GLA; 18:3 n-6), an omega-6 fatty acid that is a positional isomer of ALA. GLA, in turn, can be converted to the long-chain omega-6 fatty acid, AA, while ALA can be converted, to a lesser extent, to the long-chain omega-3 fatty acids, EPA and DHA. However, the conversion from parent fatty acids into LC PUFAs occurs slowly in humans, and conversion rates are not well understood. Because of the slow rate of conversion, and the importance of LC PUFAs to many physiological processes, humans must augment their level of LC PUFAs by consuming foods rich in these important compounds. Meat is the primary food source of AA, and fish is the primary food source of EPA.

The specific biological functions of fatty acids depend on the number and position of double bonds and the length of the acyl chain. Both EPA and AA are 20-carbon fatty acids and are precursors for the formation of prostaglandins (PGs), thromboxane (Tx), and leukotrienes (LTs)—hormone-like agents that are members of a larger family of substances called eicosanoids. Eicosanoids are localized tissue hormones that seem to be one of the fundamental regulatory classes of molecule in most higher forms of life. They do not travel in the blood, but are created in the cells to regulate a large number of processes, including the movement of calcium and other substances into and out of cells, dilation and contraction of muscles, inhibition and promotion of clotting, regulation of secretions including digestive juices and hormones, and, the control of fertility, cell division and growth.^4^

As shown in Figure 1, the long-chain omega-6 fatty acid, AA, is the precursor of a group of eicosanoids including series-2 prostaglandins (PG_2_) and series-4 leukotrienes (LT_4_). The omega-3 fatty acid, EPA, is the precursor to a group of eicosanoids including series-3 prostaglandins (PG_3_) and series-5 leukotrienes (LT_5_). The series-2 prostaglandins and series-4 leukotrienes derived from AA are involved in intense actions (such as accelerating platelet aggregation, and enhancing vasoconstriction and the synthesis of mediators of inflammation) in response to physiological stressors. The series-3 prostaglandins and series-5 leukotrienes derived from EPA are less physiologically potent than those derived from AA. More specifically, the series-3 prostaglandins are formed at a slower rate and work to attenuate excessive series-2 prostaglandins. Thus, adequate production of the series-3 prostaglandins, which are derived from the omega-3 fatty acid, EPA, may protect against heart attack and stroke as well as certain inflammatory diseases like arthritis, lupus and asthma.^4^ In addition, animal studies have demonstrated that omega-3 LC PUFAs, such as EPA and DHA, engage in multiple cytoprotective activities that may contribute to antiarrhythmic mechanisms.^5^ Arrhythmias are thought to be the cause of “sudden death” in heart disease.

In addition to affecting eicosanoid production as described above, EPA also affects lipoprotein metabolism and decreases the production of other compounds—including cytokinesinterleukin 1β (IL-1β), and tumor necrosis factor a (TNF-α)-which have pro-inflammatory effects. These compounds exert pro-inflammatory cellular actions that include stimulating the production of collagenase and increasing the expression of adhesion molecules necessary for leukocyte extravasation.^6^ The mechanism responsible for the suppression of cytokine production by omega-3 LC PUFAs remains unknown, although suppression of eicosanoid production by omega-3 fatty acids may be involved. EPA can also be converted into the longer chain omega-3 form of docosapentaenoic acid (DPA, 22:5 n-3), and then further elongated and oxygenated into DHA. EPA and DHA are frequently referred to as VLN-3FA—very long chain n-3 fatty acids. DHA, which is thought to be important for brain development and functioning, is present in significant amounts in a variety of food products, including fish, fish liver oils, fish eggs, and organ meats. Similarly, AA can convert into an omega-6 form of DPA.

Studies have reported that omega-3 fatty acids decrease triglycerides (Tg) and very low density lipoprotein (VLDL) in hypertriglyceridemic subjects, concomitant with an increase in high density lipoprotein (HDL). However, they appear to increase or have no effect on low density lipoprotein (LDL). Omega-3 fatty acids apparently lower Tg by inhibiting VLDL and apolipoprotein B-100 synthesis, and decreasing post-prandial lipemia.^7^ Omega-3 fatty acids, in conjunction with transcription factors (small proteins that bind to the regulatory domains of genes), target the genes governing cellular Tg production and those activating oxidation of excess fatty acids in the liver. Inhibition of fatty acid synthesis and increased fatty acid catabolism reduce the amount of substrate available for Tg production.^8^

As noted earlier, omega-6 fatty acids are consumed in larger quantities (> 10 times) than omega-3 fatty acids. Maintaining a sufficient intake of omega-3 fatty acids is particularly important since many of the body's physiologic properties depend upon their availability and metabolism.

## U.S. Population Intake of Omega-3 Fatty Acids

The major source of omega-3 fatty acids is dietary intake of fish, fish oil, vegetable oils (principally canola and soybean), some nuts such as walnuts, and, dietary supplements. Two population-based surveys, the third National Health and Nutrition Examination (NHANES III) 1988-94, and the Continuing Survey of Food Intakes by Individuals 1994-98 (CSFII), are the main sources of dietary intake data for the U.S. population. NHANES III collected information on the U.S. population aged ≥2 months. Mexican Americans and non-Hispanic African-Americans, children ≤5 years old, and adults ≥ 60 years old were over-sampled to produce more precise estimates for these population groups. There were no imputations for missing 24-hour dietary recall data. A total of 29,105 participants had complete and reliable dietary recall.

The CSFII 1994-96, popularly known as the “What We Eat in America” survey, addressed the requirements of the National Nutrition Monitoring and Related Research Act of 1990 (Public Law 101–445) for continuous monitoring of the dietary status of the American population. The CSFII 1994-96 utilized an improved data-collection method for 24-hour recall known as the multiple-pass approach. Given the large variation in intake from day-to-day, multiple 24-hour recalls are considered to be best suited for most nutrition monitoring and will produce stable estimates of mean nutrient intake from groups of individuals.^9^ In 1998, the Supplemental Children's Survey, a survey of food and nutrient intake by children under the age of 10 years, was conducted as a supplement to the CSFII 1994-96. The CSFII 1994-96, 1998 surveyed 20,607 people of all ages with over-sampling of low-income population (<130% of the poverty threshold). Dietary intake data from individuals of all ages were collected over two nonconsecutive days via two one-day dietary recalls.

Table 1 reports the NHANES III survey mean intake ± the standard error of the mean (SEM), in addition to the median and range for each omega-3 fatty acid. Distributions of EPA, DPA, and DHA were very skewed; therefore, the means and standard errors of the means should be used and interpreted with caution. Table 2 reports the CSFII survey mean and median intakes for each omega-3 fatty acid, along with SEMs, as reported in the Dietary Reference Intakes from the Institute of Medicine.^2^

Table 1. Estimates of the mean±standard error of the mean (SEM) intake of linoleic acid (LA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), and docosahexaenoic acid (DHA) in the US population, based on analyses of a single 24-hour dietary recall of NHANES III data

| [underlined: Grams/day] | | [underlined: % Kcal/day]
| Mean±SEM | Median (range)^1^ | Mean±SEM | Median (range)^1^
LA (18:2 n-6) | 14.1±0.2 | 9.9 (0–168) | 5.79±0.05 | 5.30 (0–39.4)
ALA (18:3 n-3) | 1.33±0.02 | 0.90 (0–17) | 0.55±0.004 | 0.48 (0–4.98)
EPA (20:5 n-3) | 0.04±0.003 | 0.00 (0–4.1) | 0.02±0.001 | 0.00 (0–0.61)
DHA (22:6 n-3) | 0.07±0.004 | 0.00 (0–7.8) | 0.03±0.002 | 0.00 (0–2.86)

1 The distributions are not adjusted for the over-sampling of Mexican-Americans, non-Hispanic African-Americans, children ≤5 years old, and adults ≥ 60 years old in the NHANES III dataset.

Table 2. Mean, range, median, and standard error of the mean (SEM) of usual daily intakes of linoleic acid (LA), total omega-3 fatty acids (n-3 FA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA) and docosahexaenoic acid (DHA) in the US population, based on CSFII data (1994-1996, 1998)

| [underlined: Grams/day]
| Mean±SEM | Median±SEM
LA (18:2 n-6) | 13.0±0.1 | 12.0±0.1
Total n-3 FA | 1.40±0.01 | 1.30±0.01
ALA (18:3 n-3) | 1.30±0.01 | 1.21±0.01
EPA (20:5 n-3) | 0.028 | 0.004
DPA (22:5 n-3) | 0.013 | 0.005
DHA (22:6 n-3) | 0.057±0.018 | 0.046±0.013

## Dietary Sources of Omega-3 Fatty Acids

Omega-3 fatty acids can be found in many different sources of food, including fish, shellfish, some nuts, and various plant oils. Selected from the USDA website, Table 3 lists the amount of omega-3 fatty acids in some commonly consumed fish, shellfish, nuts, and edible oils.^10^

Table 3. The omega-3 fatty acid content, in grams per 100 g food serving, of a representative sample of commonly consumed fish, shellfish, fish oils, nuts and seeds, and plant oils that contain at least 5 g omega-3 fatty acids per 100 g

Food item | EPA | DHA | ALA
[underlined: Fish (Raw]^a^[underlined: )]
Anchovy, European | 0.6 | 0.9 | -
Bass, Freshwater, Mixed Sp. | 0.2 | 0.4 | 0.1
Bass, Striped | 0.2 | 0.6 | trace
Bluefish | 0.2 | 0.5 | -
Carp | 0.2 | 0.1 | 0.3
Catfish, Channel | trace | 0.2 | 0.1
Cod, Atlantic | trace | 0.1 | trace
Cod, Pacific | trace | 0.1 | trace
Eel, Mixed Sp. | trace | trace | 0.4
Flounder & Sole Sp. | trace | 0.1 | trace
Grouper, Mixed Sp. | trace | 0.2 | trace
Haddock | trace | 0.1 | trace
Halibut, Atlantic and Pacific | trace | 0.3 | trace
Halibut, Greenland | 0.5 | 0.4 | trace
Herring, Atlantic | 0.7 | 0.9 | 0.1
Herring, Pacific | 1.0 | 0.7 | trace
Mackerel, Atlantic | 0.9 | 1.4 | 0.2
Mackerel, Pacific and Jack | 0.6 | 0.9 | trace
Mullet, Striped | 0.2 | 0.1 | trace
Ocean Perch, Atlantic | trace | 0.2 | trace
Pike, Northern | trace | trace | trace
Pike, Walleye | trace | 0.2 | trace
Pollock, Atlantic | trace | 0.4 | -
Pompano, Florida | 0.2 | 0.4 | -
Roughy, Orange | trace | - | trace
Salmon, Atlantic, Farmed | 0.6 | 1.3 | trace
Salmon, Atlantic, Wild | 0.3 | 1.1 | 0.3
Salmon, Chinook | 1.0 | 0.9 | trace
Salmon, Chinook, Smoked^b^ | 0.2 | 0.3 | -
Salmon, Chum | 0.2 | 0.4 | trace
Salmon, Coho, Farmed | 0.4 | 0.8 | trace
Salmon, Coho, Wild | 0.4 | 0.7 | 0.2
Salmon, Pink | 0.4 | 0.6 | trace
Salmon, Pink, Canned^c^ | 0.9 | 0.8 | trace
Salmon, Sockeye | 0.6 | 0.7 | trace
Sardine, Atlantic, Canned in Oil^d^ | 0.5 | 0.5 | 0.5
Seabass, Mixed Sp. | 0.2 | 0.4 | -
Seatrout, Mixed Sp. | 0.2 | 0.2 | trace
Shad, American | 1.1 | 1.3 | 0.2
Shark, Mixed Sp. | 0.3 | 0.5 | trace
Snapper, Mixed Sp. | trace | 0.3 | trace
Swordfish | 0.1 | 0.5 | 0.2
Trout, Mixed Sp. | 0.2 | 0.5 | 0.2
Trout, Rainbow, Farmed | 0.3 | 0.7 | trace
Trout, Rainbow, Wild | 0.2 | 0.4 | 0.1
Tuna, Fresh, Bluefin | 0.3 | 0.9 | -
Tuna, Fresh, Skipjack | trace | 0.2 | -
Tuna, Fresh, Yellowfin | trace | 0.2 | trace
Tuna, Light, Canned in Oil^e^ | trace | 0.1 | trace
Tuna, Light, Canned in Water^e^ | trace | 0.2 | trace
Tuna, White, Canned in Oil^e^ | trace | 0.2 | 0.2
Tuna, White, Canned in Water^e^ | 0.2 | 0.6 | trace
Whitefish, Mixed Sp. | 0.3 | 0.9 | 0.2
Whitefish,Mixed Sp., Smoked | trace | 0.2 | -
Wolffish, Atlantic | 0.4 | 0.3 | trace
[underlined: Shellfish (Raw)]
Abalone, Mixed Sp. | trace | - | -
Clam, Mixed Sp. | trace | trace | trace
Crab, Blue | 0.2 | 0.2 | -
Crayfish, Mixed Sp., Farmed | trace | 0.1 | trace
Lobster, Northern | - | - | -
Mussel, Blue | 0.2 | 0.3 | trace
Oyster, Eastern, Farmed | 0.2 | 0.2 | trace
Oyster, Eastern, Wild | 0.3 | 0.3 | trace
Oyster, Pacific | 0.4 | 0.3 | trace
Scallop, Mixed Sp. | trace | 0.1 | -
Shrimp, Mixed Sp. | 0.3 | 0.2 | trace
Squid, Mixed Sp. | 0.1 | 0.3 | trace
[underlined: Fish Oils]
Cod Liver Oil | 6.9 | 11.0 | 0.9
Herring Oil | 6.3 | 4.2 | 0.8
Menhaden Oil | 13.2 | 8.6 | 1.5
Salmon Oil | 13.0 | 18.2 | 1.1
Sardine Oil | 10.1 | 10.7 | 1.3
[underlined: Nuts and Seeds]
Butternuts, Dried | - | - | 8.7
Flaxseed | | | 18.1
Walnuts, English | - | - | 9.1
[underlined: Plant Oils]
Canola (Rapeseed) | - | - | 9.3
Flaxseed Oil | - | - | 53.3
Soybean Lecithin Oil | - | - | 5.1
Soybean Oil | - | - | 6.8
Walnut Oil | - | - | 10.4
Wheatgerm Oil | - | - | 6.9

Trace = <0.1; - = 0 or no data; Sp. = species;

a Except as indicated;

b Lox.;

c Solids with bone and liquid;

d Drained solids with bone;

e Drained solids.

## Disorders of Mental Health: an Overview

Disorders of mental health are becoming increasingly common in the US. It is estimated that in a given year, 22%, or one in five American adults, suffers from a diagnosable mental health disorder.^11^ These disorders, including major depression, bipolar disorder, schizophrenia, and obsessive-compulsive disorder, account for four of the ten leading causes of disability in the US and other developed countries.^12^ Many people suffer from more than one mental disorder at a given time. The Diagnostic and Statistical Manual of Mental Disorders, fourth edition (DSM-IV), published by the American Psychiatric Association, is the reference guide currently used particularly in North America to diagnosis psychiatric disorders.

The DSM approach, with its diagnostic criteria often embodied as various methods (e.g., structured interviews), has been updated several times over the past decades, an observation suggesting the need to recognize that individuals diagnosed using the different versions of DSM may actually be exhibiting varying clusters or intensities of clinical features (e.g., symptoms/behaviors).^13^ Other classification systems (e.g., ICD-10), employing diagnostic criteria which are potentially different from the DSM approach, have also been used to identify psychiatric disorders. Together, these two observations highlight the importance of considering how the ways in which psychiatric populations are identified may account for varying responses to the same interventions within clinical or research contexts.^13^ The following sections introduce the psychiatric disorders or conditions for which evidence pertinent to this systematic review was identified.

## Affective Disorders

Affective, or mood, disorders include depression (major and dysthymic) and bipolar disorder (manic depression). In a given year, it is estimated that 18.8 million American adults, or 9.5% of the population aged 18 years and older, exhibit the characteristics of a depressive disorder.^11^ Twice as many women (12%) as men (6.6%) are affected.(National Institute of Mental Health, 2001) The World Health Organization (WHO) has estimated that major depressive disorder may become the second leading cause of diability by 2020, positioning it second only to ischemic heart disease, and making it the leading cause in developing regions.^14^

The mainstay of depressive symptoms are feelings of unhappiness, loss of energy and interest, fatigue, poor concentration, altered appetite, sleep disturbances, diminished cognitive function, weight gain/loss, anxiety, agitation or irritability, chronic indecisiveness, and often, suicidal ideation.^15,^ ^16^ Individuals with dysthymic disorder (chronic, mild depression) have depressive symptoms of lesser severity than what is seen in individuals with major depression. Dysthymic disorder can begin in childhood, adolescence or early adulthood. Symptoms must persist for a minimum of two years in adults, or one year in children, in order to meet criteria for a DSM-IV diagnosis. Individuals with dysthymic disorder are usually able to manage their life, although symptoms may be severe enough to cause distress and interfere with important life responsibilities. In a given year, approximately 40 percent of adults with dysthymic disorder may end up meeting the criteria for major depressive disorder or bipolar disorder.^11^

Major depression (clinical depression, unipolar depression) is characterized by severe symptoms of depression. WHO has determined that major depression is the third leading cause of vocational disability worldwide.^12^ According to DSM-IV, major depression is defined as two or more weeks of low mood or diminished interest in usual activities, combined with four or more of the following symptoms: sleep alteration (increased or decreased); inappropriate guilt or loss of self-esteem; altered appetite (increased or decreased); diminished energy; diminished concentration; psychomotor symptoms (either agitation or retardation); or suicidal ideation. The average age of onset is the mid-twenties, and for most people, episodes of major depression last from six to nine months.^11^

Bipolar disorder (manic depression) is characterised by extreme mood swings, that is, alternating between periods of mania and periods of depression. According to DSM-IV, mania is defined as a distinct change in mood and functioning, lasting at least one week, and is characterized by a euphoric or irritable mood accompanied by symptoms such as increased energy, decreased need for sleep, rapid thinking and speech, grandiosity, poor judgement and impulsivity, and in some cases, psychosis (i.e., delusions and/or hallucinations). For patients with bipolar disorder, episodes of mania are followed by periods of major depression. Patients may also have “mixed” mood states in which the symptoms of mania and depression occur simultaneously, or “rapid cycling,” where continuous or frequently shifting mood states occur.^16^ Unlike dysthymia and major depression, where the incidence is higher in women, bipolar disorder tends to affect men and women equally. The average age of a first manic episode is the early twenties.^11^ It has been estimated that 20% to 30% of individuals with bipolar disorder will die as a direct consequence of their illness, usually by suicide.^17^

### Treatment Options

Treatment options for patients diagnosed with depression include psychotherapy, pharmacotherapy, and in some instances, electroconvulsive therapy. For individuals with severe depression, antidepressant medication is the treatment of choice, whereas psychotherapy alone may be sufficient to treat individuals with mild to moderate depression.

The most commonly used antidepressant medications include the selective serotonin reuptake inhibitors (SSRIs) and tricyclic antidepressants. The monoamine oxidase inhibitors (MAOIs) are used less frequently. Herbal therapy, including St. John's wort, has also been suggested as being helpful in the treatment of depression. The treatment of choice for bipolar disorder remains lithium or divalproex. The SSRIs and tricyclics act by slowing the reuptake of neurotransmitters, thus making them more available. The SSRIs work specifically on the neurotransmitter serotonin, whereas the tricyclics and MAOIs work on both serotonin and norepinephrine. In general, the SSRIs appear to demonstrate fewer side effects than do the tricyclics or MAOIs.

In spite of the availability of these medications, it has been estimated that 29% to 46% of patients are treatment-resistant, that is, they show no clinical response or only a partial response to the antidepressant medications. One approach to dealing with treatment-resistant depression is the use of combination therapy or the addition of a “booster drug” to augment the effects of the primary medication(s). Natural compounds, including omega-3 fatty acids, have recently been touted as potential augmentors of antidepressants' effects in treatment-resistant depression.^18,^ ^19^

## Anxiety Disorders

Anxiety disorders typically include panic disorder, generalized anxiety disorder, obsessive-compulsive disorder, post-traumatic stress disorder, and phobias (social phobia, agoraphobia). Anxiety disorders often coexist with other disorders (e.g., depressive disorders), with an estimated 75% of individuals with an anxiety disorder also meeting criteria for at least one other psychiatric illness. The NIMH estimates that within a given year, 19 million American adults between the ages of 18 and 54 years exhibit evidence of an anxiety disorder. Although equal numbers of men and women suffer from obsessive-compulsive disorder and social phobia, approximately twice as many women than men suffer from panic disorder, post-traumatic stress disorder, generalized anxiety disorder, and agoraphobia.^11^

Obsessive-compulsive disorder is estimated to afflict 2% to 3% of the world's population,^20^ including approximately 3.3 million American adults or 2.3% of the population.^11^ It is characterized by obsessive thoughts and compulsive actions (e.g., cleaning, ordering, counting) that are associated with, and often are behavioral attempts to deal with, marked anxiety or distress (DSM-IV). While it can range from mild to severe in intensity, severe obsessive-compulsive disorder can interfere with a person's ability to function.

### Treatment Options

As with other mental health disorders, treatment for anxiety disorders, including obsessive-compulsive disorder, typically involves pharmacologic and psychotherapy treatment approaches. Pharmacologic treatment options have included benzodiazepines, tricyclic antidepressants and MAOIs, but more recently include antidepressant medications such as the SSRIs. Psychotherapeutic strategies that help patients cope with their anxiety include the cognitive-behavioural therapies. For individuals with obsessive-compulsive disorder, complete remission is rare, with most people requiring longterm medication.

## Anorexia Nervosa

Anorexia nervosa is an eating disorder that more commonly afflicts females. An estimated 0.5% to 3.7% of American females suffer from anorexia during their lifetime.^21^ According to DSM-IV, criteria for the diagnosis of anorexia nervosa include an individual's refusal to maintain their body weight at or above a minimally normal weight for their age and height, an intense fear of gaining weight or becoming fat, and a refusal to acknowledge weight loss. Amenorrhea is a common concomitant because of the impact of weight loss on the endocrine system. Other potential problems include heart rhythm disturbances, abdominal abnormalities and anemia. The mortality rate for individuals with anorexia has been estimated to be 0.56% per year.^22^

### Treatment Options

The goal of treatment of individuals with anorexia is weight gain. To achieve this, physicians must restore healthy eating patterns and to address thoughts and feelings concerning body image. This usually requires individual and/or family psychotherapy, and in some instances the use of antidepressant medications.

## Attention Deficit/Hyperactivity Disorder

Attention deficit/hyperactivity disorder (AD/HD) is the most commonly diagnosed mental health disorder in children and adolescents. According to the American Academy of Pediatrics, 4% to 12% of all school-age children are estimated to be affected by AD/HD. Although traditionally associated with school-age children, its prevalence in adults and in preschoolers is being increasingly recognized. Individuals with AD/HD are often unable to focus on assigned tasks, are easily distracted, and are often impulsive and/or hyperactive (DSM-IV). AD/HD is two to three times more common in boys than in girls. DSM-IV recognizes three main subtypes, that is, where clinical features indicate AD/HD predominantly characterized by problems of inattention, hyperactivity/impulsivity, or both.

### Treatment Options

According to the American Academy of Pediatrics, children with AD/HD should be treated with a stimulant medication such as methylphenidate (Ritalin®), dextroamphetamine and/or behavior therapy.^23^ A relatively recent complementary or alternative approach, called EEG-centered biofeedback, aims to teach the child to modulate their own attentional states so that they may adapt more readily to varying environmental expectations regarding behavior.

## Tendencies or Behaviors With the Potential to Harm Others: the Spectrum of Anger/Hostility, Aggression and Violence

Numerous forms of behavior have the potential to harm others. While not always correlated with or culminating in physical action, verbally manifested anger and hostility can be quite disruptive to others. Aggression—any action that causes injury to oneself, others, or objects—is a common feature of many psychiatric disorders. According to the NIMH, more than 90% of individuals who commit suicide have a diagnosable mental health disorder, most commonly a depressive disorder or a substance abuse disorder. In a review of 28 studies, Flannery found that patients who were found to be repetitively violent more frequently than not had received a diagnosis of schizophrenia or a personality disorder; both males and females were equally represented and patients tended to be younger.^24^ Underlying factors that relate to aggression include genetics, environment (i.e., childhood experiences of aggression, parental dysfunction), structural brain abnormalities, and neurotransmitter dysfunction. The focus here is on the broad spectrum of externalizing tendencies (e.g., angry outbursts) or behaviors (e.g., physical aggression) with the potential to harm others.

### Treatment Options

Pharmacological treatment for aggression includes the full spectrum of psychotropic medications including antidepressant medications, neuroleptics, and mood stabilizers. Although these agents have been used successfully in the clinic or in clinical trials, the Food and Drug Administration (FDA) has yet to approve any agent specifically for the treatment of aggression. Approaches to dealing with anger, hostility or violence have also ranged from psychotherapy to incarceration.

## Alcoholism

According to DSM-IV, alcoholism is defined as a destructive pattern of alcohol use leading to significant social, occupational or medical impairment. Alcohol dependence and alcohol abuse are among the most common psychiatric disorders in the general population, with an estimated 8% of adults suffering from alcohol dependence and 5% from alcohol abuse. There appears to be a strong genetic predisposition toward alcoholism—the risk is three to four times higher in a close relative of individuals with alcohol dependence. Alcoholism is sometimes seen as a component of general maladaptive functioning that may include tendencies or behavior with the potential to harm others.

### Treatment Options

Treatment options for individuals with alcoholism include self-help programs and psychosocial therapy. Pharmacotherapy is often used as an adjunct to psychosocial therapy, with the former including medications such as naltrexone that block the alcohol-brain interaction(s).

## Borderline Personality Disorder

Borderline Personality Disorder, according to DSM-IV, is characterized by a pervasive pattern of unstable interpersonal relationships, self-image, and behavior. This instability often interferes with family, work and long-term planning. Although less well known than bipolar disorder or schizophrenia, borderline personality disorder is actually more common, affecting an estimated 2% of adults, including mostly young women. Unlike depression or bipolar disorder where a person can experience the same mood for weeks, a person with borderline personality disorder can exhibit intense periods of anger, depression and anxiety that each last only hours, or maybe a day. The risks of self-injury without suicidal intent or of suicide are both elevated for individuals with this disorder.^25^

### Treatment Options

Borderline personality disorder does not appear to respond well to existing pharmacotherapy approaches. In general, antidepressants and mood stabilizers are used to treat some of the defining symptoms, such as depression or psychosis. A new form of psychotherapy called dialectical behavior therapy, developed specifically to treat patients with borderline personality disorder, has shown promising results.^26^

## Schizophrenia

Schizophrenia is a debilitating condition characterized by perceptual and behavioral disturbances, conceptual disturbances, impaired ability to communicate, and social/occupational dysfunction. According to the NIMH, approximately 2.2 million American adults experience schizophrenia in a given year. Although it afflicts men and women with equal frequency, symptoms usually appear earlier in men (late teens to early twenties) than in women (twenties or early thirties). In general, diagnostic criteria for schizophrenia include at least two of the following “active phase” symptoms that persist for a significant portion of time during a one-month period: delusions, hallucinations, disorganized speech, disorganized or catatonic behavior, or negative symptoms (i.e., affective flattening, alogia, or avolition). Only one of these symptoms is required if it is accompanied with a voice that keeps a running commentary on the person's behavior or thoughts, or if two or more voices are talking with each other.

### Treatment Options

The hallmark of schizophrenia treatment remains antipsychotic medications. These help to reduce symptoms, thus allowing patients to function better and improve their quality of life. Although these medications have been available since the mid-1950's, many have demonstrated significant side effects. A new class of antipsychotic, the atypical antipsychotics, have been available since the late 1980's. These medications, which include clozapine, risperidone, olozapine, quetiapine, ziprasidone and aripiprazole, may be somewhat more effective while producing fewer side effects than the earlier neuroleptic mediations. However, side effects with these medications still occur and often it is necessary to alter dosages or add additional drugs to find the most effective approach.

## Autism

Autism is one of a spectrum of Pervasive Developmental Disorders. It is characterized by severe and pervasive impairment in thinking, feeling, language, and the ability to relate to others. Autism affects an estimated one to two per 1000 individuals, and is generally apparent by the age of three. Although autism is four times more likely to affect boys than girls, girls with autism tend to have more severe symptoms and greater cognitive impairment.^11^

### Treatment Options

There is currently no single treatment approach for individuals with autism. Most healthcare professionals agree that early intervention is important. Pharmacotherapy is sometimes used to treat associated behavioral problems (e.g., aggression, self-injurious behaviour) so that the individual can function more smoothly at home and school. The possible importance of nutrition has also been speculated upon.

## Omega-3 Fatty Acids and Mental Health

Approximately 50% to 60% of the adult brain is composed of lipids (dry weight), of which roughly 35% are phospholipids comprised of UFAs.^27^ Of the UFAs, AA and DHA are found in the highest concentrations. These components of phospholipids have important functions in maintaining nerve cell membrane integrity and fluidity, as well as contributing to neuronal signal transduction. DHA has been shown to be especially important in prenatal brain development, where it appears to play a key role in synaptogenesis.^28,^ ^29^ DHA deficiency has been linked to a number of neurophysiological deficits including cognitive impairment,^30^ decreased visual acuity,^31^ and decreased cerebellar function.^32^

In the adult biosystem, an optimal balance between omega-3 and omega-6 fatty acids is likely essential for normal neuronal function, and it has been suggested that the current imbalance in the omega-6 to omega-3 fatty acid ratio in the North American diet may be in small or large part responsible for the observed increases in disorders of all kinds.^33–45^ This imbalance has likewise suggested an etiologic mechanism by which psychiatric disorders may develop (i.e., abnormalities in PUFA metabolism), and in turn, a rationale for ways to treat them (e.g., PUFA supplementation). In both of these regards, depression and schizophrenia have been the two most investigated and speculated upon psychiatric disorders.

The strong variability in the annual prevalence rates for major depressive disorder, expressed as an almost 60-fold variation across countries,^46^ parallels the wide cross-national differences in mortality rates from coronary artery disease, suggesting that similar risk factors could be involved in both scenarios.^47^ In the 20^th^ century the increasing lifetime risk of depression has co-emerged with a shift in diet involving an increase in omega-6 fatty acid intake and a decrease in the intake of omega-3 fatty acids;^48^ and, this change in the dietary omega-6/omega-3 fatty acid intake ratio has been proposed as being responsible for the increased risk of depression.^49^ At the same time, it has been suggested that these recent changes in the especially Western diet are responsible for the increase in cardiovascular and inflammatory disorders.^49^ To add to this picture, there is some empirical evidence suggesting that major depression is strongly predictive of both coronary heart disease and myocardial infarction;^50,^ ^51^ and, some physical illnesses, such as coronary heart disease or diabetes, appear to occur with increased frequency in patients with major depression and schizophrenia.^52^

The mechanism by which diet may affect health, including depression or cardiovascular disease, is thought to involve low levels of omega-3 fatty acid content in biomarkers (e.g., red blood cells [RBCs]).^48,^ ^53^ An omega-3 fatty acid deficiency hypothesis of depression has been put forward, which has helped justify treatment with omega-3 fatty acid supplementation.^54^ These treatment-related data, as well as those reflecting the possible association of the fatty acid content of biomarkers with the risk of depression, are systematically reviewed in this report.

The membrane phospholipid hypothesis of schizophrenia has been proposed in an attempt to develop a model explaining schizophrenia's etiology.^55^ It describes the presumed biochemical dynamics underpinning a neurodevelopmental theory. Some of the evidence used to support this perspective is systematically reviewed in this review, and so these data are not presented here. Nevertheless, by way of introducing the topic, at least some of the empirical evidence suggests the existence of phospholipid and PUFA metabolic abnormalities in schizophrenia. Experimental investigations have focused on peripheral tissues, including RBCs and skin fibroblasts. Certain data pertaining to phospholipids, which are not systematically reviewed here, have shown that there are reduced levels of phospholipid subtypes (e.g., phosphatidylcholine, phosphatidylethanolamine) in schizophrenic patients.^56^ Since other work has shown increased levels of phosphodiesters (i.e., phospholipid breakdown products) and decreased levels of phosphomonoesters (i.e., used in phsopholipid synthesis) in prefrontal and temporal brain tissue of drug-naïve schizophrenic patients,^57^ it has been proposed that there exists increased phospholipid turnover in the brains of schizophrenic patients.^55^

Numerous studies have assessed the PUFA content of membrane phospholipids in schizophrenia, with controlled studies eligible for inclusion in the present review (see Chapter 2). The ensuing discussions in the literature have centered on whether there is evidence for a depletion of omega-6 and omega-3 fatty acid content in the RBCs and the brain tissue of patients with schizophrenia.^58^ At the same time, some animal studies have shown that essential and non-essential fatty acids in the diet can have a significant impact on neuronal membrane phospholipid composition.^59^ Thus, it has been posited that modifications to diet could mitigate or aggravate an underlying abnormality of phospholipid metabolism.^55^

However, the present review was not conducted specifically to test either of these hypotheses. Rather, the rationale for this two-year project investigating the possible health benefits of omega-3 fatty acids is to systematically review the evidence to aid in the development of a research agenda. Nevertheless, these emerging models regarding depression and schizophrenia do suggest plausible bases for the use of omega-3 fatty acids to treat these two psychiatric disorders. As with depression, treatment-related data, as well as those reflecting the possible association of the fatty acid content of biomarkers with the risk of schizophrenia, are systematically reviewed in this report. Evidence concerning psychiatric disorders and conditions for which there are poorly developed, or no, animal or human models suggesting the use of omega-3 fatty acids as treatment or prevention are also systematically reviewed.