# Appendix F. Additional Acknowledgements

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgement does not reflect endorsement of this report.

- Mimi Butterfield, MD, MPH
- Research Associate
- Staff Physician, Women Veterans Comprehensive Health Center
- Clinical Associate, Department of Psychiatry,
- Duke University
- Durham, NC
- (Past American Psychiatric Association representative)

- Kathryn M. Connor, MD
- Assistant Professor
- Department of Psychiatry and Behavioral Sciences
- Research Director
- Anxiety and Traumatic Stress Program
- Duke University Medical Center
- Durham, NC

- Jonathan Davidson, MD
- Director, Anxiety & Traumatic Stress Program
- Professor, Dept. of Psychiatry and Behavioral Sciences
- Duke University Medical Center
- Durham, NC

- James Friel, PhD
- Professor,
- Department of Human Nutritional Sciences
- Faculty of Human Ecology
- University of Manitoba
- Winnipeg, MB

- Paul Grof, MD, PhD
- Director, Affective Disorders Services,
- Director, Research, Mood Disorders Program
- University of Ottawa Institute of Mental Health Research
- Royal Ottawa Hospital
- Ottawa, ON

- Bill Harris, PhD
- Co-director,
- Lipid and Diabetes Research Center
- Saint Luke's
- Kansas City, MO

- Bruce Holub, PhD
- Professor
- Department of Human Biology and Nutritional Sciences
- University of Guelph
- Guelph, ON
- (Industry representative)

- Matthew Rudorfer MD
- Scientist
- National Institute of Mental Health
- Bethesda, MD

- Richard Shader, MD
- Professor
- Program Director, Pharmacology and Experimental Therapeutics Program
- Dept. of Pharmacology & Experimental Therapeutics
- Tufts University School of Medicine
- Boston, MA

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

- David Atkins MD
- Chief Medical Officer, AHRQ
- Rockville, MD

- Robin Emsley MD
- Head, Department of Psychiatry
- University of Stellenbosch
- Cape Town, South Africa

- James Friel Phd
- Department of Human Nutritional Sciences
- University of Manitoba
- Winnipeg, Manitoba

- Reeta Hakkarainen MB
- National Public Health Institute
- Department of Mental Health and Alcohol Research
- Helsinki, Finland

- Mary V Seeman MD
- Centre for Addiction and Mental Health
- Toronto, Ontario

- Anne Thurn PhD
- Director,
- Evidence-Based Review Program
- Office of Dietary Supplements
- Bethesda, MD