# Appendix E. Evidence Tables

Evidence Table 1. Experimental study evidence for the effects of omega-3 fatty acids on mental health

Author, Year, Location [N sites] | Eligibility Criteria | Prestudy/Baseline Population Characteristics | Intervention (Dose/Type/Source/Delivery) & N Enrolled/Completed | Comparator(s) (Dose/Type/Source/Delivery) & N Enrolled/Completed | Study Quality (internal validity)/Applicability (external validity)/Funding Source
Length & Design
Akkerhuis, 2003, NR [NR] | • Inclusion: NR | • Enrolled/completed: n=NR/NR | •Maximum 6g/d EPA ethyl ester | •placebo (undefined) | • Total quality: Could not evaluate
4 wk “Controlled Study” {15} | • Exclusion: NR | • Age (M & range): NR | •n=NR/NR | •n=NR/NR | •Applicability: X
| | • % Male: NR | | | •Funding: NR
| | • Race: NR
| | • Disease: bipolar disorder
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): NR
Brue, 2001, US [1]: | • Inclusion: DSM-IV for AD/HD | • Enrolled/completed: n=60/51 | •Ritalin users: 1.0 g/d n-3, from NR (flaxseed) capsules 2/d, with breakfast & afternoon snack or dinner | • non-Ritalin users: 1.0 g/d n-3, from NR (flaxseed) capsules 2/d, with breakfast & afternoon snack or dinner | • Jadad total score: 2/5
12 wk parallel RCT {1785} | • Exclusion: serious & pre-existing medical or psychological conditions, stimulant meds besides Ritalin | • Age (M & range): 8.4 (4–12) y | •Diet: NR | •Diet: NR | • Allocation concealment: Unclear
| | • % Male: 86% | •Cointerventions: NR | • n=15/15 | •Applicability: I
| | • Race: NR | •n=15/15 | • non-Ritalin users: 0 g/d n-3, from NR (slippery elm) capsules 2/d, with breakfast & afternoon snack or dinner | •Funding: NR
| | • Disease: AD/HD (DSM-IV) | | • n=15/15
| | • Duration: NR | | • Ritalin users: 0 g/d n-3, from NR (slippery elm) capsules 2x/d, with breakfast & afternoon snack or dinner
| | • Interventions: non-Ritalin pts n-3: ginkgo biloba, melissa officinalis, grapine, dimethy-aminoethanol, L-glutamine; ritalin pts n-3: Ritalin + ginkgo biloba, melissa officinalis, grapine, dimethyaminoethanol, L-glutamine | | • n=15/15
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Emsley, 2002, South Africa [1]: | • Inclusion: 18–55 y, DSM-IV criteria for schizophrenia, received fixed doses of antipsychotics >6 mo, PANSS total score >50 | • Enrolled/completed: n=40/39 | •3 g/d E-EPA, from 3×2 [0.5 g gelcap] capsules/d | • 3 g/d liquid paraffin oil, from 3×2 [0.5 g gelcap] capsules/d | • Jadad total score: 3/5
12 wk parallel RCT {89} | • Exclusion: substance abuse, significant medical conditions | • Age (M & SD): E-EPA: 46.2 (10.6) y; pb: 43.6 (13.9) y | •Diet: unchanged; EPA: 0.56 g/wk to 1.13g/wk | •Diet: unchanged; EPA: 0.56 g/wk to 1.13 g/wk | • Allocation concealment: Unclear
| | • % Male: NR | •n=20/19 | • n=20/20 | •Applicability: III
| | • Race: NR | | | •Funding: Medical Research Council of South Africa (Government), Laxdale Ltd. (Industry)
| | • Disease: schizophrenia disorder (DSM-IV; anti- psychotics >6 mo; PANSS score >50)
| | • Duration: E-EPA: 23.1 (8.5) y; pb: 22.2 (12.4) y
| | • Interventions: chlorpromazine, clozapine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Fenton, 2001, US [1]: | • Inclusion: 18–65 y, DSM-IV criteria for schizophrenia/schizo-affective disorder, no change of meds in prior 30 d, pharmacological tx that conforms to schizophrenia pt outcome research team, residual symptoms defined as ≥ 1 (+) &/or (-) symptom scores >4, total scores >45 with a score of >3 on ≥ 3 (+) or (-) items on the (+) & (-) PANSS scale | • Enrolled/completed: n=90/75 | •3 g/d EPA, from 6 [gelcap] E-EPA capsules/d; 4mg vitamin E per capsule | • 3 g/d mineral oil, from 6 [gelcap] capsules/d; 4mg vitamin E per capsule | • Jadad total score: 4/5
16 wk parallel RCT {84} | • Exclusion: substance dependence/mental retardation, bleeding disorder, fish oil supplements, anticoagulants, cholestyramine, or clofibrate antilipemic agents | • Age (M & SD): 40 (10) y | •Diet: maintain background diet; 0.367 (0.378) g/d, likely EPA or DHA, from fish in diet | •Diet: maintain background diet; 0.367 (0.378) g/d, likely EPA or DHA, from fish in diet | • Allocation concealment: Unclear
| | • % Male: 61% | •n=45/37 | • n=45/38 | •Applicability: I
| | • Race: White 84% | | | •Funding: Stanley Foundation/National Alliance for the Mentally Ill Research Institute (Government); N33: Laxdale Ltd. (Industry); National Institute on Alcohol Abuse & Alcoholism.
| | • Disease: schizophrenia disorder, schizoaffective disorder (DSM-IV)
| | • Duration: NR
| | • Interventions: neuroleptic, risperidone, olanzapine, quetiapine, clozapine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): NS
Fux, 2004, Israel [1]: | • Inclusion: current OCD according to DSM-IV, 18–75 y, currently on stable maximally tolerated dose of SSRI, response to tx but no further improvement over the last 2 mo | • Enrolled/completed: n=11/10 | •2 g/d E-EPA for 6 wk, from 4 [0.5 g gelcap] fish oil capsules/d, 0.2% vitamin E | • 2 g/d liquid paraffin oil for 6 wk | • Jadad total score: 3/5
6 wk crossover RCT {3.64} | Exclusion: unstable medical disease, alcohol/drug abuse, comorbid Axis II psychiatric diagnosis | • Age (M & SD): 33.5 (5) y | •capsules: 96% pure semi-synthetic ethyl-EPA, 4 % other fatty acids | • Capsules/d: NR | • Allocation concealment: Unclear
| | • % Male: 27% | •Diet: NR | •Diet: NR | •Applicability: III
| | • Race: NR | •Cointerventions: NR | • n=11/10 | •Funding: NR
| | • Disease: OCD (DSM-IV; YBOCS: 26.0 (5); HDRS: 11.3 (7); HAM-A: 14.3 (8) | •n=11/10
| | • Duration: 14.1 ± 8 y
| | • Interventions: paroxetine, fluvoxamine, fluoxetine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Gesch, 2002, UK [1]: | • Inclusion: >18 y | • Enrolled/completed: n=231/112 | •0.08 g/d EPA, 0.044 g/d DHA, from 4 capsules/d | • NR, likely trace g/d EPA, trace g/d DHA, from 4 capsules/d (vegetable, oil-based) | • Jadad total score: 5/5
~142-d (mean) parallel RCT {1772} | • Exclusion: NR | • Age (M & range): NR | •Diet: permitted: 1.26 g/d LA, 0.16 g/d GLA | •Diet: NR | • Allocation concealment: Adequate
| | • % Male: NR | •n=NR/57 | • n=NR/55 | •Applicability: II
| | • Race: NR | | | •Funding: Research Charity, Natural Justice (Private), Scotia Pharmaceuticals Ltd (Industry), & Unigreg Ltd. (Industry - supplied nutritional supplements)
| | • Disease: antisocial behaviour status
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Hamazaki, 2002, Thailand, [≥2]: | • Inclusion: elderly residents from farming village & employees of a university, no meds regularly | • Enrolled/completed: n=41/40 | •1.5 g/d DHA, 0.2 g/d EPA, from 10 fish oil capsules/d (3 g/d), after each meal or after two of the three meals/d | • 54.1% LA (n-6), 22.3% oleic acid (n-9), 10.8% palmitic acid (n-7), 6.8% ALA (18:3n-3), 3.7% stearic acid, 0.5% (probably trace) DHA, from 10 fish oil capsules/d (3 g/d mixed plant oil) after each meal or after 2 of 3 meals/d | • Jadad total score: 3/5
2 mo parallel RCT {97} | • Exclusion: myocardial/cerebral infarction, cancer, other disease including alcoholism & severe hypertension | • Age (M & range): NR (50–60) y | •Diet: maintain background diet | •Diet: maintain background diet | • Allocation concealment: Unclear
| | • % Male: 53.6% | •n=20/19 | • n=21/21 | •Applicability: III
| | • Race: Thai 100% | | | •Funding: Science & Technology Agency of the Japanese Government, GoHo Life Sciences International Fund, Japan-US Cooperative Medical Science Program
| | • Disease: healthy volunteers
| | • Biomarkers (S between-grp differences): NS
Hamazaki, 1998, Japan [2]: | • Inclusion: nonsmoking students, good health determined by hx & physical exam, no chronic illness including alcoholism, no meds regularly | • Enrolled/completed: n=59/46 | •1.5 g/d DHA, from 10 fish oil capsules/d, after each meal or after two of the three meals/d | • 54.1% linoleic acid, 22.3% oleic acid, 10.8% palmitic acid, 6.8% alpha linolenic acid, 3.7% stearic acid, 0.5% (probably trace) DHA, from 10 fish oil capsules/d, after each meal or after two of the three meals/d; | • Jadad total score: 3/5
3 mo parallel RCT {236} | • Exclusion: <70% capsule intake, > 3 kg changes in body weight, decrease in RBC DHA (DHA group only) | • Age (mean & range): Toyama: 22 (21–30) y; Kogakkan: NR (20–22) y | •Diet: maintain background diet | •Diet: maintain background diet | • Allocation concealment: Unclear
| | • % Male: 50.8% | •n=29/22 | • n=30/24 | •Applicability: III
| | • Race: likely Asian | | | •Funding: Shorai Foundation for Science & Technology; Special Coordination Funds for promoting science & technology of the Sciences & Technology Agency of the Japanese Government
| | • Disease: healthy volunteers
| | • Biomarkers (S between-grp differences): NS
Hamazaki, 1996, Japan [2]: | • Inclusion: healthy, nonsmoking, volunteers from 2 universities, no meds regularly | • Enrolled/completed: n=53/41 | •1.5 to 1.8 g/d DHA & some EPA, from 10 to 12 fish oil capsules/d (depending on pts weight), after each meal or after two of the three meals/d | • 54.1% LA (n-6), 22.3% oleic acid (n-9), 10.8% palmitic acid (n-7), 6.8% alpha-linolenic acid (18:3n-3), 3.7% stearic acid, 0.5% (probably trace) DHA, from 10 to 12 (depending on pt's weight) capsules/d, from 97% soybean oil + 3% fish oil after each meal or after 2 of 3 meals/d | • Jadad total score: 3/5
3 mo parallel RCT {293} | • Exclusion: NR | • Age (median & range): Toyama: 22 (21–30) y; Yokkaichi: NR (19–20) y | •Diet: maintain background diet | •Diet: maintain background diet | • Allocation concealment: Unclear
| | • % Male: 35.8% | •n=27/22 | • n=26/20 | •Applicability: III
| | • Race: Likely Asian | | | •Funding: Nissin Seifun Foundation (private) & the Japanese-US Cooperative Medical Science Program
| | • Disease: healthy volunteers
| | • Biomarkers (S between-grp differences): NS
Harding, 2003, US [1]: | • Inclusion: age 7–12 y | • Enrolled/completed: 20/20 | •0.18 g/d EPA, 0.12 g/d DHA, from NR capsules, vitamin E and other vitamins (B1, B2, B3, B5, B6, B12, C, A, D3, K) Folic acid, Biotin | • Ritalin | • Total quality: 4/11
4 wk comparative before-after study {1631} | • Exclusion: pts with comorbid disorders, meds use, street drugs, other nutritional or botanical supplements | • Age (M & range): NR (7–12) y | •n=10/10 | • n=10/10 | •Applicability: I
| | • % Male: NR | | | •Funding: NR
| | • Race: NR
| | • Disease: AD/HD (DSM-IV)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Hirayama, 2004, Japan [1]: | • Inclusion: children 6–12 y, suspected or diagnosed AD/HD according to DSM-IV & diagnostic interviews including behavioral observations by psychiatrists | • Enrolled/completed: n=40/40 | •3.6g/wk DHA, 0.7g/wk EPA, from fish oil mixed with soybean milk, bread rolls & steamed bread 2/wk | • olive oil placebo | • Jadad total score: 3/5
2 mo parallel RCT {3041} | • Exclusion: NR | • Age (M & range): n-3: 9 (6.8–11.3) y; pb: 9 (7–10.3) y | •n=20/20 | • n=20/20 | • Allocation concealment: Unclear
| | • % Male: n-3: 80%; pb: 80% | | | •Applicability: III
| | • Race: likely Asian | | | •Funding: Japan Fisheries Association (Government) & Foundation for Total Health & Promotion (Private)
| | • Disease: AD/HD (DSM-IV; N of symptoms, median scores - pts: 11 (7.5–4.5)
| | • Duration: NR
| | • Interventions: methylphenidate, risperidone, carbamazepine, fluvoxamine, sulpiride
| | • Concurrent: Asperger's syndrome, conduct disorder, learning disorder, mood disorder
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Llorente, 2003, US [1]: | • Inclusion: pregnant women, 18–42 y, planned to breastfeed their infants for ≥ 4 mo, not been pregnant >5 times | • Enrolled/completed: n=138/89 | •0.2 g/d DHA, from 1 [algae-derived TG] capsule/d | • 0 g/d DHA, from 1 [algae-derived TG] capsule/d | • Jadad total score: 5/5
4 mo parallel RCT {26} | • Exclusion: chronic medical conditions, taking dietary supplements other than vitamins, smoking | • Age (M & SD): DHA: 31.2 (4.28) y; pb: 31.7 (4.86) y | •n=NR/44 | • n=NR/45 | • Allocation concealment: Adequate
| | • % Male: 0% | | | •Applicability: II
| | • Race: White (82%), Black (NR), Hispanic (NR) | | | •Funding: Martek Biosciences Corporation (Industry)
| | • Disease: N/A (BDI M & (SD): pb: 6.5 (4.2); DHA: 7.1 (4.7))
| | • Biomarkers (S between-grp differences): NS
Marangell, 2003, US [1]: | • Inclusion: 18–65 y, MADRS score >12, HDRS score ≥17, no psychotropic meds for at ≥ 2 wk, only 1 serving of fish/wk | • Enrolled/ | •2 g/d DHA | • 0 g/d DHA (placebo: source undefined) | • Jadad total score: 2/5
6 wk parallel RCT {27} | • Exclusion: comorbid psychiatric or medical illness, tx resistance (lifetime failure of >2 antidepressant trials) | •completed: n=36/35 | •Diet: NR | • Capsules/d: NR | • Allocation concealment: Unclear
| | • Age (M & SD): n-3: 46.9 (11.6) y; pb: 47.9 (11.2) y | •Cointerventions: NR | •Diet: NR | •Applicability: X
| | • % Male: n-3: 22.2%; pb: 17.6% | •n=18/18 | • n=18/17 | •Funding: Martek Biosciences Corporation (Industry)
| | • Race: NR
| | • Disease: major depressive disorder (DSM-IV)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): active = pb (no test reported)
Nemets, 2002, Israel [1]: | • Inclusion: major depressive disorder (DSM-IV); 18–75 y | • Enrolled/completed: n=20/19 | •2 g/d E-EPA from 2 [unclear whether 0.5g or 1 g gelatin capsules] fish oil capsules/d | • 0 g/d E-EPA, from 2g/d placebo, from 0.5g gelatin capsules | • Jadad total score: 4/5
4 wk parallel RCT {101} | • Exclusion: alcohol/drug abuse, unstable medical disease, psychotic features, hypo-mania/mania, comorbid psychiatric diagnosis (except panic disorder, dysthymic disorder, OCD) | • Age (M & range): 53.4 (28–73) y | •E-EPA (ethyl ester of EPA) derived from 96 % pure fish oil, amount probably of EPA & DHA (fish oil, 4% of total dose), vitamin E corresponding to 0.2% of total dose | • Capsules/d: NR | • Allocation concealment: Unclear
| | • % Male: 15% | •Diet: NR | •Diet: NR | •Applicability: III
| | • Race: Middle Eastern | •Cointerventions: NR | • n=10/9 | •Funding: NR
| | • Disease: major depressive disorder (DSM-IV; HDRS ≥18) | •n=10/10
| | • Duration: EPA: 7.6 (7.6) y; pb: 8.0 (6.5) y
| | • Interventions: fluoxetine, mirtazapine, paroxetine, fluvoxamine, citalopram, moclobernide
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Ness, 2003, Wales [1]: | • Inclusion: 37–70 y, males, tx for angina | • Enrolled/completed: n=452/377 | •Diet: advice to eat more fatty fish (mackerel, herring, kipper, pilchard, sardine, salmon or trout), eat more fruit & vegetables, & stress management; 78% pts ate fatty fish wkly or took MaxEPA® capsules if could not tolerate taste of fish | •NR (no fish advice) | • Jadad total score: 2/5
6 mo parallel RCT (one factor in factorial RCT) {1701} | • Exclusion: denying ever having stress related chest pain, awaiting coronary artery bypass surgery, eat oily fish 2/wk, can't tolerate oily fish, serious illness, likelihood of moving from the area | • Age (M & SD): fish advice: 61.1 (6.7) y; no fish advice: 61.4 (6.2) y | •Cointerventions: NR | •Capsules/d: NR | • Allocation concealment: Unclear
| | • % Male: 100% | •n=229/226 | •Diet: no fish, fruit & vegetable, or stress management advice; 14% of pts had fish in the diet | •Applicability: II
| | • Race: NR | | • n=223/219 | •Funding: UK Medical Research Council (Government)
| | • Disease: angina pectoris
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Peet, 2002, England, Scotland [NR, likely 2]: | • Inclusion: 18–70 y, ≥15 on HDRS, on-going tx with antidepressants at adequate dose | • Enrolled/completed: n=70/60 | •4.0 g/d E-EPA (E-EPA), from 2×4 (500 mg gelcap) capsules/d, morning & evening | • 2.0 g/d E-EPA, from 2×2 (500 mg gelcap) capsules/d, 0 g/d E-EPA from 2 × 2 (500 mg gelcap) liquid paraffin capsules/d, morning & evening | • Jadad total score: 4/5
12 wk parallel RCT {87} | • Exclusion: NR | • Age (M & range): 44.8 y | •Diet: NR | •Diet: NR | • Allocation concealment: Adequate
| | • % Male: 15.7% | •Cointerventions: NR | • n=18/16 | •Applicability: II
| | • Race: NR | •n=17/15 | • g/d E-EPA, from 2×1 (500 mg gelcap) capsules/d, 0 g/d E-EPA from 2 × 3 (500 mg gelcap) liquid paraffin capsules/d, morning & evening | •Funding: Laxdale Research Ltd (industry)
| | • Disease: depression (HRSD; score ≥15) | | • n=17/15
| | • Duration: NR | | • 0 g/d E-EPA, from 2×4 (500 mg gelcap) liquid paraffin capsules/d, morning & evening
| | • Interventions: tricyclics, SSRIs, | | • n=18/14
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Peet, 2002, England [9]: | • Inclusion: met DSM-IV criteria for schizophrenia, 18–70 y, time since 1st diagnosis ≤ 20 y, no important medical conditions | • Enrolled/completed: n=122/109 | •4 g/d E-EPA, from 4×2 [gelcap] E-EPA capsules/d, morning & evening | • 2 g/d E-EPA, from 4 [gelcap] E-EPA capsules/d; 2 g/d liquid paraffin, from 4 [gelcap] capsules/d, morning & evening | • Jadad total score: 4/5
12 wk parallel RCT {104} | • Exclusion: NR | • Age (M & range): pb: 39 (22–61) y; EPA 1g: 38 (20–60) y; EPA 2g: 34 (20–62) y; EPA 4g: 37 (20–56) y | •Diet: NR | •Diet: NR | • Allocation concealment: Adequate
| | • % Male: pb: 65%: EPA 1g: 66%: EPA 2g: 71%; EPA 4g: 63% | •Cointerventions: NR | • n=32/24 | •Applicability: II
| | • Race: NR | •n=27/25 | • 1 g/d E-EPA, from 2 [gelcap] E-EPA capsules/d; 3 g/d liquid paraffin, from 6 [gelcap] capsules/d, morning & evening | •Funding: Laxdale Ltd. (Industry)
| | • Disease: schizophrenic disorder (DSM-IV; >50 on PANSS, >15 on Positive Symptoms subscale) | | • Diet: NR
| | • Duration: ≤20 y | | • n=32/29
| | • Interventions: clozapine, olanzapine, risperidone, quetiapine | | • 0 g/d E-EPA, from 4 g/d liquid paraffin, from 4 × 2 [gelcap] capsules/d, morning & evening
| | • Concurrent: NR | | • Diet: NR
| | • Cointerventions: NR | | • n=31/28
| | • Biomarkers (S between-grp differences): NR
Peet, 2001, India [1]: | • Inclusion: DSM-IV diagnosis of schizophrenia, symptomatic with PANSS score ≥40 | • Enrolled/completed: n=30/26 | •2 g/d EPA, from EPA enriched oil | • 2 g/d corn oil (pb) | • Jadad total score: 3/5
3 mo parallel RCT {140} | • Exclusion: significant physical illness or other psychiatric disorders, antipsychotic meds | • Age (M & SD): EPA: 33.4 ± 8.5 y; pb: 36.7 ± 8.1 y | •Diet: NR | • Diet: NR | • Allocation concealment: Adequate
| | • % Male: NR | •Cointerventions: NR | • n=15/12 | •Applicability: III
| | • Race: NR | •n=15/14 | | •Funding: Laxdale Ltd. (Industry)
| | • Disease: schizophrenic disorder (DSM-IV; 100% symptomatic, PANSS score ≥ 40)
| | • Duration: EPA: 5.7 (3.9) y; pb: 7.1 (4.1) y
| | • Interventions: flupenthixol, haloperidol, clozapine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): EPA = ctrl (no test reported)
Peet, 2001, England [1]: | • Inclusion: DSM-IV diagnosis of schizophrenia, symptomatic with a PANSS score ≥ 40, on stable anti-psychotic meds | • Enrolled/completed: n=55/45 | •2 g/d DHA, from DHA enriched oil | • 2 g/d EPA, from EPA enriched fish oil | • Jadad total score: 4/5
3 mo parallel RCT {140} | • Exclusion: physical illness/other psychiatric disorders | • Age (M & range): EPA: 44.2 (11.3) y; DHA: 42.0 (10.6) y; pb: 43.8 (10.8) y | •Diet: NR | • Capsules/d: NR | • Allocation concealment: Adequate
| | • % Male: EPA: 67%; DHA: 75%; pb: 57% | •Cointerventions: NR | •Diet: NR | •Applicability: II
| | • Race: NR | •n=NR/16 | • n=NR/15 | •Funding: Laxdale Ltd (Industry)
| | • Disease: schizophrenic disorder (DSM-IV; PANSS ≥40) | | • 2 g/d corn oil (pb)
| | • Duration: NR | | • Capsules/d: NR
| | • Interventions: antipsychotics, anti-cholinergic meds | | • Diet: NR
| | • Concurrent: NR | | • n=NR/14
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): EPA = DHA = ctrl (no test reported)
Richardson, 2002, UK [1]: | • Inclusion: ability normal range on BAS, reading (BAS) >2 SD below expected level, English as 1st language, endorsement from family physician, above avg. scores for age on parent rating scales (AD/HD) | • Enrolled/completed: n=41/29 | •0.186 g/d EPA, 0.48 g/d DHA, from 8 capsules/d; 0.096 g/d GLA (18:3n-3), 0.864 g/d cis-linoleic acid (n-6), 0.042 g/d AA, vitamin E & 8 mg/d thyme | • 0 g/d EPA, 0 g/d DHA, from 8 capsules/d; olive oil (n-9) | • Jadad total score: 5/5
12 wk parallel RCT {1819} | • Exclusion: use of fatty acid supplements in last 6 mo, eat oily fish >2/wk, hx of neurological/major psychiatric disorder or medical problem, receiving tx for AD/HD | • Age (M & range): 10.25 (8–12) y | •Diet: NR | •Diet: NR | • Allocation concealment: Adequate
| | • % Male: HUFA: 82%; pb: 89% | •Cointerventions: NR | • n=19/14 | •Applicability: II
| | • Race: White 100% | •n=22/15 | | •Funding: Dyslexia Research Trust (Private)
| | • Disease: learning difficulties, AD/HD (DSM-IV)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Stevens, 2003, US [1]: | • Inclusion: 6–13 y, AD/HD diagnosed by clinical psychologist, psychiatrist or paediatrician, thirst/skin problems, with a thirst/skin score of >4 | • Enrolled/completed: n=50/33 | •0.48 g/d DHA, 0.08 g/d EPA, 0.04 g/d AA, 0.096 g/d GLA, 0.024 g/d vitamin E, from 8 [PUFA] capsules/d | • 6.4 g/d olive oil, from 8 capsules/d | • Jadad total score: 3/5
4 mo parallel RCT {3107} | • Exclusion: age, distance from test site, inability to swallow capsules, lack of interest, chronic illness | • Age (M & SD): n-3: 9.5 (1.7) y; pb: 10.1 (2.0) y | •Diet: NR | •Diet: NR | • Allocation concealment: Adequate
| | • % Male: n-3: 88.9%; pb: 86.7% | •Cointerventions: NR | • n=25/15 | •Applicability: I
| | • Race: NR | •n=25/18 | | •Funding: National Institute of Mental Health (Government), Scotia Pharmaceuticals (Industry), National Fisheries Institute (Government)
| | • Disease: ADHD
| | • Duration: NR
| | • Interventions: methylphenidate
| | • Concurrent: thirst/skin symptoms
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): NS
Stoll, 1999, US [2]: | • Inclusion: male or female, 18–65 y, met DSM-IV criteria for bipolar disorder (types I or II), free medical & psychiatric comorbidity, ≥ 1 manic or hypomanic episode within last y | • Enrolled/completed: n=44/30 | •6.2 g/d EPA, 3.4 g/d DHA, from 2×7 [1g gelatin outer] menhaden fish oil capsules/d; 0.2mg t-butylhydroquinone & 2mg tocopherols per capsule | • 9.6 g/d olive oil ethyl ester, from 2×7 [1g gelatin outer] olive oil capsules/d; 0.2mg t-butylhydroquinone & 2mg tocopherols per capsule | • Jadad total score: 4/5
4 mo parallel RCT {213} | • Exclusion: no new psychotherapy tx | • Age (M & SD): n-3: 14.4 (6.8) y; pb: 44.6 (10.4) y | •Diet: NR | •Diet: NR | • Allocation concealment: Adequate
| | • % Male: n-3: 35.7%; pb: 31.25% | •Cointerventions: NR | • n=˜22/16 | •Applicability: I
| | • Race: NR | •n=˜22/14 | | •Funding: NARSAD (Government), capsules & placebo provided by the Fish Oil Test Materials Program (Government)
| | • Disease: bipolar disorder (types I or II) (DSM-IV; ≥ 1 manic or hypomanic episode within past y, major depression, euthymic, mania phase)
| | • Duration: NR
| | • Interventions: carbamazepine, gabapentin, sertraline, lithium, bupropion, alprazolam, divalproex, sertraline, trazodone, lamotrigine, bupropion, paroxetine, clonazepam
| | • Concurrent: NR
| | • Cointerventions: psychiatrist or psychotherapist
| | • Biomarkers (S between-grp differences): N/A
Su, 2003, China [1]: | • Inclusion: major depressive disorder pts (DSM-IV); no other comorbid Axis I or Axis II conditions, Rated >18 on HDRS, no change in meds or psychotherapy 4 wks prior to study, physically healthy, competent to understand study | • Enrolled/completed: n=28/22 | •0.44 g/d EPA, 0.22 g/d DHA, from 2 × 5 (gelcap) fish oil (menhaden) capsules/d; 0.2mg/g t-butylhydroquinone & 0.2mg/g tocopherols (antioxidants); orange flavor | • NR, (probably trace) amount EPA & DHA, from 2 × NR (gelcap) capsules/d, olive oil ester, same antioxidants as n-3 grp | • Jadad total score: 3/5
8 wk parallel RCT {5} | • Exclusion: NR | • Age (M & SD): n-3: 35.2 (11.6) y; pb: 42.3 (10.7) y | •Diet: NR | •Diet: NR | • Allocation concealment: Unclear
| | • % Male: pb: 20%; n-3: 16% | •Cointerventions: NR | • n=14/10 | •Applicability: III
| | • Race: likely Asian | •n=14/12 | | •Funding: National Science Council (Government), China Chemical & Pharmaceutical Co. (Industry)
| | • Disease: major depressive disorder (DSM-IV; >18 HRSD)
| | • Duration: NR
| | • Interventions: fluoxetine equivalent
| | • Concurrent: NR
| | • Cointerventions: psychotherapy
| | • Biomarkers (S between-grp differences): NR
Voigt, 2001, US [1]: | • Inclusion: diagnosis of AD/HD by physician, met DSM-IV criteria for AD/HD, tx successfully with stimulant meds, clinical impairment in social/academic functioning | • Enrolled/completed: n=63/54 | •0.345 g/d DHA, from 1 algae-derived triglyceride capsule/d | • NR | • Jadad total score: 4/5
4 mo parallel RCT {132} | • Exclusion: ineffective tx with stimulant meds, other psychotropics, other childhood psychiatric disorders, dietary supplements other than vitamins, significant life event in last 6 mo, hx of head injuries/seizures, mental retardation/ pervasive developmental disorder, premature birth, exposure to alcohol, tobacco/other drugs in utero, disorder of lipid metabolism/other chronic medical condition | • Age (M & SD): n-3: 9.1 (2.1) y; pb: 9.5 (1.7) y | •Diet: NR | • Capsules/d: NR | • Allocation concealment: Adequate
| | • % Male: n-3: 78%; pb: 78% | •Cointerventions: NR | •Diet: NR | •Applicability: I
| | • Race: n-3: 100% white; pb: 85% | •n=32/27 | • n=31/27 | •Funding: US Department of Agriculture (Government); Martek Biosciences Corporation (Industry): DHA & pb capsules
| | • Disease: AD/HD (DSM-IV)
| | • Duration: NR
| | • Interventions: methylphenidate, dextroamphetamine, amphetamine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): active = pb (no test reported)
Wardle, 2000, England [1]: | • Inclusion: serum cholesterol level >5.2 mM, no serious illness, no current/previous (within 3 mo) use of lipid-lowering meds, physician's permission to participate, signed informed consent | • Enrolled/completed: n=176/155 | •Mediterranean diet, rich in oily fish, monounsaturated fatty acid, fruit & vegetables | • Low fat diet, rich in polyunsaturated fats, low in saturated fats | • Jadad total score: 2/5
12 wk parallel RCT {1522} | • Exclusion: pregnancy, lactation, planning to become pregnant, serum cholesterol level >7.8 mM, use of lipid lowering meds in last 3 mo | • Age (M & SD): Low fat: 52 (11) y; Mediterranean: 54 (11) y; ctrl: 53 (8) y | •Diet: increase in fruit & vegetables & oily fish; reduction in fat to 30% of energy, with substitution of predominantly monounsaturated fats for saturated fats | • Capsules/d: NR | • Allocation concealment: Adequate
| | • % Male: Low fat: 58%; Mediterranean: 44%; ctrl: 43% | •Cointerventions: NR | •Diet: increase polyunsaturated fats & decrease saturated fats in the diet | •Applicability: II
| | • Race: NR | •n=61/53 | • n=59/52 | •Funding: Biotechnology & Biosciences Research Council (Government)
| | • Disease: hypercholesterolemia | | • controls not given specific advice in diet
| | • Duration: NR | | • Capsules/d: NR
| | • Interventions: NR | | • Diet: maintain background diet
| | • Concurrent: NR | | • n=56/50
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Zanarini, 2003, US [1]: | • Inclusion: women, age 18–40 y, met DSM-IV criteria for borderline personality disorder | • Enrolled/completed: n=30/27 | •g/d E-EPA, from 2 [0.5 g] capsules/d | • 0 g/d E-EPA, from 2 (mineral oil) capsules/d | • Jadad total score: 3/5
8 wk parallel RCT {64} | • Exclusion: medically ill, currently on psychotropic drugs, taking E-EPA supplements or had >1–2 servings of fatty fish/wk, abusing alcohol/actively suicidal, met criteria for schizophrenia, schizoaffective disorder, bipolar I or II disorder, currently in a major depressive episode | • Age (M & SD): 26.3 (6.2) y | •Diet: NR | •Diet: NR | • Allocation concealment: Unclear
| | • % Male: 0% | •Cointerventions: NR | • n=10/9 | •Applicability: I
| | • Race: White 76.7% | •n=20/18 | | •Funding: NARSAD
| | • Disease: borderline personality disorder (DSM-IV)
| | • Duration: NR
| | • Interventions: psychotropic medications
| | • Concurrent: NR
| | • Cointerventions: psychotherapy
| | • Biomarkers (S between-grp differences): N/A

length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; pts = participants; n = number of participants; enrolled = n qualified; completed = n completing the study; RCT = randomized controlled trial; wk = week; y = year; g = gram; mo = month; d = day; grp = group; S = significant; NS = nonsignificant; N/A = not applicable; NR = not reported; ctrl = control(s); M = mean; hx = history; pb = placebo; NBD = not broken down; tx = treatment; meds = medication/medicated; SD = standard deviation

Evidence Table 2. Observational study evidence for the association between omega-3 fatty acids and mental health

Author, Year, Location [N sites]: | Eligibility Criteria | Prestudy/Baseline Population Characteristics | Intervention (Dose/Type/Source/Delivery) & N Enrolled/Completed | Comparator(s) (Dose/Type/Source/Delivery) & N Enrolled/Completed | Study Quality (internal validity)/ Applicability (external validity)/Funding Source
Length & Design
Alling, 1984, Sweden [1]: | • Inclusion: pts: chronic alcoholics; ctrl: meds free, no somatic or mental illness | • Enrolled/completed: n=34/34 | • Chronic alcoholics | • Healthy controls | • Total quality: 2/9
N/A (i.e., no followup in cross-sectional studies), Multiple-group cross-sectional study {429} | • Exclusion: NR | • Age (M & range): pts: 54 (41–68) y; ctrl: 39 (22–58) y | • n=13 | • n=21 | • Applicability: III
| | • % Male: 100% | | | • Funding: Swedish Medical Research Council, Merck, Darmastadt (Industry)
| | • Race: NR
| | • Disease: chronic alcoholism
| | • Duration: 19 (10–37) y
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A (i.e., no followup in cross-sectional designs)
Amore, 2003, Italy [2]: | • Inclusion: schizophrenic pts, living mother | • Enrolled/completed: n=366 | • Medicated schizophrenic pts | • Siblings | • Total quality: 6/10
N/A, Case- control study {7} | • Exclusion: refusal either by pt or mother to participate | • Age (M & range): schizophrenic pts: 28 (20–62) y, siblings: 37 (10–67) y, ctrl: 36 (21–60) y | • n=113 | • n=140 | • Applicability: III
| | • % Male: schizophrenic pts: 67.3%, siblings: 46.4%, ctrl: 67.3% | | • Healthy controls | • Funding: NR
| | • Race: NR | | • n=113
| | • Disease: schizophrenia disorder (DSM-IV; Axis I disorders SCID-P)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Arvindakshan, 2003, India [1]: | • Inclusion: NR | • Enrolled/completed: n=73 | • Schizophrenic pts | • Healthy controls | • Total quality: 4/9
N/A, Multiple-group cross-sectional study at baseline of before-after study {1657} | • Exclusion: pts: WAIS-R full-scale IQ <80, high levels of dietary supplements, severe malnourishment, seizure disorder, head injury with loss of consciousness, alcohol & substance abuse & dependence, excessive smoking, type II diabetes, lipid disorders, cardiovascular disease, hypertension, obesity; ctrl: psychosis & major mood disorder, use of meds | • Age (mean & SD): schizophrenics: 29.57 (7.03) y; ctrl: 31.29 (9.86) y | • n=28 | • n=45 | • Applicability: III
| | • % Male: schizophrenic pts: 64.3%; ctrl: 66.7% | | | • Funding: Council of Scientific & Industrial Research, M.L. Vasa, Laxmichand Dayabhai NIH/Fogarty International Center, Interactive Research School for Health Affairs, Vasa Heart Foundation, Bombay, India
| | • Race: NR
| | • Disease: schizophrenic disorder (DSM-IV)
| | • Duration: 10.14 (6.04) y
| | • Interventions: haloperidol, risperidone, olanzapine, clozapine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Arvindakshan, 2003, India, [2]: | • Inclusion: 18–45 y, drug-free FEP pts with schizophrenia or schizoaffective or schizo-phreniform disorder, chronic schizophrenics | • Enrolled/completed: n=97/97 | • Non-medicated schizophrenic pts | • Medicated schizophrenic pts | • Total quality: 2/9
N/A, Multiple-group cross-sectional study {47} | • Exclusion: full scale IQ, dietary supplements, mal-nourishment, seizure disorder, head injury with loss of consciousness, alcohol/substance abuse/dependence, type II diabetes, lipid disorders, CV disease, hyperten-sion, obesity; ctrl: psychosis or major mood disorder; use of meds | • Age (M & SD): ctrl: 29.24 (8.87) y; never-med schizophrenic pts: 29.40 (9.73) y; med schizophrenic pts: 31.31 (SD 10.31) y | • n=20 | • n=32 | • Applicability: III
| | • % Male: ctrl: 55.6%; never-med pts: 60%; med pts: 65.6% | | • Healthy controls | • Funding: Stanley Research Foundation, Washington DC, NIH/Fogarty International, Council of Scientific & Industrial Research, India, Interactive Research School for Health Affairs, Bharati Vidhyapeeth, Pune, India
| | • Race: NR | | • n=45
| | • Disease: schizophrenia, schizoaffective or schizophreniform disorder (DSM-IV)
| | • Duration: non-medicated schizophrenic/schizoaffective/ schizophreniform: 2.47 (4.89) y; medicated schizophrenics: 10.12 (6.92) y
| | • Interventions: risperidone, clozapine, olanzapine, typical antipsychotics
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Assies, 2001, Holland [1]: | • Inclusion: NR | • Enrolled/completed: n=33/33 | • Schizophrenic pts & other diagnoses | • Matched controls | • Total quality: 2/9
N/A, Multiple-group cross-sectional study {149} | • Exclusion: major medical illness, mental retardation, endocrine disorders, & cholesterol-lowering diet or meds | • Age (M & SD): pts: 21.2 (2.39) y; ctrl: 20.9 (2.23) y | • n=19 | • n=14 | • Applicability: III
| | • % Male: pts: 89.5%; ctrl: 85.7% | | | • Funding: NR
| | • Race: NR
| | • Disease: schizophrenia disorder (paranoid, disorganized, undifferentiated), schizoaffective disorder, bipolar disorder, psychotic disorder (DSM-IV)
| | • Duration: schizophrenia pts: 11.2 (10.4) mo
| | • Interventions: olanzapine, pimozide, risperidone, clozapine, paroxetine, fluvoxamine, oxazepam, temazepam, alprazolam, biperideen, trihexyfenidyl, dexetimide, lithium carbonate
| | • Concurrent: cannabis abuse
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Buydens-Branchey, 2003, US [1]: | • Inclusion: DSM-IV criteria cocaine dependence | • Enrolled/completed: n=24/24 | • Aggressive cocaine addicts | • Non-aggressive cocaine addicts | • Total quality: 4/9
N/A, Multiple-group cross-sectional study {3018} | • Exclusion: intravenous substance use, used opiates during y before study, used >0.8g/kg of pure ethanol during y before study | • Age (M & SD): 39.0 (6.1) y (aggressive: 38 y; non-aggressive: 39.6 y) | • Diet: standard diet | • Diet: standard diet | • Applicability: I
| | • % Male: 100% | • n=6 | • n=18 | • Funding: Veterans Administration (Private), NIDA (Government), & NIAAA (Government)
| | • Race: NR
| | • Disease: cocaine addicts (DSM-IV)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: aggression
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Chiu, 2003, Taiwan [1]: | • Inclusion: pts: no medical illness, 18–65 y; ctrl: hx of mental disorder & use of psychotropic agents | • Enrolled/completed: n=40/40 | • Bipolar disorder pts, acute manic phase | • Healthy volunteers | • Total quality: 5/9
N/A, Multiple-group cross-sectional study {39} | • Exclusion: bipolar pts with mixed episode of mood symptoms or other comorbid Axis I disorders, low fat diet or vegetarian | • Age (M & SD): pts: 39 (10.5) y; ctrl: 38.7 (12.8) y | • n=20 | • n=20 | • Applicability: III
| | • % Male: pts: 50%; ctrl: 45% | | | • Funding: National Science Council, China Chemical & Pharmaceutical Company, Taipei, Taiwan
| | • Race: 100% Han
| | • Disease: bipolar I disorder (DSM-IV; manic phase)
| | • Duration: 11.1 (9.6) y
| | • Interventions: benzodiazepine, lithium, valproate, carbamazepine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Edwards, 1998, UK [1]: | • Inclusion: NR | • Enrolled/completed: n=24/24 | • Major depressive episode pts | • Matched healthy controls | • Total quality: 6/10
N/A, Multiple-group cross-sectional study {249} | • Exclusion: physical illness of a nature/ severity suggestive of low omega-3 fatty acid levels | • Age (M & SD): pts: 38.7 (10.2) y; ctrl: 39.4 (10.9) y | • n=10 | • n=14 | • Applicability: II
| | • % Male: pts: 20%; ctrl: 14.3% | | | • Funding: NR
| | • Race: NR
| | • Disease: major depressive episode (DSM-IV; BDI: 26.9 [4.7])
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: antidepressants
| | • Biomarkers (S between-grp differences): N/A
Ellis, 1977, UK [1]: | • Inclusion: NR | • Enrolled/completed: n=16/16 | • Depressive disorder pts | • Non-depressive psychiatric disorder pts | • Total quality: 2/9
N/A, Multiple-group cross-sectional study {1590} | • Exclusion: NR | • Age (M & range): NR | • n=6 | • n=4 | • Applicability: II
| | • % Male: NR | | • Age- & sex-matched healthy controls | • Funding: NR
| | • Race: NR | | • n=6
| | • Disease: endogenous depression, non-depressive psychiatric disorders
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Evans, 2003, US [2]: | • Inclusion: DSM-IV diagnosis of schizophrenia > 6 mo followup; medically healthy | • Enrolled/completed: n=41/41 | • FEP pts | • Healthy controls | • Total quality: 1/9
Multiple-group cross-sectional study at baseline of single prospective cohort study {3101} | • Exclusion: seizures or severe head injury with loss of conscious-ness, hx of substance abuse < 6 mo | • Age (M & SD): FEP: 19.28 (5.1) y; ctrl: 25 (4.2) y | • n=16 | • n=25 | • Applicability: I
| | • % Male: FEP: 87.5% | | | • Funding: NIH/NCCAM (Government) & Stanley Foundation (Private)
| | • Race: NR
| | • Disease: FEP & schizophreniform disorder (DSM-IV)
| | • Duration: < 1 mo
| | • Interventions: risperidone, olanzepine,
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Fehily, 1981, UK [1]: | • Inclusion: NR | • Enrolled/completed: n=NR/60 | • Endogenous depression pts | • Reactive depression pts | • Total quality: 3/9
N/A, Multiple-group cross-sectional study {2241} | • Exclusion: NR | • Age (M & range): endogenous depression: 52 (21–74) y, reactive depression: 38 (22–65) y, other psychiatric disorders: 35 (19–59) y | • n=26 | • n=23 | • Applicability: II
| | • % Male: NR | | • Other psychiatric disorder pts | • Funding: South Thames Regional Health Authority
| | • Race: NR | | • n=11
| | • Disease: endogenous depression, reactive depression, schizophrenia, personality disorders | | • Controls
| | • Duration: NR | | • n=NR
| | • Interventions: hypnotic, tranquilliser, neuroleptic
| | • Concurrent: bipolar disorder
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Fischer, 1992, Germany [1]: | • Inclusion: NR | • Enrolled/completed: n=24/24 | • Schizophrenic pts, high dose | • Schizophrenic pts, low dose | • Total quality: 1/9
N/A, Multiple-group cross-sectional study {346} | • Exclusion: NR | • Age (range): high dose: NR (24–42) y; low dose: NR (35–53) y; untreated: NR (24–33) y; ctrl: NR (21–41) y | • n=9 | • n=7 | • Applicability: III
| | • % Male: high dose: 78%; low dose: 29%; untreated: 50%; ctrl: 100% | | • Schizophrenic pts, untreated | • Funding: NR
| | • Race: NR | | • n=2
| | • Disease: schizophrenic disorder (high dose & low dose monotherapy (phenothiazine or thioxanthene) | | • Controls
| | • Duration: NR | | • n=6
| | • Interventions: perazine, flupentixol, levome-promazine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Hakkarainen, 2004, Finland [1]: | • Inclusion: males, 50–69 y, residing in south-western Finland 1985 | • Enrolled/completed: n=29,133/27,111 | • n=29,133/27,111 | • N/A | • Total quality: 5/10
9 y single prospective cohort study from RCT {3001} | • Exclusion: NR | • Age (M & range): NR | | | • Applicability: III
| | • % Male: NR | | | • Funding: NR
| | • Race: NR
| | • Disease: depression/suicide
| | • Duration: 5–8 y (median=6)
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Hibbeln, 1998, US [1]: | • Inclusion: hx of >5 episodes of violent physical aggression, absence of major medical problems, completion of the DSM-III SCID, abstinent from alcohol, meds free | • Enrolled/completed: n=58/58 | • Violent pts | • Non-violent controls | • Total quality: 2/9
N/A, Multiple-group cross-sectional study {232} | • Exclusion: violent pts: major psychotic or a major affective disorder, head trauma resulting in loss of consciousness for >1h, amphetamine, hallucinogen, or opiate dependence, & current dependence on cocaine/ other illicit drugs; ctrl: 1 episode of violent physical aggression | • Age (M & SD): pts: 38.5 (6.4) y; ctrl: 39.9 (8.0) y | • n=27 | • n=31 | • Applicability: I
| | • % Male: pts: 78%; ctrl: 71% | | | • Funding: NARSAD
| | • Race: NR
| | • Disease: violent (DSM-III-R & RDC; >5 episodes of violent, physical aggression)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: alcohol dependent
| | • Cointerventions: no pts on MAOI's or SSRI's in < 3 mo
| | • Biomarkers (S between-grp differences): N/A
Hibbeln, 1998, US [1]: | • Inclusion: ctrl: negative alcohol breath tests & urine drug testing, no major medical disorders, did not meet criteria for current or lifetime psychiatric or substance use disorder; pts: abstinent for 21–63 d at time of study | • Enrolled/completed: n=176/176 | • Early onset alcoholic pts | • Late onset alcoholic pts | • Total quality: 3/9
N/A, Multiple-group cross-sectional study {233} | • Exclusion: lifetime hx of major psychotic illness or bipolar affective disorder | • Age (M & SD): late-onset alcoholics: 45.5 (8.8) y; early-onset alcoholics: 36.5 (8.7) y; ctrl: 37 (15.7) y | • n=88 | • n=39 | • Applicability: I
| | • % Male: late-onset: 85%; early-onset: 96%; ctrl: 77.5% | | • Healthy controls | • Funding: NARSAD
| | • Race: White, Black | | • n=49
| | • Disease: alcoholics (DSM-III-R; early onset: excessive alcohol use < 25 y age)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Holman, 1995, US [1]: | • Inclusion: pts: females, diagnosed as anorexia nervosa by staff psychiatrist; ctrl: healthy females <19 y | • Enrolled/completed: n=27/27 | • Anorexic pts | • Healthy controls | • Total quality: 1/9
N/A, Multiple-group cross-sectional study {314} | • Exclusion: NR | • Age (M & range): pts: 18.4 (15–24) y, ctrl: 23.5 (1.7) y | • n=8 | • n=19 | • Applicability: I
| | • % Male: 0% | | | • Funding: Carle Foundation (Private), NIH, Harmel Foundation (Private), & by Scotia Pharmaceuticals (Industry)
| | • Race: NR
| | • Disease: anorexia nervosa
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Horrobin, 1989, England, Scotland, Ireland [3]: | • Inclusion: schizophrenia disorder according to DSM-III criteria | • Enrolled/completed: n=203/203 | • Schizophrenic pts | • Controls | • Total quality: 2/9
N/A, Multiple-group cross-sectional study {389} | • Exclusion: NR | • Age (M & range): pts: 40.8 (20–71) y; ctrl: 35.7 (19–66) y | • n=84 | • n=119 | • Applicability: II
| | • % Male: pts: 72.6%, ctrl: 51.3% | | | • Funding: NR
| | • Race: NR
| | • Disease: schizophrenic disorder (DSM-III-R & Research Diagnostic Criteria)
| | • Duration: NR
| | • Interventions: neuroleptic drugs
| | • Concurrent: tardive dyskinesia (AIMS score > 2)
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Iribarren, 2004, US [3]: | • Inclusion: Black or White, males or females, age 18–30 y | • Enrolled/completed: n=5,115/3,581 | • n=5,115/3,581 | • N/A | • Total quality: 5/9
N/A, Single population cross-sectional survey {3076} | • Exclusion: NR | • Age (M & SD): Black men 29.4 (3.7) y; White men 30.5 (3.3) y; Black women 29.6 (3.8) y; White women 30.6 (3.4) y | | | • Applicability: II
| | • % Male: 44.5% | | | • Funding: National Heart Lung & Blood Institute (Government) & the National Institutes of Health (Government)
| | • Race: Black: 45.7%, White: 54.2%
| | • Disease: Hostility
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Kaiya, 1991, Japan [1]: | • Inclusion: NR | • Enrolled/completed: n=107/107 | • Schizophrenic pts | • Other psychiatric disorder pts | • Total quality: 3/9
N/A, Multiple-group cross-sectional study {363} | • Exclusion: NR | • Age (M & SD): ctrl: 36.3 (12.6) y; schizophrenia: 35.7 (9.9) y; other disorders: 36.3 (12.6) y | • Diet: maintain Japanese diet rich in rice & seafood | • Diet: maintain Japanese diet rich in rice & seafood | • Applicability: III
| | • % Male: ctrl: 37.5%; schizophrenia: 61%; other disorders: 37.5% | • n=59 | • n=24 | • Funding: NR
| | • Race: NR | | • Controls
| | • Disease: schizophrenia, affective, & paranoid disorder (DSM-III, DSM-III-R; platelets hyposensitive to prostaglan-din) | | • Diet:maintain Japanese diet rich in rice & seafood
| | • Duration: NR | | • n=24
| | • Interventions: neuroleptics, haloperidol equivalents, antidepressants
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Khan, 2002, US, [3]: | • Inclusion: NR | • Enrolled/completed: n=68/68 | • Medicated schizophrenic pts | • Non-medicated FEP pts | • Total quality: 3/9
N/A, Multiple-group cross-sectional study {71} | • Exclusion: NR | • Age (M & SD): FEP: 22.40 (4.08) y; chronic medicated-schizophrenics: 45.89 (6.32) y; ctrl: 24 (5.6) y | • n=30 | • n=22 | • Applicability: I
| | • % Male: FEP: 81.8%; chronic med-schizophrenics: 100%; ctrl: 87.5% | | • Healthy controls | • Funding: NIH/NCCAM (Government)
| | • Race: NR | | • n=16
| | • Disease: schizophrenia or schizophreniform disorder (DSM-IV)
| | • Duration: FEP: ± 4.5 d; chronic med schizophrenics: 23.55 (7.38) y
| | • Interventions: clozapine, haloperidol, olanzapine, risperidone
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Langan, 1985, US [1]: | • Inclusion: admission to the young adult psychosomatic ward (University of Wisconsin Clinical Sciences Center for anorexia nervosa), availability of plasma leftover after laboratory studies upon admission | • Enrolled/completed: n=28/26 | • Anorexic pts | • Healthy controls | • Total quality: 2/9
N/A, Multiple-group cross-sectional study {419} | • Exclusion: NR | • Age (M & SD): pts: 16.8 (2.3) y; ctrl: 20.7 (1.0) y | • n=17 | • n=11 | • Applicability: I
| | • % Male: pts: 6% ctrl: 0% | | | • Funding: NIH
| | • Race: NR
| | • Disease: anorexia nervosa
| | • Duration: 17.2 (1–39) mo
| | • Interventions: NR
| | • Concurrent: 10/15 pts secondary amenorrhea
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Leask, 2000, UK [2]: | • Inclusion: national birth cohort 1946; national birth cohort 1958 | • Enrolled/completed: n=24,218 | • National birth cohort, 1946 | • National birth cohort, 1958 | • Total quality: 5/10
N/A, Case-control study {3142} | • Exclusion: NR | • Age (M & range): 1946: pts: 43 (NR) y; ctrl: 43 (NR) y; 1958: 16–28 y | • n=5,362 | • n=18,856 | • Applicability: II
| | • % Male: 1946: 52%; 1958: 51% | | | • Funding: Stanley Foundation Grant
| | • Race: NR
| | • Disease: 1946: schizophrenia (DSM-III-R); 1958: schizophrenia (CATEGO)
| | • Duration: N/A
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp diff): N/A
Maes, 1999, Belgium [1]: | • Inclusion: NR | • Enrolled/completed: n=48/48 | • Major depression pts | • Controls | • Total quality: 6/9
N/A, Multiple-group cross-sectional study {209} | • Exclusion: pts: Axis I dx, unipolar major depression, Axis II, borderline & anti-social personality disorder, abnormal heart & lungs XR tx fluoxetine, trazodone, MAOIs, antipsychotic drugs, anticonvulsants, lithium, ECT 1 y before study; ctrl: abnormal lab tests, acute or chronic medical illness, acute infectious/allergic reactions < 2 study, low fat diet/cholesterol lowering drugs, meds affecting fatty acid metabolism/endocrine/ | • Age (M & SD): pts: 52.2 (13.6) y; ctrl: 48.3 (15.2) y | • n=34 | • n=14 | • Applicability: III
| • immune functions, BMI >normal, smokers, not on normal Belgium diet | • % Male: pts: 53%; ctrl: 64% | | | • Funding: Funds for Scientific Research, Vlaanderen, Belgium, the Clinical Research Center Mental Health, Antwerp, Belgium, Staglin Investigator Award.
| | • Race: White 100%
| | • Disease: major depression (DSM-III-R)
| | • Duration: NR
| | • Interventions: antidepressants
| | • Concurrent: NR
| | • Cointerventions: benzodiazepines permitted
| | • Biomarkers (S between-grp differences): N/A
Maes, 1996, Belgium [1]: | • Inclusion: no medical illness | • Enrolled/completed: n=74/74 | • Major depression pts | • Minor depression pts | • Total quality: 6/9
N/A, Multiple-group cross-sectional study {285} | • Exclusion: ethnic minority, mental disorders, low fat diet, Axis I diagnosis beside unipolar depression, substance use/abuse disorder, borderline or antisocial personality disorder, MAOIs, anticonvulsants, lithium or ECT 1 y prior to study, abnormal heart & lungs XR | • Age (M & SD): ctrl: 42.0 (13.6) y; minor depression: 44.5 (14.3) y; major depression: 47.4 (17.0) y | • n=36 | • n=14 | • Applicability: III
| | • % Male: ctrl: 50%; minor: 36%; major: 31% | | • Healthy volunteers | • Funding: Elisabeth Severance Prentiss & John Pascal Sawyer Foundations; National Funds for Scientific Research, IUAP Program, Antwerp, Belgium; USPHS Research Career Scientist Award
| | • Race: 100% Flemish | | • n=24
| | • Disease: major & minor depression (DSM-III-R)
| | • Duration: NR
| | • Interventions: antidepressants, benzodiazepines, haloperidol, chlorazepate
| | • Concurrent: melancholia, adjustment disorder, depressed mood, dysthymia
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Mahadik, 1996, US [2]: | • Inclusion: DSM-III-R diagnosis of schizophrenia, BMD, monitoring of FEP pts for 1st 6 mo of illness, healthy; ctrl: no hx of psychosis, major mood disorder, type II diabetes | • Enrolled/completed: n=26/26 | • Schizophrenic pts | • Bipolar disorder pts | • Total quality: 5/9
N/A, Multiple-group cross-sectional study {278} | • Exclusion: substance abuse/dependence, seizure disorder, head injury/loss of consciousness, family hx Huntington's disease, dementia, mental retardation | • Age (M & SD): schizophrenic: 26.75 (10) y; BMD: 33.00 (6.8) y; ctrl: 33.63 (5.5) y | • n=12 | • n=6 | • Applicability: I
| | • % Male: schizophrenic: 100%; BMD: 91.7%; ctrl: 75% | | • Controls | • Funding: NR
| | • Race: NR | | • n=8
| | • Disease: schizophrenia, bipolar mood disorder (DSM-III-R)
| | • Duration: FEP pts: 4.6 (2.8) d
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
McCreadie, 1997, UK [1]: | • Inclusion: schizophrenic pts | • Enrolled/completed: n=137/137 | • Schizophrenic pts | • Siblings | • Total quality: 4/10
N/A, Case-control study {3143} | • Exclusion: NR | • Age (M & range): NR | • n=45 | • n=92 | • Applicability: II
| | • % Male: pts: 64%; ctrl: NR | | • National surveys: | • Funding: NR
| | • Race: NR | | • Great Britain 1946, n=13,687
| | • Disease: schizophrenia (ICD-9) | | • Scotland 1958, n=1,648
| | • Duration: N/A | | • Scotland 1980, n=1,718
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp diff): N/A
Mellor, 1996, England [1]: | • Inclusion: currently long- term inpatients, receiving neuroleptic meds | • Enrolled/completed: n=20/20 | • Chronic schizophrenia pts | • N/A | • Total quality: 4/10
1 wk single prospective cohort study at baseline of a non-comparative before-after study {2101} | • Exclusion: NR | • Age (M & range): 56.1 (NR) y | • n=20 | | • Applicability: II
| | • % Male: 65% | | | • Funding: Seven Seas Healthcare Ltd., Hull, for MaxEPA® capsules
| | • Race: NR
| | • Disease: chronic schizophrenia (DSM-III-R)
| | • Duration: NR
| | • Interventions: N/A
| | • Concurrent: NR
| | • Cointerventions: N/A
| | • Biomarkers (S between-grp diff): N/A
Mitchell, 1987, New Zealand [1]: | • Inclusion: diagnosed with AD/HD by parents on RBPC & by teachers on CTQ; ctrl: score < P 65 on 4 subscales of hyperactivity | • Enrolled/completed: n=97/97 | • Hyperactive children | • Controls | • Total quality: 4/8
N/A, Multiple-group cross-sectional study {401} | • Exclusion: NR | • Age (M & SD): hyperactive: 9.1 (2.3) y; ctrl: 8.7 (2.3) y | • n=48 | • n=49 | • Applicability: III
| | • % Male: hyperactive: 85.5%; ctrl: 81.8% | | | • Funding: Efamol Research Ltd (Industry), Medical Research Council of New Zealand
| | • Race: European: hyperactive: 92%; ctrl: 92%
| | • Disease: hyperactive (DSM-III, RBPC, CTQ; >P 90 on subscales of RBPC)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Mitchell, 1983, New Zealand [1]: | • Inclusion: NR | • Enrolled/completed: n=43/43 | • Maladjusted (hyperactive) children | • Normal children | • Total quality: 1/8
N/A, Multiple-group cross-sectional study {439} | • Exclusion: NR | • Age (M & range): maladjusted: (7.5–13) y; ctrl: (10–13) y | • n=23 | • n=20 | • Applicability: III
| | • % Male: maladjusted: 91%; ctrl: 50% | | | • Funding: NR
| | • Race: NR
| | • Disease: maladjusted children (Handicapped Pupils & School Health Service Regulations)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Obi, 1979, Nigeria [1]: | • Inclusion: NR | • Enrolled/completed: n=12/12 | • Schizophrenic pts | • Healthy controls | • Total quality: 1/9
N/A, Multiple-group cross-sectional study {458} | • Exclusion: NR | • Age (M & range): schizophrenia: NR (30–50) y; ctrl: NR (22–45) y | • n=6 | • n=6 | • Applicability: III
| | • % Male: NR | | | • Funding: NR
| | • Race: NR
| | • Disease: schizophrenic disorder
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Peet, 1998, England [1]: | • Inclusion: suffering from a major depressive episode, unipolar illness, 18–65 y | • Enrolled/completed: n=30/30 | • Major depressed pts, unipolar | • Healthy controls | • Total quality: 4/9
N/A, Multiple-group cross-sectional study {251} | • Exclusion: NR | • Age (M & SD): pts: 47.4 (11.0) y; ctrl: 47.0 (10.3) y | • n=15 | • n=15 | • Applicability: II
| | • % Male: pts: 53%; ctrl: 53% | | | • Funding: NR
| | • Race: NR
| | • Disease: major depressive episode, unipolar illness (DSM-IV)
| | • Duration: NR
| | • Interventions: dothiepin, paroxetine, fluoxetine, trazodone, lofepramine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Peet, 1997, UK [1]: | • Inclusion: schizophrenic pts; ctrl: non-psychiatric pts | • Enrolled/completed: n=110/110 | • Schizophrenic pts | • Non-psychiatric controls | • Total quality: 3/10
N/A, Case-control study {3145} | • Exclusion: NR | • Age (M & range): pts: 34 (NR) y; ctrl: NR | • n=55 | • n=55 | • Applicability: II
| | • % Male: pts: 85% ctrl: (NR) | | | • Funding: NR
| | • Race: NR
| | • Disease: schizophrenia (DSM-IV)
| | • Duration: NR
| | • Interventions: N/A
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Peet, 1995, UK [1]: | • Inclusion: pts: neuroleptic-treated, physically healthy, schizophrenia (DSM-III criteria); ctrl: hospital staff, no hx of mental disorder, on no meds | • Enrolled/completed: n=39/39 | • Schizophrenic pts with tardive dyskinesia | • Healthy controls | • Total quality: 3/9
N/A, Multiple-group cross-sectional study {303} | • Exclusion: NR | • Age (M & range): pts: 55 (28–75) y | • n=23 | • n=16 | • Applicability: II
| | • % Male: pts: 69.5% | | | • Funding: NR
| | • Race: NR
| | • Disease: schizophrenia disorder (DSM-III-R)
| | • Duration: >5 y
| | • Interventions: chlorpromazine
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Ranjekar, 2003, India [2]: | • Inclusion: schizophrenics or BMD | • Enrolled/completed: n=72/72 | • Schizophrenic pts | • Bipolar disorder pts | • Total quality: 4/9
N/A, Multiple-group cross-sectional study {3094} | • Exclusion: WAIS-R full scale IQ<80, high use of diet supplements, undernourishment or malnourishment, seizure disorder, head injury, sub-stance abuse/dependence, type II diabetes, lipid disorders, CV disease, hypertension, family hx of same, obesity; ctrl: medications/substance abuse | • Age (M & SD): ctrl: 39.72 (8.87) y; schizophrenics: 37.32 (7.18) y; BMD: 40.8 (8.29) y | • n=31 | • n=10 | • Applicability: III
| | • % Male: 100% | | • Healthy controls | • Funding: Mr. M.L. Vasa, Laxmichand Dayabhai (Export) Co. (Private)
| | • Race: NR | | • n=31
| | • Disease: schizophrenic disorder & BMD (DSM-IV)
| | • Duration: NR
| | • Interventions: atypical antipsychotics, antidepressants
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Sasaki, 2000, Japan [2]: | • Inclusion: schizophrenic pts | • Enrolled/completed: n=337/337 | • Schizophrenic pts | • Healthy siblings | • Total quality: 5/10
N/A, Case-control study {3144} | • Exclusion: NR | • Age (M & range): pts: 32 ± 9 y; healthy siblings: 34.6 ± 8.4; ctrl: 31 ± 10 y | • n=100 | • n=37 | • Applicability: III
| | • % Male: pts: 60%; healthy siblings: 59.5%; ctrl: 46% | | • Healthy controls | • Funding: Ministry of Welfare of Japan (Government)
| | • Race: Asian | | • n=200
| | • Disease: schizophrenia (DSM-IV)
| | • Duration: N/A
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp diff): N/A
Silvers, 2002, New Zealand [122 geographic areas; 11,921 households]: | • Inclusion: resident of New Zealand in 1996 & 1997 | • Enrolled/completed: n=12,506/4,644 | • n=12,506/4,644 (adults age > 15 y) | • N/A | • Total quality: 5/9
N/A, Single population cross-sectional survey {1483} | • Exclusion: NR | • Age (M & range): grp 1: NR (15–24) y; grp 2: NR (25–44) y; grp 3: NR (45–64) y; grp 4: >65 y | | | • Applicability: III
| | • % Male: NR | | | • Funding: New Zealand Ministry of Health (Government)
| | • Race: NR
| | • Disease: adults age >15 y
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Stevens, 1995, US [1]: | • Inclusion: males, 6–12 y, healthy with diagnosis of or suspected AD/HD, PTCRS score >15; ctrl: PTCRS <15 | • Enrolled/completed: n=96/96 | • Hyperactive (AD/HD) boys | • Normal boys | • Total quality: 3/8
N/A, Multiple-group cross-sectional study {301} | • Exclusion: NR | • Age (M & SD): AD/HD: 9.1 (2.0) y; ctrl: 9.1 (2.3) y | • n=53 | • n=43 | • Applicability: I
| | • % Male: 100% | | | • Funding: State of Indiana (Government)
| | • Race: NR
| | • Disease: AD/HD (≥15 PTCRS)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Suzuki, 2004, Japan [1]: | • Inclusion: lung cancer, diagnosis confirmed by histological examination, physically capable of completing questionnaires, no cognitive impairment, ability to provide written consent, problem with pts participation judged by physician | • Enrolled/completed: n=902/771 | • n=902/771 | • N/A | • Total quality: 7/9
N/A, Single population cross-sectional survey {3038} | • Exclusion: NR | • Age (M & SD): HADS-D ≤4: 64.0 (9.5) y; HADS-D ≥5: 64.3 (9.1) y | | | • Applicability: III
| | • % Male: HADS-D ≤4: 72.2%; HADS-D ≥5: 72% | | | • Funding: Japanese Ministry of Health, Labor, & Welfare (Government)
| | • Race: likely Asian
| | • Disease: lung cancer
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Tanskanen, 2001, Finland [1]: | • Inclusion: 25–64 y | • Enrolled/completed: n=3,004/1,767 | • n=3,004/1,767 | • N/A | • Total quality: 4/9
N/A, Single population cross-sectional survey {142} | • Exclusion: NR | • Age (M & range): 25–64 y | | | • Applicability: III
| | • % Male: NR | | | • Funding: NR
| | • Race: NR
| | • Disease: N/A
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Tanskanen, 2001, Finland [1]: | • Inclusion: 25–64 y, Finnish adults | • Enrolled/completed: n=5,105/3,204 | • n=5,105/3,204 | • N/A | • Total quality: 3/9
N/A, Single population cross-sectional survey {1874} | • Exclusion: NR | • Age (M & range): 48.8 (NR) y | | | • Applicability: III
| | • % Male: NR | | | • Funding: NR
| | • Race: NR
| | • Disease: N/A (20% mild depressive symptoms, 6.3% moderate, 1.5% severe)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Tiemeier, 2003, Holland [1]: | • Inclusion: NR | • Enrolled/completed: n=682/682 | • Depressive disorders | • Depressive symptoms | • Total quality: 5/9
N/A, Multiple-group cross-sectional study {1457} | • Exclusion: NR | • Age (M & range): subthreshold depressive pts: 73.9 (61–93) y; depressive disorder pts: 73.7 (61–97) y; ctrl: 72.5 (61–101) y | • n=106 | • n=115 | • Applicability: III
| | • % Male: subthreshold depressive pts: 22.7%; depressive disorder pts: 27.4%; ctrl: 41.4% | | • Controls | • Funding: Ministry of Education & Science; Ministry of Health, Welfare, & Sports; Grant from Numico research
| | • Race: NR | | • n=461
| | • Disease: depressive disorders (major depression, dysthymia, minor depression) (DSM-IV; >16 on CES-D)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Vaddadi, 1996, Australia [3]: | • Inclusion: NR | • Enrolled/completed: n=114/52 | • Schizophrenic pts without TD | • Schizophrenic pts with TD | • Total quality: 1/9
N/A, Multiple-group cross-sectional study at baseline of multiple prospective cohort study {282} | • Exclusion: hx of established neurological illness, developmental handicap or currently receiving nonsteroidal anti-inflammatory drugs | • Age (M & range): pts: 35.4 (18–64) y | • n=40 | • n=32 | • Applicability: III
| | • % Male: pts: 75% | | • Normal controls | • Funding: Scotia Pharmaceuticals Ltd. Guildford, UK (Industry)
| | • Race: NR | | • n=39
| | • Disease: schizophrenia & schizoaffective disorder (DSM-III-R)
| | • Duration: 12.3 (8.9) y
| | • Interventions: neuroleptics
| | • Concurrent: tardive dyskinesia (TD)
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Vancassel, 2001, France [1]: | • Inclusion: no hx of endocrine or systemic disease | • Enrolled/completed: n=33/33 | • Autistic children | • Mentally retarded children | • Total quality: 4/9
N/A, Multiple-group cross-sectional study {131} | • Exclusion: NR | • Age (M & range): autism: 8.3 (3–17) y; mentally retarded: 8.7 (1–19) y | • n=15 | • n=18 | • Applicability: III
| | • % Male: autism: 73.3%; mentally retarded: 72.2% | | | • Funding: INRA, INSERM U316, INSERM Network 4R002B, Foundation France Telecom
| | • Race: NR
| | • Disease: autism, mentally retarded (DSM-III-R & DSM-IV)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Virkkunen, 1987, Finland [1]: | • Inclusion: committed ≥1 violent crime, ≥2 episodes of loss of control of aggressive impulses resulting in serious assault/bodily harm, DSM-III criteria for antisocial personality/intermittent explosive disorder/ alcohol abuse | • Enrolled/completed: n=50/50 | • Violent antisocial personality disorder pts | • Intermittent explosive disorder pts | • Total quality: 4/9
N/A, Multiple-group cross-sectional study {397} | • Exclusion: mentally retarded (IQ < 68), chromosome abnormality, antisocial personality, no violent tendency, schizophrenia | • Age (M & range): antisocial: 28.5 (12.9) y; explosive: 36.8 (16.4) y; ctrl: 33 (11.1) y | • n=15 | • n=19 | • Applicability: III
| | • % Male: 100% | | • Healthy controls | • Funding: NR
| | • Race: NR | | • n=16
| | • Disease: violent, alcohol abuse, epilepsy, borderline personality disorder, paranoid personality disorder, antisocial personality disorder (DSM-III; committed ≥1 violent crime, ≥2 episodes of loss of control)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Woo, 2002, China [NR]: | • Inclusion: age >70 y | • Enrolled/completed: n=2,032/1,171 | • n=2,032/1,171 | • N/A | • Total quality: 4/10
36 mo single prospective cohort study {1777} | • Exclusion: NR | • Age (M & SD): 80 (7.1) y | | | • Applicability: III
| | • % Male: 49.2% | | | • Funding: NR
| | • Race: Asian 100%
| | • Disease: N/A
| | • Duration: N/A
| | • Interventions: N/A
| | • Concurrent: N/A
| | • Cointerventions: N/A
| | • Biomarkers (S between-grp differences): N/A
Yang, 1999, Taiwan [1]: | • Inclusion: pts: met DSM-IV AD/HD diagnosis, >80% on standard, Child Activity Level Form ctrl: 4–8 y, verified in good health | • Enrolled/completed: n=52/52 | • AD/HD children | • Healthy control children | • Total quality: 5/8
N/A, Multiple-group cross-sectional study {1962} | • Exclusion: ctrl: children with suspected case of AD/HD | • Age (M & SD): ctrl: 5.2 (1.1) y; pts: 5.7 (0.9) y | • n=20 | • n=32 | • Applicability: III
| | • % Male: ctrl: 91%; pts: 90% | | | • Funding: Chun Qing Infant & Child Nutritional Research Foundation
| | • Race: likely Asian
| | • Disease: AD/HD (DSM-IV; >80% on Standard, Child Activity Level Form)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Yao, 2002, US [1]: | • Inclusion: pts: IQ ≥75, 12–45 y, no hx of neuroleptic tx, DSM-IV criteria for schizophrenia, schizophreniform, schizoaffective disorder; ctrl: 12–45 y, no hx or current psychiatric/neurologic disorder | • Enrolled/completed: n=22/22 | • Drug-naïve, FEP schizophrenic pts | • Normal controls | • Total quality: 3/9
N/A, Multiple-group cross-sectional study {1459} | • Exclusion: pts: substance use within 4 wk of study, medical illness, hyperlipidemia, starvation < 2 wk, neurologic disorders, head injury with loss of consciousness, psychosis >2 y, comorbidity for DSM-IV Axis I diagnosis; ctrl: hx of psychosis or major mood disorder, family hx of psychosis/major mood disorder | • Age (M & range): pts: 26 (17–44) y; ctrl: 26 (19–39) y | • n=11 | • n=11 | • Applicability: I
| | • % Male: pts: 54.5%; ctrl: 54.5% | | | • Funding: National Institute of Mental Health, NARSAD Young Investigator Award, Office of Research & Development, Department of Veteran Affairs, Highland Drive VA Pittsburgh Healthcare System
| | • Race: NR
| | • Disease: schizophrenia, schizophreniform, schizoaffective disorder (DSM-IV)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A

length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; pts = participants; n = number of participants; enrolled = n qualified; completed = n completing the study; RCT = randomized controlled trial; wk = week; y = year; g = gram; mo = month; d = day; grp = group; S = significant; NS = nonsignificant; N/A = not applicable; NR = not reported; ctrl = control(s); M = mean; meds = medication/medicated; SD = standard deviation

Evidence Table 3: Cross-national ecological analytic evidence for the association between omega-3 fatty acids and mental health

Author, Year, Location [N sites]: | Eligibility Criteria | Prestudy/Baseline Population Characteristics | Intervention (Dose/Type/Source/Delivery) & N Enrolled/Completed | Comparator(s) (Dose/Type/Source/Delivery) & N Enrolled/Completed | Study Quality (internal validity)/Applicability (external validity)/Funding Source
Length & Design
Christensen 1988, [8 countries]: | • Inclusion: NR | • Enrolled/completed: NR | • Diet: saturated fatty acids, n-3 and n-6 fatty acids: fat from land animals & birds; 1.7–32.1% of energy derived from fat from land animals & birds; EPA, DHA & ALA: fat from vegetables, fish & seafood; 7.5–14.5% of energy derived from fat from vegetables, fish & seafood | • N/A | • Total quality: 3/9
N/A, Cross-national ecological analysis {3125} | • Exclusion: NR | • Age (M & range): NR | • n=8 countries | | • Applicability: III
| | • % Male: NR | | | • Funding: NR
| | • Race: NR
| | • Disease: schizophrenia
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Hibbeln, 2002, US [23 countries]: | • Inclusion: major postpartum depressive symptoms | • Enrolled/completed: n=14,532/14,532 | • n=23 countries (total) | • N/A | • Total quality: 7/9
N/A, Cross-national ecological analysis {59} | • Exclusion: NR | • Age (M & SD): 28.4 (1.3) y | | | • Applicability: III
| | • % Male: 0% | | | • Funding: NARSAD
| | • Race: NR
| | • Disease: major postpartum depressive symptoms (EPDS; EPDS score >12/13)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Hibbeln, 2001, [26 countries]: | • Inclusion: countries with data on seafood consumption & deaths due to homicide (WHO) | • Enrolled/completed: NR | • n=26 countries (total) | • N/A | • Total quality: 4/9
N/A, Cross-national ecological analysis {1503} | • Exclusion: US (rate of death due to homicide too high) | • Age (M & range): NR | | | • Applicability: III
| | • % Male: NR | | | • Funding: NR
| | • Race: NR
| | • Disease: homicide deaths
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Hibbeln, 1998, US [9 countries]: | • Inclusion: ≥ 1 depressive episode, including grief lasting > 1 y | • Enrolled/completed: NR | • n=9 countries | • N/A | • Total quality: 2/9
N/A, Cross-national ecological analysis {239} | • Exclusion: criteria for a manic episode | • Age (M & range): NR (18–65) y | | | • Applicability: III
| | • % Male: US: 41%, Alberta: 41%, Puerto Rico: 43%, France: 38%, Germany: 48%, Italy: 47%, Lebanon: 43%, Taiwan: 52%, Korea: 48%, New Zealand: 34% | | | • Funding: NR
| | • Race: NR
| | • Disease: major depression (DSM-III)
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Noaghiul, 2003, [11 countries (bipolar disorder), 14 countries (schizo-phrenia disorder]: | • Inclusion: community samples with clearly defined sample population, large sample size, age 18–64 y, appropriate sampling methods, structured diagnostic instruments | • Enrolled/completed: NR | n=11 countries (bipolar disorder), 14 countries (schizophrenia) | • N/A | • Total quality: 4/9
N/A, Cross-national ecological analysis {3020} | • Exclusion: NR | • Age (M & range): NR (18–64) y | | | • Applicability: III
| | • % Male: NR | | | • Funding: NR
| | • Race: NR
| | • Disease: Bipolar Disorder/Schizophrenia
| | • Duration: NR
| | • Interventions: NR
| | • Concurrent: NR
| | • Cointerventions: NR
| | • Biomarkers (S between-grp differences): N/A
Peet, 2004, UK [8 countries] | • Inclusion: data in data-bases on international variations in outcome of schizophrenia, prevalence of depression, patterns of food usage | • Enrolled/completed: 8/8 (countries) | • n=8 countries | • N/A | • Total quality: 3/9
N/A, Cross-national ecological analysis {3128} | • Exclusion: NR | • Age (M & range): NR | | | • Applicability: III
| | • % Male: NR | | | • Funding: Laxdale Ltd (Industry)
| | • Race: NR
| | • Disease: Schizophrenia/Depression
| | • Duration: NR
| | • Biomarkers (S between-grp differences): N/A

length = intervention/exposure length; design = research design; intervention = intervention/exposure; disease = diagnosis & severity; duration = time since diagnosis; concurrent = concurrent conditions; pts = participants; n = number of participants; enrolled = n qualified; completed = n completing the study; RCT = randomized controlled trial; wk = week; y = year; g = gram; mo = month; d = day; grp = group; S = significant; NS = nonsignificant; N/A = not applicable; NR = not reported; ctrl = control(s); M = mean; meds = medication/medicated; SD = standard deviation