# Appendix C. Data Assessment and Data Abstraction Forms

## Relevance Assessment Form

Please respond to each question.* Use the comments box to identify duplicate reports, a key review whose references should be checked, anomalies, etc.

a. Inclusion criteria:
  1. Does this report describe a study involving human participants?
  YES Can't Tell NO
  2. Does this study evaluate the role of: a. omega-3 fatty acid intake (diet and/or supplementation) as an intervention/exposure; or b. omega-3 or omega-6/omega-3 fatty acid content of biomarkers?
  YES Can't Tell NO
  3. Is the purpose of the study to investigate: a. the effect (e.g., efficacy, effectiveness) of omega-3 fatty acid intake (diet and/or supplementation) as (primary or supplemental) treatment for --or the association of their intake with the onset, continuation or recurrence of-- psychiatric disorders or symptoms/behaviors (e.g., depressive, bipolar, anxiety or eating disorders; ad/hd; schizophrenia; anxiety, depression, aggression/hostility, impulsivity or suicidal behavior); or b. the association of the omega-3 or omega-6/omega-3 fatty acid content of biomarkers with the onset, continuation or recurrence of these psychiatric conditions?
  YES Can't Tell NO
  4. If this is a study investigating the evidence concerning the efficacious use of omega-3 fatty acids as a primary or supplemental treatment for psychiatric disorders or symptoms/behaviors, or a study investigating the association of the omega-3 or omega-6/omega-3 fatty acid content of biomarkers with the onset, continuation or recurrence of psychiatric disorders or symptoms/behaviors, what type of research design was employed?*
  CONTROLLED (or addresses Question 2) Can't Tell UNCONTROLLED
b. Exclusion criterion:
  5. If this is a narrative or systematic review, opinion piece or editorial, letter, guideline or policy paper, etc., does it exclusively describe studies already reported elsewhere (i.e., it does not present any empirical evidence published for the first time)?
  YES Can't Tell NO
c. Context:
  6. The study appears to also or instead concern omega-3 fatty acids as an intervention/exposure associated with the following human health/disease domains (select at least one option; click on all that apply):
  __transplantation __neurology
  __cancer __eye health
  __child/maternal health __none of the above
  7. Is this report written in English?
  YES NO
  8. Comments box

*Question 4 alone was used at level 3 screening; screening levels 1 and 2 each employed questions 1–3 and 5–8.

## Data Abstraction Form

Instructions: Please answer each question. Selecting response options means clicking on them. A text box (“BOX”) requires that you provide specific data, and allows you to provide clarification, as needed (e.g., when the available data are not straightforward). When data are not reported (= NR), the question does not apply (= N/A), you cannot tell what/where the data are in the report (= CT), the data are not broken down (= NBD) to permit the required abstraction (e.g., by study group), or you have no comment to make (= NC), type the code in the BOX.

‘Participants’ refers to study participants. ‘Group’ refers to a study group, arm or cohort or, in a crossover design, a study phase. Often, you will be asked to abstract ‘full’ sample data as well as by group. If requested group data are not available, abstract full sample data and label it as such.

If more than one report describes this study, draw on each to abstract study data. This means that, for question 2, record all of the relevant report Refid#s, and for question 3, record all of the relevant reports' data. When you are abstracting data from multiple reports for a given study, point out any inconsistencies.

If the research report describes more than one unique study, answer in this eForm all the questions for the first reported study while immediately notifying the review manager that another data abstraction form is required.

BOX = single box at end of list

All abstractors access each level, for verification possibilities.

Each abstractor assigned level(s), and Refids

Initials of reviewer: BOX

Reference identification #s (Refid#s) of all report(s) referring to this study, including duplicate reports, data-splitting reports, additional follow-ups, re-analyses, etc.: BOX

First author's last name, year of publication, country(s) in which study conducted (from each relevant report), [# study sites] (e.g., Smith, 1988, Canada [1 site]): BOX

Number of unique, review-relevant studies that this report describes (if more than one, notify review manager): BOX

Publication status, per report/Refid# referring to this study (e.g., Refid 3000=journal publication, Refid 6=conference abstract):

Peer-reviewed journal publication

Journal publication

Conference abstract/poster

Book

Book chapter

HTA/technical report

Thesis

Unpublished document

Study sponsor's internal report

Internet document/material

Other

BOX

Identity of funding source(s), including category per source (e.g., government, industry, private/non-industry, hospital), and what each provided: BOX

Question(s) addressed (select all that apply):

a. Are omega-3 fatty acids efficacious as primary treatment for __________?
b. Are omega-3 fatty acids efficacious as supplemental treatment for __________?
c. Is omega-3 fatty acid intake, including diet and/or supplementation, associated with the onset of _________?
d. Is omega-3 fatty acid intake, including diet and/or supplementation, associated with the continuation of _________?
e. Is omega-3 fatty acid intake, including diet and/or supplementation, associated with the recurrence of _________?
f. Is the onset of ________ associated with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers?
g. Is the continuation of ________ associated with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers?
h. Is the recurrence of ________ associated with the omega-3 or omega-6/omega-3 fatty acid content of biomarkers?
i. Are adverse events/side effects or contraindications associated with the intake of specific sources (e.g., marine, plant), types (e.g., DHA, EPA, ALA) or doses of omega-3 fatty acids, including in specific subpopulations such as diabetics?

Psychiatric disorder(s)/symptom(s)/sign(s)/behavior(s) investigated as primary or exclusive focus of the study (select all that apply):

a. Anxiety
b. Depression/unipolar
c. Bipolar/manic depression
d. Eating
e. ADHD or key symptoms/signs (e.g., impulsivity)
f. Antisocial personality
g. Aggression/violence
h. Stress
i. Alcoholism or other drug abuse
j. Borderline personality
k. Schizophrenia/schizoaffective
l. Autism
m. Suicide
n. Other: BOX

Study design (select one):

a. RCT parallel design
b. RCT crossover design
c. RCT factorial design
d. Controlled clinical trial (non-RCT)
e. Multiple prospective cohorts
f. At least one prospective cohort and one retrospective cohort
g. Case-control
h. Cross-sectional
i. Before-after (pre-post)
j. Single prospective cohort
k. Single retrospective cohort
l. Case series (noncomparative)
m. Case study
n. Sequential
o. Other: BOX

Any notable details (e.g., restricted randomization; blocking size) or problems (i.e., no or inappropriate run-in or washout procedures or durations; study stopped prematurely): BOX

Full sample eligibility criteria (e.g., population [e.g., pediatric vs adult, required diagnosis, permitted or mandatory comorbid conditions], intervention(s)/medication(s) [mandated vs permitted], cointervention(s) [mandated vs permitted]) (complete both):

Inclusion criteria: BOX

Exclusion criteria: BOX

Were the same eligibility criteria employed with reference to each study group? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a single group study)

Adequacy of reporting of eligibility criteria (select one):

a. Likely adequate (= not inadequate)
b. Likely inadequate (= missing, incomplete or conflicting data)

Adequacy of eligibility criteria:

a. Likely adequate (= not inadequate)
b. Likely inadequate (e.g., the inclusion criteria will not lead to the study of the target population the investigators intend to study; populations with psychiatric diagnoses/conditions outside the investigators' intended scope, yet who show the same symptoms/signs as the target population, have not been identified as requiring exclusion)

Sample sizes (complete all):

Total # individuals screened: BOX

# selected/allocated participants (full [e.g., n=12]; by group [e.g., group 1 n=5; group 2 n=7]): BOX

# completers (= final followup)/total (full; per group) (e.g., group 1: n=4/5; group 2: n=6/7): BOX

Settings (complete both):

Type(s) of setting (e.g., tertiary care hospital vs community facility) (full; by group): BOX

Proportion of participants in relatively controlled (e.g., inpatients) settings during study (full; by group): BOX

Study period (complete all):

Intervention length (d, wk, mo, y) (by group only if it varies): BOX

Study duration, including units (h, d, wk, mo) (includes intervention length plus run-in period duration, washout duration[s], etc.): BOX

Run-in duration/protocol: BOX

Washout duration/protocol: BOX

Did participants in each study group receive the intervention/exposure for the same length of time? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a cross-sectional survey)

Was the same study procedure employed with reference to each study group? (select one)

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable

Were participants in each study group assessed at the same number of followups, and with the same timing, during the study (select one)?

a. Yes
b. No
c. Unclear
d. Not reported
e. Not applicable (e.g., a cross-sectional survey)

Number and timing of followups (e.g., at 6 mo; at 6 y of age), and any definition of the ‘length of followup required to observe an/no impact of the exposure/intervention:’ BOX

Adverse events, and losses to followup (complete both):

# withdrawals vs # dropouts, with reasons (full; by group): BOX

Adverse events/side effects and contraindications (full; by group): BOX

Basic population characteristics (complete all):

Mean age (mean (range) y) of all relevant participants at study onset (full; by group): BOX

Percentage of males (full; by group): BOX

Racial composition (proportions: full; by group) (e.g., Caucasian 50%, Asian 50% per group) BOX

Psychiatric status (complete all):

At/by baseline, the ‘primary diagnosis/condition (with diagnostic subtype) and concurrent diagnosis/condition’ [i.e., condition = symptom(s)/signs(s), yet no formal diagnosis] (proportions/% in full; by group) (e.g., 100% major depressive disorder [recurrent], no concurrent conditions): BOX

Severity of key defining features/symptoms/signs (full; by group): BOX

Prominent features/symptoms/signs at study onset e.g., (e.g., bipolar patients in manic phase) (full; by group): BOX

Current episode duration (full; by group): BOX

Age of onset (full; by group): BOX

Duration (i.e., time since diagnosis) (full; by group): BOX

Number of previous episodes (full; by group): BOX

Diagnostic method (e.g., interview), and classification system (e.g., DSM-IV): BOX

Method (e.g., scales) to determine severity: BOX

Pre-study medications, with daily dose (full; by group): BOX

Pre-study response to medications (e.g., symptoms well-controlled vs symptomatic) (full; by group): BOX

Pre-study psychologic interventions (full; by group): BOX

Likely etiology (full; by group): BOX

Pre-study/baseline comparability of groups regarding the definition of the primary diagnosis/subtype:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups regarding the definition of the primary/concurrent diagnosis/condition combinations:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline definition of the population (i.e., primary diagnosis/condition or primary/concurrent diagnosis/condition combinations) handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for these in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups regarding the severity of key features/symptoms/signs:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline severity of key defining features/symptoms/signs handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Comparability of groups regarding the prominent features/symptoms/signs at study onset (e.g., bipolar patients in manic phase):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences regarding the prominent features/symptoms/signs at study onset (e.g., bipolar patients in manic phase) handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Comparability of groups regarding the current episode duration:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences regarding the current episode duration handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups regarding the age of onset:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the age of onset handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for these in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups regarding duration (time since diagnosis):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in duration (time since diagnosis): handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for these in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Comparability of groups regarding the number of previous episodes:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences regarding the number of previous episodes handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups regarding medication types/daily doses:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline medication types/daily doses handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for these in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups regarding the response to medication (e.g., symptoms well-controlled vs symptomatic):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline response to medication (e.g., well-controlled vs symptomatic) handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for these in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups regarding psychologic interventions:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline psychologic interventions handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline total (daily, weekly or monthly) n-3 intake via diet, with amount per n-3 type (EPA, DHA, ALA), and source (e.g., fish servings; walnuts; flaxseed oil) (by group) (e.g., group 1: NR [likely EPA &/or DHA], from 1–2 fish servings/wk; group 2: NR, 0 fish servings/wk): BOX

Pre-study/baseline comparability of groups in the total amount of dietary n-3 intake:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type (EPA, DHA, ALA), and source (e.g., fish oil capsules) (by group) (e.g., group 1: 1.8g/d EPA, 1.2g/d DHA, from 3 fish oil capsules/d; group 2: 0g/d EPA, 0g/d DHA, water placebo): BOX

Pre-study/baseline comparability of groups in the total amount of n-3 intake from supplementation:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline (daily, weekly or monthly) total n-3 intake via all sources (diet +supplementation), per n-3 type (by group): BOX

Pre-study/baseline comparability of groups in the total amount of n-3 intake from diet and supplementation:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline total (daily, weekly or monthly) dietary n-6/n-3 intake (by group) (e.g., group 1: 15/1; group 2: 10/1): BOX

Pre-study/baseline comparability of groups in dietary n-6/n-3 intake:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline n-3 or n-6/n-3 intake handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for these in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline % (daily, weekly or monthly) caloric/energy intake from fat (by group): BOX

Pre-study/baseline comparability of groups in % caloric/energy intake from fat:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline % caloric/energy intake from fat handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for these in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Types of pre-study/baseline diet (proportion of participants on each diet: in full; by group):

High fish diet

Fish-vegetarian diet

Low fish diet

Low fat diet

High fat diet

Mediterranean diet

Other

Unclear

Not reported

BOX

Absolute n-3 fatty acid content of the pre-study/baseline diet (full; by group): BOX

Relative n-3 fatty acid content of the pre-study/baseline diet (full; by group): BOX

How was the pre-study dietary intake of n-3, n-6 and n-6/n-3 evaluated/estimated (select all that apply)?

Nutritionist-administered quantitative food-frequency survey(s)

Nutritionist-administered semi-quantitative food-frequency survey(s)

Self-administered quantitative food-frequency survey(s)

Self-administered semi-quantitative food-frequency survey(s)

Parent-administered quantitative food-frequency survey(s)

Parent-administered semi-quantitative food-frequency survey(s)

Direct measurement(s) of food intake

Survey(s) (e.g., 24-hour recall): BOX

Survey(s), yet no details provided

Other: BOX

Unclear

Not reported

Pre-study/baseline use of other licit (prescription and non-prescription) drugs (full; by group): BOX

Pre-study/baseline comparability of groups in use of other licit (prescription and non-prescription) drugs:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline use of other licit (prescription and non-prescription) drugs handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline use of other supplements (e.g., vitamins, minerals), including dose/frequency (full; by group): BOX

Pre-study/baseline comparability of groups in use of other supplements (e.g., vitamins, minerals), including dose/frequency:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline use of other supplements (e.g., vitamins, minerals), including dose/frequency, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline use of other complementary/alternative therapies, including dose/frequency (full; by group): BOX

Pre-study/baseline comparability of groups in use of other complementary/alternative therapies, including dose/frequency:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline use of other complementary/alternative therapies, including dose/frequency, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline (ab)use of alcohol (full; by group): BOX

Pre-study/baseline comparability of groups in (ab)use of alcohol:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline (ab)use of alcohol handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline use of illicit drugs (full; by group): BOX

Pre-study/baseline comparability of groups in use of illicit drugs:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline use of illicit drugs handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline use of smoking tobacco (full; by group): BOX

Pre-study/baseline comparability of groups in use of smoking tobacco:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline use of smoking tobacco handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline general health status (full; by group): BOX

Pre-study/baseline comparability of groups in general health status:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline general health status handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline status of other factors affecting (and affected by) mental health (e.g., stressors; exercise; quality of sleep; social support) (full; by group): BOX

Pre-study/baseline comparability of groups regarding the status of other factors affecting (and affected by) mental health (e.g., stressors; exercise; quality of sleep; social support):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline status of other factors affecting (and affected by) mental health (e.g., stressors; exercise; quality of sleep; social support) handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline family history of psychiatric problems, including known diagnoses (full; by group): BOX

Pre-study/baseline comparability of groups in terms of a family history of psychiatric problems, including known diagnoses:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline family history of psychiatric problems, including known diagnoses, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline employment status (full; by group): BOX

Pre-study/baseline comparability of groups in terms of employment status:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline employment status handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline income (full; by group): BOX

Pre-study/baseline comparability of groups in terms of income:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline income handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline education (full; by group): BOX

Pre-study/baseline comparability of groups in terms of education:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline education handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline marital status (full; by group): BOX

Pre-study/baseline comparability of groups in terms of marital status:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline marital status handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

Pre-study/baseline biomarkers data (by biomarker: e.g., RBCs; for DHA, EPA, AA, AA/EPA, AA/DHA, AA/EPA+DHA levels, with units [e.g., % total fatty acids; absolute amount) (full; by group): BOX

Pre-study/baseline comparability of groups in terms of DHA status (per biomarker):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups in terms of EPA status (per biomarker):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups in terms of EPA+DHA status (per biomarker):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups in terms of AA status (per biomarker):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups in terms of AA/DHA status (per biomarker):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups in terms of AA/EPA status (per biomarker):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

Pre-study/baseline comparability of groups in terms of AA/EPA+DHA status (per biomarker):

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., a single group study

BOX

How were any between-group differences in the pre-study/baseline biomarker EFA status handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for these in the analysis

Not reported = no description of whether/how accounted for in the analysis

Not applicable = e.g., a single group study

BOX

### ON-STUDY

Was the n-3 exposure provided/received as primary or supplemental intervention? BOX

How was on-study dietary intake of n-3 or n-6/n-3 evaluated/estimated (select all that apply)?

Nutritionist-administered quantitative food-frequency survey(s)

Nutritionist-administered semi-quantitative food-frequency survey(s)

Self-administered quantitative food-frequency survey(s)

Self-administered semi-quantitative food-frequency survey(s)

Parent-administered quantitative food-frequency survey(s)

Parent-administered semi-quantitative food-frequency survey(s)

Direct measurement(s) of food intake

Survey(s) (e.g., 24-hour recall): BOX

Survey(s), yet no details provided

Other: BOX

Unclear

Not reported

On-study GROUP 1 (highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR; e.g., 3g/d EPA+DHA [NBD], from 3 [1g gelcap] fish oil capsules/d, NR, 50mg Vitamin E per capsule; e.g., 0g/d, from 3 [1g gelcap] olive oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 intake from diet+supplementation: BOX

total (daily, weekly or monthly) n-6/n-3 intake: BOX (e.g., 10:1 g/d): BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures, with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

protocol (e.g., what is mandated vs permitted), with method and target values, to modify daily, weekly or monthly n-6 or n-6/n-3 intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet): BOX

On-study GROUP 2 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR; e.g., 3g/d EPA+DHA [NBD], from 3 [1g gelcap] fish oil capsules/d, NR, 50mg Vitamin E per capsule; e.g., 0g/d, from 3 [1g gelcap] olive oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 intake from diet+supplementation: BOX

total (daily, weekly or monthly) n-6/n-3 intake: BOX (e.g., 10:1 g/d): BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures, with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

protocol (e.g., what is mandated vs permitted), with method and target values, to modify daily, weekly or monthly n-6 or n-6/n-3 intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet): BOX

On-study GROUP 3 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR; e.g., 3g/d EPA+DHA [NBD], from 3 [1g gelcap] fish oil capsules/d, NR, 50mg Vitamin E per capsule; e.g., 0g/d, from 3 [1g gelcap] olive oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 intake from diet+supplementation: BOX

total (daily, weekly or monthly) n-6/n-3 intake: BOX (e.g., 10:1 g/d): BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures, with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

protocol (e.g., what is mandated vs permitted), with method and target values, to modify daily, weekly or monthly n-6 or n-6/n-3 intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet): BOX

On-study GROUP 4 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR; e.g., 3g/d EPA+DHA [NBD], from 3 [1g gelcap] fish oil capsules/d, NR, 50mg Vitamin E per capsule; e.g., 0g/d, from 3 [1g gelcap] olive oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 intake from diet+supplementation: BOX

total (daily, weekly or monthly) n-6/n-3 intake: BOX (e.g., 10:1 g/d): BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures, with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

protocol (e.g., what is mandated vs permitted), with method and target values, to modify daily, weekly or monthly n-6 or n-6/n-3 intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet): BOX

On-study GROUP 5 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR; e.g., 3g/d EPA+DHA [NBD], from 3 [1g gelcap] fish oil capsules/d, NR, 50mg Vitamin E per capsule; e.g., 0g/d, from 3 [1g gelcap] olive oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 intake from diet+supplementation: BOX

total (daily, weekly or monthly) n-6/n-3 intake: BOX (e.g., 10:1 g/d): BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures, with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

protocol (e.g., what is mandated vs permitted), with method and target values, to modify daily, weekly or monthly n-6 or n-6/n-3 intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet): BOX

On-study GROUP 6 (next highest dose n-3 [or lowest n-6/n-3 ratio if both n-3 and n-6 are modified] study first, active comparator next (e.g., n-6), placebo control last) (complete all; click [underlined: here] if there are no more study groups):

total (daily, weekly or monthly) n-3 dose via supplementation, with amount per n-3 type; source, frequency and timing of delivery; other active ingredients (e.g., 1.8g/d EPA, 1.2g/d DHA, from 3 [1g vegan outer] fish oil capsules/d, with breakfast, NR; e.g., 3g/d EPA+DHA [NBD], from 3 [1g gelcap] fish oil capsules/d, NR, 50mg Vitamin E per capsule; e.g., 0g/d, from 3 [1g gelcap] olive oil capsules/d, with breakfast, NR): BOX

total (daily, weekly or monthly) n-3 exposure via diet, with amount per n-3 type, source, frequency and timing of delivery (e.g., NR, likely EPA or DHA, from 2 0.5oz oily fish servings/wk, as dinner; e.g., NR, likely ALA, from 8–10oz/wk flaxseed oil as salad dressing, NR): BOX

total (daily, weekly or monthly) n-3 exposure via all sources (diet+supplementation), per n-3 type (e.g., NR, at least 3g/d EPA+DHA): BOX

total (daily, weekly or monthly) n-6 intake from diet+supplementation: BOX

total (daily, weekly or monthly) n-6/n-3 intake: BOX (e.g., 10:1 g/d): BOX

type, source and total (daily, weekly or monthly) intake of other mandated or permitted exposures, with dose/serving/frequency: BOX

n allocated-selected/ n completed (e.g., n=24/21): BOX

protocol (e.g., what is mandated vs permitted), with method and target values, to modify daily, weekly or monthly n-6 or n-6/n-3 intake (e.g., increase daily n-3 intake to Y% of total daily fat intake, decrease daily n-6 intake to X% of total daily fat intake; e.g., none, participants told to maintain background diet): BOX

Briefly describe whether there was a clearly planned and instituted difference, between study groups, in their (daily, weekly or monthly) total-gram n-3 and/or n-6/n-3 intake: BOX

Briefly describe whether there was a clearly planned and instituted equivalence, across study groups, of (daily, weekly or monthly) caloric/energy intake from study-relevant exposures/interventions: BOX

Briefly describe any problems with compliance whereby notable deviations (e.g., decreases) from the planned amounts of dietary or supplement intake (e.g., capsules or servings) in one or more of the study groups violated the difference(s) established a priori between study groups for n-3 and/or n-6/n-3 intake or the equivalence established a priori across study groups for caloric/energy intake (full; by group): BOX

Briefly describe whether, and which, study groups/participants were asked to maintain their (pre-study/baseline) background diet while on-study (full; by group): BOX

Briefly describe whether, and how, without specific instruction to do so, or with specific instruction not to do so, participants' (pre-study/baseline) background diet was altered while on-study (full; by group): BOX

Briefly describe whether, and which, study groups/participants were asked to maintain their (pre-study/baseline) therapies/medications while on-study (full; by group): BOX

Briefly describe whether, and how, without specific instruction to do so, or with specific instruction not to do so, participants' (pre-study/baseline) therapies/medication were altered while on-study (full; by group): BOX

Briefly describe any evidence of selection bias: BOX

Between-group comparability of within-group changes in the primary/concurrent diagnosis/condition combination[s] (i.e., population definition) from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the primary/concurrent diagnosis/condition combination[s] (i.e., population definition) from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the primary/concurrent diagnosis/condition combinations (i.e., population definition) from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the primary/concurrent diagnosis/condition combinations (i.e., population definition) from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in the severity of key defining features/symptoms/signs (e.g., leading to a change in medication type/dose) from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the severity of key defining features/symptoms/signs (e.g., leading to a change in medication type/dose) from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the severity of key defining features/symptoms/signs (e.g., leading to a change in medication type/dose) from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the severity of key defining features/symptoms/signs (e.g., leading to a change in medication type/dose) from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in the prominent features/symptoms/signs observed at study onset/baseline (e.g., bipolar patients in manic phase), to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significanceUnclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the prominent features/symptoms/signs observed at study onset/baseline (e.g., bipolar patients in manic phase), to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the prominent features/symptoms/signs observed at study onset/baseline (e.g., bipolar patients in manic phase), to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the prominent features/symptoms/signs observed at study onset/baseline (e.g., bipolar patients in manic phase), to each followup in each group: BOX

Between-group comparability of within-group changes in the medication types/daily doses from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the medication types/daily doses from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the medication types/daily doses from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the medication types/daily doses from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in the response to medication (symptoms well-controlled vs symptomatic) from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the response to medication (symptoms well-controlled vs symptomatic) from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the response to medication (symptoms well-controlled vs symptomatic) from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the response to medication (symptoms well-controlled vs symptomatic) from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in the psychologic interventions from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the psychologic interventions from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the psychologic interventions from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the psychologic interventions from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in the use of other licit (prescription and non-prescription) drugs from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the use of other licit (prescription and non-prescription) drugs from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the use of other licit (prescription and non-prescription) drugs from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the use of other licit (prescription and non-prescription) drugs from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in other supplement use (vitamins; minerals), including dose/frequency, from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in other supplement use (vitamins; minerals), including dose/frequency, from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in other supplement use (vitamins; minerals), including dose/frequency, from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in other supplement use (vitamins; minerals), including dose/frequency, from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in other complementary/alternative therapies from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in other complementary/alternative therapies from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in other complementary/alternative therapies from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in other complementary/alternative therapies from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in the (ab)use of alcohol from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the (ab)use of alcohol from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the (ab)use of alcohol from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the (ab)use of alcohol from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in illicit drug use from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in illicit drug use from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in illicit drug use from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in illicit drug use from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in smoking tobacco from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in smoking tobacco from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in smoking tobacco from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in smoking tobacco from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in general health status from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in general health status from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in general health status from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in general health status from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in the other factors affecting (and affected by) mental health (e.g., stressors; exercise; quality of sleep; social support) from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the other factors affecting (and affected by) mental health (e.g., stressors; exercise; quality of sleep; social support) from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in other factors affecting (and affected by) mental health (e.g., stressors; exercise; quality of sleep; social support) from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in other factors affecting (and affected by) mental health (e.g., stressors; exercise; quality of sleep; social support) from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in the family history of psychiatric problems, including known diagnoses, from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in the family history of psychiatric problems, including known diagnoses, from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in the family history of psychiatric problems, including known diagnoses, from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in the family history of psychiatric problems, including known diagnoses, from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in employment status from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in employment status from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in employment status from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in employment status from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in income from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in income from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in income from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in income from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in education from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in education from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in education from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in education from baseline, to each followup in each group: BOX

Between-group comparability of within-group changes in marital status from baseline, to the followup required to observe an/no effect:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

Between-group comparability of within-group changes in marital status from baseline, to final followup:

Adequate = statistically nonsignificant difference(s) reported (e.g., p-value; stated result of statistical test)

Possibly adequate = no result of statistical test of significance reported, yet no notable difference(s) in reported data

Inadequate = statistically significant difference(s) reported

Possibly inadequate = no result of statistical test of significance reported, yet at least one notable difference in reported data

Single group study, adequate = statistically nonsignificant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly adequate = no notable change in reported data in this group yet no reported result of statistical test of significance

Single group study, inadequate = statistically significant change in this group (e.g., p-value; stated result of statistical test)

Single group study, possibly inadequate = notable change in reported data in this group yet no reported result of statistical test of significance

Unclear = no result of statistical test of significance reported, and, incomplete or conflicting data reported

Not reported = no reported data or result of a statistical test of significance

Not applicable = e.g., no followup, as in a cross-sectional study

BOX

How were any between-group differences in the within-group change(s) in marital status from baseline, to each followup, handled in the study analysis? Or, if a single group study, how was any within-group change in this variable from baseline, to each followup, handled in the study analysis?

Adequately = taken into consideration in the analysis

Inadequately = not taken into consideration in the analysis

No differences = no differences reported

Unclear = not enough information to rule out possibility that did not account for it in the analysis

Not reported = no description of whether/how accounted for it in the analysis

Not applicable = a single group study

BOX

Briefly describe the nature of the change in marital status from baseline, to each followup in each group: BOX

Name of n-3 product (e.g., Almarin, Coromega, Eiconol; Efamed, Epagis, MaxEPA, Menhaden oil, ResQ, Omacor, Ropufa): BOX

Manufacturer: BOX

Purity data: BOX

Presence of other, potentially active agents in n-3 product: BOX

n-3 composition (%) of the exposure (e.g., 18% EPA, 12% DHA in each fish oil capsule): BOX

Reported method(s) to maintain the freshness (i.e., preclude rancidity) of n-3 exposures/interventions (e.g., added anti-oxidants to capsules, with fish oil exposure, to minimize oxidation): BOX

Reported method(s) to eliminate methylmercury from fish or its products/derivatives: BOX

Note any descriptions of inappropriate methods of lipid extraction/preparation (e.g., failure to extract blood after a [overnight] fasting period; failure to collect blood in EDTA- or EGTA-containing vials): BOX

Note any descriptions of inappropriate methods of lipid storage (e.g., failure to store samples at -70 to -80 degrees C if not analyzed immediately): BOX

Note any descriptions of inappropriate methods of lipid analysis (e.g., failure to conduct lab measurements on coded samples by technicians blinded to participants' identity and allocation; failure to use a standard protocol [e.g., Bligh & Dyer] requiring, for example, purging samples with nitrogen, or using thin-layer chromatography or gas liquid chromatography): BOX

Adequacy of method to deodorize smell of especially fish oil exposure (select one):

Adequate = reported that study participants could not reliably guess which exposure they received

Inadequate = reported that participants could reliably guess which exposure they received

Unclear = incomplete or conflicting data reported

Not reported = no method reported, or method reported but no data reported

Not applicable = did not use an exposure requiring or permitting such a method (e.g., flaxseed; full fish servings)

If this is a controlled study, briefly describe whether clinical outcome data from all study groups (e.g., active vs placebo) were simultaneously entered into data analysis: BOX

If this is a controlled study, briefly describe whether biomarker data from all study groups (e.g., active vs placebo) were simultaneously entered into data analysis: BOX

Data were analyzed according to which criterion (select one)?

Intention-to-treat (all randomized/enrolled)

Those receiving at least one dose/serving

Those completing the study (i.e., with final follow-up data)

Unclear

Other: BOX

Was the study adequately powered to detect a difference? BOX

Any further comments about the study: BOX

## Quality Assessment Form—Randomized Controlled Trials

1. Randomization: Was the study described as randomized (i.e. including words such as

randomly, random, randomization)? Yes = 1 No = 0 =___

A trial reporting that it is ‘randomized’ is to receive one point. Trials describing an appropriate method of randomization (table of random numbers, computer generated) receive an additional point. Appropriate = 1 Not appropriate = 0 = ___

However, if the report describes the trial as randomized and uses an inappropriate method of randomization (e.g. date of birth, hospital numbers), a point is deducted.

TOTAL POINTS: 0 1 2 [underlined: SCORE]= ___

2. Double-blinding: Was the study described as double-blind? Yes = 1 No = 0 =___

A trial reporting that it is ‘double-blind’ is to receive one point. Trials that describe an appropriate method of double-blinding (identical placebo: color, shape, taste) are to receive an additional point. Yes = 1 No = 0 =___

However, if the report describes the trial as double-blind and uses an inappropriate method (e.g. comparison of tablets vs. injection with no dummy), a point is deducted.

TOTAL POINTS: 0 1 2 [underlined: SCORE]= ___

3. Withdrawals and dropouts: Was there a description of withdrawals and dropouts?

Yes = 1 No = 0 [underlined: SCORE]= ___

A trial reporting the number of and reasons for withdrawals or dropouts is to receive one point. If there is no description, no point is given.

[underlined: JADAD TOTAL SCORE]= ___

4. Adequacy of Allocation Concealment: ( select one ):

-Central randomization; numbered or coded bottles or containers; drugs prepared by a pharmacy, serially numbered, opaque, sealed envelopes, etc ADEQUATE

-Alternation; reference to case record # or date of birth, etc INADEQUATE

-Allocation concealment is not reported, or, fits neither category UNCLEAR

## Quality Assessment (Internal Validity) Forms—Designs Other than an RCT

### Controlled Study Designs

DESIGN: COMPARATIVE BEFORE-AFTER STUDY

1. Description of validated method(s) to identify the target population
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
2. Control for selection bias
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
3. Description of withdrawals/dropouts
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Comparability of study groups on the basis of the design or analysis: age and sex
  a. Study controls for age and sex at baseline = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
5. Comparability of study groups on the basis of the design or analysis: background diet
  a. Study controls for background diet (omega-6/omega-3 fatty acid intake) at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
6. Comparability of study groups on the basis of the design or analysis: caloric/energy intake
  a. Study controls for caloric/energy intake at baseline and in light of possible changes during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
7. Comparability of study groups on the basis of the design or analysis: the severity of the psychiatric disorder/condition
  a. Study controls for the severity of the psychiatric disorder/condition at baseline and in light of possible changes unrelated to the exposure during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
8. Comparability of study groups on the basis of the design or analysis: psychotropic medication
  a. Study controls for psychotropic medication at baseline and in light of possible changes unrelated to the exposure during intervention period = 1
  b. Study fails to control for this confounding influence = 0
  c. Unable to determine = 0
9. Description of a validated primary clinical outcome measure(s)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
10. Blind assessments of outcome
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
11. Description of type and amount of omega-3 fatty acid content in the intervention/exposure
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

DESIGN: CASE-CONTROL STUDY (Newcastle-Ottawa, with assessment of an additional confounder)

1. Is the case definition adequate?
  yes, with independent validation (e.g., clinical/research diagnostic criteria) (1 point)
  yes: e.g., record linkage or based on reports
  no description
2. Representativeness of the cases
  a. consecutive or obviously representative series of cases (1 point)
  b. potential for selection biases, or not stated
3. Selection of controls
  a. community controls (1 point)
  b. hospital controls
  c. no description
4. Definition of controls
  a. no history of disease (requires clinical/research diagnostic criteria to determine this) (1 point)
  b. no description of source
5. Comparability of cases and controls on the basis of the design or analysis: smoker status
  a. study controls for smoker status at baseline and in possible changes unrelated to the exposure during “intervening period” (1 point)
  b. study fails to control for this confounding influence
6. Comparability of cases and controls on the basis of the design or analysis: type and dose of psychotropic medication
  a. study controls for type and dose of psychotropic medication at baseline and in possible changes unrelated to the exposure during “intervening period” (1 point)
  b. study fails to control for this confounding influence
7. Comparability of cases and controls on the basis of the design or analysis: omega-6 fatty acid intake
  a. study controls for omega-6 fatty acid intake at baseline and in possible changes unrelated to the exposure during “intervening period” (1 point)
  b. study fails to control for this confounding influence
8. Ascertainment of exposure
  a. validated dietary assessment questionnaire or structured interview where blind to case/control status (1 point)
  b. interview not blinded to case/control status
  c. written self-report or medical record only
  d. no description
9. Same method of ascertainment for cases and controls
  a. yes (1 point)
  b. no
10. Non-response rate
  a. same rate for both groups (1 point)
  b. non respondents described
  c. rate different and no designation

DESIGN: (MULTIPLE-GROUP) CROSS-SECTIONAL STUDY

1. Control for selection bias
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
2. Description of the same validated method to distinguish the study populations (i.e., to confirm/diagnose the presence and absence of psychiatric disorder/condition in the target and control population(s), respectively)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
3. Homogeneity of the target psychiatric population: psychiatric diagnosis/condition
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Homogeneity of the target psychiatric population: psychotropic medication(s) and dose(s)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Comparability of study groups on the basis of the design or analysis: age and sex
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
6. Comparability of study groups on the basis of the design or analysis: current amount of omega-3 fatty acid intake in background diet
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
7. Comparability of study groups on the basis of the design or analysis: current amount of omega-6 fatty acid intake, or omega-6/omega-3 fatty acid intake, in background diet
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
8. Comparability of study groups on the basis of the design or analysis: current smoker status
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Description of a validated primary clinical outcome measure(s)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
10. Description of the same appropriate methods used to extract, prepare, store and analyze lipid data from all study populations
  a. No inappropriate descriptions = 1
  b. At least one inappropriate description = 0
  c. Different methods used for different study groups = 0
  d. Unable to determine for one or more of the methods = 0

### Uncontrolled Study Designs

DESIGN: SINGLE PROSPECTIVE COHORT STUDY (Modified Newcastle-Ottawa)

1. 1. Representativeness of the exposed cohort
  a. Truly or somewhat representative of the average individual at no (or elevated) risk for a psychiatric disorder/symptoms in the community = 1
  b. Selected group of users e.g., nurses, volunteers = 0
  c. No description of the derivation of the cohort = 0
2. Ascertainment of exposure
  a. Validated dietary assessment questionnaire or structured interview = 1
  b. Written self-report = 0
  c. No description = 0
3. Demonstration that outcome of interest was not present at start of study
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Description of a validated method to quantify the amount, per type, of omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Assessment of outcome
  a. Independent blind assessment = 1
  b. Record linkage = 1
  c. Self-report = 0
  d. No description = 0
6. Was followup long enough for outcomes to occur?
  a. Yes (5 years) = 1
  b. No = 0
  c. Unable to determine = 0
7. Adequacy of followup of cohort
  a. Complete followup, all subjects accounted for = 1
  b. Subjects lost to followup unlikely to introduce bias, small number lost, at least 90% followup, or description provided of those lost = 1
  c. Followup rate of less than 90% and no description of those lost = 0
8. Analytic control for confounding: age and sex
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Analytic control for confounding: omega-6 fatty acid intake or omega-6/omega-3 fatty acid intake ratio
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
10. Analytic control for confounding: smoking history
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

DESIGN: CROSS-SECTIONAL SURVEY

1. Description of appropriate sampling technique(s) to identify the sample population
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
2. Description of a validated method to identify/diagnose the target psychiatric disorder/condition
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
3. Description of a validated method to identify the current intake of (foods or supplements containing) omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
4. Description of a validated method to quantify the amount, per type, of omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Analytic control for confounding: age and sex
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
6. Analytic control for confounding: smoking history/status
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
7. Analytic control for confounding: severity of psychiatric disorder/condition
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
8. Analytic control for confounding: current intake of (foods or supplements containing) omega-6 fatty acids or omega-6/omega-3 fatty acids
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Response rate (at least 75%):
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0

DESIGN: CROSS-NATIONAL ECOLOGICAL ANALYSIS

1. Description of the same validated method to identify all of the target study populations
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
2. Description of the same validated method to identify intake of omega-3 fatty acids (from foods known to contain them) from all of the target study populations
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
3. Description of appropriate sampling techniques to identify all of the target populations
  a. Yes = 1 (random sampling; stratified sampling to represent key population elements; large enough)
  b. No = 0
  c. Unable to determine = 0
4. Description of sampling or analytic techniques to control for possible confounding (i.e., factors that can influence diet or mental health): age and sex
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
5. Description of sampling or analytic techniques to control for possible confounding (i.e., factors that can influence diet or mental health): other social factors (e.g., education)
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
6. Description of sampling or analytic techniques to control for possible confounding (i.e., factors that can influence diet or mental health): economic factors
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
7. Description of sampling or analytic techniques to control for possible confounding (i.e., factors that can influence diet or mental health): omega-6 fatty acid intake, or omega-6/omega-3 fatty acid intake ratio
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
8. Description of sampling or analytic techniques to control for possible confounding (i.e., factors that can influence diet or mental health): smoking history/status
  a. Yes = 1
  b. No = 0
  c. Unable to determine = 0
9. Description of analytic techniques to control for possible confounding (i.e., factors that can influence diet or mental health): re-analysis excluding outlier data
  a. Yes = 1
  b. No outlier data identified = 1
  c. No = 0
    Unable to determine = 0

## Applicability Indices

For studies involving at least one target population identified with a psychiatric disorder or condition (i.e., symptom/behavior): ^1^

1 Note that a control group (e.g., within a case-control design) might have been composed of individuals without an identified psychiatric diagnosis or condition.

Assign ‘I’ to a target study population of otherwise “healthy” North American (or similar) individuals identified with a psychiatric disorder or condition, diagnosed using a “typical” North American methodology/nomenclature (e.g., DSM-IV) or identified using at least one established psychiatric research instrument, with or without comorbid psychiatric conditions, potentially receiving “typical” North American types of treatment (e.g., medication types and doses) for the primary diagnosis, representing a somewhat broad socio-demographic spectrum (i.e., gender, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio of at least 15).

Assign ‘II’ to a target study population of otherwise ‘healthy’ North American (or similar) individuals identified with a psychiatric disorder or condition, likely diagnosed using a ‘typical’ North American methodology/nomenclature (e.g., DSM-IV) or identified using at least one established psychiatric research instrument, with or without comorbid psychiatric conditions, likely receiving ‘typical’ North American types of treatment (e.g., medication types and doses) for the primary diagnosis, yet representing a more circumscribed socio-demographic picture (e.g., Asian-American/Canadian), and likely eating a diet “somewhat different” from that of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio notably less than 15, yet likely not reaching a value of 4, such as observed in Japan).

Assign ‘III’ to a target study population identified with a psychiatric disorder or condition, with or without comorbid psychiatric conditions, potentially diagnosed using a methodology/nomenclature or an established psychiatric research instrument other than a “typical” North American one, receiving treatment (e.g., medication types and doses) for the primary diagnosis that is potentially “atypical” of North America, representing a population whose socio-demographic characteristics are notably “atypical” of a broad spectrum North American population, and eating a diet that is “notably different” from that of a broad spectrum North American population (e.g., with an estimated omega-6/omega-3 intake ratio perhaps reaching a value of 4, such as observed in Japan, or 38–50, as observed in urban India).

Assign ‘X’ when applicability cannot be ascertained due to incomplete or conflicting reporting of the details concerning the target study population, particularly relating to the primary diagnosis/condition and/or the background diet.

For studies involving a target population with or without a known elevated risk for a psychiatric disorder or condition (i.e., symptom/behavior):

Assign ‘I’ to a target study population of otherwise “healthy” North American (or similar) individuals, with or without a known elevated risk for onset of a psychiatric disorder or problems, representing a somewhat broad socio-demographic spectrum (i.e., gender, race), and eating a diet “typical” of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio of at least 15).

Assign ‘II’ to a target study population of otherwise “healthy” North American (or similar) individuals, with or without a known elevated risk for onset of a psychiatric disorder or problems, yet representing a more circumscribed socio-demographic picture (e.g., Asian-American/Canadian), and likely eating a diet “somewhat different” from that of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio notably less than 15, yet likely not reaching a value of 4, as observed in Japan).

Assign ‘III’ to a target study population of otherwise “healthy” individuals, with or without a known elevated risk for onset of a psychiatric disorder or problems, yet representing a very circumscribed population whose socio-demographic characteristics are “notably atypical” of a broad spectrum North American population, and eating a diet that is “notably different” from that of a broad spectrum North American population (e.g., with an omega-6/omega-3 intake ratio perhaps reaching a value of 4, such as observed in Japan, or 38–50, as observed in urban India).

Assign ‘X’ when applicability cannot be ascertained due to incomplete or conflicting reporting of the details concerning the target study population, particularly relating to the background diet.