# Appendix A. Search Strategies

## Search Strategy 1

Ovid interface for Medline, Embase, PsycInfo, Cochrane Central Register of Controlled Trials

1. exp mental disorders/
2. exp mental disease/
3. suicide attempt/
4. attempted suicide/
5. exp suicide/
6. suicid$.mp.
7. exp Aggression/
8. Aggressiveness/
9. Aggressive behavior/
10. exp Impulsive Behavior/
11. Impulsiveness/
12. exp Impulse Control Disorders/
13. or/1–12
14. exp fatty acids, omega-3/
15. fatty acids, essential/
16. Dietary Fats, Unsaturated/
17. linolenic acids/
18. exp fish oils/
19. (n 3 fatty acid$ or omega 3).tw.
20. docosahexa?noic.tw,hw,rw.
21. eicosapenta?noic.tw,hw,rw.
22. alpha linolenic.tw,hw,rw.
23. (linolenate or cervonic or timnodonic).tw,hw,rw.
24. menhaden oil$.tw,hw,rw.
25. (mediterranean adj diet$).tw.
26. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
27. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
28. (fish adj2 oil$).tw.
29. (cod liver oil$ or marine oil$ or marine fat$).tw.
30. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
31. (fish consumption or fish intake or (fish adj2 diet$)).tw.
32. diet$ fatty acid$.tw.
33. or/14–32
34. dietary fats/
35. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
36. random$.tw.
37. exp clinical trials/ or evaluation studies/
38. follow-up studies/ or prospective studies/
39. or/35–38
40. 34 and 39
41. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
42. (omega 3 or n 3).mp.
43. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
44. 42 and 43
45. 33 or 40 or 41 or 44
46. 13 and 45

## Search Strategy 2

Mental Health with free text supplement

Ovid interface for CDSR

1. exp mental disorders/
2. exp mental disease/
3. suicide attempt/
4. attempted suicide/
5. exp suicide/
6. suicid$.mp.
7. exp Aggression/
8. Aggressiveness/
9. Aggressive behavior/
10. exp Impulsive Behavior/
11. Impulsiveness/
12. exp Impulse Control Disorders/
13. or/1–12
14. exp fatty acids, omega-3/
15. fatty acids, essential/
16. Dietary Fats, Unsaturated/
17. linolenic acids/
18. exp fish oils/
19. (n 3 fatty acid$ or omega 3).tw.
20. docosahexa?noic.tw,hw,rw.
21. eicosapenta?noic.tw,hw,rw.
22. alpha linolenic.tw,hw,rw.
23. (linolenate or cervonic or timnodonic).tw,hw,rw.
24. menhaden oil$.tw,hw,rw.
25. (mediterranean adj diet$).tw.
26. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.
27. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.
28. (fish adj2 oil$).tw.
29. (cod liver oil$ or marine oil$ or marine fat$).tw.
30. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.
31. (fish consumption or fish intake or (fish adj2 diet$)).tw.
32. diet$ fatty acid$.tw.
33. or/14–32
34. dietary fats/
35. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.
36. random$.tw.
37. exp clinical trials/ or evaluation studies/
38. follow-up studies/ or prospective studies/
39. or/35–38
40. 34 and 39
41. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.
42. (omega 3 or n 3).mp.
43. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.
44. 42 and 43
45. 33 or 40 or 41 or 44
46. 13 and 45
47. remove duplicates from 46
48. mental health.mp.
49. psychiat$.mp.
50. schizophr$.mp.
51. bipolar$.mp.
52. depressi$.mp.
53. (mania$ or hypomani$).mp.
54. unipolar$.mp.
55. (psychotic$ or psychosis$).mp.
56. (schizoaffective or schizo-affective).mp.
57. (aggressi$ and behav$).mp.
58. Aggression.mp.
59. aggressivity.mp.
60. impulsiv$.mp.
61. Impulse Control$.mp.
62. or/48–61
63. 45 and 62
64. 47 or 63

## Search Strategy 3

Mental Health with freetext supplement

Silverplatter interface for CAB Health

#1. “mental-disorders” in SU

#2. “depression-” in SU

#3. “neuroses-” in SU

#4. “mental-health” in SU

#5. “suicide-” in SU

#6. mental health in ti,ab,su

#7. psychiat* in ti,ab,su

#8. schizophr* in ti,ab,su

#9. bipolar* in ti,ab,su

#10. depressi* in ti,ab,su

#11. (mania* or hypomani*) in ti,ab,su

#12. unipolar* in ti,ab,su

#13. (psychotic* or psychosis*) in ti,ab,su

#14. (schizoaffective or schizo-affective) in ti,ab,su

#15. (aggressi* near10 behav*) in ti,ab,su

#16. aggression in ti,ab,su

#17. aggressivity in ti,ab,su

#18. impulsiv* in ti,ab,su

#19. impulse control* in ti,ab,su

#20. (“delusory-parasitoses” in SU) or (“psychoses-” in SU) or (“schizophrenia-” in SU)

#21. (“aggression-” in SU) or (“aggressive-behaviour” in SU) or (“fighting-” in SU)

#22. #1 or #2, #3, #4, #5, #6, #7, #8, #9, #10, #11, #12, #13, #14, #15, #16, #17, #18, #19, #20, #21

#23. omega 3

#24. (“essential-fatty-acids” in SU) or (“linolenic-acid” in SU)

#25. (“docosahexaenoic-acid” in SU) or (“eicosapentaenoic-acid” in SU)

#26. explode “plant-oils” in SU

#27. explode “fish-oils” in SU

#28. “fish-consumption” in SU

#29. “polyenoic-fatty-acids” in SU

#30. “polyunsaturated-fats” in SU

#31. “dietary-fat” in SU

#32. (n 3 fatty acid* or omega 3) in ti,ab,su

#33. (docosahexanoic or docosahexaenoic) in ti,ab,su

#34. (eicosapentanoic or eicosapentaenoic) in ti,ab,su

#35. (alpha linolenic)in ti,ab,su

#36. (linolenate or cervonic or timnodonic) in ti,ab,su

#37. (mediterranean diet) in ti,ab,su

#38. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or menhaden) and oil*) in ti,ab,su

#39. (walnut* or butternut* or soybean* or pumpkin seed*) in ti,ab,su

#40. (fish oil* or cod liver oil* or marine oil* or marine fat*) in ti,ab,su

#41. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov*) in ti,ab,su

#42. (fish consumption or fish intake) in ti,ab,su

#43. (diet* fatty acid*) in ti,ab,su

#44. (ropufa or maxepa or omacor or efamed or resq or epagis or almarin or coromega) in ti,ab,su

#45. ((omega 3 or n 3) and (polyunsaturated fat* or pufa or dha or epa or long chain or longchain or lc*)) in ti,ab,su

#46. “long-chain-fatty-acids” in SU

#47. (fish and diet) in ti,ab,su

#48. (explode “essential-oils” in SU) or (explode “olive-oil” in SU) or (explode “palm-oils” in SU) or (explode “plant-oils” in SU) or (explode “seed-oils” in SU)

#49. explode “fish-liver-oils” in SU

#50. (“long-chain-fatty-acids” in SU) or (((omega 3 or n 3) and (polyunsaturated fat* or pufa or dha or epa or long chain or longchain or lc*)) in ti,ab,id) or ((ropufa or maxepa or omacor or efamed or resq or epagis or almarin or coromega) in ti,ab,id) or ((diet* fatty acid*) in ti,ab,id) or ((n 3 fatty acid* or omega 3) in ti,ab,id) or (“dietary-fat” in SU) or (“polyunsaturated-fats” in SU) or (“polyenoic-fatty-acids” in SU) or (“fish-consumption” in SU) or (explode “fish-oils” in SU) or (explode “plant-oils” in SU) or ((“docosahexaenoic-acid” in SU) or (“eicosapentaenoic-acid” in SU)) or ((“essential-fatty-acids” in SU) or (“linolenic-acid” in SU)) or (omega 3) or ((fish consumption or fish intake) in ti,ab,id) or ((salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov*) in ti,ab,id) or ((fish oil* or cod liver oil* or marine oil* or marine fat*) in ti,ab,id) or ((walnut* or butternut* or soybean* or pumpkin seed*) in ti,ab,id) or (((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed or menhaden) and oil*) in ti,ab,id) or ((mediterranean diet) in ti,ab,id) or ((linolenate or cervonic or timnodonic) in ti,ab,id) or ((alpha linolenic)in ti,ab,id) or ((eicosapentanoic or eicosapentaenoic) in ti,ab,id) or ((docosahexanoic or docosahexaenoic) in ti,ab,id) or (explode “fish-liver-oils” in SU) or ((explode “essential-oils” in SU) or (explode “olive-oil” in SU) or (explode “palm-oils” in SU) or (explode “plant-oils” in SU) or (explode “seed-oils” in SU)) or ((fish and diet) in ti,ab,id)

#51. ((explode “almond-oil” in SU) or (explode “castor-oil” in SU) or (explode “coconut-oil” in SU) or (explode “cottonseed-oil” in SU) or (explode “groundnut-oil” in SU) or (explode “jojoba-oil” in SU) or (explode “linseed-oil” in SU) or (explode “maize-oil” in SU) or (explode “melon-seed-oil” in SU) or (explode “mustard-oil” in SU) or (explode “palm-kernel-oil” in SU) or (explode “rapeseed-oil” in SU) or (explode “rice-oil” in SU) or (explode “safflower-oil” in SU) or (explode “sesame-oil” in SU) or (explode “soyabean-oil” in SU) or (explode “sunflower-oil” in SU) or (explode “tung-oil” in SU) or (explode “wheat-germ-oil” in SU)) or ((“cod-liver-oil” in SU) or (“menhaden-oil” in SU))

#52. #50 or #51

#53. #22 and #52