# List of Acronyms/Abbreviations

Acronyms | Abbreviation
AA (20:4 n-6) | Arachidonic acid
ACE | Angiotensin-converting enzyme
AHRQ | Agency for Healthcare Research and Quality
AI | Adequate intake
ALA (18:3 n-3) | Alpha linolenic acid
Apo | Apoprotein
Aza | Azathioprine
BMI | Body mass index
BP | Blood pressure
CAB | Commonwealth Agricultural Bureau
cAMP | Cyclic adenosine monophosphate
CCTR | Cochrane Central Register of Controlled Trials
CPK | Creatinine phosphokinase
CsA | Cyclosporine
CSF II | Continuing Food Survey of Intakes by Individuals 1994-1998
CVD | Cardiovascular disease
DBP | Diastolic blood pressure
DHA (22:6 n-3) | Decosahexaenoic acid
DM | Diabetes mellitus
DPA (22:5 n-3 or n-6) | Docosapentaenoic acid
DRI | Dietary reference intakes
DTPA | Diethylenetriamine pentoacetic acid
EFA | Essential fatty acid
EPA (20:5 n-3) | Eicosapentaenoic acid
EPC | Evidence-based Practice Center
FDA | Food and Drug Administration
GLA (18:3 n-6) | Gamma linolenic acid
GFR | Glomerular filtration rate
HRZMS | Hawksley random zero mercury sphygmomanometer
HDL | High density lipoprotein
HTN | Hypertension
IL | Interleukin
IOM | Institute of Medicine
LA (18:2 n-6) | Linoleic acid
LC PUFA | Long-chain polyunsaturated fatty acid
LDL | Low density lipoprotein
LP | Lipoprotein
LT | Leukotriene
MAP | Mean arterial pressure
NCHS | National Center for Health Statistics
NHANES III | National Health and Nutrition Examination 1988-1994
NEMC | New England Medical Center
NIH | National Institutes of Health
ODS | Office of Dietary Supplements
PAH | Para-aminohippurate
PG | Prostaglandin
PIR | Poverty Income Ratio
PUFA | Polyunsaturated fatty acid
RBC | Red blood cell
RDA | Recommended dietary allowances
SBP | Systolic blood pressure
SD | Standard deviation
SEM | Standard error of the mean
TEP | Technical Expert Panel
Tg | Triglycerides
TNF | Tumor necrosis factor
TPA | Tissue plasminogen activator
Tx | Thromboxane
UO | University of Ottawa
USDA | United States Department of Agriculture
VCAM | Vascular cell adhesion molecule
VEB | Ventricular ectopic beats
VF | Ventricular fibrillation
VFT | Ventricular fibrillation threshold
VLDL | Very low density lipoprotein
VPB | Ventricular premature beat

U.S. Department of Health and Human Services

Mike Leavitt, Secretary

Office of Public Health and Science

Richard H. Carmona, M.D., M.P.H., F.A.C.S., Surgeon General of the United States

Agency for Healthcare Research and Quality

Carolyn M. Clancy, M.D., Director