# Listing of Excluded Studies

### Reason for Rejection: No omega-3 fatty acids used

Barbagallo C M, Cefalu A B, Gallo S, et al. Effects of Mediterranean diet on lipid levels and cardiovascular risk in renal transplant recipients. Nephron. 1999;82(3):199-204. [pmid: 10395991].
Browne B J, Jordan S, Welsh M S, et al. Diet and cyclosporin A--pharmacokinetic comparison between Neoral and Sandimmune gelatin capsules. Transplantation Proceedings. Oct. 1994;26(5):2959-60. [pmid: 7940934].
Ford C, Whitlock J A, Pietsch J B. Glutamine-supplemented tube feedings versus total parenteral nutrition in children receiving intensive chemotherapy. J Pedi Oncol Nursing. Apr. 1997;14(2):68-72.
Kho T L, Leunissen K M, Wirtz J J, et al. Cyclosporine and urinary prostaglandins. Transplantation Proceedings. Feb. 1989;21(1:Pt 2):t-5. [pmid: 2652485].
Knight R J, Vathsala A, Schoenberg L, et al. Treatment of hyperlipidemia in renal transplant patients with gemfibrozil and dietary modification. Transplantation. Jan. 1992;53(1):224-5. [pmid: 1733073].
Kovarik J M, Hartmann S, Figueiredo J, et al. Effect of food on everolimus absorption: quantification in healthy subjects and a confirmatory screening in patients with renal transplants. Pharmacotherapy. Feb. 2002;22(2):154-9. [pmid: 11837553].
Lapillonne A, Hakme C, Mamoux V, et al. Effects of liver transplantation on long-chain polyunsaturated fatty acid status in infants with biliary atresia. J Pedi Gastroenterol Nutr. May. 2000;30(5):528-32.
Lenssen P, Bruemmer B A, Bowden R A, et al. Intravenous lipid dose and incidence of bacteremia and fungemia in patients undergoing bone marrow transplantation. Am J Clin Nutr. 1998;67(5):927-33. [pmid: 9583851].
Levinsky R J, Davies E G, Butler M, et al. Problems of mismatched bone marrow transplantation for severe combined immunodeficiency after soybean lectin fractionation. Birth Defects: Original Article Series. 1983;19(3):147-50. [pmid: 6360233].
McHugh M I, Wilkinson R, Elliott R W, et al. Immunosuppression with polyunsaturated fatty acids in renal transplantation. Transplantation. Oct. 1977;24(4):263-7. [pmid: 335584].
Shen S Y, Lukens C W, Alongi S V, et al. Patient profile and effect of dietary therapy on post-transplant hyperlipidemia. Kidney Int - Supplement. Dec. 1983;16:S147-S152.
Soylu A, Kavukcu S, Turkmen M, et al. Eight-year experience in pediatric renal transplantation. Transplantation Proceedings. 2002;34(6):2062-5. [pmid: 12270314].
Tan K K, Trull A K, Uttridge J A, et al. Effect of dietary fat on the pharmacokinetics and pharmacodynamics of cyclosporine in kidney transplant recipients. Clin Pharmacol & Therapeutics. Apr. 1995;57(4):425-33.
Taylor R F, Buckner C D. Fat overload from 10 percent soybean oil emulsion in a marrow transplant recipient. Western J Med. Apr. 1982;136(4):345-9.
Thomas E L, Taylor-Robinson S D, Barnard M L, et al. Changes in adipose tissue composition in malnourished patients before and after liver transplantation: a carbon-13 magnetic resonance spectroscopy and gas-liquid chromatography study. Hepatology. Jan. 1997;25(1):178-83. [pmid: 8985287].
Young J B. Fish oil and antioxidants after heart transplantation: future strategies or eye of newt and wing of bat revisited?. J Heart Lung Transplantation. Nov. 1995;14(6:Pt 2):t-4.

### Reason for Rejection: No transplant patients

Beale RJ, Bryg DJ, Bihari DJ. Immunonutrition in the critically ill: A systematic review of clinical outcome. Critical Care Med 1999;(12):2799–805.
Bechoua S, Dubois M, Vericel E, et al. Influence of very low dietary intake of marine oil on some functional aspects of immune cells in healthy elderly people. Br J Nutr Apr. 2003;89(4):523-31.
Bougnoux P, Germain E, Chajes V, et al. Cytotoxic drugs efficacy correlates with adipose tissue docosahexaenoic acid level in locally advanced breast carcinoma. Br J Cancer. Apr. 1999;79(1112):1765-9. [pmid: 10206290].
Brister S J, Buchanan M R. Effects of linoleic acid and/or marine fish oil supplements on vessel wall thromboresistance in patients undergoing cardiac surgery. Advances in Experimental Medicine & Biology. 1997;433:275-8. [pmid: 9561151].
Burke P A, Ling P R, Forse R A, et al. Sites of conditional essential fatty acid deficiency in end stage liver disease. J Parenteral Enteral Nutr. Jul. 2001;25(4):188-93.
Koller M, Senkal M, Kemen M, et al. Impact of omega-3 fatty acid enriched TPN on leukotriene synthesis by leukocytes after major surgery. Clin Nutr. 2003;22(1):59-64. [pmid: 12553951].
Senkal M, Mumme A, Eickhoff U, et al. Early postoperative enteral immunonutrition: clinical outcome and cost-comparison analysis in surgical patients. Critical Care Med. Sep. 1997;25(9):1489-96. [pmid: 9295822].
Senkal M, Zumtobel V, Bauer K H, et al. Outcome and cost-effectiveness of perioperative enteral immunonutrition in patients undergoing elective upper gastrointestinal tract surgery: A prospective randomized study. Arch Surgery. 1999;134(12):1309-16.
Wachtler P, Konig W, Senkal M, et al. Influence of a total parenteral nutrition enriched with omega-3 fatty acids on leukotriene synthesis of peripheral leukocytes and systemic cytokine levels in patients with major surgery. Journal of Trauma-Injury Infection & Critical Care. Feb. 1997;42(2):191-8.
Weiss G, Meyer F, Matthies B, et al. Immunomodulation by perioperative administration of n-3 fatty acids. Br J Nutr 2002 Jan;87:Suppl-94.
Westaby S, Parry A, Giannopoulos N, et al. Replacement of the thoracic aorta with collagen-impregnated woven Dacron grafts. Early results. J Thoracic & Cardiovascular Surgery. Sep. 1993;106(3):427-33.

### Reason for Rejection: Not human study

Jevnikar A M, Petric R, Holub B J, et al. Effect of cyclosporine on plasma lipids and modification with dietary fish oil. Transplantation. 1988;46(5):722-5. [pmid: 3194939].

### Reason for Rejection: Review, abstract, or other articles without primary data

Badalamenti S P. Fish oil improves renal perfusion in cyclosporin-treated liver transplanted patients [abstract]. Nephrol Dial Transplant. 1993;8:1034.
Badalamenti S S. Fish oil improves renal perfusion in liver transplanted (OLTx) patieents on chronic cyclosporine (CsA) treatment [EASL abstract]. J Hepatol. 1993;18(Suppl 1):S92.
Bilo H J STaea. Influence of Fish Oil on Renal Function in Cyclosporin-treated Psoriasis Patients [abstract]. Nephrol Dial Transplant. 1989;4:511.
Corda C M. Randomised, double blind study of the possible protective effects by fish oil polyunsaturated omega3 fatty acids, against cyclosporine A (CyA) induced renal damage in kidney transplants. Fundam Clin Pharmacol. 1992;6(45):223.
Darracott VE. The effects of dietary supplementation with fish oil on renal function in cyclosporine-treated renal transplant recipients: Editorial comment. J Urol;144(6):1564.
Hogg R J. A randomized, placebo-controlled, multicenter trial evaluating alternate-day prednisone and fish oil supplements in young patients with immunoglobulin A nephropathy. Scientific Planning Committee of the IgA Nephropathy Study. Am J Kidney Dis. Nov. 1995;26(5):792-6. [pmid: 7485134].
Kehn P, Fernandes G. The importance of omega-3 fatty acids in the attenuation of immune-mediated diseases. J Clin Immunol. 2001;21(2):99-101. [pmid: 11332659].
Raynard B, Nitenberg G, Gory-Delabaere G, et al. Summary of the Standards, Options and Recommendations for nutritional support in patients undergoing bone marrow transplantation (2002). Br J of Cancer. 2003;89(SUPPL. 1):S101-S106. [pmid: 12915910].
Van der Heide J J, Lynch C T. Dietary fish oil after renal transplantation. Ann Intern Med. 1994;120(6 SUPPL. 2):41.
Wanner C, Frommherz K, Horl W H. Hyperlipoproteinemia in chronic renal failure: Pathophysiological and therapeutic aspects. Cardiology. 1991;78(3):202-17. [pmid: 1868498].

### Other Reasons for Rejection

Reason: Only one patient with transplant got fish oil and the impact on lipid levels was not extractable
Shah B, Nair S, Sirsat R A, et al. Dyslipidemia in patients with chronic renal failure and in renal transplant patients. Journal of Postgraduate Medicine. Apr. 1994;40(2):57-60. [pmid: 8737552].