# References and Included Studies

### References

1 USDA. Individual Fatty Acid Intakes: Results from the 1995 Continuing Survey of Food Intakes by Individuals (data table set 4). Available online at http://www.barc.usda.gov/bhnrc/foodsurvey/home.htm. 1995.
2 Institute of Medicine. Dietary Reference Intakes: Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids (Macronutrition). 2002. The National Academy Press.
3 Simopoulos A, Leaf A. Essentiality of and recommended dietary intakes for omega-6 and omega-3 fatty acids. Ann Nutr Metab. 1999;43(2):127-130. [pmid: 10436312].
4 Fallon, S and Enig MG. Tripping Lightly Down the Prostaglandin Pathways.The Price-Pottenger Nutrition Foundation. Avaliable online at http://www.price-pottenger.org/Articles/Prostaglandin.htm. 2001.
5 Nair J, Vaca C E, Velic I, et al. High dietary omega-6 polyunsaturated fatty acids drastically increase the formation of etheno-DNA base adducts in white blood cells of female subjects. Cancer Epidemiol Biomarkers Prev. 1997;6(8):597-601. [pmid: 9264272].
6 James M J, Gibson R A, Cleland L G. Dietary polyunsaturated fatty acids and inflammatory mediator production. Am J Clin Nutr. 2000;71(1 Suppl.):343S-8S. [pmid: 10617994].
7 Krummel D. Nutrition in Cardiovascular Disease. In: Mahan LK and Escot-Stump S, editors. Krause's Food, Nutrition, and Diet Therapy. W.B. Saunder Company; 1996
8 Hornstra, G. Omega-3 long-chain polyunsaturated fatty acids and health benefits. Amended and updated version of the English translation of “Oméga-3 et bénéfice santé”, initially published by Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (NutriScience). Available online: http://www.vita-web.com/whatsnew/Omega 3.pdf. Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (NutriScience).
9 Wright, J. D., Ervin, B, and Briefel, R. R. Consensus workshop on dietary assessment: nutrition monitoring and tracking the year 2000 objectives. Available on line at http://www.cdc.gov/nchs/data/misc/nutri94acc.pdf. 1994. Hyattsville, MD, National Center for Health Statistics.
10 U.S. Department of Agriculture Agricultural Research Service. USDA National Nutrient Database for Standard Reference, Release 16. Nutrient Data Laboratory Home Page. 2003.
11 Post S, Goerig M, Menger M D. Eicosanoids and hepatic preservation for organ transplantation. Prostaglandins Leukotrienes & Essential Fatty Acids. 1994;51(5):299-309.
12 Wardle E N. Eicosanoids and renal allograft rejection. Nephron. 1995;70(2):151-154. [pmid: 7566297].
13 Calder P C. Immunoregulatory and anti-inflammatory effects of n-3 polyunsaturated fatty acids. Brazilian Journal of Medical & Biological Research. 1998;31(4):467-490. [pmid: 9698798].
14 Chapman J R, Marcen R, Arias M, et al. Hypertension after renal transplantation. A comparison of cyclosporine and conventional immunosuppression. Transplantation. 1987;43(6):860-4. [pmid: 3296353].
15 Murray B M, Paller M S, Ferris T F. Effect of cyclosporine administration on renal hemodynamics in conscious rats. Kidney Int. 1985;28(5):767-74. [pmid: 3910916].
16 Myers B D, Ross J, Newton L, Luetscher J, Perlroth M. Cyclosporine-associated chronic nephropathy. N Engl J Med. 1984;311(11):699-705. [pmid: 6382005].
17 Perico N, Benigni A, Zoja C, Delaini F, Remuzzi G. Functional significance of exaggerated renal thromboxane A2 synthesis induced by cyclosporin A. Am J Physiol. 1986;251(4 Pt 2):581-7.
18 Perico N, Pasini M, Gaspari F, Abbate M, Remuzzi G. Co-participation of thromboxane A2 and leukotriene C4 and D4 in mediating cyclosporine-induced acute renal failure. Transplantation. 1991;52(5):873-8. [pmid: 1835198].
19 McNally P G, Feehally J. Pathophysiology of cyclosporin A nephrotoxicity: experimental and clinical observations. Nephrol Dial Transplant. 1992;7(8):791-804. [pmid: 1325611].
20 Elzinga L, Kelley V E, Houghton D C, Bennett W M. Modification of experimental nephrotoxicity with fish oil as the vehicle for cyclosporine. Transplantation. 1987;43(2):271-4. [pmid: 3810835].
21 Rogers T S, Elzinga L, Bennett W M, Kelley V E. Selective enhancement of thromboxane in macrophages and kidneys in cyclosporine-induced nephrotoxicity. Dietary protection by fish oil. Transplantation. 1988;45(1):153-6. [pmid: 3422115].
22 von Schacky C, Fischer S, Weber P C. Long-term effects of dietary marine omega-3 fatty acids upon plasma and cellular lipids, platelet function, and eicosanoid formation in humans. J Clin Invest. 1985;76(4):1626-31. [pmid: 2997286]. [pmcid: 424148].
23 Kelley V E, Kirkman R L, Bastos M, Barrett L V, Strom T B. Enhancement of immunosuppression by substitution of fish oil for olive oil as a vehicle for cyclosporine. Transplantation. 1989;48(1):98-102. [pmid: 2665242].
24 Otto D A, Kahn D R, Hamm M W, Forrest D E, Wooten J T. Improved survival of heterotopic cardiac allografts in rats with dietary n-3 polyunsaturated fatty acids. Transplantation. 1990;50(2):193-8. [pmid: 2382285].
25 Endres S, Ghorbani R, Kelley V E, et al. The effect of dietary supplementation with n-3 polyunsaturated fatty acids on the synthesis of interleukin-1 and tumor necrosis factor by mononuclear cells. N Engl J Med. 1989;320(5):265-71. [pmid: 2783477].
26 Billiar T R, Bankey P E, Svingen B A, et al. Fatty acid intake and Kupffer cell function: fish oil alters eicosanoid and monokine production to endotoxin stimulation. Surgery. 1988;104(2):343-9. [pmid: 3041642].
27 Lee T H, Hoover R L, Williams J D, et al. Effect of dietary enrichment with eicosapentaenoic and docosahexaenoic acids on in vitro neutrophil and monocyte leukotriene generation and neutrophil function. N Engl J Med. 1985;312(19):1217-24. [pmid: 2985986].
28 Hernandez D, Guerra R, Milena A, et al. Dietary fish oil does not influence acute rejection rate and graft survival after renal transplantation: a randomized placebo-controlled study. Nephrol Dial Transplant. 2002;17(5):897-904. [pmid: 11981081].
29 Ford H R, Hoffman R A, Tweardy D J, et al. Evidence that production of interleukin 6 within the rejecting allograft coincides with cytotoxic T lymphocyte development. Transplantation. 1991;51(3):656-61. [pmid: 2006523].
30 Noronha I L, Hartley B, Cameron J S, Waldherr R. Detection of IL-1 beta and TNF-alpha message and protein in renal allograft biopsies. Transplantation. 1993;56(4):1026-9. [pmid: 8212184].
31 Noronha I L, Eberlein-Gonska M, Hartley B, et al. In situ expression of tumor necrosis factor-alpha, interferon-gamma, and interleukin-2 receptors in renal allograft biopsies. Transplantation. 1992;54(6):1017-24. [pmid: 1281560].
32 Dallman M J, Roake J, Hughes D, Toogood G, Morris P J. Sequential analysis of IL-2 gene transcription in renal transplants. Transplantation. 1992;53(3):683-5. [pmid: 1372454].
33 Yard B A, Daha M R, Kooymans-Couthino M, et al. IL-1 alpha stimulated TNF alpha production by cultured human proximal tubular epithelial cells. Kidney Int. 1992;42(2):383-9. [pmid: 1405321].
34 Vandenbroecke C, Caillat-Zucman S, Legendre C, et al. Differential in situ expression of cytokines in renal allograft rejection. Transplantation. 1991;51(3):602-9. [pmid: 1900962].
35 Noronha I L, Kruger C, Andrassy K, Ritz E, Waldherr R. In situ production of TNF-alpha, IL-1 beta and IL-2R in ANCA-positive glomerulonephritis. Kidney Int. 1993;43(3):682-92. [pmid: 8455368].
36 Pang G, Couch L, Batey R, Clancy R, Cripps A. GM-CSF, IL-1 alpha, IL-1 beta, IL-6, IL-8, IL-10, ICAM-1 and VCAM-1 gene expression and cytokine production in human duodenal fibroblasts stimulated with lipopolysaccharide, IL-1 alpha and TNF-alpha. Clin Exp Immunol. 1994;96(3):437-43. [pmid: 8004813]. [pmcid: 1534573].
37 Kasiske B L, Umen A J. Persistent hyperlipidemia in renal transplant patients. Medicine (Baltimore). 1987;66(4):309-16. [pmid: 3298932].
38 Wynn J, Distant D, Pirsch J, Norman D. Chapter VI: Kidney and Pancreas Transplantation. 2003.
39 Ojo A O, Hanson J A, Wolfe R A, et al. Long-term survival in renal transplant recipients with graft function. Kidney Int. 2000;57(1):307-13. [pmid: 10620213].
40 Balk E, Chung M, Lichtenstien A et al. Effects of Omega-3 fatty Acids on Cardiovascular Risk Factgors and Intermediate Markers of Cardiovascular Disease. Evidence Report/Technology Assessment No. 93. (Prepared by Tufts-New England Medical Center Evidence-based Practice Center) under contract No. 290-02-0022). AHRQ Publication NO 04-E10-2. 2004. Rockville, MD. March 2004.
41 Textor S C, Canzanello V J, Taler S J, et al. Cyclosporine-induced hypertension after transplantation. Mayo Clin Proc. 1994;69(12):1182-93. [pmid: 7967781].
42 Geleijnse J M, Giltay E J, Grobbee D E, Donders A R, Kok F J. Blood pressure response to fish oil supplementation: metaregression analysis of randomized trials. J Hypertens. 2002;20(8):1493-1499. [pmid: 12172309].
43 Takatsuka H, Yamada S, Okamoto T, et al. Predicting the severity of intestinal graft-versus-host disease from leukotriene B4 levels after bone marrow transplantation. Bone Marrow Transplant. 2000;26(12):1313-6. [pmid: 11223971].
44 Shimokawa H, Lam J Y, Chesebro J H, Bowie E J, Vanhoutte P M. Effects of dietary supplementation with cod-liver oil on endothelium-dependent responses in porcine coronary arteries. Circulation. 1987;76(4):898-905. [pmid: 3115623].
45 Shimokawa H, Vanhoutte P M. Dietary omega 3 fatty acids and endothelium-dependent relaxations in porcine coronary arteries. Am J Physiol. 1989;256(4 Pt 2):968-73.
46 Shimokawa H, Vanhoutte P M. Dietary cod-liver oil improves endothelium-dependent responses in hypercholesterolemic and atherosclerotic porcine coronary arteries. Circulation. 1988;78(6):1421-30. [pmid: 3191596].
47 Fish R D, Nabel E G, Selwyn A P, et al. Responses of coronary arteries of cardiac transplant patients to acetylcholine. J Clin Invest. 1988;81(1):21-31. [pmid: 3121675]. [pmcid: 442468].
48 Nellessen U, Lee T C, Fischell T A, et al. Effects of acetylcholine on epicardial coronary arteries after cardiac transplantation without angiographic evidence of fixed graft narrowing. Am J Cardiol. 1988;62(16):1093-7. [pmid: 3055925].
49 Cartwright I J, Pockley A G, Galloway J H, Greaves M, Preston F E. The effects of dietary omega-3 polyunsaturated fatty acids on erythrocyte membrane phospholipids, erythrocyte deformability and blood viscosity in healthy volunteers. Atherosclerosis. 1985;55(3):267-81. [pmid: 4015748].
50 Terano T, Hirai A, Hamazaki T, et al. Effect of oral administration of highly purified eicosapentaenoic acid on platelet function, blood viscosity and red cell deformability in healthy human subjects. Atherosclerosis. 1983;46(3):321-31. [pmid: 6303363].
51 van Acker B A, Bilo H J, Popp-Snijders C, et al. The effect of fish oil on lipid profile and viscosity of erythrocyte suspensions in CAPD patients. Nephrol Dial Transplant. 1987;2(6):557-61. [pmid: 2831474].
52 Terano T, Hirai A, Hamazaki T, et al. Effect of oral administration of highly purified eicosapentaenoic acid on platelet function, blood viscosity and red cell deformability in healthy human subjects. Atherosclerosis. 1983;46(3):321-31. [pmid: 6303363].
53 Kobayashi S, Hirai A, Terano T, et al. Reduction in blood viscosity by eicosapentaenoic acid. Lancet. 1981;2(8239):197. [pmid: 6114257].
54 Ernst E. Effects of n-3 fatty acids on blood rheology. J Intern Med Suppl. 1989;225(731):129-32. [pmid: 2539829].
55 Balk E M, Bonis P A, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287(22):2973-82. [pmid: 12052127].
56 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
57 Schulz K F, Chalmers I, Hayes R J, Altman D G. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-12. [pmid: 7823387].
58 Juni P, Witschi A, Bloch R, Egger M. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
59 Levey A S, Coresh J, Balk E, et al. National Kidney Foundation practice guidelines for chronic kidney disease: evaluation, classification, and stratification. Ann Intern Med. 2003;139(2):137-47. [pmid: 12859163].
60 Post T, Rose B. Assessment of renal function: plasma creatinine; BUN; and GFR. Wellesley: UpToDate, 2004.
61 Normand S L. Meta-analysis: formulating, evaluating, combining, and reporting. Stat Med. 1999;18(3):321-59. [pmid: 10070677].
62 Salen P, De Lorgeril M, Boissonnat P, et al. Effects of a French Mediterranean diet on heart transplant recipients with hypercholesterolemia. American Journal of Cardiology. 1994;73(11):825-827. [pmid: 8093149].
63 Kooijmans-Coutinho M F, Rischen-Vos J, Hermans J, Arndt J W, van der Woude F J. Dietary fish oil in renal transplant recipients treated with cyclosporin-A: no beneficial effects shown. J Am Soc Nephrol. 1996;7(3):513-518. [pmid: 8704119].
64 Homan van der Heide J, Bilo H J G, Donker J M, Wilmink J M, Tegzess A M. Effect of dietary fish oil on renal function and rejection in cyclosporine-treated recipients of renal transplants. N Engl J Med. 1993;329(11):769-773. [pmid: 8350886].
65 Busnach G, Stragliotto E, Minetti E, et al. Effect of n-3 polyunsaturated fatty acids on cyclosporine pharmacokinetics in kidney graft recipients: a randomized placebo-controlled study. J Nephrol. 1998;11(2):87-93. [pmid: 9589380].
66 Bennett W M, Carpenter C B, Shapiro M E, et al. Delayed omega-3 fatty acid supplements in renal transplantation. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. Transplantation. 1995;59(3):352-356. [pmid: 7871564].
67 Berthoux F C, Guerin C, Burgard G, Berthoux P, Alamartine E. One-year randomized controlled trial with omega-3 fatty acid-fish oil in clinical renal transplantation. Transplantation Proceedings. 1992;24(6):2578-2582. [pmid: 1465872].
68 Castro R, Queiros J, Fonseca I, et al. Therapy of post-renal transplantation hyperlipidaemia: comparative study with simvastatin and fish oil. Nephrol Dial Transplant. 1997;12(10):2140-2143. [pmid: 9351079].
69 Maachi K, Berthoux P, Burgard G, Alamartine E, Berthoux F. Results of a 1-year randomized controlled trial with omega-3 fatty acid fish oil in renal transplantation under triple immunosuppressive therapy. Transplantation Proceedings. 1995;27(1):846-849. [pmid: 7879202].
70 Santos J, Queiros J, Silva F, et al. Effects of fish oil in cyclosporine-treated renal transplant recipients. Transplantation Proceedings. 2000;32(8):2605-2608. [pmid: 11134724].
71 Grekas D, Kassimatis E, Makedou A, et al. Combined treatment with low-dose pravastatin and fish oil in post-renal transplantation dislipidemia. Nephron. 2001;88(4):329-333. [pmid: 11474227].
72 Hansen J M, Lokkegaard H, Hoy C E, et al. No effect of dietary fish oil on renal hemodynamics, tubular function, and renal functional reserve in long-term renal transplant recipients. J Am Soc Nephrol. 1995;5(7):1434-1440. [pmid: 7703381].
73 Homan van der Heide J, Bilo H J, Donker A J, et al. The effects of dietary supplementation with fish oil on renal function and the course of early postoperative rejection episodes in cyclosporine-treated renal transplant recipients. Transplantation. 1992;54(2):257-263. [pmid: 1496538].
74 Homan van der Heide J, Bilo H J, Donker A J, et al. Dietary supplementation with fish oil modifies renal reserve filtration capacity in postoperative, cyclosporin A-treated renal transplant recipients. Transplant Int. 1990;3(3):171-175.
75 Urakaze M, Hamazaki T, Yano S, et al. Effect of fish oil concentrate on risk factors of cardiovascular complications in renal transplantation. Transplantation Proceedings. 1989;21(1:Pt 2):t-6. [pmid: 2652688].
76 Urakaze M, Hamazaki T, Kashiwabara H, et al. Favorable effects of fish oil concentrate on risk factors for thrombosis in renal allograft recipients. Nephron. 1989;53(2):102-109. [pmid: 2812166].
77 Andreassen A K, Hartmann A, Offstad J, et al. Hypertension prophylaxis with omega-3 fatty acids in heart transplant recipients. J Am Coll Cardiol. 1997;29(6):1324-1331. [pmid: 9137231].
78 Barbir M, Hunt B, Kushwaha S, et al. Maxepa versus bezafibrate in hyperlipidemic cardiac transplant recipients. Am J Cardiol. 1992;70(20):1596-1601. [pmid: 1466329].
79 Fleischhauer F J, Yan W D, Fischell T A. Fish oil improves endothelium-dependent coronary vasodilation in heart transplant recipients. J Am Coll Cardiol. 1993;21(4):982-989. [pmid: 8450169].
80 Holm T, Berge R K, Andreassen A K, et al. Omega-3 fatty acids enhance tumor necrosis factor-alpha levels in heart transplant recipients. Transplantation. 2001;72(4):706-711. [pmid: 11544435].
81 Ventura H O, Mehra M R, Stapleton D D, Smart F W. Cyclosporine-induced hypertension in cardiac transplantation. Medical Clinics of North America. 1997;81(6):1347-1357. [pmid: 9356603].
82 Badalamenti S, Salerno F, Lorenzano E, et al. Renal effects of dietary supplementation with fish oil in cyclosporine-treated liver transplant recipients. Hepatology. 1995;22(6):1695-71. [pmid: 7489976].
83 Takatsuka H, Takemoto Y, Iwata N, et al. Oral eicosapentaenoic acid for complications of bone marrow transplantation. Bone Marrow Transplantation. 2001;28(8):769-774. [pmid: 11781629].
84 Butani L, Palmer J. Effect of fish oil in a patient with post-transplantation IgA nephropathy. Nephrol Dial Transplant. 2000;15(8):1264-1265. [pmid: 10910466].
85 Ng R. Fish oil therapy in recurrent IgA nephropathy. Ann Intern Med. 2003;138(12):1011-1012. [pmid: 12809474].
86 Donadio J V, Grande J P. The role of fish oil/omega-3 fatty acids in the treatment of IgA nephropathy. Semin Nephrol. 2004;24(3):225-43. [pmid: 15156528].
87 Dillon J J. Fish oil therapy for IgA nephropathy: efficacy and interstudy variability. J Am Soc Nephrol. 1997;8(11):1739-1744. [pmid: 9355077].
88 Homan van der Heide J, Bilo H J, Tegzess A M, Donker A J. The effects of dietary supplementation with fish oil on renal function in cyclosporine-treated renal transplant recipients. Transplantation. 1990;49(3):523-527. [pmid: 2316014].
89 Holm T, Andreassen A K, Aukrust P, et al. Omega-3 fatty acids improve blood pressure control and preserve renal function in hypertensive heart transplant recipients. Eu Heart Journal. 2001;22(5):428-436.
90 Badalamenti S S. Fish oil improves renal perfusion in liver transplanted (OLTx) patieents on chronic cyclosporine (CsA) treatment. J Hepatol. 1993;18(Suppl 1):S92.
91 Rodriguez A P DBG-PJT. Treatment of hyperlipidemia after renal transplantation: Comparative effect of lovastatin and omega-3 fatty acids. <ORIGINAL> TRATAMIENTO DE LA DISLIPEMIA POSTRASPLANTE RENAL: EFECTO COMPARATIVO DE LA LOVASTATINA Y ACIDOS GRASOS POLIINSATURADOS OMEGA-3. Nefrologia. 1997;17(1):49-54.
92 Anderson M, Fritsche K L. (n-3) Fatty acids and infectious disease resistance. J Nutr. 2002;132(12):3566-76. [pmid: 12468590].
93 Levi M, Wilmink J, Buller H R, Surachno J, ten Cate J W. Impaired fibrinolysis in cyclosporine-treated renal transplant patients. Analysis of the defect and beneficial effect of fish-oil. Transplantation. 1992;54(6):978-983. [pmid: 1465791].
94 Schut N H, Bilo H J, Popp-Snijders C, Goedhart P T, Wilmink J M. Erythrocyte deformability, endothelin levels, and renal function in cyclosporin-treated renal transplant recipients: effects of intervention with fish oil and corn oil. Scand J Clin & Lab Invest. 1993;53(5):499-506. [pmid: 8210973].
95 Schut N H, Hardeman M R, Goedhart P T, Bilo H J G, Wilmink J M. Blood viscosity measurements are not sensitive enough to detect changes in erythrocyte deformability in cyclosporin-treated patients and its subsequent reversal with fish and corn oil. Clin Hemorheology. 1993;13(4):465-472.
96 Kahan B D, Welsh M, Rutzky L P. Challenges in cyclosporine therapy: the role of therapeutic monitoring by area under the curve monitoring. Ther Drug Monit. 1995;17(6):621-4. [pmid: 8588231].
97 Alexander J, Metze T, Goodman H, Cardi M, Austin J. Simultaneous corticosteroid avoidance and calcinuerin inhibitor minimization in renal transplantation. in press 2004.
98 Takatsuka H, Takemoto Y, Yamada S, et al. Oral eicosapentaenoic acid for acute colonic graft-versus-host disease after bone marrow transplantation. Drugs Under Experimental & Clinical Research. 2002;28(4):121-125. [pmid: 12512229].

### Bibliography of Included Studies

Andreassen A K, Hartmann A, Offstad J, et al. Hypertension prophylaxis with omega-3 fatty acids in heart transplant recipients. J Am Coll Cardiol. 1997;29(6):1324-31. [pmid: 9137231].
Badalamenti S, Salerno F, Lorenzano E, et al. Renal effects of dietary supplementation with fish oil in cyclosporine-treated liver transplant recipients. Hepatology. 1995;22(6):1695-71. [pmid: 7489976].
Barbir M, Hunt B, Kushwaha S, et al. Maxepa versus bezafibrate in hyperlipidemic cardiac transplant recipients. Am J of Cardiol. 1992;70(20):1596-601. [pmid: 1466329].
Bennett W M, Carpenter C B, Shapiro M E, et al. Delayed omega-3 fatty acid supplements in renal transplantation. A double-blind, placebo-controlled study. Transplantation. 1995;59(3):352-6. [pmid: 7871564].
Berthoux F C, Guerin C, Burgard G, et al. One-year randomized controlled trial with omega-3 fatty acid-fish oil in clinical renal transplantation. Transplantation Proceedings. 1992;24(6):2578-82. [pmid: 1465872].
Busnach G, Stragliotto E, Minetti E, et al. Effect of n-3 polyunsaturated fatty acids on cyclosporine pharmacokinetics in kidney graft recipients: a randomized placebo-controlled study. J Nephrol. 1998;11(2):87-93. [pmid: 9589380].
Butani L, Palmer J. Effect of fish oil in a patient with post-transplantation IgA nephropathy. Nephrology Dialysis Transplantation. 2000;15(8):1264-5.
Castro R, Queiros J, Fonseca I, et al. Therapy of post-renal transplantation hyperlipidaemia: comparative study with simvastatin and fish oil. Nephrology Dialysis Transplantation. 1997;12(10):2140-3.
Fleischhauer F J, Yan W D, Fischell T A. Fish oil improves endothelium-dependent coronary vasodilation in heart transplant recipients. J Am Coll Cardiol. 1993;21(4):982-9. [pmid: 8450169].
Grekas D, Kassimatis E, Makedou A, et al. Combined treatment with low-dose pravastatin and fish oil in post-renal transplantation dislipidemia. Nephron. 2001;88(4):329-33. [pmid: 11474227].
Hansen J M, Lokkegaard H, Hoy C E, et al. No effect of dietary fish oil on renal hemodynamics, tubular function, and renal functional reserve in long-term renal transplant recipients. J Am Soc Nephrol. 1995;5(7):1434-40. [pmid: 7703381].
Hansen J M, Hoy C E, Strandgaard S. Fish oil and cyclosporin A-induced renal hypoperfusion in kidney-transplanted patients. Nephrol Dial Transplant. 1995;10(9):1745-50. [pmid: 8559499].
Hernandez D, Guerra R, Milena A, et al. Dietary fish oil does not influence acute rejection rate and graft survival after renal transplantation: a randomized placebo-controlled study. Nephrol Dial Transplant. 2002;17(5):897-904. [pmid: 11981081].
Holm T, Berge R K, Andreassen A K, et al. Omega-3 fatty acids enhance tumor necrosis factor-alpha levels in heart transplant recipients. Transplantation. 2001;72(4):706-11. [pmid: 11544435].
Holm T, Andreassen A K, Aukrust P, et al. Omega-3 fatty acids improve blood pressure control and preserve renal function in hypertensive heart transplant recipients. European Heart Journal. 2001;22(5):428-36. [pmid: 11207085].
Homan van der Heide J, Bilo H J, Donker A J, et al. Dietary supplementation with fish oil modifies renal reserve filtration capacity in postoperative, cyclosporin A-treated renal transplant recipients. Transplant International. 1990;3(3):171-5. [pmid: 2271089].
Homan van der Heide J, Bilo H J, Tegzess A M, et al. The effects of dietary supplementation with fish oil on renal function in cyclosporine-treated renal transplant recipients. Transplantation. 1990;49(3):523-7. [pmid: 2316014].
Homan van der Heide J, Bilo H J, Donker A J, et al. The effects of dietary supplementation with fish oil on renal function and the course of early postoperative rejection episodes in cyclosporine-treated renal transplant recipients. Transplantation. 1992;54(2):257-63. [pmid: 1496538].
Homan van der Heide J, Bilo H J G, Donker J M, et al. Effect of dietary fish oil on renal function and rejection in cyclosporine-treated recipients of renal transplants. N Engl J Med. 1993;329(11):769-73. [pmid: 8350886].
Kooijmans-Coutinho M F, Rischen-Vos J, Hermans J, et al. Dietary fish oil in renal transplant recipients treated with cyclosporin-A: no beneficial effects shown. J Am Soc Nephrol. 1996;7(3):513-8. [pmid: 8704119].
Levi M, Wilmink J, Buller H R, et al. Impaired fibrinolysis in cyclosporine-treated renal transplant patients. Analysis of the defect and beneficial effect of fish-oil. Transplantation. 1992;54(6):978-83. [pmid: 1465791].
Maachi K, Berthoux P, Burgard G, et al. Results of a 1-year randomized controlled trial with omega-3 fatty acid fish oil in renal transplantation under triple immunosuppressive therapy. Transplantation Proceedings. 1995;27(1):846-9. [pmid: 7879202].
Ng R. Fish oil therapy in recurrent IgA nephropathy. Ann Intern Med. Jun 17. 2003;138(12):1011-2. [pmid: 12809474].
Rodriguez A P DBG-PJT. Treatment of hyperlipidemia after renal transplantation: Comparative effect of lovastatin and omega-3 fatty acids. <ORIGINAL> TRATAMIENTO DE LA DISLIPEMIA POSTRASPLANTE RENAL: EFECTO COMPARATIVO DE LA LOVASTATINA Y ACIDOS GRASOS POLIINSATURADOS OMEGA-3. Nefrologia. 1997;17(1):49-54.
Salen P, De Lorgeril M, Boissonnat P, et al. Effects of a French Mediterranean diet on heart transplant recipients with hypercholesterolemia. Am J Cardiol. 1994;73(11):825-7. [pmid: 8093149].
Santos J, Queiros J, Silva F, et al. Effects of fish oil in cyclosporine-treated renal transplant recipients. Transplantation Proceedings. 2000;32(8):2605-8. [pmid: 11134724].
Schut NH, Hardeman MR, Goedhart PT, et al. Blood viscosity measurements are not sensitive enough to detect changes in erythrocyte deformability in cyclosporin-treated patients and its subsequent reversal with fish and corn oil. Clin Hemorheology 1993;(4):465–72.
Schut N H, Bilo H J, Popp-Snijders C, et al. Erythrocyte deformability, endothelin levels, and renal function in cyclosporin-treated renal transplant recipients: effects of intervention with fish oil and corn oil. Scandinavian Journal of Clinical & Laboratory Investigation. 1993;53(5):499-506. [pmid: 8210973].
Sweny P, Wheeler D C, Lui S F, et al. Dietary fish oil supplements preserve renal function in renal transplant recipients with chronic vascular rejection. Nephrol Dial Transplant. 1989;4(12):1070-5. [pmid: 2517328].
Sweny P. Use of dietary fish oils in renal allograft recipients with chronic vascular rejection. Transplantation Proceedings. 1993;25(2):2089-91. [pmid: 8470281].
Takatsuka H, Takemoto Y, Iwata N, et al. Oral eicosapentaenoic acid for complications of bone marrow transplantation. Bone Marrow Transplantation. 2001;28(8):769-74. [pmid: 11781629].
Takatsuka H, Takemoto Y, Yamada S, et al. Oral eicosapentaenoic acid for acute colonic graft-versus-host disease after bone marrow transplantation. Drugs Under Experimental & Clinical Research. 2002;28(4):121-5. [pmid: 12512229].
Urakaze M, Hamazaki T, Yano S, et al. Effect of fish oil concentrate on risk factors of cardiovascular complications in renal transplantation. Transplantation Proceedings. 1989;21(1:Pt 2):t-6. [pmid: 2652688].
Urakaze M, Hamazaki T, Kashiwabara H, et al. Favorable effects of fish oil concentrate on risk factors for thrombosis in renal allograft recipients. Nephron. 1989;53(2):102-9. [pmid: 2812166].
Ventura HO, Mehra MR, Stapleton DD, et al. Cyclosporine-induced hypertension in cardiac transplantation. Medical Clinics of North America 1997;(6):1347–57.
Yoa R G, Corda C, Rapin J R, et al. Hemorheological benefits of omega-3 polyunsatured fatty acids on erythrocyte deformability in renal transplanted patients. Clin Hemorheology. 1994;14(5):663-75.
Zolotarski V, Cohen J, Sharabani E, et al. Parenteral fish oil administered to heart-beating organ donors and to renal transplant recipients: effects on renal function. Transplantation Proceedings. 2003;35(2):624. [pmid: 12644071].