# Acknowledgments

We would like to acknowledge with appreciation the following members of the Technical Expert Panel for their advice and consultation to the Evidence-based Practice Center during preparation of this report.

## Technical Expert Panel

- William S. Harris, PhD
- Daniel Lauer/Missouri Professor of Metabolism and Vascular Research
- University of Missouri, School of Medicine, Kansas City
- Co-Director, Lipid and Diabetes Research Center
- Mid America Heart Institute at Saint Luke's Hospital
- Kansas City, Missouri

- Ronald Perrone, MD
- Professor of Medicine
- Tufts University School of Medicine
- Associate Chief, Division of Nephrology
- Tufts-New England Medical Center
- Boston, Massachusetts

- John A. Jarcho, MD
- Clinical Assistant Professor of Medicine
- Harvard Medical School
- Associate Physician Division of Cardiology
- Brigham and Women's Hospital
- Boston, Massachusetts

- J. Wesley Alexander, M.D.
- Technical Expert, for the American Society of Transplant Surgeons and the American Society for Transplantation
- Professor of Surgery
- Department of Surgery
- University of Cincinnati Medical Center
- Cincinnati, Ohio

- Alice H. Lichtenstein, DSc
- Stanley N. Gershoff Professor of Nutrition Science and Policy
- Gerald J. & Dorothy R. Friedman School of Nutrition Science & Policy
- Director and Senior Scientist, Cardiovascular Nutrition Laboratory
- Jean Mayer USDA Human Nutrition Research Center on Aging
- Tufts University
- Boston, Massachusetts

- Patricia J. Kehn, MS
- Technical Expert and Representative, National Institute of Allergy and Infectious Disease
- Div. of Allergy, Immunology & Transplantation
- National Institute of Allergy and Infectious Disease
- Bethesda, Maryland