# Results

This chapter summarizes results of our literature search and findings from the studies that passed our screening and selection process. We considered all types of transplants together in attempting to answer the key questions posed by the TEP whenever feasible. An example is the effect of omega-3 fatty acid supplementation on the pharmacokinetics of cyclosporine, an interaction that may be apparent regardless of the type of transplant. On the other hand, all key questions were also addressed with specific consideration of the different transplantation types (i.e., kidney, heart, bone marrow, and liver) since the potential effects may vary by transplant type and because there are clinical issues specific to each form of transplantation.

## Summary of Studies Found

The literature search identified 1,281 abstracts. From these, and from the articles found in bibliographies, a total of 78 studies were ultimately selected for full-text screening (based upon the initial abstract screening and review of the bibliographies of retrieved studies including review articles). Thirty nine of these were rejected because they did not fulfill inclusion (See Reference List of Rejected Articles) criteria leaving 39 for inclusion. Careful additional review of these studies revealed 8 that were duplicate reports of the same patients leaving a total of 31 independent reports. There were 23 kidney transplant studies with a total of 846 patients, 6 heart transplant studies with 233 patients, 1 liver transplant study with 26 patients, and 1 bone marrow transplant study with 17 patients. The study designs of the qualifying studies include 21 RCTs, 2 non-RCTs, 6 prospective cohort studies and 2 case reports (Figure 3.1). Fish oil supplements were used in all but 1 heart transplant study in which a Mediterranean diet was used.^62^ Since the biological effects of long-chain omega-3 fatty acids (EPA and DHA) are different from ALA, the results should be considered separately. As a result, the findings of this report apply almost exclusively to fish oil supplementation.

Figure 3.2 Random Effects Model Meta-Analysis of Graft Survival in Randomized-Controlled Trials in Kidney Transplant Patients

Figure 3.3 Random Effects Model Meta-Analysis of Proportion of Patients with an Acute Rejection Episode within First Month of Kidney Transplantation in Randomized-Controlled Trials

Figure 3.4 Random Effects Model Meta-Analysis of the Proportion of Patients with an Acute Rejection Episode Within One Year of Kidney Transplantation in Randomized-Controlled Trials

Figure 3.1 Summary of study selection processes. RCTs indicates randomized-controlled trials; non-RCT Indicates non-randomized-controlled trials

Twelve study authors of the largest controlled trials were contacted (by telephone or email or both) and, of them, 5 responded. None was aware of additional published or unpublished data. Similarly, the final list of included studies was considered to be complete after review by the TEP. One member of the TEP reported that he was involved in a pilot study involving omega-3 fatty acids in kidney transplantation that had not yet been completed; he provided a draft manuscript, which is described at the end of this chapter.

The studies are described in the evidence tables, which have been designed to feature key elements of the studies and allow for easy comparison across studies.

## Quality of the Studies

Studies were generally small, and many had important methodological limitations as indicated by the quality measures in summary tables. Masking and methods of randomization were generally not well described. Even among studies in which masking of patients and caregivers was described, it is likely that patients and caregivers became unmasked since fish oil supplementation was frequently associated with a fishy taste and dyspeptic side-effects in the active intervention arm, especially early in the course of treatment. Many controlled trials did not use isocaloric treatments or fats with comparable fatty-acid profiles in the control group, potentially biasing comparisons, especially for cardiovascular outcomes. Furthermore, there was variability in the degree to which compliance was assessed.

Similarly, there was variability in the rigor with which endpoints were defined and measured. Important covariates (such as use of antihypertensive agents or the intensity of immunosuppression) were often not well described or uniformly applied even when the study considered outcomes that may have been confounded by these factors.

Summary results were potentially underpowered since very few controlled studies analyzed the statistical significance for net differences in effects. Most studies only analyzed differences between groups at various time points during the study.

## Graft Related Outcomes

### Question 1: What is the evidence that omega-3 fatty acid supplementation reduced rejection episodes or graft failure in patients (adults or children) who received an organ transplant?

#### Kidney Transplantation

##### Patient survival

There were 7 deaths out of a total of 846 kidney transplant patients, all of which were reported in 3 studies.^63–65^ A total of 4 patients died with a functional graft within 1 year of transplant (1 patient in the fish oil group and 3 patients in the placebo group).^63^ One patient died of myocardial infarction in the placebo group.^64^ In a 9-month randomized controlled trial (RCT), 2 patients in the fish oil group died due to hemorrhagic shock from removal of native polycystic kidney and intestinal infarction.^65^

##### Graft survival

A total of 10 RCTs, with 291 patients in the fish oil group and 312 patients in the placebo or control group, described graft survival among kidney transplant recipients.^28,^ ^63–70^ However, most studies did not perform quantitative, graft survival analyses underscoring the excellent overall results in kidney transplantation regardless of fish oil supplementation. One exception was a RCT in which one-year graft survival tended to be better in the fish oil group, although results did not achieve statistical significance.^64^ Two other RCTs showed no statistically significant difference in one-year graft and patient survival rates between fish oil and placebo or control group.^28,^ ^67^

Fish oil supplementation was begun 3 days post-transplant in 7 of these 10 reports with a total of 228 and 234 subjects in the fish oil and control groups, respectively (Table 3.1). The studies were all of low or intermediate quality. The pooled relative risk of graft survival in those receiving fish oil supplementation was 1.00 (95% CI 0.96, 1.05). There was no statistical heterogeneity among studies.

Table 3.1 Effects of Fish oil on Graft Survival in Randomized-Controlled Trials in Kidney Transplant Patients

Author, Year | Fish oil EPA+DHA (g/d) | Placebo or Control Arm | Treatment Duration | [underlined: Fish oil] | | [underlined: Control] | | RR | Treatment Started (Post-transplant) | [underlined: Quality] ^b^
| | | | Event | Total | Event | Total | (95% CI) | | Summary | Jadad | Allocation Conceal
Homan van der Heide, 1992 | 3.0 | Coconut oil | 1 mo | 39 | 40 | 47 | 48 | 1 | Day 3 | B | 3 | Un
| | | | | | | | (0.93–1.06)
Homan van der Heide, 1993 | 3.0 | Coconut oil | 1 yr | 30 | 31 | 28 | 32 | 1.11 | Day 3 | B | 3 | Un
| | | | | | | | (0.96–1.28)
Kooijmans-Coutinho, 1996 | 3.0 | Coconut oil | 1 yr | 20 | 24 | 20 | 23 | 0.96 | Day 3 | B | 5 | In
| | | | | | | | (0.75–1.22)
Santos, 2000 | 3.0 | Placebo | 1 yr | 15 | 15 | 15 | 15 | 1 | Day 2 | B | 2 | Un
| | | | | | | | (0.88–1.13)
Berthoux, 1992 | 2.7 | No placebo | 1 yr | 11 | 14 | 11 | 15 | 1.07 | Day 3 | C | 1 | Un
| | | | | | | | (0.71–1.61)
Busnach, 1998 | 2.6 | Olive oil | 9 mo | 17 | 19 | 19 | 21 | 0.99 | Day 1 | B | 3 | Un
| | | | | | | | (0.80–1.22)
Maachi, 1995 | 2.5 | No placebo | 1 yr | 35 | 40 | 35 | 40 | 1 | Day 3 | C | 1 | Un
| | | | | | | | (0.85–1.18)
Hernandez, 2002 | 1.9 | Soy oil | 3 mo ^a^ | 39 | 45 | 36 | 40 | 0.96 | Day 2 | B | 3 | Un
| | | | | | | | (0.83–1.12)
Random effects model meta-analysis: | | | | 206 | 228 | 211 | 234 | 1.00
Total patients = | | | | | | | | (0.96–1.05)

Yr = year(s); mo = month(s); RR = Relative risk of fish oil arm to placebo/controlled arm; CI = confidence interval; Event = Number of survived grafts

a Treatment stopped at 3 months with follow-up results observed at 1 year

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

In 2 studies,^66,^ ^68^ fish oil was begun at 16 weeks and over one year post-transplant. Thus, the enrolled patients would be expected to have relatively stable renal function compared to the studies in which treatment was begun within days after transplant. No benefit from fish oil treatment was observed in either study (Table 3.2).

Table 3.2 Effects of Fish oil on Graft Survival in Randomized-Controlled Trials in Kidney Transplant Patients Who Received Delayed Treatment

Author, Year | Fish oil EPA+DHA (g/d) | Placebo or Control Arm | Treatment Duration | [underlined: Fish oil] | | [underlined: Control] | | RR | Treatment Started (Post-transplant) | [underlined: Quality] ^b^
| | | | Event | Total | Event | Total | (95% CI) | | Summary | Jadad | Allocation Conceal
Bennet, 1995 | 5.4 | Corn oil | 26 wks | 22 | 22 | 50 | 50 ^a^ | 0.99 | 16 weeks | B | 3 | Un
| | | | | | | | (0.92–1.06)
| 2.7 | Corn oil | 26 wks | 18 | 18 | 50 | 50 ^a^ | 0.98
| | | | | | | | (0.91–1.06)
Castro, 1997 | 3 | Simvastatin | 3 mo | 18 | 18 | 25 | 25 | 0.99 | ≥1 year | C | 2 | In
| | 10 mg/d | | | | | | (0.94–1.03

Wks = weeks; mo = month(s); RR = Relative risk of fish oil arm to placebo/controlled arm; Event = Number of survived grafts

a Data on high-dose and low-dose controls were combined.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

Furthermore, all grafts and patients survived in 2 prospective cohort studies with a total of 42 kidney transplant recipients who received fish oil treatments at least 6 months post-transplant.^71,^ ^72^

##### Rejection Episodes

Acute rejection episodes were described at varying time points in a total of 11 controlled trials, including 297 patients in the fish oil group and 282 patients in the placebo or control group.^28,^ ^63–67,^ ^69,^ ^70,^ ^73–76^ The studies were all of low or intermediate quality. In all but 2 studies (published in 3 papers^66,^ ^75,^ ^76^), treatment had been initiated within 3 days following transplantation.

One study reported only total episodes of rejection according to treatment (rather than the proportion of patients having a rejection episode), noting a statistically significant reduction in the total number of rejection episodes in the group receiving fish oil.^64^ However, it was not possible to tell whether these differences could have been accounted for by multiple episodes of rejection in a small number of patients (or even a single patient). The authors described six episodes of rejection in the fish oil group compared with 10 in the control group at one month. In the second and third months, there was only 1 acute rejection episode in the fish oil group compared with 9 in the control group (P=0.016). In months 4 through 6, there were no rejection episodes in either group. Between month 6 and 12, there was 1 rejection episode in each group. Thus, during the year after transplantation, the total number of acute rejection episodes was significantly lower in the fish oil group than in the controls (8 versus 20, P=0.029). These results did not translate into statistically significant improved graft survival at one year (97 versus 84 percent, P=0.097).

The other 8 randomized controlled trials (in which treatment was started within 3 days post-transplant) described the proportion of patients with at least one rejection episode. The results for “early” and “late” rejection (as defined above) were combined using a random effects model, which showed no significant benefit at any time point examined (Table 3.3). Results for 2 studies that reported rejection episodes between 2 to 9 and 3 to 12 months were not pooled since the time points reported combined “early” and “late” episodes together.^63,^ ^65^ The pooled relative risk of a rejection episode in those receiving fish oil supplementation was 0.91 (95% CI 0.75, 1.11) in four studies with a total of 224 subjects that reported the longest follow-up (i.e., 1 year). There was no significant heterogeneity among the studies. To allow for clinically meaningful comparisons across studies, rejection episodes were defined as being “early” (within the first 6 months of transplant) or “late” (after 6 months), corresponding with generally accepted clinical criteria.

Table 3.3 Effects of Fish oil on the Proportion of Patients with an Acute Rejection Episode in Randomized-Controlled Trials in Kidney Transplant Patients Who Received Treatment Immediately after Transplant

Author, Year | Fish oil EPA+DHA (g/d) | Placebo or Control Arm | Treatment Duration | [underlined: Fish Oil] | | [underlined: Control] | | RR | Treatment Started (Post-transplant) | [underlined: Quality] ^b^
| | | | Event | Total | Event | Total | (95% CI) | | Summary | Jadad | Allocation Conceal
Homan van der Heide, 1992 | 3.0 | Coconut oil | 1 mo | 15 | 40 | 12 | 48 | 1.50 | Day 3 | B | 3 | Un
| | | | | | | | (0.80–2.82)
Kooijmans-Coutinho, 1996 | 3.0 | Coconut oil | 1 mo | 11 | 25 | 11 | 25 | 1.00 | Day 3 | B | 5 | In
| | | | | | | | (0.54–1.87)
Homan van der Heide 1990a | 3.0 | Coconut oil | 1 mo | 3 | 14 | 6 | 17 | 0.61 | Day 3 | B | 3 | Un
| | | | | | | | (0.18–2.00)
Busnach, 1998 | 2.6 | Olive oil | 1 mo | 3 | 17 | 2 | 19 | 1.68 | Day 1 | B | 3 | Un
| | | | | | | | (0.32–8.88)
Hernandez, 2002 | 1.9 | Soy oil | 1 mo | 16 | 45 | 12 | 40 | 1.19 | Day 2 | B | 3 | Un
| | | | | | | | (0.64–2.19)
Random effects meta-analysis: | | | | 48 | 141 | 43 | 149 | 1.16
Total patients = | | | | | | | | (0.83–1.63)
Kooijmans-Coutinho, 1996 | 3.0 | Coconut oil | 2–3 mo | 13 | 23 | 3 | 24 | 4.52 | Day 3 | B | 5 | In
| | | | | | | | (1.48–13.8)
Hernandez, 2002 | 1.9 | Soy oil | 2–3 mo | 4 | 45 | 4 | 40 | 0.89 | Day 2 | B | 3 | Un
| | | | | | | | (0.23–3.3)
Random effects meta-analysis: | | | | 17 | 68 | 7 | 64 | 2.04
Total patients = | | | | | | | | (0.43–9.62)
Busnach, 1998 | 2.6 | Olive oil | 2–9 mo | 0 | 17 | 1 | 19 | - | Day 1 | B | 3 | Un
Kooijmans-Coutinho, 1996 | 3.0 | Coconut oil | 3–12 mo | 3 | 22 | 3 | 22 | 1.00 | Day 3 | B | 5 | In
| | | | | | | | (0.23–4.42)
No meta-analysis performed for this group of data
Santos, 2000 | 3.0 | Placebo | 1 yr | 4 | 15 | 6 | 15 | 0.67 | Day 2 | B | 2 | Un
| | | | | | | | (0.23–1.89)
Berthoux, 1992 | 2.7 | No placebo | 1 yr | 9 | 14 | 10 | 15 | 0.96 | Day 3 | C | 1 | Un
| | | | | | | | (0.57–1.64)
Maachi, 1995 | 2.5 | No placebo | 1 yr | 29 | 40 | 32 | 40 | 0.8 | Day 3 | C | 1 | Un
| | | | | | | | (0.71–1.16)
Hernandez, 2002 | 1.9 | Soy oil | 3 mo ^a^ | 20 | 45 | 19 | 40 | 0.94 | Day 2 | B | 3 | Un
| | | | | | | | (0.59–1.48)
Random effects meta-analysis: | | | | 62 | 114 | 67 | 110 | 0.91
Total patients = | | | | | | | | (0.75–1.11)

Yr = year(s); mo = month(s); RR = Relative risk of fish oil arm to placebo/controlled arm; Event = number of patients with at least one rejection episodes

a Treatment was stopped at 3 months with follow-up results reported at 1 year

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

In 2 studies published in 3 papers^66,^ ^75,^ ^76^ fish oil supplementation was begun at 16 weeks and an average of 25 months post-transplant. No significant differences in acute rejection episodes were found in either study (Table 3.4).

Table 3.4 Effects of Fish oils on the Proportion of Patients with an Acute Rejection Episode in Randomized-Controlled Trials in Kidney Transplant Patients Who Received Delayed Treatment

Author, Year | Fish oil EPA+DHA (g/d) | Placebo or Control Arm | Treatment Duration | [underlined: Fish Oil] | | [underlined: Control] | | RR | Treatment Started (Post-transplant) | [underlined: Quality] ^c^
| | | | Event | Total | Event | Total | (95% CI) | | Summary | Jadad | Allocation Conceal
Bennet, 1995 | 5.4 | Corn oil | 26 wks | 2 ^b^ | 22 | 2 | 50 ^a^ | 2.27 | 16 weeks | B | 3 | Un
| | | | | | | | (0.34–15.1)
| 2.7 | Corn oil | 26 wks | 0 | 18 | 2 | 50 ^a^ | 0.54
| | | | | | | | (0.03–10.7)
Urakaze 1989; Urakaze 1989 | 2.2 | No treatment | 6 mo | 0 | 14 | 0 | 16 | 1.13 | Mean 25 months | B | 1 | Un
| | | | | | | | (0.02–53.7)

Wks = week(s); mo = month(s); RR = Relative risk of fish oil arm to placebo/controlled arm; Event = number of patients with at least one rejection episodes

a Data on high-dose and low-dose controls were combined.

b Authors stated that plasma EPA values in these 2 patients were not different from values in placebo, indicating noncompliance.

c Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

Overall, either immediate or delayed supplementation with fish oil showed no benefit on graft survival among patients who had kidney transplants. No reduction in either early or late acute rejections was found with fish oil supplementation.

#### Heart Transplantation

Although 6 studies described a variety of outcomes in a total of 233 heart transplant recipients (see Evidence Table II). ^62,^ ^77–81^, the studies were small, had various designs, and there was little detailed information on rejection episodes or graft survival from which to derive inferences regarding the effect of omega-3 fatty acid supplementation.

- In 1 report, 2 patients (one in the treatment group and the other a control) died of “vascular rejection” at 7 and 8 weeks and were excluded from the analysis.^77^ Graft survival was similar in both treatment groups (14 of 15 in those receiving fish oil supplementation and 14 of 15 in those receiving corn oil).
- One episode of acute rejection was described in the control group in another study.^78^ A 60-year-old patient with angiographic evidence of accelerated coronary disease died of congestive heart failure secondary to myocardial infarction in the fish oil group.
- Similar graft survival was described for patients receiving fish oil supplementation (21 of 23) or corn oil (20 of 22) in another RCT.^80^
- All grafts survived in 41 transplant recipients in an open-label prospective cohort study of a Mediterranean diet, which is rich in ALA.^62^
- Two patients in the placebo group dropped out of a RCT due to acute rejection.^81^

#### Other Transplants

A study of liver transplantation focused on the renal effects of fish oil supplementation in those with stable liver graft function (at least 6 months after transplant).^82^ The study duration was only two months. No effects on rejection or graft survival were described.

A study in bone marrow transplant recipients focused on predictors of acute colonic graft versus host disease but did not present outcomes related to the success of the transplant.^43^ A separate report of the same patients^83^ found a significantly higher patient survival rate in the group that received fish oil supplementation and improvement in biochemical markers of the systemic inflammatory response.^83^

### Question 2: What is the evidence that omega-3 fatty acid supplementation is renoprotective (improves glomerular filtration rate or increases kidney size) or is protective against primary kidney disease recurrence following kidney transplantation?

#### Kidney transplantation

No study reported kidney size as a measure of renal function following transplantation or described primary disease recurrence following kidney transplantation. Two case reports suggested that fish oil supplementation improved proteinuria in patients who developed recurrent IgA nephropathy.^84,^ ^85^ The observation is potentially important since some studies have found a benefit from fish oil supplementation in IgA nepropathy in the non-transplant setting.^86,^ ^87^

Eleven randomized-controlled trials in 14 publications and 1 prospective cohort study reported the effects of fish oil supplementation on GFR (Table 3.5 & 3.6). No consistent benefit was observed in patients treated shortly after transplantation or those with stable renal function in whom treatment was started several months after transplantation, although there were exceptions. The magnitude of benefit suggested in trials with positive findings was modest, and, as noted above, did not translate into improved graft survival with up to 1-year of follow-up.^64,^ ^67,^ ^69,^ ^88^

Table 3.5 Effects of Fish Oil on Glomerular Filtration Rate (GFR) or Creatinine Clearance (Cr Cl) in Randomized-Controlled Trials

Author, Year | GFR or Cr Cl method | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA (g/d) | N | Placebo or Control | [underlined: Results] ^a^ | | | [underlined: Quality] ^b^
| | | | | | | Base (ml/min/ (1.73m2)) | Net Δ | P | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Hernandez, 2002 | EDTA | Day 2 | 45 | 1.9 | 40 | Soy oil | 50.8 | +2.8 | n.d. | B | 3 | Un
Santos, 2000 | EDTA | Day 2 | 15 | 3.0 | 15 | Placebo | ND | +4.1 ^c^ | n.d. | C | 2 | Un
Homan van der Heide, 1992 | Cr Cl | Day 3 | 39 | 3.0 | 47 | Coconut oil | ND | +4.0 ^d^ | n.d. | C | 3 | Un
Homan van der Heide, 1993 | ^125^I | Day 3 | 30 | 3.0 | 28 | Coconut oil | 42.0 | +3.0 | n.d. | B | 3 | Un
Kooijmans-Coutinho, 1996 | ^125^I | Day 3 | 14 | 3.0 | 17 | Coconut oil | 46.1 | -1.0 | n.d. | B | 5 | In
Homan van der Heide, 1990a | ^125^I | Day 3 | 14 | 3.0 | 17 | Coconut oil | ND | -4.0 ^c^ | n.d. | C | 2 | Un
Berthoux, 1992 | Inulin | Day 3 | 14 | 2.7 | 15 | No placebo | 44.6 ^e^ | +0.2 | n.d. | C | 1 | Un
Maachi, 1995 | Inulin | Day 3 | 40 | 2.5 | 40 | No placebo | 47.5 | +2.1 | n.d. | C | 1 | Un
Bennett, 1995 | DTPA | 16 wks | 22 | 5.4 | 50 | Corn oil | 68.0 | -19.0 | n.d. | B | 3 | Un
| | | 18 | 2.7 | | | 73.0 | -19.0 | n.d.
Homan van der Heide, 1990b | ^125^I | 9 mo | 11 | 3.0 | 10 | Corn oil | 56.0 | +16.5 | <.01 | B | 3 | Un
Schut ,1993; Schut,1993; Schut ,1992; Levi, 1992 | ^125^I | 1 yr | 5 | Fish oil: 3.0 + CsA | 5 | Corn oil + CsA | 57.0 | -10.0 | n.d. | B | 2 | Un
| | | 5 | Fish oil: 3.0 +CsA & Pred | 5 | Corn oil + CsA + Pred | 50.0 | +3.0 | n.d.
| | | 5 | Fish oil: 3.0 +Aza & Pred | 4 | Corn oil + Aza + Pred | 62.0 | +5.0 | n.d.
| | | Heart Transplant
Andreassen, 1997 | Cr Cl | Day 4 | 14 | 3.4 | 14 | Corn oil | 57.0 | +7.0 | n.d. | B | 2 | Un
Holm, 2001; Holm, 2001 | Cockroft & Gaults | Mean 6 yrs (range 1–12 yrs) | 21 | 3.4 | 20 | Corn oil | ND | +5.0 ^f^ | n.d. | B | 3 | Un
| | | Liver Transplant
Badalamenti, 1995 | Inulin | ND | 13 | 3.6 | 13 | Corn oil | 71.0 | +20.4 | .05 | B | 3 | Un

99m ND = no data; n.d. = not done; NS = not significant; DTPA = Tc-diethylenetriaminepentaacetate; ^125^I = ^125^I-iothalamate; EDTA = [^51^Cr] EDTA; Inulin = Inulin clearance; wks = weeks; mo = months; yrs = years

a Base = in treatment arm; Net Δ = Net difference in effect of omega-3 fatty acids and effect of control, see Methods; P = p-value of the net difference between treatment and control arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

c Only the difference after intervention between the 2 groups could be calculated due to lack of baseline data.

d Only the difference after intervention between the 2 groups could be calculated due to lack of baseline data. Median values were used because mean values were not reported.

e No baseline data were available; the 3-month measures served as baseline values.

f Estimated from figure.

Table 3.6 Effects of Fish Oil on Glomerular Filtration Rate (GFR) in a Prospective Cohort Study in Kidney Transplant Recipients

Author, Year | GFR | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA (g/d) | [underlined: Results] ^a^ | | | Quality
| | | | | Base (ml/min/ (1.73m ^2^)) | Δ | P W/in
Hansen 1995a | DTPA | Mean 16 (range 6–71) months | 10 | 3.5 | 61.9 | +2.2 | NS | B

99m ND = no data; n.d. = not done; NS = not significant; DTPA = Tc-diethylenetriaminepentaacetate

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the change within group.

Comparison of studies with positive and negative findings did not reveal any patient or study-related factors that could account for the heterogeneity. Two of the largest studies that reached disparate conclusions had almost identical designs.^63,^ ^64^ In both, there was improvement in the GFR during the 12-month observation period in treated and control patients. In the study with positive findings,^64^ GFR in the fish oil group increased from 42 to 45, to 49, and to 53 ml/min/1.73m^2^ from at 1, 3, 6, and 12 months, respectively. Corresponding values in the control group were 32, 38, 41, and 40. The differences were statistically significant at the 3, 6, and 12 month time-points.

By contrast, in the study with the negative results,^63^ GFR increased from 46.1 ml/min/1.73m^2^ at 1 month to 54.4 at 12 months in the fish oil group and from 43.2 to 52.5 in the control group at the same time points. Thus, in both studies there were similar degrees of improvement in both treated and control patients relative to baseline. The main difference between studies was the lower values of GFR at all time points in the control group in the study with the positive findings.^64^ This may have been due to fewer episodes of rejection in the fish oil group. However, given the small size of the study, it is also possible that unmeasured factors contributed to relatively poor graft function in the control arm. On the other hand, lower baseline values of GFR or higher rates of rejection for the control group did not appear to account for the positive finding that was observed in a different trial.^69^

#### Heart Transplantation

Renal function was also examined in studies of heart transplant recipients. Although the effect of fish oil supplementation on renal function in transplants other than kidney was not specifically requested in the key question above, it is useful to compare renal outcomes with fish oil supplementation in other forms of transplant.

Three controlled trials in 4 reports in heart transplantation, with a total of 79 patients in the fish oil group and 77 patients in the control group, described the effect of fish oil supplementation on renal function.^77,^ ^78,^ ^80,^ ^89^ Two of these reported both serum creatinine levels and GFR or creatinine clearance (Table 3.5).

In 1 report, measured creatinine clearance 6 months after transplant improved in both treated and control patients with an insignificantly higher value in the group randomized to fish oil supplementation.^77^

No significant difference was observed in the calculated GFR in a second trial.^89^ However, serum creatinine increased significantly in the control group but did not increase in the group receiving fish oil supplementation. The calculated GFR decreased in the placebo group while remaining unchanged in the fish oil group.

In a third trial, serum creatinine levels remained stable in a group receiving fish oil supplementation while they increased in a group receiving bezafibrate.^78^ While the differences were statistically significant, serum creatinine alone is considered to be a poor measure of renal function.

#### Other Transplants

Renal function was evaluated in 1 controlled trial^90^ in liver transplantation (Table 3.5). GFR increased by 33 percent in patients randomized to receive fish oil supplementation compared with no change in the corn oil group. The mean percent change was statistically significant (P=0.05).

## Cardiovascular Disease-Related Outcomes

### Question 3: What is the evidence that omega-3 fatty acid supplementation lowers cardiovascular disease risk factors or events in organ transplant recipients (adults or children)?

Several factors are well known to be associated with the risk of cardiovascular disease. These include serum lipoproteins, blood pressure, diabetes mellitus, and related metabolic disorders. Multiple studies have demonstrated that improvement or suppression of these factors can reduce the risk. The effects of omega-3 fatty acid supplementation on these risk factors have been reviewed in detail in the non-transplant setting.^40^ A large, consistent benefit was found only for triglyceride levels. Little or no effect was found for a variety of other cardiovascular risk factors and markers of cardiovascular disease.

#### Kidney Transplantation

Cardiovascular risk factors evaluated in studies of kidney transplantation focused on the effects of fish oils on lipid profiles and on blood pressure.

##### Total Cholesterol

Changes in total cholesterol were described in 8 randomized controlled trials (a total of 186 and 147 patients in the fish oil and control groups, respectively) and 2 uncontrolled studies (a total of 44 patients in the fish oil group) (Table 3.7, 3.8; 3.9). The studies were all of low or intermediate quality. A lesser degree of increase in total cholesterol in the fish oil group compared with control was described in 1 controlled trial.^28^ Total cholesterol increased from 187 to 234 mg/dL by month 3 in the fish oil group compared with 176 to 251 mg/dL in controls. Fish oil supplementation was less effective than simvastatin or lovastatin in 2 controlled trials.^68,^ ^91^

Table 3.7 Randomized-Controlled Trials of the Effects of Fish Oil on Total Cholesterol (Duration: 12 weeks to 1 year)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA (g/d) | N | Placebo or Control | [underlined: Results] ^a^ | | | [underlined: Quality] ^b^
| | | | | | | Base (mg/dl) | Net Δ | P | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Busnach, 1998 | ND | Day 1 | 21 | 2.6 | 21 | Olive oil | 202 | -9 | n.d. | B | 3 | Un
Santos, 2000 | ND | Day 2 | 15 | 3.0 | 15 | Placebo | 155 | -13 | n.d. | B | 2 | Un
Hernandez, 2002 | ND | Day 2 | 45 | 1.9 | 40 | Soy oil | 187 | -28 | n.d. | B | 3 | Un
Berthoux, 1992 | ND | Day 3 | 14 | 2.7 | 15 | No placebo | 242^c^ | -22 | n.d. | C | 1 | Un
Maachi, 1995 | ND | Day 3 | 40 | 2.5 | 40 | No placebo | 233^c^ | -19 | n.d. | C | 1 | Un
Yoa, 1994 | ND | Mean 36 months | 12 | 1.2 | 11 | Olive oil | 208 | +8 | n.d. | B | 2 | Un
| | | Heart Transplant
Andreassen, 1997 | Methyl-prednisolone | Day 4 | 14 | 3.4 | 14 | Corn oil | 193 | -28 | NS | B | 2 | Un
Ventura, 1993 | ND | Mean 3.5 months | 10 | 3.0 | 6 | Corn oil | 275 | -32 | n.d. | B | 3 | Un
Holm, 2001 | Statins | Mean 6 (range 1–12) years | 21 | 3.4 | 20 | Corn oil | 267 | 0 | NS | B | 3 | Un

ND = no data; n.d. = not done; NS = not significant

a Base = Baseline level in treatment arm; Net Δ = Net difference in effect of omega-3 fatty acids and effect of control, see Methods; P = p-value of the net difference between treatment and control arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

c No baseline data were available; the 3-month measures served as baseline values.

Table 3.8 Randomized- and non-Randomized-Controlled Trials of the Effects of Fish Oil vs. Other Lipid-Lowering Drugs on Total Cholesterol (Duration: 3 to 6 months)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | [underlined: Cohorts] | | | [underlined: Results] ^a^ | | | | [underlined: Quality] ^b^
| | | N | Source | Dose | Base (mg/dl) | Δ | P W/in | P Btw | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Castro, 1997 | None | ≥ 1 year | 18 | Fish oil | EPA+DHA = 3.0 g/d | 266 | -26 | <.001 | n.d. | C | 2 | In
| | | 25 | Simvastatin | 10 mg/d | 271 | -43 | <.001
Rodriguez, 1997 | None | 40.3 mo | 18 | Fish oil | EPA+DHA = 3.0 g/d | 272 | -34 | <.001 | <0.01 | B | 2 | Un
| | 50.9 mo | 16 | Lovastatin | 20 mg/d | 278 | -57 | <.001
| | | Heart Transplant
Barbir, 1992 | ND | ND | 44 | Fish oil | EPA+DHA = 3.0 g/d | 286 | 0 | n.d. | .0003 | C | 1 | Un
| | | 43 | Bezafibrate | 400 mg/day | 278 | -33 | n.d.

ND = no data; n.d. = not done; NS = not significant; mo = months

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the difference within the group. P Btw = p-value for the net difference between the study arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

Table 3.9 Prospective Cohort Studies of the Effects of Omega-3 Fatty Acids on Total Cholesterol (Duration: 8 weeks to 6 months)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | [underlined: Cohorts] | | | | [underlined: Results] ^a^ | | | Quality
| | | N | Source | g/d | | Base (mg/dl) | Δ | P W/in
| | | Kidney Transplant
Sweny, 1993; Sweny, 1989 | ND | Mean 58 (range 13–132) months | 14 | Fish oil | EPA+DHA | 0.06 g/kg BW/d | 291 | +18 | NS | C
Grekas, 2001 | Pravastatin 20 mg/d | Mean 8.7 years | 30 | Fish oil | EPA+DHA | 0.30 | 229 | -42 | <.02 | C
| | | Heart Transplant
Salen, 1994 | ND | n.d. | 41 | French Mediterranean diet | ALA | 0.39 | 317 | -39 | .005 | C

ND = no data; n.d. = not done; NS = not significant; ALA = alpha-linolenic acid dosage

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the change within the group.

##### High-Density Lipoprotein (HDL)

Six controlled trials (with a total of 124 and 138 patients in the fish oil and control groups, respectively) and 1 uncontrolled trial included levels of HDL cholesterol as an endpoint. No significant benefit from fish oil supplementation was observed (Table 3.10, 3.11; 3.12)

Table 3.10 Randomized-Controlled Trials of the Effects of Fish Oil on High-Density Lipoprotein (HDL) (Duration: 12 weeks to 1 year)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA (g/d) | N | Placebo or Control | [underlined: Results] ^a^ | | | [underlined: Quality] ^b^
| | | | | | | Base (mg/dl) | Net Δ | P | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Santos, 2000 | ND | Day 2 | 15 | 3.00 | 15 | Placebo | 36.0 | +7.0 | n.d. | B | 2 | Un
Busnach, 1998 | ND | Day 1 | 21 | 2.55 | 21 | Olive oil | 45.7 | +14.0 | n.d. | B | 3 | Un
Bennett, 1995 | ND | 16 weeks | 22 | 5.40 | 50 | Corn oil | 58.0 | +1.0 | n.d. | B | 3 | Un
| | | 18 | 2.70 | | | 59.0 | +4.0 | n.d.
Yoa, 1994 | ND | Mean 36 months | 12 | 1.20 | 11 | Olive oil | 62.0 | -1.0 | n.d. | B | 2 | Un
| | | Heart Transplant
Andreassen, 1997 | ND | Day 4 | 14 | 3.4 | 14 | Corn oil | 30.0 | +2.0 | NS | B | 2 | Un
Ventura, 1993 | ND | Mean 3.5 months | 10 | 3.0 | 6 | Corn oil | 47.0 | -2.0 | n.d. | B | 3 | Un
Holm, 2001; Holm, 2001 | ND | Mean 6 (range 1–12) years | 21 | 3.4 | 20 | Corn oil | 50.3 | +7.7 | NS | B | 3 | Un

ND = no data; n.d. = not done; NS = not significant;

a Base = Baseline level in treatment arm; Net Δ = Net difference in effect of omega-3 fatty acids and effect of control, see Methods; P = p-value of the net difference between treatment and control arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

Table 3.11 Randomized-Controlled Trials of the Effects of Fish Oil vs. Other Lipid-Lowering Drugs on High-Density Lipoprotein (HDL) (Duration: 3 to 6 months)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | [underlined: Cohorts] | | | [underlined: Results] ^a^ | | | | [underlined: Quality] ^b^
| | | N | Source | Dose | Base (mg/dl) | Δ | PW/in | P Btw | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Castro, 1997 | None | ≥1 year | 18 | Fish oil | EPA+DHA = 3.0 g/d | 63.0 | -10.0 | <.01 | n.d. | C | 2 | In
| | | 25 | Simvastatin | 10 mg/d | 58.0 | -2.0 | NS
Rodriguez, 1997 | None | 40.3 mo | 18 | Fish oil | EPA+DHA = 3.0 g/d | 48.1 | +1.1 | NS | NS | B | 2 | Un
| | 50.9 mo | 16 | Lovastatin | 20 mg/d | 60.2 | +0.1 | NS
| | | Heart Transplant
Barbir, 1992 | ND | n.d. | 44 | Fish oil | EPA+DHA = 3.0 g/d | 41.4 | 0 | n.d. | .0023 | C | 1 | Un
| | | 43 | Bezafibrate | 400 mg/day | 40.6 | +12.2 | n.d.

ND = no data; n.d. = not done; NS = not significant; mo = months

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the difference within the group. P Btw = p-value for the net difference between the study arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

Table 3.12 Prospective Cohort Studies of the Effects of Omega-3 Fatty Acids on High-Density Lipoprotein (HDL)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | [underlined: Cohorts] | | | | [underlined: Results] ^a^ | | | Quality
| | | N | Source | g/d | | Base (mg/dl) | Δ | P W/in
| | | Kidney Transplant
Grekas, 2001 | Pravastatin 20 mg/d | Mean 8.7 yrs | 30 | Fish oil | EPA+DHA | 0.3 | 46.0 | +3.0 | NS | C
| | | Heart Transplant
Salen, 1994 | ND | n.d. | 41 | French Mediterranean diet | ALA | 0.39 | 54.1 | +0.8 | NS | C

ND = no data; n.d. = not done; NS = not significant

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the change within the group.

##### Low-Density Lipoprotein (LDL)

Four controlled trials (with a total of 91 and 106 patients in the fish oil and control groups, respectively) and 1 uncontrolled study included levels of LDL cholesterol as an endpoint (Table 3.13, 3.14; 3.15). No significant benefit was observed in the controlled trials. Lovastatin was significantly more effective than fish oil in 1 study.^91^

Table 3.13 Randomized-Controlled Trials of the Effects of Fish Oil on Low-Density Lipoprotein (LDL) (12 weeks to 1 year)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA(g/d) | N | Placebo or Control | [underlined: Results] ^a^ | | | [underlined: Quality] ^b^
| | | | | | | Base (mg/dl) | Net Δ | P | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Santos, 2000 | ND | Day 2 | 15 | 3.00 | 15 | Placebo | 100 | +13 | n.d. | B | 2 | Un
Bennett, 1995 | ND | 16 weeks | 22 | 5.40 | 50 | Corn oil | 133 | 0 | n.d. | B | 3 | Un
| | | 18 | 2.70 | | | 176 | -3 | n.d.
| | | Heart Transplant
Ventura, 1993 | ND | Mean 3.5 months | 10 | 3.0 | 6 | Corn oil | 185 | -22 | n.d. | B | 3 | Un
Holm, 2001 ; Holm, 2001 | ND | Mean 6 (range 1–12) years | 21 | 3.4 | 20 | Corn oil | 170 | 0 | NS | B | 3 | Un

ND = no data; n.d. = not done; NS = not significant

a Base = Baseline level in treatment arm; Net Δ = Net difference in effect of omega-3 fatty acids and effect of control, see Methods; P = p-value of the net difference between treatment and control arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

Table 3.14 Randomized- and non-Randomized-Controlled Trials of the Effects of Fish Oil vs. Other Lipid-Lowering Drugs on Low-Density Lipoprotein (LDL) (Duration: 3 to 6 months)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | [underlined: Cohorts] | | | [underlined: Results] ^a^ | | | | [underlined: Quality] ^b^
| | | N | Source | Dose | Base (mg/dl) | Δ | P W/in | P Btw | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Castro, 1997 | None | ≥1 year | 18 | Fish oil | EPA+DHA = 3.0 g/d | 162 | -4 | NS | n.d. | C | 2 | In
| | | 25 | Simvastatin | 10 mg/d | 177 | -33 | <.01
Rodriguez, 1997 | None | 40.3 mo | 18 | Fish oil | EPA+DHA = 3.0 g/d | 105 | -7 | NS | <.01 | B | 2 | Un
| | 50.9 mo | 16 | Lovastatin | 20 mg/d | 121 | -42 | <.01
| | | Heart Transplant
Barbir, 1992 | ND | n.d. | 44 | Fish oil | EPA+DHA = 3.0 g/d | 201 | 0 | n.d. | .0002 | C | 1 | Un
| | | 43 | Bezafibrate | 400 mg/day | 193 | -35 | n.d.

ND = no data; n.d. = not done; NS = not significant; mo = months

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the difference within the group. P Btw = p-value for the net difference between the study arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

Table 3.15 Prospective Cohort Studies of the Effects of Omega-3 Fatty Acids on Low-Density Lipoprotein (LDL) (Duration: 8 weeks to x months)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | [underlined: Cohorts] | | | | [underlined: Results] ^a^
| | | N | Source | g/d | | Base (mg/dl) | Δ | P W/in | Quality
| | | Kidney Transplant
Grekas, 2001 | Pravastatin 20 mg/d | Mean 8.7 yrs | 30 | Fish oil | EPA+DHA | 0.3 | 151 | -27 | <.03 | C
| | | Heart Transplant
Salen, 1994 | ND | n.d | 41 | French Meditteranean diet | ALA | 0.39 | 240 | -35 | .004 | C

ND = no data; n.d. = not done; NS = not significant

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the change within the group.

##### Triglycerides

Nine controlled trials (with a total of 200 and 199 patients in the fish oil and control groups, respectively) and 3 uncontrolled studies (with a total of 52 patients in the fish oil group) included triglycerides as an outcome (Table 3.16, 3.17; 3.18). While there were exceptions, in aggregate, the data support a benefit of fish oil in lowering serum triglyceride concentrations, which is consistent with observations made in the non-transplant setting.^40^ One study comparing fish oil supplementation to lovastatin found the former to be more effective in reducing triglycerides.^91^

Table 3.16 Randomized-Controlled Trials of the Effects of Fish Oil on Triglycerides (Duration: 12 weeks to 1 year)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA(g/d) | N | Placebo or Control | [underlined: Results] ^a^ | | | [underlined: Quality] ^b^
| | | | | | | Base (mg/dl) | Net Δ | P | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Busnach, 1998 | ND. | Day 1 | 21 | 2.6 | 21 | Olive oil | 208 | -107 | n.d. | B | 3 | Un
Santos, 2000 | ND | Day 2 | 15 | 3.0 | 15 | Placebo | 150 | +46 | n.d. | B | 2 | Un
Hernandez, 2002 | ND | Day 2 | 45 | 1.9 | 40 | Soy oil | 203 | -46 | n.d. | B | 3 | Un
Berthoux, 1992 | ND | Day 3 | 14 | 2.7 | 15 | No Placebo | 138^c^ | -0.8 | n.d. | C | 1 | Un
Maachi, 1995 | ND | Day 3 | 40 | 2.5 | 40 | No placebo | 137 | -25 | n.d. | C | 1 | Un
Urakaze, 1989; Urakaze, 1989 | ND | Mean 25 months | 14 | 2.2 | 16 | No placebo | 148 | -42 | NS | B | 1 | Un
Yoa, 1994 | ND | Mean 36months | 12 | 1.2 | 11 | Olive oil | 133 | +9 | n.d. | B | 2 | Un
| | | Heart Transplant
Andreassen, 1997 | ND | Day 4 | 14 | 3.4 | 14 | Corn oil | 181 | -71 | <.0.5 | B | 2 | Un
Ventura, 1993 | ND | Mean 3.5 months | 10 | 3.0 | 6 | Corn oil | 157 | -6 | n.d. | B | 3 | Un
Holm, 2001; Holm, 2001 | ND | Mean 6 (range 1–12 years | 21 | 3.4 | 20 | Corn oil | 195 | -62 | .07 | B | 3 | Un

ND = no data; n.d. = not done; NS = not significant

a Base = Baseline level in treatment arm; Net Δ = Net difference in effect of omega-3 fatty acids and effect of control, see Methods; P = p-value of the net difference between treatment and control arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

c No baseline data were available; the 3-month measures served as baseline values.

Table 3.17 Randomized- and non-Randomized-Controlled Trials of the Effects of Fish Oil vs. Other Lipid-Lowering Drugs on Triglycerides (Duration: 3 to 6 months)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | [underlined: Cohorts] | | | [underlined: Results] ^a^ | | | | [underlined: Quality] ^b^
| | | N | Source | Dose | Base (mg/dl) | Δ | P W/in | P Btw | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Castro, 1997 | None | ≥1 year | 18 | Fish oil | EPA+DHA = 3.0 g/d | 203 | -47 | .02 | n.d. | C | 2 | In
| | | 25 | Simvastatin | 10 mg/d | 180 | -46 | <.01
Rodriguez, 1997 | None | Mean 40.3 mo | 18 | Fish oil | EPA+DHA = 3.0 g/d | 261 | -64 | <.01 | <.05 | B | 2 | Un
| | Mean 50.9 mo | 16 | Lovastatin | 20 mg/d | 235 | -36 | NS
| | | Heart Transplant
Barbir, 1992 | ND | n.d. | 44 | Fish oil | EPA+DHA = 3.0 g/d | 292 | -96 | n.d. | NS | C | 1 | Un
| | | 43 | Bezafibrate | 400 mg/day | 257 | -85 | n.d.

ND = no data; n.d. = not done; NS = not significant; mo = months

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the difference within the group. P Btw = p-value for the net difference between the study arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

Table 3.18 Prospective Cohort Studies of the Effects of Omega-3 Fatty Acids on Triglycerides (Duration: 5 days to 6 months)

Author, Year | Lipid lowering drugs | Treatment Started (Post-transplant) | [underlined: Cohorts] | | | | [underlined: Results] ^a^ | | | Quality
| | | N | Source | g/d | | Base (mg/dl) | Δ | PW/in
| | | Kidney Transplant
Zolotarski, 2003 | ND | Day 1 | 8 | Fish oil | EPA+DHA | 0.1 g/kg BW/d | 159 | 11 | NS | C
Sweny, 1993; Sweny, 1989 | ND | Mean 58 (range 13–132) months | 14 | Fish oil | EPA+DHA | 0.06 g/kg BW/d | 278 | -103 | <.003 | C
Grekas, 2001 | Pravastatin 20 mg/d | Mean 8.7 yrs | 30 | Fish oil | EPA+DHA | 0.3 | 169 | -45 | <.03 | C
| | | Heart Transplant
Salen, 1994 | ND | n.d. | 41 | French Mediterranean diet | ALA | 0.39 | 317 | -39 | .005 | C

ND = no data; n.d. = not done; NS = not significant; BW = body weight

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the change within the group.

##### Mean Arterial Blood Pressure

Nine controlled trials (with a total of 228 and 241 patients in the fish oil and control groups, respectively) and 2 uncontrolled studies (with a total of 28 patients in the fish oil group) evaluated changes in blood pressure following kidney transplantation (Table 3.19 & 3.20). There were potentially clinically important differences among reports in use of specific antihypertensive agents and criteria for introducing them, limiting direct comparisons. Nevertheless, no consistent benefit of fish oil supplementation on mean arterial blood pressure was observed.

Table 3.19 Randomized-Controlled Trials of the Effects of Fish Oil on Mean Arterial Blood Pressure (MAP)

Author, Year | Anti-hypertensive agents | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA (g/d) | N | Placebo or Control | [underlined: Results] ^a^ | | | [underlined: Quality] ^b^
| | | | | | | Base (mmHg) | Net Δ | P | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Santos, 2000 | β-blockers plus diuretics (if needed) or centrally acting vasodilators; calcium channel blockers, or ACE inhibitors (2nd line) | Day 2 | 15 | 3.0 | 15 | Placebo | 101 | +4.0 | n.d. | B | 2 | Un
Hernandez, 2002 | β-blockers, α-adrenergic antagonists, calcium channel blockers, diuretics as needed | Day 2 | 45 | 1.9 | 40 | Soy oil | 106 | -1.7 | n.d. | B | 3 | Un
Homan van der Heide, 1993 | Diuretics, β-blockers, vasodilatory agent. calcium channel blockers as needed | Day 3 | 30 | 3.0 | 28 | Coconut oil | 100 | -7.0 | n.d. | B | 3 | Un
Homan van der Heide, 1992 | ND | Day 3 | 39 | 3.0 | 47 | Coconut oil | ND | -3.0 ^c^ | n.d. | C | 3 | Un
Kooijmans-Coutinho, 1996 | β-blockers plus diuretics (if needed) or centrally acting vasodilators; calcium channel blockers (rescue Rx) | Day 3 | 20 | 3.0 | 18 | Coconut oil | 108 | -3.5 | n.d. | B | 5 | In
Homan van der Heide, 1990a | ND | Day 3 | 14 | 3.0 | 17 | Coconut oil | ND | -1.0 ^c^ | n.d. | C | 2 | Un
Bennett, 1995 | Calcium antagonists, ACE inhibitors | 16 weeks | 22 | 5.4 | 50 | Corn oil | 109 | -9.7 | n.d. | B | 3 | Un
| | | 18 | 2.7 | | | 104 | -5.0 | n.d.
Homan van der Heide, 1990b | Diuretics, β-blockers | 9 months | 11 | 3.0 | 10 | Corn oil | 106 | -10.5 | <.01 | B | 3 | Un
Urakaze, 1989; Urakaze, 1989 | ND. | Mean 25 months | 14 | 2.2 | 16 | No placebo | 104 | -3.0 | NS | B | 1 | Un
| | | Heart Transplant
Andreassen, 1997 | Enalapril as needed | Day 4 | 14 | 3.4 | 14 | Corn oil | 93 | -8.9 | <.01 | B | 2 | Un
Ventura, 1993 | Calcium-channel blocker, ACE inhibitor, or both | Mean 3.5±1.5 months | 10 | 3.0 | 6 | Corn oil | 120 | -18.0 | n.d. | B | 3 | Un
Holm, 2001; Holm, 2001 | ACE, calcium antagonist, β-blockers, diuretics | Mean 6 (1–12) years | 21 | 3.4 | 20 | Corn oil | 105 | -6.7 | .02 | B | 3 | Un
| | | Liver Transplant
Badalamenti, 1995 | ND | n.d. | 13 | 3.6 | 13 | Corn oil | 101 | -3.0 | n.d. | B | 3 | Un

ND = no data; n.d. = not done; NS = not significant;

a Base = Baseline level in treatment arm; Net Δ = Net difference in effect of omega-3 fatty acids and effect of control, see Methods; P = p-value of the net difference between treatment and control arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

c Only the difference after intervention between the 2 groups could be calculated due to lack of baseline data.

Table 3.20 Prospective Cohort Studies and a non-Randomized-Controlled Trial of the Effects of Fish Oil on Mean Arterial Blood Pressure (MAP)

Author, Year | GFR or Cr Cl method | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA (g/d) | [underlined: Results] ^a^ | | | Quality
| | | | | Base (mmHg) | Δ | P W/in
| | | Kidney Transplant
Hansen 1995a | ACE inhibitors, calcium antagonist, β-blockers, diuretics, hydralazine | Mean 16 (range 6–71) months | 10 | 3.5 | 106 | 0 | NS | B
Hansen 1995b | Diuretics, Diltiazem, β-blockers, ACE inhibitors | Mean 42±17 months | 9 | Fish oil: 3.5 + CsA | 121 | -2.0 | n.d. | B
| | Mean 149±44 months | 9 | Fish oil:3.5 + AzA | 110 | -7.0 | <.05
| | | Heart Transplant
Fleischhauer, 1993 | Diltiazem, Hydralazine, Enalapril, Captopril, Clonidine | 1 to 6 years | 7 | 5.7 | 116 | -9.0 | NS | C
| | | 7 | No fish oil | 114 | -5.0 | NS

ND = no data; n.d. = not done; NS = not significant

a Base = Baseline level in treatment arm; Δ = difference of the effect at the end of the study to the baseline. P W/in = p-value for the change within group.

#### Heart Transplantation

Several studies in heart transplant recipients evaluated cardiovascular risk factors post transplant (Table 3.7–3.20). The following summarizes the main findings in each study.

- A statistically significant reduction in systolic and diastolic blood pressure and serum triglycerides levels was reported in 1 RCT.^77^ A statistically significant correlation was found between the changes in systolic blood pressure and the dose of EPA and DHA. However, use of enalapril was also permitted in both groups. Data were insufficiently reported to determine whether the total dose of enalapril and proportion of patients receiving enalapril were similar across groups, raising the possibility of confounding.
- Bezafibrate was significantly more effective than fish oil supplementation in lowering total cholesterol, HDL and LDL levels in a non-RCT.^78^ No significant differences were observed in triglyceride levels.
- No significant differences were observed in mean arterial pressure or heart rate in a controlled trial.^79^ Patients receiving fish oil supplements showed a normal vasodilator response to acetylcholine infusion compared with control patients, who demonstrated a vasoconstrictor response. The authors concluded that fish oil supplementation significantly altered endothelium-dependent coronary vasodilation in heart transplant recipients, a group known to have endothelial dysfunction. Whether this change altered the natural history of atherosclerosis following transplant could not be determined.
- No change in systolic or diastolic blood pressure compared with a significant increase in these parameters in the corn oil group was observed in a RCT.^89^ A significant reduction in triglyceride levels was observed while no significant differences were found for total cholesterol, HDL, or LDL. The percentage of subjects who were considered to be normotensive at 12 months was significantly higher in the fish oil group (9 of 21 compared with 0 of 20). A significant correlation was observed between changed in systolic blood pressure and serum concentrations of EPA and DHA.

Patients received several additional antihypertensive drugs during the course of the study raising the possibility of confounding. However, the authors stated that all medications remained unchanged during the three months prior to the investigation and during the study.

- A prospective cohort study of the French Mediterranean diet found a significant reduction in total cholesterol and LDL levels compared with pretreatment values.^62^ However since total calories and percentage of saturated fats in the French Mediterranean diet were significantly decreased at the same time, the observed effects could not be solely attributed to ALA. No significant changes were observed in serum triglycerides or HDL, or weight. A significant reduction in platelet aggregation was also described.
- In a RCT, a significant reduction in mean arterial pressure and systemic vascular resistance was described in a group receiving fish oil supplementation when results were compared with baseline.^81^ Whether these changes were significant compared with the placebo group was not described, although no changes in those receiving corn oil were reported. The authors also reported a reduction in left ventricular mass compared with baseline values in the fish oil group.

#### Other Transplants

Lipid profiles were not reported in the studies of bone marrow and liver transplantation.^83,^ ^90^. In the RCT of liver transplant, fish oil supplementation had no significant effect on mean arterial pressure compared to the placebo (Table 3.19).

## Infectious Outcomes

### Question 4. What is the evidence that omega-3 fatty acid supplementation reduces serious infectious complications following organ transplantation?

Infections are an important cause of morbidity and mortality following all forms of organ transplantation. Animal and limited human data suggest that supplementation with omega-3 fatty acids may modulate the host's ability to respond to infections.^13,^ ^92^However, no study included in this evidence report described infectious outcomes. Thus, its benefit in the transplant setting could not be determined.

## All Outcomes

### Question 5. What is the evidence that any benefits to organ transplant recipients from omega-3 fatty acid supplementation differ in different subsets of patients?

#### Kidney Transplantation

Two controlled trials in kidney transplantation (with a total of 53 patients in the fish oil group and 64 patients in the coconut oil group), both from the same center, described outcomes in patients with and without an episode of rejection.^73,^ ^74^ In 1 of these reports, patients randomized to the fish oil group demonstrated a significantly better recovery of renal function following an episode of histologically-confirmed rejection.^73^ The authors concluded that fish oil supplementation favorably influenced renal function in the recovery phase following a rejection episode.

In an earlier report the authors analyzed a subset of patients without an episode of rejection during the course of study.^74^ Patients receiving fish oil had a significantly higher filtration fraction, a significantly lower effective renal plasma flow (164 versus 262 mL/min per 1.73 m^2^) and a significantly better response of the GFR following amino acid infusion (15.3 versus 10.6 percent).

#### Other Transplants

Effects of omega-3 fatty acid supplementation on subsets of patients were not reported for heart, liver, or bone marrow transplantation.

### Question 6. What is the evidence that effects of omega-3 fatty acid supplementation on outcomes of interest vary depending on the time of administration relative to transplantation procedures (pre- or post-transplant)?

#### Kidney Transplantation

All studies evaluated patients who received fish oil supplementation after transplant. While there was no individual study in which patients were randomly assigned to receive supplementation at different time points relative to the transplant, variability was observed across studies allowing for indirect comparisons.

Figure 3.5 depicts the net difference in GFR and 95% confidence intervals across studies in kidney transplant recipients who received supplementation at various intervals following the transplant. Higher values suggest better renal function in those who received fish oil supplementation. Confidence intervals could not be calculated for four studies in which the standard deviation was not reported.^64,^ ^73,^ ^74,^ ^88^ Nevertheless, the data do not support a clear relationship between the time in which the supplement was begun and the treatment effect.

Figure 3.5 Net Differences in GFR and 95% Confidence Intervals Across Randomized-Controlled Trials in Kidney Transplant Recipients who Received Fish Oil Supplementation at Various Intervals Post-Operatively

The plotted data points represent the longest follow-up values considered in each report. Thus, it is possible that there may be differences in benefit related to the timing of supplementation at earlier time intervals following transplantation. However, even if such a relationship existed, the clinical significance is unclear since the benefit did not appear to be durable or (as noted above) translate into improved graft survival.

#### Other Transplants

Omega-3 fatty acid supplementation was started after transplant in all heart transplant recipients ranging from as early as four days post transplant^77^ to as late as six years after transplant.^89^ In two studies, the specific time was not described.^62,^ ^78^ No study described a relationship between time of transplant and treatment effects. Similarly, no relevant data were described in the studies of liver and bone marrow transplantation.

## Effects on Immunosuppressive Agents and Related Drugs

### Question 7. What is the evidence in patients (adults or children) who receive an organ transplant that the benefits of omega-3 fatty acid supplementation interact with the concomitant administration of various immunosuppressive agents/drugs?

No study in any of the types of transplantation provided a detailed evaluation of the interaction between omega-3 fatty acid supplementation and the various immunosuppressive drugs, except for dosing of cyclosporine (discussed below).

One series of reports on kidney transplantation of the same patients in three separate publications^93–95^ compared outcomes in patients treated with CsA versus those treated with azathioprine. The following observations were made:

- Administration of fish oil was associated with significant improvement in fibrinolysis in patients receiving CsA but not azathioprine.^93^
- Erythrocyte deformability improved with fish oil in patients treated with CsA but not azathioprine.^94^
- No change in blood viscosity was apparent in CsA or azathioprine treated patients receiving fish oil despite the improvement in erythrocyte deformability noted in the CsA group.^95^

### Question 8. What is the evidence in patients (adults or children) who receive an organ transplant that serum levels of immunosuppressive agents/drugs are altered by omega-3 fatty acid supplementation?

Included studies used differing immunosuppressive protocols which varied in the choice of agent, target (and achieved) blood levels of CsA for induction and maintenance therapy, and use of concomitant immunosuppressive agents such as corticosteroids and anti-thymocyte globulin (see Evidence Table Ib, Evidence Table II & III). Furthermore, no study evaluated levels and dosages of all the immunosuppressant drugs that were used concurrently.

The effect of fish oil supplementation on immunosuppression was most fully described for CsA. Several studies in kidney and heart transplantation reported trough and total doses of CsA in patients who received or did not receive omega-3 fatty acids (Table 3.21). Fish oil did not appear to have an effect on either of these measures. Considered together, these data provide evidence against a clinically significant interaction between CsA and fish oil.

Table 3.21 Changes in Serum Levels of Cyclosporine (CsA) in Randomized-Controlled Trials of Fish Oil Supplementation

Author, Year | Anti-Rejection Treatments | Treatment Started (Post-transplant) | N | Fish oil EPA+DHA (g/d) | N | Placebo or Control | [underlined: Results] ^a^ | | | [underlined: Quality] ^b^
| | | | | | | Base (ng/mL) | Net Δ | P | Summary | Jadad | Allocation Conceal
| | | Kidney Transplant
Kooijmans-Coutinho, 1996 | Methylprednisolone | Day 3 | 14 | 3.0 | 17 | Coconut oil | 288 | -49 | n.d. | B | 5 | In
Homan van der Heide, 1993 | Methylprednisolone | Day 3 | 30 | 3.0 | 28 | Coconut oil | 245 | -37 | n.d. | B | 3 | Un
Homan van der Heide, 1992 | Methylprednisolone | Day 3 | 39 | 3.0 | 47 | Coconut oil | ND | +22^d^ | n.d. | C | 3 | Un
Santos, 2000 | ND | Day 2 | 15 | 3.0 | 15 | Placebo | ND | +20^d^ | n.d. | C | 2 | Un
Homan van der Heide, 1990a | Methylprednisolone | Day 3 | 14 | 3.0 | 17 | Coconut oil | ND | -4.0^d^ | n.d. | C | 2 | Un
Berthoux, 1992 | ND | Day 3 | 14 | 2.7 | 15 | No placebo | 433^c^ | -29 | n.d. | C | 1 | Un
Maachi, 1995 | ND | Day 3 | 40 | 2.5 | 15 | No placebo | 438 | +2.1 | n.d. | C | 1 | Un
Hernandez, 2002 | Methylprednisolone | Day 2 | 45 | 1.9 | 40 | Soy oil | 244 | +0.5 | n.d. | B | 3 | Un
Homan van der Heide, 1990b | ND | 9 mo | 11 | 3.0 | 10 | Corn oil | 90 | -3.0 | NS | B | 3 | Un
| | | Heart Transplant
Andreassen, 1997 | Methylprednisolone | Day 4 | 14 | 3.4 | 14 | Corn oil | 342 | +6.0 | n.d. | B | 2 | Un
Barbir, 1992 ^e^ | ND | ND | 44 | 3.0 | 43 | Bezafibrate 400 mg/d | 199 | +38 | NS | C | 1 | Un

ND = no data; n.d. = not done; NS = not significant

a Base = Baseline level in treatment arm; Net ∆ = Net difference in effect of omega-3 fatty acids and effect of control, see Methods; P = p-value of the net difference between treatment and control arms.

b Ad = adequate allocation concealment; In = inadequate allocation concealment; Un = allocation concealment unclear. See Methods.

c No baseline data were available; the 3-month measures served as baseline values.

d Only the difference after intervention between the 2 groups could be calculated due to lack of baseline data.

e Non-randomized controlled trial

However, the trough and total doses of CsA do not provide a complete picture of its pharmacokinetics. Another measure of the intensity to exposure to CsA is the area time-concentration curve, generally referred to as the “area under the curve” (AUC). The AUC is generally considered to be the most useful indicator to exposure to CsA, since it reflects the intra-and inter-patient variability among concentrations after dosing.^96^

The AUC (as well as maximal concentration, minimal concentration) at 8 five-hour time points was evaluated in a RCT in kidney transplantation.^65^ Study patients received quadruple immunosuppressive therapy, which included CsA, antilymphocyte globulin, azathioprine, and 6-methylprednisolone. After one year, patients who received fish oil had a significantly lower plasma creatinine concentration (1.26 versus 1.88 mg/dL) and higher peak CsA levels. CsA dosages were comparable. The AUC was higher in patients who received fish oil and they had less variance in the time to peak levels, although differences in these measures did not achieve statistical significance. The authors concluded that this pattern provided evidence for better CsA absorption and metabolism in kidney transplant patients receiving fish oil.

### Question 9. What is the evidence in patients (adults or children) who receive an organ transplant that omega-3 fatty acid supplementation can replace or reduce the need for other more potent anti-inflammatory or immunosuppressive drugs (such as steroids and nonsteroidal anti-inflammatory agents)?

No study reported that fish oil supplementation reduced or replaced the need for other more potent anti-inflammatory drugs. Potential effects on CsA absorption are described above.

## Unpublished Data

The frequency with which clinical trials of omega-3 fatty acid supplementation in transplantation have appeared in the literature has decreased in recent years. The last relevant publication described in this evidence report was in 2002.

No additional publications were encountered while preparing this report, and no members of the TEP were aware of unpublished data that had been presented in preliminary form. Only 1 unpublished manuscript was uncovered after contact with the TEP.^97^ The manuscript has been submitted for publication but a preliminary version was provided by Dr. Wesley Alexander.

The report included 64 patients who were enrolled in 3 sequential pilot open-label studies designed to evaluate the effects of CsA dose and length of administration in a steroid-free protocol in kidney transplant recipients (cadaveric and live donor). All patients had been treated with thymoglobulin induction, sirolimus (rapamycin), mycophenolate mofetil (MMF), CsA, and immunonutrients (arginine and canola oil). The amount of ALA consumed was approximately 1.93 grams per day.

Corticosteroids were avoided in most patients while MMF was discontinued in 70 percent of patients by two years. Despite the reduction in these immunosuppressive drugs, only 15 rejection episodes were observed in the first two years, and none past 24 months. Combining all patients, 84 percent were rejection-free at one year while 70 percent of patients during the past three years were receiving monotherapy with sirolimus (rapamycin) and the dietary supplements. There were no late cardiac events or patients who developed diabetes mellitus.

These preliminary data suggest that the immunosuppressive protocols used combined with the immunonutrients may have long-term benefits in patients undergoing kidney transplant. However, the degree to which omega-3 fatty acid supplementation as canola oil contributed to these benefits is unclear.