# Methods

## Overview

This evidence report on omega-3 fatty acids and organ transplantation is based on a systematic review of the literature. The Tufts-New England Medical Center Evidence-based Practice Center (Tufts-NEMC EPC) held meetings and teleconferences with technical experts including a Technical Expert Panel (TEP) as well as individual experts in relevant areas of transplantation to identify specific issues central to this report. A comprehensive search of the medical literature was conducted to identify studies addressing the key questions. Evidence tables of study characteristics and results were compiled, and the methodological quality of the studies was appraised. Study results were summarized with qualitative reviews of the evidence, summary tables, and meta-analyses, as appropriate.

A number of individuals and groups supported the Tufts-NEMC EPC in preparing this report. The TEP served as our science partner. It included technical experts, representatives from the Agency for Healthcare Research and Quality (AHRQ), and institutes at the National Institutes of Health (NIH) to work with the EPC staff to refine key questions, identify important issues, and define parameters to the report. Additional domain expertise was obtained through local experts who joined the EPC.

The Tufts-NEMC EPC also worked in conjunction with EPCs at the University of Ottawa and the Southern California EPC-RAND. The 3 EPCs coordinated efforts to produce evidence reports on 10 topics related to omega-3 fatty acids over a 2-year period, with the goal of producing evidence reports with a uniform format. Evidence table layout, and study quality assessment were standardized. In addition, literature searches for all evidence reports were performed by the University of Ottawa EPC, using identical search terms for studies of omega-3 fatty acids. The 3 EPCs agreed on a common definition of omega-3 fatty acids; however some variation in definitions and study eligibility criteria were permitted that reflected different topics and key questions. The studies included are described below, under Full Article Inclusion Criteria.

## Key Questions Addressed in this Report

Nine key questions are addressed in this report, which fall under 5 major categories.

### Graft-Related Outcomes

Question 1. What is the evidence that omega-3 fatty acid supplementation reduced rejection episodes or graft failure in patients (adults or children) who received an organ transplant?

Question 2. What is the evidence that omega-3 fatty acid supplementation is renoprotective (improves glomerular filtration rate or increases kidney size) or is protective against primary kidney disease recurrence following kidney transplantation?

### Cardiovascular Disease-Related Outcomes

Question 3. What is the evidence that omega-3 fatty acid supplementation lowers cardiovascular disease risk factors or events in organ transplant recipients (adults or children)?

### Infectious Outcomes

Question 4. What is the evidence that omega-3 fatty acid supplementation reduces serious infectious complications following organ transplantation?

### All Outcomes

Question 5. What is the evidence that any benefits to organ transplant recipients from omega-3 fatty acid supplementation differ in different subsets of patients?

Question 6. What is the evidence that effects of omega-3 fatty acid supplementation on outcomes of interest vary depending on the time of administration relative to transplantation procedures (pre- or post-transplant)?

### Effects On Immunosuppressive Agents And Related Drugs

Question 7. What is the evidence in patients (adults or children) who receive an organ transplant that the benefits of omega-3 fatty acid supplementation interact with the concomitant administration of various immunosuppressive agents/drugs?

Question 8. What is the evidence in patients (adults or children) who receive an organ transplant that serum levels of immunosuppressive agents/drugs are altered by omega-3 fatty acid supplementation?

Question 9. What is the evidence in patients (adults or children) who receive an organ transplant that omega-3 fatty acid supplementation can replace or reduce the need for other more potent anti-inflammatory or immunosuppressive drugs (such as steroids and non-steroidal anti-inflammatory drugs)?

## Analytic Framework

To guide our assessment of studies that examine the association between omega-3 fatty acids and transplantation outcomes, we developed an analytic framework that maps the specific linkages associating the populations of interest, the exposures, modifying factors, and outcomes of interest (Figure 2.1). The framework, depicted graphically below, presents the key components of the study questions:

Figure 2.1 Analytic framework for omega-3 fatty acid intervention and transplantation outcomes

1. What type of organ transplantation did the participants receive?
2. What were the interventions?
3. What were the outcomes of interest (intermediate and clinical outcomes)?
4. What were the study designs?

The analytic framework illustrates the chain of logic that evidence must support to link the intervention (exposure to omega-3 fatty acids) to improved clinical outcomes.

This report reviews the evidence addressing the associations or effects of omega-3 fatty acid supplementation in organ transplant recipients on graft-related, cardiovascular-disease related, infectious, and all other transplantation-related outcomes. Also examined are effects on immunosuppressive agents and related drugs.

The most important questions relating to omega-3 fatty acid supplementation pertain to their effects on clinical outcomes such as graft survival or cardiovascular events. However, some of these (such as cardiovascular events) are difficult to assess since they may not occur for many years after transplantation. As a result, established risk factors for such adverse outcomes (such as hyperlipidemia) are also relevant since they may provide a surrogate measure of potential treatment benefits. Thus, in addition to clinical events such as episodes of rejection and rates of graft survival, this report examines whether omega-3 fatty acid supplementation reduces the likelihood or severity of risk factors (such as hyperlipidemia, high blood pressure) for clinical events.

Some of these measures are potentially modified by various factors, including use of concomitant drugs (such as lipid lowering agents), demographic features (e.g., sex, age), baseline diet, the time in which treatment was begun relative to the transplant, and subject characteristics (e.g., baseline renal function). This report considers the potential influences of these factors on the observed results following omega-3 fatty acid supplementation.

The analytic framework does not directly address the level of evidence that is necessary to evaluate each of the effects. Large randomized controlled trials that are adequately blinded and otherwise free of substantial bias provide the best evidence to prove a causal relationship between intervention and outcome. Thus, the current analysis relies as much as possible on high quality, randomized controlled trials.

However, randomized controlled trials are not always available (or feasible), and may not be well-conducted or reported. Thus, other types of study designs must also be considered. Crossover trials have the advantage of controlling fully for bias due to differences between study arms but may introduce bias due to incomplete washout or an order effect. In addition, they are generally small and have a narrow range of subjects. Uncontrolled trials and observational studies provide lesser degrees of evidence that are usually hypothesis-generating regarding causality.

## Literature Search Strategy

We conducted a comprehensive literature search to address the key questions (Appendix A.1, available electronically at http://www.ahrq.gov/clinic/epcindex.htm). Relevant studies were identified primarily through search strategies conducted in collaboration with the University of Ottawa EPC. The Tufts-NEMC EPC used the Ovid search engine to conduct preliminary searches on the MEDLINE database. The final searches used 6 databases including MEDLINE, MEDLINE In Process and Other Non-Indexed Citations, Embase, CAB abstracts, BIOSIS abstracts, and Central Cochrane Database of Systematic Reviews from 1966 to week 4 2003. Subject headings and text words were selected so that the same set could be applied to each of the different databases. Following the initial electronic search, tables of contents of major transplant and clinical specialty journals were hand searched during the period while this report was being completed until preparation of the final manuscript.

Additional sources of published and unpublished data were sought by contacting the TEP as well as authors of controlled trials identified in our initial search. Bibliographies of all retrieved studies (including review articles) were also examined.

## Study Selection

### Abstract Screening

All abstracts identified through the literature search were screened manually and in triplicate by three independent investigators. Triplicate screening was performed because the modest number of abstracts allowed us to gather additional data for methodology research pertaining to the most efficient method of abstract screening. Eligibility criteria were defined broadly to include all studies (regardless of language of publication, experimental design, or size) that evaluated any potential source of omega-3 fatty acids in human subjects who underwent organ transplantation, and reported any outcome. Any abstract identified by any independent investigator was retrieved for further review.

### Full Article Inclusion Criteria

The full text of studies selected by the abstract screening process was reviewed by 3 independent investigators. Studies of any design (including controlled trials, cohort studies, case series and case reports), size, and language were included provided that they reported any outcome in adults or children undergoing organ transplantation who received omega-3 fatty acids.

Studies were excluded if they focused on nonhuman subjects, were review articles or other articles without primary sources of data, focused on subjects who did not undergo organ transplantation, did not use omega-3 fatty acids, or if the amount of omega-3 fatty acids could not be quantified. Acceptable sources of omega-3 fatty acids included fish oil, vegetable oils containing ALA (i.e., canola, rapeseed, soybean, flaxseed, linseed, walnut, mustard seed), Mediterranean diet, or other sources where the quantity was reported explicitly. Pharmaceutical companies and individuals in relevant countries were contacted when a brand name of a fish oil supplement was provided without a quantitative description of its components.

The authors, study locations, and dates of all retrieved studies were compared to identify duplicate reports of the same subjects. Where there was any ambiguity, an attempt was made to contact authors of the relevant publications. Duplicate reports were included if they provided additional data; however, subjects were included and accounted for only once.

## Data Extraction Process

Electronic data extraction forms and a database were created in a multi-step process during which the key study questions were translated into a structure that was applicable to all types of transplants and outcomes of interest. Frequent and regular discussions helped to ensure use of uniform definitions. Thus, multiple versions of the data extraction forms were tested by several investigators on samples of the included studies, until a final version was achieved. All investigators were trained on how to complete the form to assure consistency among extractors.

All studies were extracted by 3 independent investigators to allow for future methodology research aimed at comparing double versus single data extraction. The extraction team included investigators skilled in foreign languages so that non-English studies could be included.

Study features extracted included the design, blinding, randomization method, allocation concealment method, country, funding source, duration, quantity and type of omega-3 fatty acids, eligibility criteria, control interventions, sample characteristics (and their comparability), reasons for withdrawals and all reported outcomes. (Appendix B, available electronically at http://www.ahrq.gov/clinic/epcindex.htm). In addition, each study was categorized based on study quality as described below.

Two investigators compared the results of the triplicate data extraction forms. Discrepancies were resolved by discussion and review of the original study until consensus was achieved for all data points.

## Grading of the Evidence

Studies accepted in evidence reports have been designed, conducted, analyzed, and reported with varying degrees of methodological rigor and completeness. Deficiencies in any of these components can lead to biased reporting and interpretation of the results. While it is desirable to grade individual studies to highlight the degree of potential bias, the grading of study quality is not straightforward. Most factors commonly used in quality assessment of randomized controlled trials have not been sufficiently validated to be certain about their relationship to estimates of treatment effects.^55^ Thus, there is still no uniform approach to grade studies. As a result, various EPCs have previously used different approaches to grade study quality.

### Common Elements for Grading Methodological Quality of Randomized Controlled Trials in Evidence Reports

As part of the overall omega-3 fatty acid project, the 3 collaborating EPCs agreed to use the Jadad Score and adequacy of random allocation concealment as elements to grade individual randomized controlled trials.^56,^ ^57^ The EPCs also agreed to permit inclusion of other quality elements that were considered to be appropriate for a generic quality score.

There was consensus among the 3 EPCs that studies should not be graded using a single, quantitative summary score, since such scores are often arbitrary and unreliable.^58^ The Jadad Score assesses the quality of randomized controlled trials using 3 criteria: adequacy of randomization, double blinding, and dropouts.^56^ Studies fulfilling all three criteria receive a maximum score of 5 points. In addition, adequacy of allocation concealment was assessed using the criteria by Schulz et al, as “adequate,” “inadequate,” or “unclear”.^57^

### Generic Summary Quality Grade for Studies

A limitation of the Jadad and Schulz scores is that they address only some aspects of the methodological quality. These scores do not include other elements of study quality, such as potential biases due to reporting and analytic problems. Furthermore, these scoring systems are applicable only to randomized controlled trials.

Thus, to supplement these scores, a 3-category grading system (A, B, C) was applied to each study. This grading system has been used in most of the previous evidence reports from the Tufts-NEMC EPC as well as in evidence-based clinical practice guidelines.^59^ This system defines a generic grading system that is applicable to varying study designs including randomized controlled trials, cohort, and case-control studies:

A. Category A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized study; clear description of the population, setting, interventions and comparison groups; clear description of the content of the placebo used; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20% dropout; clear reporting of dropouts; and no obvious bias.
B. Category B studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
C. Category C studies have significant bias that may invalidate the results. These studies have serious errors in design, analysis or reporting, have large amounts of missing information, or discrepancies in reporting.

In addition to applying these 3 grading systems, additional comments relating to potential sources of bias and other study limitations were recorded by each investigator during the data extraction process. Such comments are included in the evidence tables.

Applicability grades, used in other evidence reports related to omega-3 fatty acids, were not included. The grades were designed to address the relevance of a given study to a population of interest. Such a framework was not considered to be relevant in the current report since all studies focused on patients undergoing organ transplantation, which is already a narrowly defined population.

## Reporting Results

Results that are included in this report were determined through discussions with members of the TEP as well as additional experts in transplantation. This process allowed us to focus on the major outcomes of interest (and methods for their measurement) that were relevant to the TEP key questions, were available in the identified literature, and relevant for specific area of transplantation. These endpoints are featured in the evidence tables, but all measured endpoints are also included.

- Major outcomes for kidney transplantation included the post-transplant glomerular filtration rate (GFR), blood pressure, lipid profile, patient and graft survival, episodes of rejection, and dose and trough levels of CsA.
- Major outcomes for heart transplantation included post-transplant hypertension, renal function, lipid levels, rejection episodes (including surrogate markers) and coronary disease (including surrogate markers).
- All outcomes for other forms of transplant (i.e, bone marrow and liver) were included in the evidence tables since, as will be noted below, only 1 study in each category was identified.

As a general rule, when more than 1 time-point was reported for a specific outcome (e.g., glomerular filtration rate), the result representing the longest time point from study inception was included in the primary analysis. However, additional analyses were performed for questions that were of clinical interest or relevant to the TEP questions (e.g., examining the effects of fish oil supplementation on early versus late rejection).

Studies describing renal function after transplantation frequently described the results of more than 1 method to assess it. All methods are described in the evidence tables. However, the most rigorous method was highlighted and used for comparison across studies whenever available. In particular, direct measurement of the GFR with a radioisotope study or inulin clearance was considered to provide the best estimate of renal function compared with indirect methods (such as the calculated GFR) or serologic markers such as the plasma concentration of blood urea nitrogen or creatinine.^60^

Important covariates and study characteristics were also featured. These included, for example, the doses and types of immunosuppressant medications, type of transplant (live donor versus cadaveric), specific time in which the omega-3 fatty acid was introduced relative to the transplant, duration of follow-up, concomitant use of antihypertensive medications and lipid lowering agents, all of which may have an influence on the major outcomes of interest.

Many of the outcomes of interest were continuous variables such as blood pressure, GFR, and lipid levels. For these outcomes, the summary tables describe 3 sets of data: the mean baseline level in the omega-3 fatty acid arm, the net change of the outcome, and the reported P values of the difference between the omega-3 fatty acid and the control arms. The net change of the outcome is the difference between the change in the omega-3 fatty acid arm and the change in the control arm:

Net change = (Omega-3 _Final_ - Omega-3 _Initial_) - (Control _Final_ - Control _Initial_).

While some studies reported adjusted and unadjusted within-arm and between-arm (net) differences, to maintain consistency across studies, we calculated the unadjusted net change using the above formula for all studies when the data were available. All exceptions and caveats are described in footnotes.

We included only the reported P values for the net differences. We did not calculate any P values, but, when necessary, used provided information on the 95% confidence interval or standard error of the net difference to determine whether it was less than .05. We included any reported P value less than .10. Those above .10 and those reported as “non-significant” were described as “NS” (non-significant) in the tables.

For measures expressed using standard or Systeme International (SI) units (e.g. lipid levels), the original units reported in the study were included in the evidence tables. However, all such measurements were converted to standard units in the summary and results tables to facilitate comparisons.

Uncontrolled trials were described (e.g. case reports), and, when within group comparisons were made, the within-group change was reported along with its associated P value.

### Meta-analysis

For dichotomous or categorical variables, the rates in the treatment and control groups were expressed as a relative risk and 95% confidence intervals. Among these, there were sufficient, clinically comparable data to combine the results of graft or patient survival and rejection episodes in kidney transplantation. This was accomplished using a random effects model meta-analysis.^61^

For rejection episodes, calculations were performed with the patient (not the rejection episode) as the unit of analysis (since individual patients could have had more than one rejection episode). Thus, the proportion of patients having a rejection episode at various time points (rather than the total number of rejection episodes) was compared across treatment groups.

## Evidence and Summary Tables

The evidence is described in two complementary ways:

Evidence tables offer a detailed description of the studies that addressed each of the key questions. These tables provide information about the study design, patient characteristics, inclusion and exclusion criteria, interventions and comparison groups evaluated, and outcomes. Outcome data are reported in the units and metrics reported in the articles. Each study appears once regardless of how many interventions our outcomes were reported. Studies are ordered alphabetically by the first author.

Summary tables report succinctly using summary measures of the main outcomes. They include information regarding study size, intervention and control, study population, outcome measures, and methodological quality. These tables were developed by condensing information from the evidence tables. Outcome units and metrics are reported in standard units and as in common metrics, regardless of how these were reported in the articles. They are designed to facilitate comparisons and synthesis across studies. Studies reporting multiple outcomes may appear several times in summary tables.

Studies are grouped first according to the time of introduction of omega-3 fatty acids relative to the transplant and then by the dose of omega-3 fatty acids used. Controlled trials are featured separately from uncontrolled trials and case series.