# Introduction

This evidence report has been prepared by the Tufts-New England Medical Center (Tufts-NEMC) Evidence-based Practice Center (EPC) concerning the health benefits of omega-3 fatty acids on transplantation. These reports are among several that address topics related to omega-3 fatty acids, and that were requested and funded by the Office of Dietary Supplements, National Institutes of Health, through the EPC program at the Agency for Healthcare Research and Quality (AHRQ). Three EPCs - the Tufts-NEMC EPC, the Southern California EPC-RAND, and the University of Ottawa EPC - each produced evidence reports. To ensure consistency of approach, the 3 EPCs collaborated on selected methodological elements, including literature search strategies, rating of evidence, and data table design.

The aim of the reports is to summarize the current evidence on the health effects of omega-3 fatty acids (eicosapentaenoic acid [EPA; chemical abbreviation: 20:5 n-3], docosahexaenoic acid [DHA; 22:6 n-3], alpha-linolenic acid [ALA, 18:3 n-3], and docosapentaenoic acid [DPA, 22:5 n-3]) on the following: cardiovascular disease, cancer, child and maternal health, eye health, gastrointestinal diseases, kidney diseases, asthma, autoimmune diseases, immune-mediated diseases, organ transplantation, mental health, and neurological diseases and conditions. In addition to informing the research community and the public on the effects of omega-3 fatty acids on various health conditions, it is anticipated that the findings of the reports will also be used to help define the agenda for future research.

The focus of this report is on organ transplantation. In this chapter, the metabolism, physiological functions, and the sources of omega-3 fatty acids are discussed briefly. Subsequent chapters describe the methods used to identify and review studies related to omega-3 fatty acids and organ transplantation, findings related to the effects of omega-3 fatty acids on organ transplantation, and recommendations for future research in this area.

## Background

### Metabolism and Biological Effects of Essential Fatty Acids

Dietary fat is an important source of energy for biological activities in human beings. Dietary fat encompasses saturated fatty acids, which are usually solid at room temperature, and unsaturated fatty acids, which are liquid at room temperature. Unsaturated fatty acids can be divided further into monounsaturated and polyunsaturated fatty acids. Polyunsaturated fatty acids can be classified on the basis of their chemical structure into two groups: omega-3 (n-3) fatty acids and omega-6 (n-6) fatty acids. The omega-3 or n-3 notation indicates that the first double bond from the methyl end of the molecule is in the third position. The same principle applies to the omega-6 or n-6 notation. Despite their differences in structure, all fats contain the same amount of energy (9 kcal/g or 37 kJ/g).

Of all fats found in food, 2 — ALA and linoleic acid (LA, 18:2 n-6) — cannot be synthesized in the human body in adequate amount, yet are necessary for proper physiological functioning. For this reason, these 2 fats are classified as essential fatty acids. These essential fatty acids can be converted in the liver to what are commonly termed very long-chain polyunsaturated fatty acids, which have a higher number of carbon atoms and double bonds. The metabolic product of LA is arachidonic acid (AA, 20:4 n-6) and products of ALA are EPA and DHA. These very long-chain polyunsaturated fatty acids retain the omega type (n-3 or n-6) of the parent essential fatty acids.

ALA and LA comprise the majority of the total polyunsaturated fatty acids consumed in a typical North American diet. Typically, LA comprises 89% of the total polyunsaturated fatty acids consumed, while ALA comprises 9%. Smaller amounts of other polyunsaturated fatty acids make up the remainder.^1^ Both ALA and LA are present in a variety of plant-based foods. For example, LA is present in high concentrations in many commonly used vegetable oils, including safflower, sunflower, soy, and corn oil. ALA, which is consumed in smaller quantities, is present in leafy green vegetables and in some commonly used vegetable oils, primarily canola and soybean oil. Some novelty oils, such as flaxseed oil, contain relatively high concentrations of ALA, but these oils are not commonly found in the food supply. Small amounts of AA come from animal products and EPA and DHA from cold-water fish.

The Institute of Medicine has recently established adequate intake levels (AI) for ALA and LA. Sufficient data were not available to establish recommended dietary allowances (RDA). The AIs for adults 19 and older are 1.1–1.6 g/day for ALA and 11–17 g/day for LA.^2^ AI's for ALA and LA differ by age and gender groups, and for special conditions such as pregnancy and lactation.

As shown in Figure 1.1, EPA and DHA can act as competitors for the same metabolic pathways as AA. In human studies, the analyses of fatty-acid compositions in both blood phospholipids and adipose tissue showed reciprocal relationship between EPA plus DHA and AA. The Institute of Medicine, due to lack of sufficient data, has not established either RDAs or AIs for AA, EPA or DHA. Dietary recommendations have been made for these very long chain fatty acids by other countries worldwide, however, these specific amounts vary widely among countries.^3^ Furthermore, there remain numerous unanswered questions relating to the metabolic interrelationship between omega-3 and omega-6 fatty acid. For example, it remains unclear to what extend ALA is converted to EPA and DHA in humans and whether this conversion varies among aged groups or physiological states (i.e. pregnancy), and to what extent the intake of omega-6 fatty acids impacts on the conversion rate or alters the biological effects attributed solely to EPA and DHA. Without resolution of these 2 foundational questions, it remains difficult to fully understand the relative roles of omega-6 and omega-3 fatty acid in human health.

Figure 1.1 Classical omega-3 and omega-6 fatty acid synthesis pathways and the role of omega-3 fatty acid in regulating health/disease markers

### Metabolic Pathways of Omega-3 and Omega-6 Fatty Acids

Omega-3 and omega-6 fatty acids share a common pool of enzymes and go through the same oxidation pathways while being metabolized (Figure 1.1). Once ingested, ALA and LA can be elongated and desaturated into long-chain polyunsaturated fatty acids. LA can be converted into gamma-linolenic acid (GLA, 18:3 n-6), an omega-6 fatty acid that is a positional isomer of ALA. GLA, in turn, can be converted to the very long-chain omega-6 fatty acid, AA. ALA can be converted, to a lesser extent, to the very long-chain omega-3 fatty acids, EPA and DHA. However, the conversion from parent fatty acids into very long-chain polyunsaturated fatty acids occurs slowly in humans, and conversion rates nor the determinants thereof are not well understood. Meat is the primary food source of AA, while cold-water fish has traditionally been the primary food source of EPA and DHA.

The specific biological functions of fatty acids depend on the number and position of double bonds and the length of the acyl chain. Both EPA and AA are 20-carbon fatty acids and are precursors for the formation of prostaglandins, thromboxane, and leukotrienes — hormone-like agents that are members of a larger family of substances called eicosanoids. Eicosanoids are localized tissue hormones that seem to be one of the fundamental regulatory classes of molecules in higher forms of life. They do not travel in the blood, but are synthesized in the cells and regulate a large number of processes, including the movement of calcium and other substances into and out of cells, dilation and contraction of muscles, inhibition and promotion of clotting, regulation of secretions including digestive juices and hormones, and control of fertility, cell division, and growth.^4^

As shown in Figure 1.1, AA is the precursor of a group of eicosanoids including series-2 prostaglandins and series-4 leukotrienes. EPA is the precursor to a group of eicosanoids including series-3 prostaglandins and series-5 leukotrienes. The series-2 prostaglandins and series-4 leukotrienes derived from AA are involved in accelerating platelet aggregation and enhancing vasoconstriction and the synthesis of inflammatory mediators in response to physiological stressors. The series-3 prostaglandins and series-5 leukotrienes that are derived from EPA are less physiologically potent than those derived from AA. More specifically, the series-3 prostaglandins are formed at a slower rate and work to attenuate excessive series-2 prostaglandins. Thus, adequate production of the series-3 prostaglandins, which are derived from EPA may protect against heart attack and stroke as well as certain inflammatory diseases like arthritis, lupus, and asthma.^4^ In addition, animal studies, have demonstrated that EPA and DHA involved in cytoprotective activities may contribute to antiarrhythmic mechanisms.^5^ Arrhythmias are a common cause of “sudden death” in heart disease.

In addition to affecting eicosanoid production as described above, EPA als affects lipoprotein metabolism and decreases the production of other compound from AA-genases including cytokines, interleukin 1β (IL1β), and tumor necrosis factor α (TNFα) - that have proinflammatory effects. These compounds stimulate the production of collagenases and increase the expression of adhesion molecules necessary for leukocyte extravasation.^6^ The mechanism responsible for the suppression of cytokine production by omega-3 fatty acids remains unknown, although suppression of eicosanoid production by omega-3 fatty acids may be involved. EPA can also be converted into the longer chain omega-3 form of docosapentaenoic acid (n-3 DPA), and then further elongated and oxygenated into DHA. EPA and DHA are frequently referred to as very long chain omega-3 fatty acids (and commonly known as “fish oil”). DHA, which is thought to be important for brain development and functioning, is present in significant amounts in a variety of food products, including fish, fish liver oils, fish eggs, and organ meats. Similarly, AA can convert into n-6 DPA.

Studies have reported that omega-3 fatty acids decrease triglycerides (Tg) and very low density lipoprotein (VLDL) in hypertriglyceridemic subjects, with a concomitant increase in high density lipoprotein (HDL). However, they appear to increase or have no effect on low density lipoprotein (LDL). Omega-3 fatty acids lowers plasma Tg by inhibiting VLDL and apolipoprotein B-100 synthesis.^7^ Omega-3 fatty acids, in conjunction with transcription factors (small proteins that bind to the regulatory domains of genes), target the genes governing cellular Tg production and those activating oxidation of excess fatty acids in the liver. Inhibition of fatty acid synthesis and increased fatty acid catabolism reduce the amount of substrate available for Tg production.^8^

### Population Intake of Omega-3 Fatty Acids in the United States

The major source of EPA and DHA is dietary intake of fish and fish oil, and that of ALA is dietary intake of vegetable oils (principally canola and soybean), some nuts including walnuts, and dietary supplements. Two population-based surveys, the third National Health and Nutrition Examination (NHANES III) 1988-94 and the Continuing Food Survey of Intakes by Individuals (CSFII) 1994-98, are the main source of dietary intake data for the U.S. population. NHANES III collected information on the U.S. population aged ≥2 months. Mexican Americans and non-Hispanic African-Americans, children ≤5 years old, and adults ≥ 60 years old were over-sampled to produce more precise estimates for these population groups. There were no imputations for missing 24-hour dietary recall data. A total of 29,105 participants had complete and reliable dietary recall. Complete descriptions of the methods used and fuller analyses are available in the report Effects of Omega-3 Fatty Acids on Cardiovascular Disease, under “Methods: Method to Assess the Dietary Intake of Omega-3 Fatty Acids in the US population” and “Results: Population Intake of Omega-3 Fatty Acids in the United States”.

CSFII 1994-96, popularly known as the What We Eat in America survey, addressed the requirements of the National Nutrition Monitoring and Related Research Act of 1990 (Public Law 101–445) for continuous monitoring of the dietary status of the American population. In CSFII 1994-96, an improved data-collection method known as the multiple-pass approach for the 24-hour recall was used. Given the large variation in intake from day-to-day, multiple 24-hours recalls are considered to be the best suited for most nutrition monitoring and will produce stable estimates of mean nutrient intakes from groups of individuals.^9^

In 1998, the Supplemental Children's Survey, a survey of food and nutrient intake by children under age of 10, was conducted as the supplement to the CSFII 1994-96. The CSFII 1994-96, 1998 surveyed 20,607 people of all ages with over-sampling of low-income population (<130% of the poverty threshold). Dietary intake data by individuals of all ages were collected over 2 nonconsecutive days by use of two 1-day dietary recalls.

Table 1.1 reports the NHANES III survey mean intake ± the standard error of the mean (SEM), as well as, the median and range for each omega-3 fatty acid. Distributions of EPA, DPA, and DHA were skewed; therefore, the means and standard errors of the means should be used and interpreted with caution. Table 1.2 reports the CSFII survey mean and median intakes for each omega-3 fatty acid, along with SEMs, as reported in Dietary Reference Intakes by the Institute of Medicine.^2^ Estimates of intake from these reports may underestimate total consumption since they do not include intake from dietary supplements and fortified foods.

Table 1.1 Estimates of the mean±standard error of the mean (SEM) intake of linoleic acid (LA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), and docosahexaenoic acid (DHA) in the United States population, based on analyses of a single 24-hour dietary recall of NHANES III data

| [underlined: Grams/day] | | [underlined: % Kcal/day]
| Mean±SEM | Median (range) ^a^ | Mean±SEM | Median (range)^a^
LA (18:2 n-6) | 14.1±0.2 | 9.9 (0 – 168) | 5.79±0.05 | 5.30 (0 – 39.4)
ALA (18:3 n-3) | 1.33±0.02 | 0.90 (0 – 17) | 0.55±0.004 | 0.48 (0 – 4.98)
EPA (20:5 n-3) | 0.04±0.003 | 0.00 (0 – 4.1) | 0.02±0.001 | 0.00 (0 – 0.61)
DHA (22:6 n-3) | 0.07±0.004 | 0.00 (0 – 7.8) | 0.03±0.002 | 0.00 (0 –2.86)

a The distributions are not adjusted for the over-sampling of Mexican Americans, non-Hispanic African-Americans, children ≤5 years old, and adults ≥ 60 years old in the NHANES III dataset.

Table 1.2 Mean, range, median, and standard error of the mean (SEM) of usual daily intakes of linoleic acid (LA), total omega-3 fatty acids (n-3 FA), alpha-linolenic acid (ALA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA) and docosahexaenoic acid (DHA) in the US population, based on CSFII data (1994-1996, 1998)

| [underlined: Grams/day]
| Mean±SEM | Median±SEM
LA (18:2 n-6) | 13.0±0.1 | 12.0±0.1
Total n-3 FA | 1.40±0.01 | 1.30±0.01
ALA (18:3 n-3) | 1.30±0.01 | 1.21±0.01
EPA (20:5 n-3) | 0.028 | 0.004
DPA (22:5 n-3) | 0.013 | 0.005
DHA (22:6 n-3) | 0.057±0.018 | 0.046±0.013

### Dietary Sources of Omega-3 Fatty Acids

Omega-3 fatty acids can be found in many different sources of food, including EPA and DHA from fish and shellfish, and ALA from some nuts and various plant oils. They are summarized on the USDA website http://www.nal.usda.gov/fnic/foodcomp (accessed November 3, 2003; Finfish and Shellfish Products: sr16fg15.pdf; Fats and Oils: sr16fg04.pdf; and Nut and Seed Products: sr16fg12.pdf).^10^

## Potential Benefits of Omega-3 Fatty Acids in Organ Transplantation

The multiple biological effects of omega-3 fatty acids and observations in non-transplant settings provided a rationale for clinical trials in organ transplantation.^11–13^ The largest experience has been in kidney transplantation in which laboratory, animal and early human studies suggested that omega-3 fatty acid supplementation, mostly fish oil, had the potential to decrease cyclosporine (CsA) nephrotoxicity, decrease rejection, improve hyperlipidemia, and reduce hypertension. Other benefits had also been suggested such as improvement in risk factors for thrombosis, restoration of erythrocyte deformability, and blood viscosity. There is far less experience in other forms of organ transplantation, although the effects of omega-3 fatty acids have been evaluated in the setting of heart, liver and bone marrow transplantation where similar benefits had been anticipated.

### Reduction in CsA nephrotoxicity

A major advance in organ transplantation was the introduction of cyclosporine (CsA), which greatly improved graft survival. However, CsA is associated with many side effects, especially nephrotoxicity. CsA causes a dose-dependent decrease in glomerular filtration rate (GFR), leading to afferent arteriolar vasoconstriction an increase in blood pressure.^14–16^ These effects appear to be related to alteration in the production of vasodilatory and vasoconstrictive eicosanoids. In particular, CsA-induced kidney dysfunction is associated with increased production of thromboxane A2, leukotriene C4, and leukotriene D4.^17,^ ^18^

Kidney dysfunction occurring within the first few weeks after transplantation may be reversible. Possible causes include acute tubular necrosis, rejection, vascular thrombosis, urinary obstruction or leak, hemolytic-uremic syndrome, and CsA nephrotoxicity. Amelioration of CsA-induced vasoconstriction by omega-3 fatty acids would be clinically relevant. Of greater concern is chronic nephropathy, which is characterized by the development of diffuse interstitial fibrosis and progressive loss of kidney function.^19^

Animal studies of cyclosporine nephrotoxicity demonstrated that supplementation with omega-3 fatty acids improved markers of nephrotoxicity while reducing tissue and urine concentrations of thromboxane A2.^20^ Similar results have been observed in cell culture studies in which macrophages stimulated with CsA produced less thromboxane A2 when animal had been fed a diet enriched with fish oil.^21^ Human studies also demonstrated that supplementation with fish oil reduced production of thromboxane A2.^22^

### Reduction in rejection

Several lines of evidence suggested that omega-3 fatty acids had the potential to reduce organ rejection following transplantation. Enhanced immunosuppressive effects of CsA and delayed hypersensitivity were observed in rats undergoing heart transplantation.^23,^ ^24^ Reduction in generation of pro-inflammatory products (such as interleukins-1, -2, and-6, and tumor necrosis factor alpha) had also been described in humans and animals.^25–28^ Expression of these cytokines is increased in kidney allograft rejection.^29–34^ Interleukin-1 and tumor necrosis factor alpha both stimulate the production of interleukin-6 (a primary mediator of the acute phase response) while also participating in B- and T-cell activation and maturation.^33–35^ Tumor necrosis factor alpha and interleukin-1 also stimulate macrophages and increase the expression of the class II major histocompatability complex.^33,^ ^34,^ ^36^

### Hyperlipidemia

Hyperlipidemia is common following organ transplantation.^37^Atherosclerosis resulting from hyperlipidemia is associated with increased long-term morbidity and mortality related to heart and cerebrovascular disease, particularly following kidney transplantation. Data from the United Network for Organ Sharing suggest that overall 10-year patient survival following kidney transplantation is 58 and 77 percent, for recipients of deceased donor and living related allografts, respectively.^38^ Cardiovascular disease remains the major cause of death with a functioning graft.^39^

The most frequently observed form of hyperlipidemia is hypertriglyceridemia, although some patients have isolated hypercholesterolemia. Regardless of the type of transplant, the cause is multifactorial, but in large part related to the use of corticosteroids and other immunosuppressive agents such as CsA.

The potential effect of omega-3 fatty acid supplementation on lipid metabolism in the non-transplant setting has been reviewed in detail in a previous evidence report from the Tufts-NEMC EPC.^40^ The available data suggested that there is a large, consistent benefit of omega-3 fatty acids only on triglyceride levels while small or inconsistent effects were found for a variety of other cardiovascular risk factors and markers of cardiovascular disease.

### Hypertension

Hypertension is common following organ transplantation. Although its etiology is incompletely understood, it is generally agreed that CsA is a major contributor. Studies in bone marrow and heart transplantation (settings in which initial or baseline kidney dysfunction is less likely to be present and thus contribute to hypertension) demonstrated that the incidence of hypertension was below 10 percent prior to the introduction of CsA, compared with 33 to 60 percent following bone marrow transplantation and 70 to 100 percent following heart transplantation after CsA had been introduced.^41^

A potential modest benefit of omega-3 fatty acids on blood pressure may result from favorable changes in the eicosanoid profile, helping to restore the balance between vasodilatory and vasoconstrictive eicosanoids. In a systematic review in the non-transplant setting conducted by the Tufts-NEMC EPC,^40^ fish oil supplementation was associated with a mean net change in systolic and diastolic blood pressure of -2.1 mm Hg (95% confidence interval -3.2, -1.0) and -1.6 mm Hg (-2.2, -1.0), respectively.^42^

### Miscellaneous effects

A variety of other potential benefits from omega-3 fatty acid supplementation have been proposed in the non-transplant setting, all of which provided the basis for study in patients undergoing transplantation.

- The observation that an elevated level of leukotriene B4 was a risk factor for acute colonic graft versus host disease following bone marrow transplantation suggested that omega-3 fatty acid supplementation may help prevent this complication.^43^
- Dietary supplementation with fish oil improved endothelial function in hypercholesterolemic and atherosclerotic porcine models.^44–46^ Endothelial dysfunction is known to be present in patients undergoing heart transplantation.^47,^ ^48^
- CsA may decrease erythrocyte deformability, a mechanism that may contribute to its toxicity. Supplementation with fish oil had favorable effects on erythrocyte deformability in healthy subjects and those on dialysis.^49–51^
- Fish oil decreased whole blood viscosity in healthy subjects.^52–54^